# Appendix Q - Quality assessment category scores ^a^

Category | Range | Mean
Representativeness | 0%–94% | 58%
Bias and Confounding | 0%–67% | 28%
Therapy | 0%–100% | 65%
Outcomes | 0%–83% | 53%
Statistical Analysis | 0%–100% | 61%
Overall | 3%–88% | 53%

a Scores were computed only for randomized controlled trials, non-randomized controlled trials, and cohort studies.