# Appendix P - Article Summary Information for Study Topics

Topic | # of Studies | # of Eyes Enrolled Range (mean/median) | Mean Age Range (mean/median) | Proportion of Patients African-American Range (mean/median) | Mean Reported Followup Range (median) | Quality Score Mean (Range)
Long-Term IOP Control | 44 | 19 to 310 (110/88) | 63 to 81 (74/74) | 0.0 to 0.17 (0.06/0.03) | 6–11 months to ≥24 months (12–23 months) | 50%^a^ (2% to 83%)
Short-Term IOP Control | 15 | 16 to 310 (96/68) | 69 to 80 (74/75) | 0.07 to 0.31 (0.14/0.11) | ≤24 hours to 12–23 months (6–11 months) | 55%^b^ (23% to 75%)
Development of Cataract after Glaucoma Surgery | 22 | 22 to 776 (175/140) | 50 to 72 (62/63) | 0.05 to 1.0 (0.29/0.12) | 3–5 months to ≥24 months (12–23 months) | 64%^c^ (23% to 88%)
Risks/Benefits of Anti-Fibrosis Agents | 16 | 24 to 174 (62/44) | 50 to 76 (71/74) | 0.03 to 0.77 (0.36/0.03) | 3–5 months to ≥24 months (12–23 months) | 61%^d^ (33% to 80%)
One-Site versus Two-Site Procedures | 7 | 20 to 132 (68/50) | 65 to 78 (74/75) | Reported for only one study. | 6–11 months to 12–23 months (1–-23 months) | 40%^e^ (10% to 64%)
Nuclear Expression versus Phacoemulsification | 11 | 47 to 397 (117/70) | 71 to 78 (76/76) | 0 to 0.11 (0.04/0) | 6–11 months to ≥24 months (12–23 months) | 40%^f^ (13% to 54%)
Staged versus Combined Procedures | 5 | 40 to 106 (76/79) | 50 to 76 (67/71) | 0.08 to 0.24 (0.16/0.16) | 12–23 months to ≥24 months (12–23 months) | Calculated only for one study.
Trabeculectomy versus Other Glaucoma Procedures | 3 | 58 to 70 (63/60) | 78 to 80 (79/79) | Reported for only one study. | Reported for only one study. | 43%^g^ (21% to 59%)

a 30 studies

b 15 studies

c 13 studies

d 14 studies

e 7 studies

f 11 studies

g 3 studies