# Appendix O - Study Topics Assigned During Quality Assessment

Study Question Addressed | Number of Articles ^a^
Effect of cataract surgery on long-term IOP control in open angle glaucoma patients. | 43
Effect of cataract surgery on short-term IOP control in open angle glaucoma patients. | 15
Effect of glaucoma surgery on the development and progression of cataract. | 22
Risks and benefits of staged versus combined procedures. | 5
Risks and benefits of anti-fibrosis agents. | 16
Risks and benefits of single-site versus two-site operations. | 7
Risks and benefits of trabeculectomy versus endoscopic laser versus deep sclerectomy/viscocanulostomy. | 3
Risks and benefits of nuclear expression versus phacoemulsification for patients with cataract and glaucoma. | 11

a An article may address more than one topic.