# Appendix N - Reasons for exclusion during quality assessment

Reason for Exclusion | Number of Articles
Does not report outcomes relevant to our study questions. | 6
Was neither a controlled trial nor a case series ≥ 100 patients. | 4
No original data. | 3
Only addresses intracapsular cataract extraction. | 3
Data reported in an unabstractable fashion. | 2
Other (e.g., more than half the patients did not have glaucoma) | 2
Does not address open angle or primary angle closure glaucoma. | 1