# APPENDIX M - Articles excluded during quality assessment

Bobrow JC. Prospective intrapatient comparison of extracapsular cataract extraction and lens implantation with and without trabeculectomy. Am J Ophthalmol 2000;129:291-6.

Collaborative Normal-Tension Glaucoma Study Group. Comparison of glaucomatous progression between untreated patients with normal-tension glaucoma and patients with therapeutically reduced intraocular pressures. Am J Ophthalmol 2000;126(4):487-97.

Dreyer EB, Chaturvedi N, Zurakowski D. Effect of mitomycin C and fluorouracil-supplemented trabeculectomies on the anterior segment. Arch Ophthalmol 2000;113(5):578-80.

Fanous S, Brouillette G. Combined trabeculectomy and cataract extraction: modified technique. Can J Ophthalmol 2000;18(6):274-7.

Galin MA, Hung PT, Obstbaum SA. Cataract extraction in glaucoma. Am J Ophthalmol 2000;87(2):124-9.

Galin MA, Obstbaum SA, Asano Y et al. Laser trabeculoplasty and cataract surgery. Trans. Ophthalmol. Soc. U.K. 1984;104:72-5.

Hopkins JJ, Apel A, Trope GE et al. Early intraocular pressure after phacoemulsification combined with trabeculectomy. Ophthalmic Surg Lasers 2000;29(4):273-9.

Jacobi PC, Dietlein TS, Krieglstein GK. Comparative study of trabecular aspiration vs trabeculectomy in glaucoma triple procedure to treat pseudoexfoliation glaucoma. Arch Ophthalmol 2000;117(10):1311-8.

Luntz MH, Freedman J. The fornix-based conjunctival flap in glaucoma filtration surgery. Ophthalmic Surg 2000;11(8):516-21.

Maltzman BA, Agin M. Argon peripheral iridotomy and cataract formation. Ann Ophthalmol 2000;20(1):28-30.

O'Connell EJ, Karseras AG. Intraocular surgery in advanced glaucoma. Br J Ophthalmol 2000;60(2):124-31.

Park HJ, Kwon YH, Weitzman M et al. Temporal corneal phacoemulsification in patients with filtered glaucoma. Arch Ophthalmol 2000;115(11):1375-80.

Raitta C, Vesti E. The effect of sodium hyaluronate on the outcome of trabeculectomy. Ophthalmic Surg 2000;22(3):145-9.

Shammas HJ. Anterior intraocular lens dislocation after combined cataract extraction trabeculectomy. J Cataract Refract Surg 2000;22(3):358-61.

Sharpe ED, Simmons RJ. A prospective comparison of Amvisc (TM) and Healon (Reg.trademark) in cataract surgery. J Cataract Refract Surg 2000;12(1):47-9.

Shin DH, Hughes BA, Song MS et al. Primary glaucoma triple procedure with or without adjunctive mitomycin. Prognostic factors for filtration failure. Ophthalmology 2000;103(11):1925-33.

Shin DH, Simone PA, Song MS et al. Adjunctive subconjunctival mitomycin C in glaucoma triple procedure. Ophthalmology 2000;102(10):1550-8.

Stewart RH, Loftis MD. Combined cataract extraction and thermal sclerostomy versus combined cataract extraction and trabeculectomy. Ophthalmic Surg 2000;7(3):93-5.

Tezel G, Kolker AE, Kass MA et al. Late removal of releasable sutures after trabeculectomy or combined trabeculectomy with cataract extraction supplemented with antifibrotics. J Glaucoma 2000;7(2):75-81.

Veldman E, Greve EL. Glaucoma filtering surgery, a retrospective study of 300 operations. Doc Ophthalmol 2000;67(1-2):151-70.

Yamagami S, Araie M, Mori M et al. Posterior chamber intraocular lens implantation in filtered or nonfiltered glaucoma eyes. Jpn J Ophthalmol 2000;38(1):71-9.