# Appendix L - Study topics assigned during abstract review

Study Topic on Abstract Review Form^a^ | Number of Abstracts
Development of cataract after glaucoma surgery | 32
Acute control of IOP after cataract surgery, in glaucoma patients | 17
Long-term control of IOP after cataract surgery, in glaucoma patients | 45
Preferred surgical technique | 75

a Note: Reviewers did not have to agree on topic and could select multiple topics for each abstract.