# APPENDIX K - Reasons for exclusion during abstract review process

Exclusion Criterion on Abstract Review Form^a^ | Number Excluded
Did not include human data | 13
Adults not part of study population | 0
Not in English | 1
No original data | 28
Does not address open angle glaucoma or primary open angle closure glaucoma | 483
Was neither a controlled trial nor a case series ≥ 100 patients | 403
Only addresses intracapsular cataract extraction | 27
Only addresses full thickness glaucoma surgery | 2
Meeting abstract | 0
Other (e.g., does not address cataract surgery) | 30

a Note: Reviewers did not have to agree on reason for exclusion