# Appendix J - Searching Summary

| | | Number of Citations
Source | Search Strategy | Date | Retrieved | Unique (included in abstract review process) | Included in Article Review Process
PubMed | PubMed core | Nov 22, 1999 | 781 | 781 | 120
CENTRAL | CENTRAL core | Nov 22, 1999 | 85 | 6 | 3
Issue 4 1999
CENTRAL | CENTRAL core | Feb 14, 2000 | 88 | 3 | 0
Issue 1 2000
PubMed | PubMed core | Mar 13, 2000 | 795 | 18 | 4
Handsearch | table of contents of priority journals | to Apr 15, 2000 | 6 | 3 | 1
PubMed | revised PubMed (citations uniquely retrieved by change to strategy) | Jul 18, 2000 | 109 | 108 | 3
| | TOTAL | 1864 | 919 | 131