# Appendix A - Peer Review Representatives of Stakeholder Organizations

American Board of Eye Surgery

Robert Dotson, MD

American Glaucoma Society

Robert N. Weinreb, MD

American Optometric Association

John F. Amos, OD, MS

American Society of Cataract & Refractive Surgery

Alan Robin, MD

Cochrane Collaboration: Eyes & Vision CRG

Richard Wormald, MA, MB, MSc

Glaucoma Patient Perspective

Ms. Edith Marks

Glaucoma Research Foundation

Lars Vistnes, MD (patient)

Ruth Williams, MD

Health Care Financing Administration

John J. Whyte, MD, MPH

The Glaucoma Foundation

Ms. Ali Hodin