# Appendixes

Appendix A - Peer Review Representatives of Stakeholder Organizations

Appendix B - Question Refinement Mailing

Appendix C - PubMed Core Strategy

Appendix D - Priority Journals

Appendix E - Abstract Review Form

Appendix F - Article Quality Assessment Form

Appendix G - Article Content Abstraction Form

Appendix H - List of Questions Addressed by Literature Review and Associated Evidence Tables

Appendix I - Initial Evidence Grade Assignments

Appendix J - Searching Summary

APPENDIX K - Reasons for exclusion during abstract review process

Appendix L - Study topics assigned during abstract review

APPENDIX M - Articles excluded during quality assessment

Appendix N - Reasons for exclusion during quality assessment

Appendix O - Study Topics Assigned During Quality Assessment

Appendix P - Article Summary Information for Study Topics

Appendix Q - Quality assessment category scores ^a^