# Bibliography

Abruzzo GK, Flattery AM, Gill CJ, et al Evaluation of water-soluble pneumocandin analogs L-733560, L-705589, and L-731373 with mouse models of disseminated aspergillosis, candidiasis, and cryptococcosis Antimicrob Agents Chemother 1995 39(5):1077 81 162686 7625792
Abruzzo GK, Flattery AM, Gill CJ, et al Evaluation of the echinocandin antifungal MK-0991 (L-743,872): Efficacies in mouse models of disseminated aspergillosis, candidiasis, and cryptococcosis Antimicrob Agents Chemother 1997 41(11):2333 8 164124 9371329
Ackerman Z, Zeltser R, Maayan S AIDS and oropharyngeal candidiasis Isr J Dent Sci 1989 2(3):162 6 2490931
Adamson GD Three-day treatment of vulvovaginal candidiasis Am J Obstet Gynecol 1988 158(4):1002 5 3364485
Adler-Storthz K, Ficarra G, Woods KV, et al Prevalence of Epstein-Barr virus and human papillomavirus in oral mucosa of HIV-infected patients J Oral Pathol Med 1992 21(4):164 70 1318379
Aguirre JM, Echebarria MA, Ocina E, et al Reduction of HIV-associated oral lesions after highly active antiretroviral therapy Oral Surg Oral Med Oral Pathol Oral Radiol Endod 1999 88(2):114 5 10468448
Aihara Y, Mori M, Yokota S Successful treatment of onychomycosis with fluconazole in two patients with hyperimmunoglobulin E syndrome Pediatr Dermatol 1996 13(6):493 5 8987061
Alcabes P, Schoenbaum EE, Klein RS Correlates of the rate of decline of CD4+ lymphocytes among injection drug users infected with the human immunodeficiency virus Am J Epidemiol 1993 137(9):989 1000 8100395
Alessi E, Berti E, Cusini M, et al Oral hairy leukoplakia J Am Acad Dermatol 1990 22(1):79 86 2153716
Allukian MJ, Barry MA AIDS in Massachusetts: The role and responsibility of the dentist J Mass Dent Soc 1986 35(1):15 17, 19, 25-6 passim 2939162
Alvarez MEA, Sanchez-Sousa A, Baquero F A reevaluation of nystatin in prophylaxis and treatment of oropharyngeal candidiasis Rev Esp Quimioter 1998 11(4):295 315 9990144
Anaissie E, Bodey GP, Kantarjian H, et al Fluconazole therapy for chronic disseminated candidiasis in patients with leukemia and prior amphotericin B therapy Am J Med 1991 91(2):142 50 1867240
Anderson B, Farrow JA Incarcerated adolescents in Washington State: Health services and utilization J Adolesc Health 1998 22(5):363 7 9589336
Andreo JA, Vivancos F, Serrano P, et al Visceral leishmaniasis with partial response to ketoconazole in patients with antibodies to human immunodeficiency virus Med Clin 1991 97(12):476 7
Annas GJ Protecting patients from discrimination -- the Americans with Disabilities Act and HIV infection N Engl J Med 1998 339(17):1255 9 9780348
Anneroth G, Anneroth I, Lynch DP Acquired immune deficiency syndrome (AIDS) in the United States in 1986: Etiology, epidemiology, clinical manifestations, and dental implications J Oral Maxillofac Surg 1986 44(12):956 64 3537239
Acer may have transmitted AIDS to another Florida patient Minn Med 1993 76(6):50 1
Antifungal chemotherapy in patients with acquired immunodeficiency syndrome. British Society for Antimicrobial Chemotherapy Working Party Lancet 1992 340(8820):648 51 1355218
Are dentists allowed to wear the gloves for the prevention of HIV infection for more than one patient? Ned Tijdschr Geneeskd 1991 135(14):622 3 2030793
Children born to women with HIV-1 infection: Natural history and risk of transmission European Collaborative Study. Lancet 1991 337(8736):253 60
Dental management of the HIV-infected patient. J Am Dent Assoc. 1995;Suppl:1-40.
Digestive system candidiasis and cancer: The efficacy of fluconazole, the risk of septicemia Concours Med 1991 113(16):
Drugs for AIDS and associated infections Med Lett Drugs Ther 1995 37(959):87 94 7565297
Epidemiologic notes and reports update: Transmission of HIV infection during an invasive dental procedure -- Florida Arch Dermatol 1991 127(3):309 11
From the Centers for Disease Control. Possible transmission of human immunodeficiency virus to a patient during an invasive dental procedure JAMA 1990 264(9):1092 3 2384928
From the Centers for Disease Control. Update: Transmission of HIV infection during an invasive dental procedure -- Florida JAMA 1991 265(5):563, 567 8
Kissing reported as possible cause of HIV transmission J Can Dent Assoc 1997 63(8):
More frequent dental visits prescribed for children with AIDS Dent Today 1995 14(6):
Mouth disorders occur in AIDS-infected patients N Y State Dent J 1989 55(6):
New therapy for HIV-periodontitis J Dent Hyg 1988 62(10):
Oral fluconazole for vaginal candidiasis Med Lett Drugs Ther 1994 36(931):81 2 8072449
Oral manifestations in AIDS and HIV-positive patients Compendium 1988 9(7):
Oral single treatment. The innovation in the therapy of vaginal mycoses Tw Gynakologie 1991 4(1):15 22
Periodontal disease and AIDS J Tenn Dent Assoc 1988 68(3):54 5 3210679
Periodontal lesions absent in HIV-positive children N Y State Dent J 1995 61(6):
Periodontitis-causing pathogens detected in HIV-positive children, siblings J Am Dent Assoc 1995 126(8):
Risk of HIV transmission during dental treatment Lancet 1992 340(8830):1259 60 1359324
Saperconazole Drugs of the Future 1994 19(12):
Sporanox Hosp Formul 1997 32(5):
Thrush prophylaxis in AIDS and ARC Nurs Stand 1992 6(39):
Transmission of HIV-1 infection during an invasive dental procedure -- United States CDR 1991 1(5):
Truths about AIDS -- dispelling eight common myths Dent Abstr 1985 30(6):364 8 3158555
Update: Investigations of persons treated by HIV-infected health-care workers -- United States JAMA 1993 269(20):2622 3 8487437
Update: Transmission of HIV infection during an invasive dental procedure -- California JAMA 1991 265(5):563, 567 8
Update: Transmission of HIV infection during an invasive dental procedure: United States Can Dis Wkly Rep 1991 17(4):17 22
Update: Transmission of HIV infection during invasive dental procedures CMAJ 1992 146(4):519 21 1737316 1488431
Update: Transmission of HIV infection during invasive dental procedures -- Florida Arch Dermatol 1991 127(8):1126 7
Xerostomia and treatment with DDI Nurs Stand 1992 7(4):
Antinori S, Esposito R, Ridolfo AL, et al Highly active antiretroviral therapy as an effective treatment for azole-refractory candidiasis Infect Dis Clin Pract 1999 8(8):403 7
Aoun H, Aoun P Issues raised by the possible transmission of HIV from a dentist to a patient N Engl J Med 1991 324(4):265 6 1985249
Aragues M, Sanchez Perez J, Fraga J, et al Hairy leucoplakia -- a clinical, histopathological and ultrastructural study in 33 patients Clin Exp Dermatol 1990 15(5):335 9 2171819
Arai S, Iguchi K, Kamiya H, et al Experience of fluconazole in pediatric patients Jpn J Antibiot 1989 42(1):165 70 2540362
Arendorf TM, Bredekamp B, Cloete C, et al Intergroup comparisons of oral lesions in HIV-positive South Africans Oral Dis 1997 3(Suppl 1):54 7
Arias E, El-Tonsy H, Hafez ESE Conception control and HIV/STD infections Adv Contracept Deliv Syst 1988 4(2-3):97 193 12281619
Arnow PM, Chou T, Shapiro R, et al Maintaining confidentiality in a look-back investigation of patients treated by a HIV-infected dentist Public Health Rep 1993 108(3):273 8 8497563 1403376
Asseri L, Nguvumali HI, Matee MIN, et al Chronic osteomyelitis of the mandible following tooth extraction in HIV infection Oral Dis 1997 3(3):193 5 9467365
Avery CM, Gallagher P, Birnbaum W Double gloving and a glove perforation indication system during the dental treatment of HIV-positive patients: Are they necessary? Br Dent J 1999 186(1):27 9 10028739
Ba J Some indications for the gynaecological use of budesonide (Apulein) Ther Hung 1992 40(2):90 2 1462284
Bader JD, Shugars DA, Rozier G, et al. Evidence report: Diagnosis and management of dental caries. Rockville, MD: Agency for Healthcare Research and Quality; 2000.
Bailey EM, Sobel JD Update on the prophylaxis, diagnosis, and treatment of candidal infections in hospitalized patients Hosp Formul 1993 28(11):914 32
Bajo Arenas J, Abad Martinez L, Aldama Magnet J, et al Multicentre study with a single oral dose of fluconazole (150 mg) for the treatment of vaginal candidiasis Acta Ginecol 1994 51(5):165 70
Ball SC, Sepkowitz KA, Jacobs JL Thalidomide for treatment of oral aphthous ulcers in patients with human immunodeficiency virus: Case report and review Am J Gastroenterol 1997 92(1):169 70 8995965
Balslev U, Monforte AD, Stergiou G, et al Influence of age on rates of new AIDS-defining diseases and survival in 6546 AIDS patients Scandinavian J Infect Dis 1997 29(4):337 43
Balthazar EJ, Stern J Necrotizing Candida enterocolitis in AIDS: CT features J Comput Assist Tomogr 1994 18(2):298 300 8126287
Baqui A, Meiller TF, Jabra-Rizk MA, et al Association of HIV viral load with oral diseases Oral Dis 1999 5(4):294 8 10561716
Baqui A, Meiller TF, Zhang M, et al The effects of HIV viral load on the phagocytic activity of monocytes activated with lipopolysaccharide from oral microorganisms Immunopharmacol Immunotoxicol 1999 21(3):421 38 10466072
Barbaro G, Barbarini G, Di Lorenzo G Fluconazole compared with itraconazole in the treatment of esophageal candidiasis in AIDS patients: A double-blind, randomized, controlled clinical study Scandinavian J Infect Dis 1995 27(6):613 7
Barbaro G, Barbarini G, Di Lorenzo G Fluconazole vs. flucytosine in the treatment of esophageal candidiasis in AIDS patients: A double-blind, placebo-controlled study Endoscopy 1995 27(5):377 83 7588352
Barbaro G, Barbarini G, Di Lorenzo G Fluconazole vs itraconazole-flucytosine association in the treatment of esophageal candidiasis in AIDS patients: A double-blind, multicenter placebo-controlled study Chest 1996 110(6):1507 14 8989069
Barbaro G, Di Lorenzo G Comparison of therapeutic activity of fluconazole and itraconazole in the treatment of oesophageal candidiasis in AIDS patients: A double-blind, randomized, controlled clinical study Ital J Gastroenterol 1995 27(4):175 80 8520033
Barchiesi F, Arzeni D, Del Prete MS, et al Fluconazole susceptibility and strain variation of Candida albicans isolates from HIV-infected patients with oropharyngeal candidosis [published erratum appears in J Antimicrob Chemother 1998;42(3):413] J Antimicrob Chemother 1998 41(5):541 8 9630407
Barchiesi F, Colombo AL, McGough DA, et al In vitro activity of a new antifungal triazole, D0870, against Candida albicans isolates from oral cavities of patients infected with human immunodeficiency virus Antimicrob Agents Chemother 1994 38(11):2553 6 188240 7872746
Barchiesi F, Giacometti A, Arzeni D, et al Fluconazole and ketoconazole in the treatment of oral and esophageal candidiasis in AIDS patients J Chemother 1992 4(6):381 6 1287140
Barchiesi F, Hollis RJ, Del Poeta M, et al Transmission of fluconazole-resistant Candida albicans between patients with AIDS and oropharyngeal candidiasis documented by pulsed-field gel electrophoresis Clin Infect Dis 1995 21(3):561 4 8527544
Barchiesi F, Hollis RJ, McGough DA, et al DNA subtypes and fluconazole susceptibilities of Candida albicans isolates from the oral cavities of patients with AIDS Clin Infect Dis 1995 20(3):634 40 7756488
Barchiesi F, Najvar LK, Luther MF, et al Variation in fluconazole efficacy for Candida albicans strains sequentially isolated from oral cavities of patients with AIDS in an experimental murine candidiasis model Antimicrob Agents Chemother 1996 40(5):1317 20 163320 8723495
Barnett JH, Gilson I Zidovudine-related thrombocytopenia simulating rapid growth of Kaposi's sarcoma Arch Dermatol 1991 127(7):1068 9 2064415
Baron S, Poast J, Richardson CJ, et al Oral transmission of human immunodeficiency virus by infected seminal fluid and milk: A novel mechanism J Infect Dis 2000 181(2):498 504 10669332
Barr C, Lopez MR, Rua-Dobles A Periodontal changes by HIV serostatus in a cohort of homosexual and bisexual men J Clin Periodontol 1992 19(10):794 801 1452807
Barr CE, Lopez MR, Rua-Dobles A, et al HIV-associated oral lesions: immunologic, virologic and salivary parameters J Oral Pathol Med 1992 21(7):295 8 1355794
Barr CE, Qureshi MN, Qiu Z, et al Oral HIV-1 recovery in the presence of periodontal disease Oral Dis 1996 2(3):198 201 9081759
Barr CE, Robbins MR Clinical and radiographic presentations of HIV-1 necrotizing ulcerative periodontitis Spec Care Dentist 1996 16(6):237 41 9582696
Barr CE, Rua-Dobles A, Puig N Dental care for HIV-positive patients Spec Care Dentist 1989 9(6):191 4 2533728
Barr CE, Torosian JP, Quinones-Whitmore GD Oral manifestations of AIDS: The dentist's responsibility in diagnosis and treatment Quintessence Int 1986 17(11):711 7 2947259
Barr LC, Cox PJ, Maskell GF, et al Benign parotid cysts associated with human immunodeficiency virus infection Br J Surg 1993 80(1):
Barr S The 1990 Florida dental investigation: Is the case really closed? Ann Intern Med 1996 124(2):250 4 8534001
Barrios TJ, Aria AA, Brahney C Cancrum oris in an HIV-positive patient J Oral Maxillofac Surg 1995 53(7):851 5 7595806
Barson WJ, Marcon MJ Successful therapy of Candida albicans arthritis with a sequential intravenous amphotericin b and oral fluconazole regimen Pediatr Infect Dis J 1996 15(12):1119 22 8970223
Bartizal K, Abruzzo G, Trainor C, et al In vitro antifungal activities and in vivo efficacies of 1,3-beta-D-glucan synthesis inhibitors L-671,329, L-646,991, tetrahydroechinocandin B, and L- 687,781, a papulacandi Antimicrob Agents Chemother 1992 36(8):1648 57 192025 1416847
Bautista LE, Orostegui M Dental care associated with an outbreak of HIV infection among dialysis patients Pan Am J Public Health 1997 2(3):194 202
Beckelheimer RG, Shade NL, Zwolensky JR, et al Dental emergency in a HIV-positive patient Gen Dent 1987 35(6):476 8 2965058
Becker J, Leser U, Marschall M, et al Expression of proteins encoded by Epstein-Barr virus trans-activator genes depends on the differentiation of epithelial cells in oral hairy leukoplakia Proc Natl Acad Sci U S A 1991 88(19):8332 6 52502 1656439
Begg C, Cho M, Eastwood S, et al Improving the quality of reporting of randomized controlled trials. The CONSORT statement JAMA 1996 276(8):637 9 8773637
Begg MD, Lamster IB, Panageas KS, et al A prospective study of oral lesions and their predictive value for progression of HIV disease Oral Dis 1997 3(3):176 83 9467362
Begg MD, Panageas KS, Mitchell-Lewis D, et al Oral lesions as markers of severe immunosuppression in HIV-infected homosexual men and injection drug users Oral Surg Oral Med Oral Pathol Oral Radiol Endod 1996 82(3):276 83 8884825
Beitler JJ, Vikram B, Silver CE, et al Low-dose radiotherapy for multicystic benign lymphoepithelial lesions of the parotid gland in HIV-positive patients: Long-term results Head Neck 1995 17(1):31 5 7533750
Bell SC, Elborn JS, Campbell IA, et al Candida albicans infection complicating percutaneous gastrostomy in cystic fibrosis Br J Clin Pract 1995 49(2):109 10 7779640
Bellegrandi S, D'Offizi G, Ansotegui IJ, et al Propolis allergy in an HIV-positive patient J Am Acad Dermatol 1996 35(4):
Bennett ME, Weyant RJ, Wallisch JM, et al Dentists' attitudes toward the treatment of HIV-positive patients J Am Dent Assoc 1995 126(4):509 14 7722113
Berberi A, Mokhbat J, Nasseh I, et al Non Hodgkin's lymphoma of the maxilla as a first clinical manifestation of HIV infection: Report of a case Bull Group Int Rech Sci Stomatol Odontol 1995 38(3-4):77 80 7492897
Berenguer J, Blazquez R, Ocana I, et al Candida and cryptococcal infections Enferm Infecc Microbiol 1998 16(Suppl 1):29 35
Berenguer J, Diaz-Guerra TM, Ruiz-Diez B, et al Genetic dissimilarity of two fluconazole-resistant Candida albicans strains causing meningitis and oral candidiasis in the same AIDS patient J Clin Microbiol 1996 34(6):1542 5 229058 8735114
Bergbrant IM, Faergemann J Quantitative cultures of Candida from mouthwash fluid in HIV-infected patients: A longitudinal study Mycoses 1997 40(9-10):377 80 9470426
Berman DS, Wenglin BD, Ehrenkranz NJ, et al HIV transmission in a dental practice Ann Intern Med 1992 117(9):793 5
Berrey MM, Shea T Oral sex and HIV transmission J Acquir Immune Defic Syndr 1997 14(5):
Berthold P, Stewart J, Cumming C, et al Candida organisms in dental plaque from AIDS patients J Infect Dis 1994 170(4):1053 4 7930712
Birchall MA, Horner PD, Stafford ND Changing patterns of HIV infection in otolaryngology Clin Otolaryngol 1994 19(6):473 7 7895376
Bischoff A Oral treatment of dermatomycosis Z Allgemeinmed 1992 68(6):
Blaschke-Hellmessen R, Schwarze R Amphotericin concentration in faeces and serum during oral administration in newborns at risk Mycoses 1994 37(Suppl 1):84 8 7854372
Blomgren J, Berggren U, Jontell M Fluconazole versus nystatin in the treatment of oral candidosis Acta Odontol Scand 1998 56(4):202 5 9765010
Boag FC, Dean R, Hawkins DA, et al Abnormalities of liver function during HIV seroconversion illness Int J STD AIDS 1992 3(1):46 8 1347463
Bodenstein NP, Boustred RN, McIntosh WA Cystic parotomegaly in an HIV-seropositive patient: A case report S Afr J Surg 1992 30(1):24 6 1566201
Boken DJ, Swindells S, Rinaldi MG Fluconazole-resistant Candida albicans Clin Infect Dis 1993 17(6):1018 21 8110924
Bologna M, Azzarita F, Bello A, et al Prevention of AIDS and other infectious diseases among dental professionals: A survey in two Italian regions Int J Immunopathol Pharmacol 1990 3(Suppl 2):127 9
Bolski E, Hunt RJ The prevalence of AIDS-associated oral lesions in a cohort of patients with hemophilia Oral Surg Oral Med Oral Pathol 1988 65(4):406 10 3163132
Bonuck KA, Arno PS, Green J, et al Self-perceived unmet health care needs of persons enrolled in HIV care J Community Health 1996 21(3):183 98 8726209
Borne MJ, Elliott JH, O'Day DM Ocular fluconazole treatment of Candida parapsilosis endophthalmitis after failed intravitreal amphotericin B Arch Ophthalmol 1993 111(10):1326 7 8216010
Borum ML, Mintz ML Esophageal infections in AIDS Infect Med 1998 15(5):314 8, 321-2
Brady LJ, Walker C, Oxford GE, et al Oral diseases, mycology and periodontal microbiology of HIV-1-infected women Oral Microbiol Immunol 1996 11(6):371 80 9467369
Brawner DL, Cutler JE Oral Candida albicans isolates from nonhospitalized normal carriers, immunocompetent hospitalized patients, and immunocompromised patients with or without acquired immunodeficiency syndrome J Clin Microbiol 1989 27(6):1335 41 267553 2666442
Bray F, Chapman S AIDS and dentistry in Australia: Knowledge, infection control practices and attitudes to treatment in a random sample of Australian dentists Community Health Stud 1990 14(4):384 93 2073777
Brede HD A single dose of fluconazole in the treatment of vaginal candidiasis Tw Gynakologie 1990 3(5):365 9
Brehmer-Andersson E, Lucht E, Lindskog S, et al Oral hairy leukoplakia: Pathogenetic aspects and significance of the lesion Acta Derm Venereol 1994 74(2):81 9 7911633
Brennan B, Leyden JJ Overview of topical therapy for common superficial fungal infections and the role of new topical agents J Am Acad Dermatol 1997 36(Suppl 2):3 8
Breuer J, Jeffries DJ HIV and hepatitis B virus infection in health-care workers: A risk to patients? Rev Med Microbiol 1992 3(1):1 8
Brockmeyer NH, Tillmann I, Mertins L, et al Pharmacokinetic interaction of fluconazole and zidovudine in HIV-positive patients Eur J Med Res 1997 2(9):377 83 9300934
Broder HL, Catalanotto FA, Reisine S, et al Compliance is poor among HIV-infected children with unmet dental needs Pediatr Dent 1996 18(2):137 8 8710716
Broder HL, Russell SL, Varagiannis E, et al Oral health perceptions and adherence with dental treatment referrals among caregivers of children with HIV AIDS Educ Prev 1999 11(6):541 51 10693649
Bruatto M, Vidotto V, Marinuzzi G, et al Candida albicans biotypes in human immunodeficiency virus type 1-infected patients with oral candidiasis before and after antifungal therapy J Clin Microbiol 1991 29(4):726 30 269861 1679764
Brucker G Risks of transmission of an infection from the health care staff to patients Medecine et Maladies Infectieuses 1995 25(12):1174 7
Buckley P, Holohan MK, Ryan WJ A.I.D.S. -- a review: Its relationship to dentistry J Ir Dent Assoc 1990 36(3):94 5 2098444
Cacciapuoti A, Loebenberg D, Parmegiani R, et al Comparison of SCH 39304, fluconazole, and ketoconazole for treatment of systemic infections in mice Antimicrob Agents Chemother 1992 36(1):64 7 189227 1590702
Cahill MR, Colvin BT Haemophilia Postgrad Med J 1997 73(858):201 6 9156121
Caiaffa WT, Graham NM, Galai N, et al Instability of delayed-type hypersensitivity skin test anergy in human immunodeficiency virus infection Arch Intern Med 1995 155(19):2111 7 7575072
Cameron ML, Schell WA, Bruch S, et al Correlation of in vitro fluconazole resistance of Candida isolates in relation to therapy and symptoms of individuals seropositive for human immunodeficiency virus type 1 Antimicrob Agents Chemother 1993 37(11):2449 53 192407 8285632
Camisa C, Rindler JM Diseases of the oral mucous membranes Curr Probl Dermatol 1996 8(2):41 96
Campomori A, Bonati M Fluconazole treatment for vulvovaginal candidiasis during pregnancy Ann Pharmacother 1997 31(1):118 9 8997479
Capilouto EI, Piette J, White BA, et al Perceived need for dental care among persons living with acquired immunodeficiency syndrome Med Care 1991 29(8):745 54 1875741
Capilouto EI, Weinstein MC, Hemenway D, et al What is the dentist's occupational risk of becoming infected with hepatitis B or the human immunodeficiency virus? Am J Public Health 1992 82(4):587 9 1546781 1694082
Carlin EM, Hannan M, Walsh J, et al Nasopharyngeal flora in HIV seropositive men who have sex with men Genitourin Med 1997 73(6):477 80 9582465
Carrassi A, Sardella A, Abati S, et al Prevalence of oral mucosal lesions in a sample of HIV-positive and HIV-negative Italian hemophiliacs Oral Dis 1997 3(1):
Carter YH, Greenfield SM, Kenkre JE A national survey to medical and dental schools to assess the level of undergraduate teaching and research about HIV/AIDS in the UK Int J STD AIDS 1997 8(2):88 94 9061407
Cartledge JD, Denning DW, Dupont B, et al Treatment of HIV-related fluconazole-resistant oral candidosis with D0870, a new triazole antifungal AIDS 1998 12(4):411 6 9520171
Cartledge JD, Midgley J, Gazzard BG Clinical response to ketoconazole of HIV-related oral candidosis is predicted by Odds' relative growth method of susceptibility testing J Antimicrob Chemother 1997 40(1):117 9 9249214
Cartledge JD, Midgley J, Gazzard BG Clinically significant azole cross-resistance in Candida isolates from HIV-positive patients with oral candidosis AIDS 1997 11(15):1839 44 9412702
Cartledge JD, Midgley J, Gazzard BG Itraconazole cyclodextrin solution: The role of in vitro susceptibility testing in predicting successful treatment of HIV-related fluconazole-resistant and fluconazole-susceptible oral candidosis AIDS 1997 11(2):163 8 9030362
Cartledge JD, Midgley J, Gazzard BG Itraconazole solution: Higher serum drug concentrations and better clinical response rates than the capsule formulation in acquired immunodeficiency syndrome patients with candidosis J Clin Pathol 1997 50(6):477 80 9378812 499974
Cartledge JD, Midgley J, Gazzard BG Non-albicans oral candidosis in HIV-positive patients J Antimicrob Chemother 1999 43(3):419 22 10223601
Cartledge JD, Midgley J, Gazzard BG Prior fluconazole exposure as an independent risk factor for fluconazole resistant candidosis in HIV positive patients: A case-control study Genitourin Med 1997 73(6):471 4 9582463
Cartledge JD, Midgley J, Gazzard BG Relative growth measurement of Candida species in a single concentration of fluconazole predicts the clinical response to fluconazole in HIV infected patients with oral candidosis J Antimicrob Chemother 1996 37(2):275 83 8707737
Cartledge JD, Midgley J, Gazzard BG Transmission of fluconazole-resistant Candida strains between HIV-positive patients and their sexual partners AIDS 1998 12(10):1249 51 9677179
Cartledge JD, Midgley J, Petrou M, et al Unresponsive HIV-related oro-oesophageal candidosis -- an evaluation of two new in-vitro azole susceptibility tests J Antimicrob Chemother 1997 40(4):517 23 9372421
Cartry O, Moja P, Quesnel A, et al Quantification of IgA and IgG and specificities of antibodies to viral proteins in parotid saliva at different stages of HIV-1 infection Clin Exp Immunol 1997 109(1):47 53 9218823 1904726
Casiano RR, Cooper JD, Gould E, et al Value of needle biopsy in directing management of parotid lesions in HIV-positive patients Head Neck 1991 13(5):411 4 1938357
Cassone A, De Bernardis F, Torosantucci A, et al In vitro and in vivo anticandidal activity of human immunodeficiency virus protease inhibitors J Infect Dis 1999 180(2):448 53 10395861
Cataldo E, Santis HR, Kabani S Oral manifestations of human immunodeficiency virus (HIV) infection J Mass Dent Soc 1987 36(4):165 71 3482220
Cauda R, Tacconelli E, Tumbarello M, et al Role of protease inhibitors in preventing recurrent oral candidosis in patients with HIV infection: A prospective case-control study J Acquir Immune Defic Syndr 1999 21(1):20 5 10235510
Cavicchini S, Brezzi A, Alessi E Ultrastructural findings in mucocutaneous infections of patients seropositive to HIV Am J Dermatopathol 1993 15(4):320 5 8214389
Ceballos-Salobrena A, Aguirre-Urizar JM, Bagan-Sebastian JV Oral manifestations associated with human immunodeficiency virus infection in a Spanish population J Oral Pathol Med 1996 25(10):523 6 8986962
1993 revised classification system for HIV infection and expanded surveillance case definition for AIDS among adolescents and adults MMWR 1992 41(RR-17):1 19
1999 USPHS/IDSA guidelines for the prevention of opportunistic infections in persons infected with human immunodeficiency virus. U.S. Public Health Service (USPHS) and Infectious Diseases Society of America.
Perspectives in disease prevention and health promotion update: Universal precautions for prevention of transmission of human immunodeficiency virus, hepatitis B virus, and other bloodborne pathogens in health care settings MMWR 1988 37(24):377 88 2836717
Pneumocystis pneumonia -- Los Angeles MMWR 1996 45(34):729 33 8778581
Possible transmission of human immunodeficiency virus to a patient during an invasive dental procedure MMWR 1990 39(29):489 93 2115100
Recommendations for prevention of HIV transmission in health care settings MMWR 1987 36(Suppl 2):
Recommended infection-control practices for dentistry MMWR 1986 35(15):237 42 3083228
Recommended infection-control practices for dentistry, 1993. MMWR. 1993;42. [please provide page numbers].
Update -- transmission of HIV infection during an invasive dental procedure -- Florida MMWR 1991 40(2):21 7, 33 1850497
Update: Trends in AIDS incidence, deaths, and prevalence -- United States 1996 MMWR 1997 46(08):165 73 9072676
Chamberland ME, Bell DM HIV transmission from health care worker to patient: What is the risk? Ann Intern Med 1992 116(10):871 3 1567103
Chandeying V, Skov S, Kemapunmanus M, et al Evaluation of two clinical protocols for the management of women with vaginal discharge in southern Thailand Sex Transm Infect 1998 74(3):194 201 9849555
Chapnick EK, Gradon JD, Lutwick LI Treatment of human immunodeficiency virus associated with oral aphthous ulcers with inhaled steroids N Y State J Med 1992 92(5):
Charak BS, Parikh PM, Banavali SD, et al Comparison of clotrimazole with nystatin in preventing oral candidiasis in neutropaenic patients Indian J Med Res 1988 88(5):416 20 3198184
Charbonneau A, Maheux B, Beland F Do people with HIV/AIDS disclose their HIV-positivity to dentists? AIDS Care 1999 11(1):61 70 10434983
Chaudhry Z, Barrett AW, Corbett E, et al Oral mucosal leishmaniasis as a presenting feature of HIV infection and its management J Oral Pathol Med 1999 28(1):43 6 9890457
Chavanet P, Clement C, Duong M, et al Toxicity and efficacy of conventional amphotericin B deoxycholate versus escalating doses of amphotericin B deoxycholate-fat emulsion in HIV-infected patients with oral candidosis Clin Microbiol Infect 1997 3(4):455 61 11864156
Chavanet P, Lopez J, Grappin M, et al Cross-sectional study of the susceptibility of Candida isolates to antifungal drugs and in vitro-in vivo correlation in HIV-infected patients AIDS 1994 8(7):945 50 7946104
Chavanet PY, Garry I, Charlier N, et al Trial of glucose versus fat emulsion in preparation of amphotericin for use in HIV infected patients with candidiasis BMJ 1992 305(6859):921 5 1458072 1883525
Chave JP, Cajot A, Bille J, et al Single-dose therapy for oral candidiasis with fluconazole in HIV-infected adults: A pilot study J Infect Dis 1989 159(4):806 7 2538523
Chetty R Parotid MALT lymphoma in an HIV positive child Histopathology 1996 29(2):195 7 8872160
Chiang CP, Chueh LH, Lin SK, et al Oral manifestations of human immunodeficiency virus-infected patients in Taiwan J Formos Med Assoc 1998 97(9):600 5 9795527
Chimura T, Funayama T Clinical effect of combined use of Shouhu-san and mequitazine in recurrent vaginal candidiasis received protracted antibiotic therapy Jpn J Antibiot 1994 47(5):553 60 8051796
Chintu C, Luo C, Bhat G, et al Cutaneous hypersensitivity reactions due to thiacetazone in the treatment of tuberculosis in Zambian children infected with HIV-I Arch Dis Child 1993 68(5):665 8 7686737
Christensen RP Infection control procedures -- who should decide what cannot be used? J Can Dent Assoc 1996 62(6):471 3 8752643
Chrysomali E, Greenspan JS, Dekker N, et al Apoptosis-associated proteins in oral hairy leukoplakia Oral Dis 1996 2(4):279 84 9171511
Chryssanthou E, Torssander J, Petrini B Oral Candida albicans isolates with reduced susceptibility to fluconazole in Swedish HIV-infected patients Scandinavian J Infect Dis 1995 27(4):391 5
Ciesielski C, Marianos D, Ou CY, et al Transmission of human immunodeficiency virus in a dental practice Ann Intern Med 1992 116(10):798 805 1567094
Ciesielski CA, Marianos DW, Schochetman G, et al The 1990 Florida dental investigation: The press and the science Ann Intern Med 1994 121(11):886 8 7978703
Clumeck N Primary prophylaxis against opportunistic infections in patients with AIDS N Engl J Med 1995 332(11):739 40 7854383
Coates E, Slade GD, Goss AN, et al Oral conditions and their social impact among HIV dental patients Aust Dent J 1996 41(1):33 6 8639112
Coates EA, Gorkic E, Rogers G, et al Necrotising ulcerative stomatitis in association with necrotising ulcerative periodontitis in an HIV infected male Venereology- Interdisciplinary International Journal of Sexual Health 1995 8(3):172 3
Cobb M, MacNeill R, Tobin J Oral hairy leukoplakia with ultrastructural evidence of Merkel-like cells in human tongue epithelium Bull GroupIntRcch Sc Stomatol Odontol 1998 40(1):24 37
Cohen AS, Jacobsen EL, BeGole EA National survey of endodontists and selected patient samples: Infectious diseases and attitudes toward infection control Oral Surg Oral Med Oral Pathol Oral Radiol Endod 1997 83(6):696 702 9195626
Cohen C, Silenzio VMB Current guidelines for preventing opportunistic infections in HIV disease Drug Ther Bull 1993 23(2):38 40, 45-6, 49
Cohen DM, Green JG, Howell RM Risks and potential legal problems associated with treatment of human immunodeficiency virus (HIV) positive patients J Dent Pract Adm 1987 4(3):95 9 2970530
Cohen LA, Grace EG, Ward MA Patient perceptions of the risk of contracting HIV in the dental office Gen Dent 1993 41(4):332 4 8262349
Coker RJ, Bell D, Peters BS, et al Cavitating pulmonary cryptococcosis developing in an HIV antibody patient despite prior treatment with fluconazole Genitourin Med 1992 68(1):42 4 1548011
Colebunders R, Francis H, Mann JM, et al Parotid swelling during human immunodeficiency virus infection Arch Otolaryngol Head Neck Surg 1988 114(3):330 2 3342129
Colebunders R, Ryder R, Francis H, et al Seroconversion rate, mortality, and clinical manifestations associated with the receipt of a human immunodeficiency virus-infected blood transfusion in Kinshasa, Zaire J Infect Dis 1991 164(3):450 6 1869835
Collin B, Clancy CJ, Nguyen MH Antifungal resistance in non-albicans Candida species Drug Resist Updates 1999(1):9 14
Conley LJ, Bush TJ, Buchbinder SP, et al The association between cigarette smoking and selected HIV-related medical conditions AIDS 1996 10(10):1121 6 8874629
Conner HD, Haberman S, Collings CK, et al Bacteremias following periodontal scaling in patients with healthy appearing gingiva J Peridontol 1967 38(6):466 72
Contreras A, Slots J Mammalian viruses in human periodontitis Oral Microbiol Immunol 1996 11(6):381 6 9467370
Cooper H Root canal treatment on patients with HIV infection Int Endod J 1993 26(6):369 71 8144247
Coppola S, Angarano G, Montagna MT, et al Efficacy of itraconazole in treating AIDS-associated infections due to Candida krusei Eur J Epidemiol 1995 11(2):243 4 7672085
Corless IB Much ado about something: The restriction of HIV-infected health-care providers AIDS & Public Policy J 1992 7(2):82 8 11654032
Cortes P, Cardenosa N, Romani J, et al Oral leishmaniasis in an HIV-positive patient caused by two different zymodemes of Leishmania infantum Trans R Soc Trop Med Hyg 1997 91(4):438 9 9373646
Costa LR, Villena RS, Sucasas PS, et al Oral findings in pediatric AIDS: A case control study in Brazilian children ASDC J Dent Child 1998 65(3):186 90 9668947
Coulter ID, Marcus M, Freed JR, et al Use of dental care by HIV-infected medical patients J Dent Res 2000 79(6):1356 61 10890713
Coutlee F, Trottier AM, Ghattas G, et al Risk factors for oral human papillomavirus in adults infected and not infected with human immunodeficiency virus Sex Transm Dis 1997 24(1):23 31 9018780
Craven DE, Duncan RA, Stram JR, et al Response of lymphoepithelial parotid cysts to antiretroviral treatment in HIV-infected adults Ann Intern Med 1998 128(6):455 9 9499329
Crosher RF, Llewelyn J, MacFarlane A Should patients with facial fractures be regarded as high risk for HIV? Br J Oral Maxillofac Surg 1997 35(1):59 63 9043008
Cross DL, Smith GL Comparison of periodontal disease in HIV seropositive subjects and controls (II). Microbiology, immunology and predictors of disease progression J Clin Periodontol 1995 22(7):569 77 7560241
Croucher R, Robinson P, Zakrzewska JM, et al Satisfaction with care of patients attending a dedicated dental clinic: Comparisons between 1989 and 1994 Int J STD AIDS 1997 8(3):150 3 9089024
Cruz GD, Lamster IB, Begg MD, et al The accurate diagnosis of oral lesions in human immunodeficiency virus infection: Impact on medical staging Arch Otolaryngol Head Neck Surg 1996 122(1):68 73 8554749
Cubie HA, Felix DH, Southam JC, et al Application of molecular techniques in the rapid diagnosis of EBV-associated oral hairy leukoplakia J Oral Pathol Med 1991 20(6):271 4 1716319
Currey CJ, Johnson M, Ogden B Willingness of health-professions students to treat patients with AIDS Acad Med 1990 65(7):472 4 2242206
Dancaster JT, Dancaster LA Confidentiality concerning HIV-AIDS status -- the implications of the appeal court decision S Afr Med J 1995 85(3):141 4 7777958
Danila RN, MacDonald KL, Rhame FS, et al A look-back investigation of patients of an HIV-infected physician -- public health implications N Engl J Med 1991 325(20):1406 11 1922251
Dannaoui E, Colin S, Pichot J, et al Evaluation of the E test for fluconazole susceptibility testing of Candida albicans isolates from oropharyngeal candidiasis Eur J Clin Microbiol Infect Dis 1997 16(3):228 32 9131326
Darling M, Arendorf T, Samaranayake LP Oral care of HIV-infected patients: The knowledge and attitudes of South African dentists J Dent Assoc S Afr 1992 47(9):399 402 9511621
Davis DR, Knapp JF The significance of AIDS to dentists and dental practice J Prosthet Dent 1984 52(5):736 8 6238163
Davis IP, Siegal MD, Carnahan BW Access to dental care for HIV-infected individuals Ohio Dent J 1990 64(1):15, 17 8
De Almeida OP, de Souza Filho FJ, Scully C, et al HIV prevalence in dental outpatients in Brazil Oral Surg Oral Med Oral Pathol Oral Radiol Endod 1997 84(4):365 7 9347499
Dean DA, Burchard KW Surgical perspective on invasive Candida infections World J Surg 1998 22(2):127 34 9451927
De Asis ML, Bernstein LJ, Schliozberg J Treatment of resistant oral aphthous ulcers in children with acquired immunodeficiency syndrome J Pediatr 1995 127(4):663 5 7562298
De Bernardis F, Boccanera M, Rainaldi L, et al The secretion of aspartyl proteinase, a virulence enzyme, by isolates of Candida albicans from the oral cavity of HIV-infected subjects Eur J Epidemiol 1992 8(3):362 7 1356827
DeBry RW, Abele LG, Weiss SH, et al Dental HIV transmission? Nature 1993 361(6414):
De Lalla F, Pellizzer G, Manfrin V, et al Maintenance therapy for cryptococcosis in patients with AIDS after successful primary therapy: Oral fluconazole (300 mg daily) versus oral itraconazole (300 mg daily) Clin Microbiol Infect 1999 5(9):567 70 11851710
Delaney M, McHenry M, Langford A Dental care of HIV positive patients at Berlin clinic EDS Magazine 1991 2(4):11 14 1840319
De Laurenzi A, Matteocci A, Lanti A, et al Amphotericin B prophylaxis against invasive fungal infections in neutropenic patients: A single center experience from 1980 to 1995 Infection 1996 24(5):361 6 8923046
De los Reyes C, Edelman DE, De Bruin MF Clinical experience with single-dose fluconazole in vaginal candidiasis. A review of the worldwide database Int J Gynecol Obstet 1992 37(Suppl 1):9 15
Del Palacio A Fungal skin and soft tissue infections Curr Opinion Infect Dis 1992 5(5):687 94
Del Palacio A, Cuetara MS, Ferro M, et al Fluconazole in the management of endophthalmitis in disseminated candidosis of heroin addicts Mycoses 1993 36(5-6):193 9 8264716
Del Rosso JQ, Zellis S, Gupta AK Itraconazole in the treatment of superficial cutaneous and mucosal Candida infections J Am Osteopath Assoc 1998 98(9):497 502 9785744
Delwart EL, Busch MP, Kalish ML, et al Rapid molecular epidemiology of human immunodeficiency virus transmission AIDS Res Hum Retroviruses 1995 11(9):1081 93 8554905
Denning DW Can we prevent azole resistance in fungi? Lancet 1995 346(8973):454 5 7637473
Denning DW, Donnelly JP, Hellreigel KP, et al Antifungal prophylaxis during neutropenia or allogeneic bone marrow transplantation: What is the state of the art? Chemotherapy 1992 38(Suppl 1):43 9 1611930
De Pauw BE, Raemaekers JMM, Donnelly JP, et al An open study on the safety and efficacy of fluconazole in the treatment of disseminated Candida infections in patients treated for hematological malignancy Ann Hematol 1995 70(2):83 7 7880929
De Repentigny L, Ratelle J, Baril JG, et al Comparison of itraconazole and ketoconazole in HIV-positive patients with oropharyngeal or esophageal candidiasis. Human Immunodeficiency Virus Itraconazole Ketoconazole Project Group Chemotherapy 1996 42(5):374 83 8874977
Desai PC, Johnson BA Oral fluconazole for vaginal candidiasis Am Fam Physician 1996 54(4):1337 40 8816577
DeVincenzo JP, Burchet SK Prolonged thalidomide therapy for human immunodeficiency virus-associated recurrent severe esophageal and oral aphthous ulcers Pediatr Infect Dis J 1996 15(5):465 46 8724075
De Wit S, Clumeck N Therapeutic approach to mycotic infections in AIDS patients Rev Med Microbiol 1991 2(1):57 60
De Wit S, Dupont B, Cartledge JD, et al A dose comparison study of a new, triazole antifungal (D0870) in HIV-postive patients with oral candidiasis AIDS 1997 11(6):759 63 9143608
De Wit S, Goossens H, Clumeck N Single-dose versus 7 days of fluconazole treatment for oral candidiasis in human immunodeficiency virus-infected patients: A prospective, randomized pilot study J Infect Dis 1993 168(5):1332 3 8228378
De Wit S, O'Doherty E, De Vroey C, et al Safety and efficacy of single-dose fluconazole compared with a 7-day regimen of itraconazole in the treatment of AIDS-related oropharyngeal candidiasis J Intern Med Res 1998 26(3):159 70
De Wit S, O'Doherty E, Edwards J, et al Pharmacokinetics of two multiple-dosing regimens of D0870 in human immunodeficiency virus-positive patients: A phase I study Antimicrob Agents Chemother 1998 42(4):903 6 105564 9559805
De Wit S, Urbain D, Rahir F, et al Efficacy of oral fluconazole in the treatment of AIDS associated oesophageal candidiasis Eur J Clin Microbiol Infect Dis 1991 10(6):503 5 1915385
De Wit S, Weerts D, Goossens H, et al Comparison of fluconazole and ketoconazole for oropharyngeal candidiasis in AIDS Lancet 1989 1(8641):746 8 2564563
Dewsnup DH, Stevens DA Efficacy of oral amphotericin B in AIDS patients with thrush clinically resistant to fluconazole J Med Vet Mycol 1994 32(5):389 93 7844704
Dhuley JN Hamycin treatment of candidiasis in normal and diabetic rats FEMS Immunol Med Microbiol 1999 26(2):175 80 10536305
Di Alberti L, Ngui SL, Porter SR, et al Presence of human herpes virus 8 variants in the oral tissues of human immunodeficiency virus-infected persons J Infect Dis 1997 175(3):703 7 9041349
Diaz-Guerra TM, Martinez-Suarez JV, Laguna F, et al Change in fluconazole susceptibility patterns and genetic relationship among oral Candida albicans isolates AIDS 1998 12(13):1601 10 9764778
Dichtel Jr WJ Oral manifestations of human immunodeficiency virus infection Otolaryngol Clin North Am 1992 25(6):1211 26
Dickinson GM, Morhart RE, Klimas NG, et al Absence of HIV transmission from an infected dentist to his patients: An epidemiologic and DNA sequence analysis JAMA 1993 269(14):1802 6 8459511
Di Luca D, Mirandola P, Ravaioli T, et al Human herpes viruses 6 and 7 in salivary glands and shedding in saliva of healthy and human immunodeficiency virus positive individuals J Med Virol 1995 45(4):462 8 7666047
Discacciati JAC, Sander HH, De Castilho LS, et al Confirmation of spatter dispersion during dental work Rev Panam Salud Publica Pan Am J Public Health 1998 3(2):84 7
Dismukes WE, Wade JS, Lee JY, et al A randomized, double-blind trial of nystatin therapy for the candidiasis hypersensitivity syndrome N Engl J Med 1990 323(25):1717 23 2247104
Diz Dios P, Ocampo A, Miralles C, et al Frequency of oropharyngeal candidiasis in HIV-infected patients on protease inhibitor therapy Oral Surg Oral Med Oral Pathol Oral Radiol Endod 1999 87(4):437 41 10225625
Diz Dios P, Vazquez Garcia E, Feijoo JF Dental extractions performed in HIV-positive patients J Dent Res 1998 77(4):533 4 9539454
Diz Dios PD, Alvarez Alvarez J, Fernandez Feijoo J, et al Fluconazole response patterns in HIV-infected patients with oropharyngeal candidiasis Oral Surg Oral Med Oral Pathol Oral Radiol Endod 1995 79(2):170 4 7614179
Dodd CL, Greenspan D, Greenspan JS Oral Kaposi's sarcoma in a woman as a first indication of HIV infection J Am Dent Assoc 1991 122(4):61 3
Dodd CL, Greenspan D, Katz MH, et al. Oral candidiasis in HIV infection: Pseudomembranous and erythematous candidiasis show similar rates of progression to AIDS. AIDS. 1991;5:1339-43. [pmid: 1768382].
Dodds EM, Lowder CY, Boskovich SA, et al Simultaneous syphilitic necrotizing retinitis and placoid chorioretinitis in acquired immune deficiency syndrome Retina 1995 15(4):354 6 8545584
Dodson TB HIV status and the risk of post-extraction complications J Dent Res 1997 76(10):1644 52 9326896
Dodson TB Predictors of postextraction complications in HIV-positive patients Oral Surg Oral Med Oral Pathol Oral Radiol Endod 1997 84(5):474 9 9394376
Dodson TB, Nguyen T, Kaban LB Prevalence of HIV infection in oral and maxillofacial surgery patients Oral Surg Oral Med Oral Pathol 1993 76(3):272 5 8378039
Dodson TB, Perrott DH, Gongloff RK, et al Human immunodeficiency virus serostatus and the risk of postextraction complications Int J Oral Maxillofac Surg 1994 23(2):100 3 8035049
Donnelly JP Is there a rationale for the use of antimicrobial prophylaxis in neutropenic patients? J Intern Med Suppl 1997 242(740):79 88 9350187
Dougherty MA, Slots J Periodontal diseases in young individuals J Calif Dent Assoc 1993 21(1):55 69 7682608
Douglas R, Spelman D, Czarny D, et al Successful desensitization of two patients who previously developed Stevens-Johnson syndrome while receiving trimethoprim-sulfamethoxazole Clin Infect Dis 1997 25(6):
Downey DC Oral manifestations and their management in AIDS and HIV-positive patients J Oreg Dent Assoc 1987 57(1):36 8 3478460
Doyal L Good ethical practice in the dental treatment of patients with HIV/AIDS Oral Dis 1997 3(Suppl 1):214 20
Dranitsaris G, Phillips P, Rotstein C, et al Economic analysis of fluconazole versus amphotericin B for the treatment of candidemia in non-neutropenic patients Pharmacoeconomics 1998 13(5I):509 18 10180750
Driessen M, Ellis JB, Muwazi F, et al The treatment of systemic candidiasis in neonates with oral fluconazole Ann Trop Paediatr 1997 17(3):263 71 9425383
Drinkard CR, Decher L, Little JW, et al Periodontal status of individuals in early stages of human immunodeficiency virus infection Community Dent Oral Epidemiol 1991 19(5):281 5 1742994
Driscoll JM, Hoffman MA Exploring attitudes of white dental students regarding willingness to treat people with HIV J Dent Educ 1997 61(9):717 26 9316591
Dromer F, Improvisi L, Dupont B, et al Oral transmission of Candida albicans between partners in HIV-infected couples could contribute to dissemination of fluconazole-resistant isolates AIDS 1997 11(9):1095 1101 9233455
Dronda F, Alonso-Sanz M, Laguna F, et al Mixed oropharyngeal candidiasis due to Candida albicans and non-albicans Candida strains in HIV-infected patients Eur J Clin Microbiol Infect Dis 1996 15(6):446 52 8839637
Dube MP, Sattler FR Prevention and treatment of opportunistic infections Curr Opin Infect Dis 1993 6(2):230 6
Duffy RE, Adelson R, Niessen LC, et al VA oral HIV surveillance program: Understanding the disease J Am Dent Assoc 1992 123(10):57 62
Dull JS, Sen P, Raffanti S, et al Oral candidiasis as a marker of acute retroviral illness South Med J 1991 84(6):733 5, 739 2052963
Dupont B, Drouhet E. Fluconazole for the treatment of fungal diseases in immunosuppressed patients. Ann N Y Acad Sci. 1988;544:564-70. [pmid: 2850757].
Dupont B, Drouhet E Fluconazole in the management of oropharyngeal candidosis in a predominantly HIV antibody-positive group of patients J Med Vet Mycol 1988 26(1):67 71 2837559
Dupont BF, Dromer F, Improvisi L The problem of azole resistance in Candida Journal de Mycologie Medicale 1996 6(Suppl 2):12 9
Durham TM, Hodges ED, Swindels S, et al Facial nerve paralysis related to HIV disease. Case report and dental considerations Oral Surg Oral Med Oral Pathol 1993 75(1):37 40 7678319
Eichel M, Just-Nubling G, Helm EB, et al Itraconazole suspension in the treatment of HIV-infected patients suffering from fluconazole-resistant oropharyngeal and oesophageal candidosis Mycoses 1996 39(Suppl 1):102 6 8767280
Eickhoff TC, Gullen DJ, Addington W, et al Human immunodeficiency virus infection Clin Infect Dis 1994 18(6):963 73 8086560
Eickhoff TC, Gullen DJ, Addington W, et al Human immunodeficiency virus (HIV) infection Ann Intern Med 1994 120(4):310 19 8291825
Eisenberg E, Krutchkoff D, Yamase H Incidental oral hairy leukoplakia in immunocompetent persons: A report of two cases Oral Surg Oral Med Oral Pathol 1992 74(3):332 3 1328983
el-Labban N, Rindum J, Nielsen H, et al Crystalline inclusions in epithelial cells of hairy leukoplakia: A new ultrastructural finding Scand J Dent Res 1988 96(4):353 9 2842854
Elkins DA, Torabinejad M, Schmidt RE, et al Polymerase chain reaction detection of human immunodeficiency virus DNA in human periradicular lesions J Endod 1994 20(8):386 8 7996105
Elliott JN, Oertel YC Lymphoepithelial cysts of the salivary glands: Histologic and cytologic features American J Clin Pathol 1990 93(1):39 43
Ellis E, Sinn DP Use of homologous bone in maxillofacial surgery J Oral Maxillofac Surg 1993 51(11):1181 93 8229389
Elmets CA Management of common superficial fungal infections in patients with AIDS J Am Acad Dermatol 1994 31(3 II):S60 S63 8077510
Enwonwu CO, Meeks VI, Sawiris PG Elevated cortisol levels in whole saliva in HIV infected individuals Eur J Oral Sci 1996 104(3):322 4 8831069
Epstein JB Management of oral Kaposi's sarcoma and a proposal for clinical staging Oral Dis 1997 3(Suppl 1):124 8
Epstein JB Oropharyngeal candidiasis in the immunocompetent host Journal de Mycologie Medicale 1996 6(Suppl 2):31 41
Epstein JB, Sherlock CH, Greenspan JS Hairy leukoplakia-like lesions following bone-marrow transplantation AIDS 1991 5(1):101 2 1647786
Erbsloh-Moller B, Steinhoff J, Sack K Peritoneal dialysis in the treatment of Candida peritonitis Dtsch Med Wochenschr 1993 118(33):1216 17 8359118
Ertl L, Pletschette M HIV infection and dentistry. Basic aspects and prevention Z Stomatol 1988 85(5):289 311 3079096
Ertl L, Wewalka G, Koller W, et al Dental care of HIV carriers Z Stomatol 1989 86(5 Suppl 4):1 12
Escalante Aguilar RM, Marchante Cepillo I, De la Maya Retamar MD, et al Chronic disseminated candidiasis and treatment with liposomal amphotericin B in children Farmacia e Clinica 1997 14(10):679 82
Esposito R, Castagna A, Uberti Foppa C Maintenance therapy of oropharyngeal candidiasis in HIV-infected patients with fluconazole AIDS 1990 4(10):1033 4
European Community Clearinghouse on Oral Problems Related to HIV Infection and World Health Organization Collaborating Centre on Oral Manifestations of the Immunodeficiency Virus: Classification and diagnostic criteria for oral lesions in HIV infection. J Oral Pathol Med. 1993;22:289-91. [pmid: 8229864].
Evans WK, Shepherd FA, Feld R, et al Nystatin lozenges: A useful treatment for oral candidiasis in cancer patients Curr Ther Res 1987 42(6):1201 9
Eversole LR Viral infections of the head and neck among HIV-seropositive patients Oral Surg Oral Med Oral Pathol 1992 73(2):155 63 1312690
Eversole LR, Reichart PA, Ficarra G, et al Oral keratinocyte immune responses in HIV-associated candidiasis Oral Surg Oral Med Oral Pathol Oral Radiol Endod 1997 84(4):372 80 9347501
Eyster ME, Rabkin CS, Hilgartner MW, et al Human immunodeficiency virus-related conditions in children and adults with hemophilia: Rates, relationship to CD4 counts, and predictive value Blood 1993 81(3):828 34 8427974
Fan-Havard P, Capano D, Smith SM, et al Development of resistance in Candida isolates from patients receiving prolonged antifungal therapy Antimicrob Agents Chemother 1991 35(11):2302 5 245375 1804002
Fan-Havard P, O'Donovan C, Smith SM, et al Oral fluconazole versus amphotericin B bladder irrigation for treatment of candidal funguria Clin Infect Dis 1995 21(4):960 5 8645847
Farace R, Passannanti G, Cirillo D, et al Single dose oral fluconazole in the treatment of vaginal candidiasis Giornale Italiano di Ostetricia e Ginecologia 1992 14(2):99 101
Faro S New treatments for vulvovaginal candidiasis Infect Dis Obstet Gynecol 1996 4(4):247 54 18476101
Faruque S, Edlin BR, McCoy CB, et al Crack cocaine smoking and oral sores in three inner-city neighborhoods J Acquir Immune Defic Syndr 1996 13(1):87 92
Fauci AS. Field Hearings on AIDS, Senate Appropriations Committee, Subcommittee on Labor, Health and Human Services, and Education: San Francisco. July 9, 1999.
Feigal DW, Katz MH, Greenspan D, et al The prevalence of oral lesions in HIV-infected homosexual and bisexual men: Three San Francisco epidemiological cohorts AIDS 1991 5(5):519 25 1863403
Felix DH, Jalal H, Cubie HA, et al Detection of Epstein-Barr virus and human papillomavirus type 16 DNA in hairy leukoplakia by in situ hybridisation and the polymerase chain reaction J Oral Pathol Med 1993 22(6):277 81 8394930
Felix DH, Watret K, Wray D, et al Hairy leukoplakia in an HIV-negative, nonimmunosuppressed patient Oral Surg Oral Med Oral Pathol 1992 74(5):563 6 1331928
Felix DH, Wray D The prevalence of oral candidiasis in HIV-infected individuals and dental attenders in Edinburgh J Oral Pathol Med 1993 22(9):418 20 8301607
Fernandez JF, Benito MA, Lizaldez EB, et al Oral hairy leukoplakia: A histopathologic study of 32 cases Am J Dermatopathol 1990 12(6):571 8 2176438
Ferraro FJJ, Rush BFJ, Ruark D, et al Enucleation of parotid lymphoepithelial cyst in patients who are human immunodeficiency virus positive Surg Gynecol Obstet 1993 177(5):524 6 8211607
Fetter A, Partisani M, Koenig H, et al Asymptomatic oral Candida albicans carriage in HIV-infection: Frequency and predisposing factors J Oral Pathol Med 1993 22(2):57 9 8095300
Ficarra G, Barone R, Gaglioti D, et al Oral hairy leukoplakia among HIV-positive intravenous drug abusers: A clinicopathologic and ultrastructural study Oral Surg Oral Med Oral Pathol 1988 65(4):421 6 3283634
Ficarra G, Chiodo M, Morfini M, et al Oral lesions among HIV-infected hemophiliacs: A study of 54 patients Haematologica 1994 79(2):148 53 8063262
Ficarra G, Gaglioti D, Di Pietro M, et al Oral hairy leukoplakia: Clinical aspects, histologic morphology and differential diagnosis Head Neck 1991 13(6):514 21 1791145
Ficarra G, Miliani A, Adler-Storthz K, et al Recurrent oral condylomata acuminata and hairy leukoplakia: An early sign of myelodysplastic syndrome in an HIV-seronegative patient J Oral Pathol Med 1991 20(8):398 402 1658314
Ficarra G, Romagnoli P, Piluso S, et al Hairy leukoplakia with involvement of the buccal mucosa J Am Acad Dermatol 1992 27(5 Pt 2):855 8 1469145
Fichtenbaum CJ, Powderly WG Refractory mucosal candidiasis in patients with human immunodeficiency virus infection Clin Infect Dis 1998 26(3):556 65 9524822
Fidel PLJ, Cutright JL, Sobel JD Efficacy of D0870 treatment of experimental Candida vaginitis Antimicrob Agents Chemother 1997 41(7):1455 9 163939 9210665
Field EA, Millns B, Pearce PK, et al Fluconazole therapy of oropharyngeal candidiasis in a patient with multiple endocrine failure does not correlate with Candida albicans susceptibility to fluconazole in vitro J Med Vet Mycol 1996 34(3):205 8 8803802
Finfer MD, Schinella RA, Rothstein SG, et al Cystic parotid lesions in patients at risk for the acquired immunodeficiency syndrome Arch Otolaryngol Head Neck Surg 1988 114(11):1290 4 3166761
Fisher DA, Daniels TE, Greenspan JS Oral hairy leukoplakia unassociated with human immunodeficiency virus: Pseudo oral hairy leukoplakia J Am Acad Dermatol 1992 27(2 Pt 1):257 8 1430365
Flaitz CM, Hicks MJ, Carter AB, et al Saliva collection technique for cytologic, microbiologic and viral evaluation in pediatric HIV infection ASDC J Dent Child 1998 65(5):318 24, 355 9795735
Flaitz CM, Nichols CM, Hicks MJ Oral malignancies diagnosed in an HIV-dedicated dental clinic Tex Dent J 1996 113(6):49 57 9518848
Flanigan TP Fluconazole prophylaxis in AIDS: The jury is not yet out AIDS 1995 9(1):
Flynn PM, Cunningham CK, Kerkering T, et al Oropharyngeal candidiasis in immunocompromised children: A randomized, multicenter study of orally administered fluconazole suspension versus nystatin. The Multicenter Fluconazole Study Group J Pediatr 1995 127(2):322 8 7636666
Foltyn P Dry mouth in HIV infection Med J Aust 1993 159(5):
Foltyn P HIV/AIDS and dental services Med J Aust 1991 154(6):
Fong IW Clinical and cost considerations in the pharmacotherapy of vulvovaginal candidiasis Pharmacoeconomics 1996 9(6):497 505 10160477
Fong IW The value of chronic suppressive therapy with itraconazole versus clotrimazole in women with recurrent vaginal candidiasis Genitourin Med 1992 68(6):374 7 1336762
Force RW, Nahata MC Salivary concentrations of ketoconazole and fluconazole: Implications for drug efficacy in oropharyngeal and esophageal candidiasis Ann Pharmacother 1995 29(1):10 15 7711339
Fotos PG. Evaluation of prognosis and survival of the HIV-infected patient. Oral Surg Oral Med Oral Pathol. 1992;74:386-92. [pmid: 1408007].
Fox PC Saliva and salivary gland alterations in HIV infection J Am Dent Assoc 1991 122(12):46 48 1686879
Fox R, Neal KR, Leen CLS, et al Fluconazole resistant Candida in AIDS J Infect 1991 22(2):201 4
Freedberg KA, Scharfstein JA, Seage GR, et al The cost-effectiveness of preventing AIDS-related opportunistic infections [published erratum appears in JAMA 1999;281(21):1989] JAMA 1998 279(2):130 6 9440663
Freeman EM AIDS file: New oral antifungal may replace i.v. treatment Am J Nurs 1990 90(5):
Frega A, Gallo G, Di Renzi F, et al Persistent vulvovaginal candidiasis: Systemic treatment with oral Fluconazole Clin Exp Obstet Gynecol 1994 21(4):259 62 7994878
Freund BJ, McKay G, Silver N, et al AIDS in dentistry: Risks and protocol Ont Dent 1987 64(4):81 6 2952928
Friedland IR HIV-related practices and ethics -- survey of opinions in a paediatric department S Afr Med J 1991 79(9):529 32 2024207
Friedman PR The patient with AIDS Management procedures. Oral Health 1987 77(8):27 31
Friedman RB, Gunsolley J, Gentry A, et al Periodontal status of HIV-seropositive and AIDS patients J Peridontol 1991 62(10):623 7
Friese K, Mendling W Oral versus local therapy of vagina candidiasis Gynakologe 1996 29(3):221 8
Fromtling RA, Castaner J Voriconazole Drugs of the Future 1996 21(3):266 71
Fuerst ML Current trends in the treatment and prevention of opportunistic infections AIDS Patient Care 1993 7(1):38 9
Fuji R, Matsumoto S, Sakiyama Y, et al A clinical study of fluconazole-granules and -injectable in pediatric patients with deep-seated mycoses Jpn J Antibiot 1993 46(8):654 85 8230735
Galaif ER, Stein JA, Nyamathi AM Ethnic differences in risk for HIV infection and STDs in a sample of African-American and Latina homeless women Journal of Sex Education & Therapy 1999 24(1-2):71 80
Gallagher PD, Gealer M, Birnbaum W Resource implications for oral care of patients with HIV Oral Dis 1998 4(1):22 5 9655040
Gallo RC, Salahuddin SZ, Popovic M., et al. Frequent detection and isolation of cytopathic retrovirus (HTLV-III) from patients with AIDS and at risk for AIDS. Science. 1984;224:500-3. [pmid: 6200936].
Garamvolgyi Gy, Gasztonyi Z, Lintner F Topical application of Nizoral cream on external genitalia Magyar Noorvosok Lapja 1991 54(2):105 7
Garber GE Fluconazole: A new option in the treatment of Candida mucositis and esophageal candidiasis J Otolaryngol 1992 21(2):92 4 1583715
Garber GE Treatment of oral Candida mucositis infections Drugs 1994 47(5):734 40 7520855
Garcia-Hermoso D, Dromer F, Improvisi L, et al Fluconazole concentrations in saliva from AIDS patients with oropharyngeal candidosis refractory to treatment with fluconazole Antimicrob Agents Chemother 1995 39(3):656 60 162600 7793868
Gasparini R, Pozzi T, Bonanni P, et al Study on the hygienic conditions of dentist offices in the province of Siena in the years 1992-1993 Journal of Preventive Medicine & Hygiene 1995 36(1-2):15 23
Geier SA, Libera S, Klauss V, et al Sicca syndrome in patients infected with the human immunodeficiency virus [published erratum appears in Ophthalmology 1996;103(2):204] Ophthalmology 1995 102(9):1319 24 9097769
Gentry EM, Nowak G, Salmon CT, et al Addressing the public's concerns about human immunodeficiency virus transmission in health-care settings Arch Intern Med 1993 153(20):2334 40 8215736
Gerberding JL, Henderson DK Management of occupational exposures to bloodborne pathogens: Hepatitis B virus, hepatitis C virus, and human immunodeficiency virus Clin Infect Dis 1992 14(6):1179 85 1623073
Gerbert B, Bernzweig J, Bleecker T, et al How dentists see themselves, their profession, the public J Am Dent Assoc 1992 123(12):72 8
Gerbert B, Bleecker T, Berlin M, et al HIV-infected health care professionals: Public opinion about testing, disclosing, and switching Arch Intern Med 1993 153(3):313 20 8427536
Gerbert B, Bleecker T, Saub E Risk perception and risk communication: Benefits of dentist-patient discussions J Am Dent Assoc 1995 126(3):333 9 7897102
Gerbert B, Maguire BT, Spitzer S Patients' attitudes toward dentistry and AIDS J Am Dent Assoc 1989Suppl:16 21
Gerbert B, Sumser J, Chamberlin K, et al Dental care experience of HIV-positive patients J Am Dent Assoc 1989 119(5):601 3 2532657
Gershon RRM, Karkashian C, Vlahov D, et al Correlates of infection control practices in dentistry Am J Infect Control 1998 26(1):29 34 9503110
Gibbs DL Fluconazole in the treatment of systemic candidiasis: An open-label, noncomparative, multinational study Curr Ther Res 1998 59(4):197 202
Gibson BJ, Freeman R Dangerousness and dentistry: An explanation of dentists' reactions and responses to the treatment of HIV-seropositive patients Community Dent Oral Epidemiol 1996 24(5):341 5 8954221
Gibson BJ, Freeman RE, McCartan BE Levels of dangerousness: An analysis of Irish dentists' clinical responses to HIV-seropositive patients Int J STD AIDS 1997 8(7):451 5 9228593
Gil A, Lavilla P, Lopez Dupla M, et al Treatment of Candida esophagitis with fluconazole in acquired immunodeficiency syndrome: Comparative study of two therapeutic regimens Med Clin 1992 98(16):612 7
Gil A, Lavilla P, Valencia E, et al Safety and efficacy of fluconazole treatment for Candida oesophagitis in AIDS Postgrad Med J 1991 67(788):548 52 1924024
Gilbert AD, Nuttall NM Blood-borne viruses: Recommendations regarding the teaching of the clinical management of dental patients to undergraduate dental students Med Teach 1996 18(1):47 9
Gilbert AD, Nuttall NM Knowledge of the human immunodeficiency virus among final year dental students J Dent 1994 22(4):229 35 7962898
Gillespie GM, Marino R Oral manifestations of HIV infection: A Panamerican perspective J Oral Pathol Med 1993 22(1):2 7 7678293
Gilmore N HIV disease: Present status and future directions Oral Surg Oral Med Oral Pathol 1992 73(2):236 43 1532239
Girmenia C, Martino P, White MH Fluconazole and the changing epidemiology of candidemia Clin Infect Dis 1998 27(1):232 33 9675496
Glatt AE Therapy for oropharyngeal candidiasis in HIV-infected patients J Acquir Immune Defic Syndr 1993 6(12):1317 8 8254468
Glick M Clinical protocol for treating patients with HIV disease Gen Dent 1990 38(6):418 25 2151446
Glick M A clinician's view of the HIV question N Y State Dent J 1993 59(3):39 42 8459948
Glick M Evaluation of prognosis and survival of the HIV-infected patient Oral Surg Oral Med Oral Pathol 1992 74(3):386 92 1408007
Glick M, Abel SN, Muzyka BC, et al Dental complications after treating patients with AIDS J Am Dent Assoc 1994 125(3):296 301 8157842
Glick M, Burris S The professional responsibility for care Oral Dis 1997 3(Suppl 1):221 4
Glick M, Muzyka BC, Lurie D, et al Oral manifestations associated with HIV-related disease as markers for immune suppression and AIDS Oral Surg Oral Med Oral Pathol 1994 77(4):344 9 8015797
Glick M, Muzyka BC, Salkin LM, et al Necrotizing ulcerative periodontitis: A marker for immune deterioration and a predictor for the diagnosis of AIDS J Peridontol 1994 65(5):393 7
Gloeb DJ, Lai S, Efantis J, et al Survival and disease progression in human immunodeficiency virus-infected women after an index delivery Am J Obstet Gynecol 1992 167(1):152 7 1359787
Goa KL, Barradell LB Fluconazole An update of its pharmacodynamic and pharmacokinetic properties and therapeutic use in major superficial and systemic mycoses in immunocompromised patients. Drugs 1995 50(4):658 90
Goddart D, Francois A, Ninane J, et al Parotid gland abnormality found in children seropositive for the human immunodeficiency virus (HIV) Ped Radiol 1990 20(5):355 7
Godin G, Naccache H, Brodeur JM, et al Understanding the intention of dentists to provide dental care to HIV+ and AIDS patients Community Dent Oral Epidemiol 1999 27(3):221 7 10385361
Goldberg MH, Nemarich AN, Marco WP Complications after mandibular third molar surgery: A statistical analysis of 500 consecutive procedures in private practice J Am Dent Assoc 1985 111(2):277 9 3862695
Goldstein J, Rubin J, Silver C, et al Radiation therapy as a treatment for benign lymphoepithelial parotid cysts in patients infected with human immunodeficiency virus-1 Int J Radiat Oncol Biol Phys 1992 23(5):1045 50 1639639
Goldstein SM Advances in the treatment of superficial Candida infections Semin Dermatol 1993 12(4):315 30 8312148
Gomez RS, de Souza PE, da Costa JE, et al CD30+ lymphocytes in chronic gingivitis from HIV-positive patients: A pilot study J Peridontol 1997 68(9):881 83
Gooch BF, Siew C, Cleveland JL, et al Occupational blood exposure and HIV infection among oral and maxillofacial surgeons Oral Surg Oral Med Oral Pathol Oral Radiol Endod 1998 85(2):128 34 9503444
Gordon DL, Maddern J Treatment of Candida epididymo-orchitis with oral flucanozole Med J Aust 1992 156(10):
Gore SM, Felix DH, Bird AG, et al Occupational risk and precautions related to HIV infection among dentists in the Lothian region of Scotland J Infect 1994 28(2):209 22 8035002
Gorney M A tale of two heartaches Ann Plast Surg 1997 39(6):666 7 9418934
Gornitsky M Canadian hospital dental department is engaged in HIV and AIDS research J Can Dent Assoc 1988 54(9):
Gornitsky M, Clark DC, Siboo R, et al Clinical documentation and occurrence of putative periodontopathic bacteria in human immunodeficiency virus-associated periodontal disease J Peridontol 1991 62(9):576 85
Gostin LO, Feldblum C, Webber DW Disability discrimination in America: HIV/AIDS and other health conditions JAMA 1999 281(8):745 52 10052447
Gottfredsson M, Cox GM, Indridason OS, et al Association of plasma levels of human immunodeficiency virus type 1 RNA and oropharyngeal Candida colonization J Infect Dis 1999 180(2):534 7 10395877
Gould IM Systemic anti-fungal prophylaxis in immunocompromised patients Antiinfective Drugs & Chemotherapy 1996 14(3):181 5
Gowdey G, Alijanian A Necrotizing ulcerative periodontitis in an HIV patient J Calif Dent Assoc 1995 23(1):57 9
Grace EG, Cohen LA Attitudes of Maryland dentists toward AIDS and hepatitis patients Am J Dent 1993 6(1):32 4 8329159
Graham NM, Nelson KE, Solomon L, et al Prevalence of tuberculin positivity and skin test anergy in HIV-1-seropositive and -seronegative intravenous drug users JAMA 1992 267(3):369 73 1727959
Graham PE, Harel-Reviv M The law and ethics in relation to dentists treating HIV-positive patients: Report on a recent U.S. Supreme Court case J Can Dent Assoc 1999 65(1):27 30 9973763
Graybill JR Future directions of antifungal chemotherapy Clin Infect Dis 1992 14(Suppl 1):170 81
Graybill JR, Montalbo E, Kirkpatrick WR, et al Fluconazole versus Candida albicans: A complex relationship Antimicrob Agents Chemother 1998 42(11):2938 42 105969 9797229
Graybill JR, Najvar LK, Holmberg JD, et al Fluconazole treatment of Candida albicans infection in mice: Does in vitro susceptibility predict in vivo response? Antimicrob Agents Chemother 1995 39(10):2197 200 162913 8619566
Graybill JR, Vazquez J, Darouiche RO, et al Randomized trial of itraconazole oral solution for oropharyngeal candidiasis in HIV/AIDS patients Am J Med 1998 104(1):33 9 9528717
Grbic JT, Lamster IB, Mitchell-Lewis D Inflammatory and immune mediators in crevicular fluid from HIV-infected injecting drug users J Peridontol 1997 68(3):249 55
Grbic JT, Mitchell-Lewis DA, Fine JB, et al The relationship of candidiasis to linear gingival erythema in HIV-infected homosexual men and parenteral drug users J Peridontol 1995 66(1):30 7
Green J Psychological aspects of infection control and the care of the patient with HIV in dentistry Oral Dis 1997 3(Suppl 1):225 8
Greenberg MS, Dubin G, Stewart JC, et al Relationship of oral disease to the presence of cytomegalovirus DNA in the saliva of AIDS patients Oral Surg Oral Med Oral Pathol Oral Radiol Endod 1995 79(2):175 9 7614180
Greene VA, Chu SY, Diaz T, et al Oral health problems and use of dental services among HIV-infected adults. Supplement to HIV/AIDS Surveillance Project Group J Am Dent Assoc 1997 128(10):1417 22 9332143
Greenspan D Treatment of oral candidiasis in HIV infection Oral Surg Oral Med Oral Pathol 1994 78(2):211 5 7936591
Greenspan D Treatment of oropharyngeal candidiasis in HIV-positive patients J Am Acad Dermatol 1994 31(3 Pt 2):S51 5 7915732
Greenspan D, de Villiers EM, Greenspan JS, et al Unusual HPV types in oral warts in association with HIV infection J Oral Pathol 1988 17(9-10):482 8 2854850
Greenspan D, Greenspan JS The mouth in human immunodeficiency virus infection Semin Dermatol 1994 13(2):144 50 8060827
Greenspan D, Shirlaw PJ Management of the oral mucosal lesions seen in association with HIV infection Oral Dis 1997 3(Suppl 1):S229 34 9456695
Greenspan JS. Periodontal complications of HIV infection. Compendium. 1994;Suppl 18:S694-8. [pmid: 8039207].
Greenspan JS Sentinels and signposts: The epidemiology and significance of the oral manifestations of HIV disease Oral Dis 1997 3(Suppl 1):S13 7 9456650
Greenspan JS, Barr CE, Sciubba JJ, et al Oral manifestations of HIV infection: Definitions, diagnostic criteria, and principles of therapy. The USA Oral AIDS Collaborative Group Oral Surg Oral Med Oral Pathol 1992 73(2):142 4 1532234
Greenspan JS, Greenspan D, Winkler JR Diagnosis and management of the oral manifestations of HIV infection and AIDS Infect Dis Clin North Am 1988 2(2):373 85 3060523
Grimes RM, Stevenson GC Oropharyngeal lesions in AIDS Gastrointest Endosc Clin N Am 1998 8(4):783 809 9730932
Grimoud AM, Arnaud C, Dellamonica P, et al Salivary defence factor concentrations in relation to oral and general parameters in HIV positive patients Eur J Oral Sci 1998 106(6):979 85 9879908
Gripshover BM, Valdez H, Salata RA, et al Withdrawal of fluconazole suppressive therapy for thrush in patients responding to combination antiviral therapy including protease inhibitors AIDS 1998 12(18):2513 4 9875599
Groll A, Nowak-Gottl U, Wildfeuer A, et al Fluconazole treatment of oropharyngeal candidosis in spediatric cancer patients with severe mucositis following antineoplastic chemotherapy Mycoses 1992 35(Suppl 1):35 40 1406787
Groll AH, Just-Nubling G, Kurz M, et al Fluconazole versus nystatin in the prevention of Candida infections in children and adolescents undergoing remission induction or consolidation chemotherapy for cancer J Antimicrob Chemother 1997 40(6):855 62 9462438
Growe G, Akabutu J, Ritchie B, et al Hemophilia and von Willebrand's disease: 1. Diagnosis, comprehensive care and assessment CMAJ 1995 153(1):19 25 7796372 1337937
Growe G, Akabutu J, Ritchie H, et al Hemophilia and von Willebrand's disease: 2. Management CMAJ 1995 153(2):147 57 7600466 1338053
Grumbrecht C, Sarnow E Oral therapy of vagina candidiasis: Double-blind, comparative study with a single oral dose of fluconazole (150 mg) vs. intravaginal clotrimazole during 3 days Therapiewoche Schweiz 1992 8(4):337 40
Guccion JG, Redman RS Oral hairy leukoplakia: An ultrastructural study and review of the literature Ultrastruct Pathol 1999 23(3):181 7 10445285
Guiot HFL, Fibbe WE Prevention of oral candidiasis and systemic fungal infection in patients with hematologic malignancies Journal de Mycologie Medicale 1996 6(Suppl 2):26 30
Guistino V, Ayer WA, Wilson CJ Access to dental care: Changes over time for HIV+/AIDS patients Northwest Dent Res 1997 7(2):28 30 9487909
Guntinas-Lichius O, Wagner M, Krueger GF, et al Severe CMV sialadenitis in adults is not always an opportunistic infection of AIDS Int J STD AIDS 1997 8(3):206 7 9089035
Gupta G Viral pathogenesis and opportunistic infections J Calif Dent Assoc 1993 21(9):29 36 7508496
Gurevich I, Dubin R, Cunha BA Dental instrument and device sterilization and disinfection practices J Hosp Infect 1996 32(4):295 304 8744514
Gussenhoven MJ, Haak A, Peereboom-Wynia JD, et al Stevens-Johnson syndrome after fluconazole Lancet 1991 338(8759):
Gyorgy I, Mezey Gy J Treatment of vaginal candidal infection with single dose Diflucan(TM) (fluconazole 150 mg) capsule in adolescence Magyar Noorvosok Lapja 1997 60(4):305 8
Haber J, Koleskova E, Klener P, et al Experience with fluconazole in oropharyngeal and oesophageal candidiasis in immunocompromised patients Lekarsky Obzor 1991 40(5):245 9
Hadfield PJ, Birchall MA, Novelli V, et al The ENT manifestations of HIV infection in children Clin Otolaryngol 1996 21(1):30 6 8674220
Halsey NA, Coberly JS, Holt E, et al Sexual behavior, smoking, and HIV-1 infection in Haitian Women [published erratum appears in JAMA 1992;268(24):3434] JAMA 1992 267(15):2062 6 1485894
Hamilton JN, Thompson SH, Scheidt MJ, et al Correlation of subclinical candidal colonization of the dorsal tongue surface with the Walter Reed staging scheme for patients infected with HIV-1 Oral Surg Oral Med Oral Pathol 1992 73(1):47 51 1534883
Hardie J A 1985 update on AIDS J Can Dent Assoc 1985 51(7):499 502 3161603
Hardie J AIDS and dentistry: A retrospective analysis of the Florida case J Can Dent Assoc 1993 59(12):987 91, 1000 8275392
Hardie J The attitudes and concerns of Canadian dental health care workers toward infection control and the treatment of AIDS patients J Can Dent Assoc 1992 58(2):131 8 1531437
Hardie J Cross-contamination with dental equipment Lancet 1993 341(8838):180 1 Associated with providing dental care to patients with HIV-infected and AIDS patients Med Oral Pathol 1992 73(2):231 5
Hardin TC, Sharkey PK, Lam YF, et al Pharmacokinetics of SCH-39304 in human immunodeficiency virus-infected patients following chronic oral dosing Antimicrob Agents Chemother 1992 36(12):2790 3 245546 1482146
Haria M, Bryson HM Amorolfine: A review of its pharmacological properties and therapeutic potential in the treatment of onychomycosis and other superficial fungal infections Drugs 1995 49(1):103 20 7705210
Haria M, Bryson HM, Goa KL Itraconazole -- a reappraisal of its pharmacological properties and therapeutic use in the management of superficial fungal infections Drugs 1996 51(4):585 620 8706596
Haring JI Case 1: HIV-associated periodontitis RDH 1990 10(1):
Haring JI Case study. Case 7: Kaposi's sarcoma RDH 1989 9(7):13 4 2626548
Hartshorne JE, Carstens IL, Engelbrecht JJ, et al Dental and oral hygiene students' knowledge of HIV infection and AIDS J Dent Assoc S Afr 1994 49(4):161 7 9508935
Hata K, Kimura J, Miki H, et al Efficacy of ER-30346, a novel oral triazole antifungal agent, in experimental models of aspergillosis, candidiasis, and cryptococcosis Antimicrob Agents Chemother 1996 40(10):2243 7 163511 8891122
Hata K, Kimura J, Miki H, et al In vitro and in vivo antifungal activities of ER-30346, a novel oral triazole with a broad antifungal spectrum Antimicrob Agents Chemother 1996 40(10):2237 42 163510 8891121
Hauman CH, Thompson IO, Theunissen F, et al Oral carriage of Candida in healthy and HIV-seropositive persons Oral Surg Oral Med Oral Pathol 1993 76(5):570 2 8247500
Havlir DV, Dube MP, McCutchan JA, et al Prophylaxis with weekly versus daily fluconazole for fungal infections in patients with AIDS Clin Infect Dis 1998 27(6):1369 75 9868644
Hay IS Recognition of oral lesions of HIV infection Br Dent J 1991 170(3):
Hay RJ Antifungal drugs on the horizon J Am Acad Dermatol 1994 31(3 Pt 2):S82 5 8077515
Hay RJ Antifungal therapy of yeast infections J Am Acad Dermatol 1994 31(3 Pt 2):S6 9 8077509
Hazelkorn HM The reaction of dentists to members of groups at risk of AIDS J Am Dent Assoc 1989 119(5):611 9 2532659
Heald AE, Cox GM, Schell WA, et al Oropharyngeal yeast flora and fluconazole resistance in HIV-infected patients receiving long-term continuous versus intermittent fluconazole therapy AIDS 1996 10(3):263 8 8882665
Healy E, Meenan J, Mulcahy F, et al The spectrum of HIV related skin diseases in an Irish population Ir Med J 1993 86(6):188 90 8106224
Hegener P, Troke PF, Fatkenheuer G, et al Treatment of fluconazole-resistant candidiasis with voriconazole in patients with AIDS AIDS 1998 12(16):2227 8 9833866
Heimdahl A, Nord CE Oral infections in immunocompromised patients J Clin Periodontol 1990 17(7 II):501 3 2202747
Heinic GS, Greenspan D, MacPhail LA, et al Oral Geotrichum candidum infection associated with HIV infection: A case report Oral Surg Oral Med Oral Pathol 1992 73(6):726 8 1437044
Heinic GS, Greenspan D, MacPhail LA, et al Oral Histoplasma capsulatum infection in association with HIV infection: A case report J Oral Pathol Med 1992 21(2):85 9 1556667
Heinic GS, Stevens DA, Greenspan D, et al Fluconazole-resistant Candida in AIDS patients: Report of two cases Oral Surg Oral Med Oral Pathol 1993 76(6):711 5 8284074
Heller EM, Sidhu GS, Kaufman D Pathologic quiz case 1. Oral hairy leukoplakia (HL) Arch Otolaryngol Head Neck Surg 1989 115(5):636 8
Herbst JS, Morgan J, Raab-Traub N, et al Comparison of the efficacy of surgery and acyclovir therapy in oral hairy leukoplakia J Am Acad Dermatol 1989 21(4 Pt 1):753 6 2808791
Hernandez-Sampelayo T Fluconazole versus ketoconazole in the treatment of oropharyngeal candidiasis in HIV-infected children. Multicentre Study Group Eur J Clin Microbiol Infect Dis 1994 13(4):340 4 8070443
Hicks MJ, Carter AB, Rossmann SN, et al Detection of fungal organisms in saliva from HIV-infected children: A preliminary cytologic analysis Pediatr Dent 1998 20(3):162 8 9635310
Hillis DM, Huelsenbeck JP Support for dental HIV transmission Nature 1994 369(6475):24 5 8164734
Hilton JF Functions of oral candidiasis episodes that are highly prognostic for AIDS Stat Med 2000 19(7):989 1004 10750064
Hilton JF, Donegan E, Katz MH, et al Development of oral lesions in human immunodeficiency virus-infected transfusion recipients and hemophiliacs Am J Epidemiol 1997 145(2):164 74 9006313
Hiruma M Efficacy and limitations of new antifungal drugs used against subcutaneous mycoses Jpn J Med Mycology 1994 35(4):353 9
Hoc S Single dose treatment of genital mycoses with fluconazole Dtshe Apoth Ztg 1993 133(2):30 2
Hoch BS, Namboodiri NK, Banayat G, et al The use of fluconazole in the management of Candida peritonitis in patients on peritoneal dialysis Perit Dial Int 1993 13(Suppl 2):S357 9 8399611
Hodgson TA HIV-associated oral lesions: Prevalence in Zambia Oral Dis 1997 3(Suppl 1):S46 50 9456656
Hoegl L, Thoma-Greber E, Rocken M, et al Persistent oral candidosis by non-albicans Candida strains including Candida glabrata in a human immunodeficiency virus-infected patient observed over a period of 6 years Mycoses 1998 41(7-8):335 8 9861840
Hofer D, Hammerle CH, Grassi M, et al The effect of a single mechanical treatment on the subgingival microflora in patients with HIV-associated gingivitis J Clin Periodontol 1996 23(3 Pt 1):180 7 8707976
Hogg RS, Rhone SA, Yip B, et al Antiviral effect of double and triple drug combinations amongst HIV-infected adults: Lessons from the implementation of viral load-driven antiretroviral therapy AIDS 1998 12(3):279 84 9517990
Hollier LM, Cox SM Fluconazole (Diflucan(TM)) Infect Dis Obstet Gynecol 1995-96 3(6):222 5
Holmes J, Clements D Jaundice in HIV positive haemophiliac Lancet 1989 1(8645):
Hood S, Bonington A, Evans J, et al Reduction in oropharyngeal candidiasis following introduction of protease inhibitors AIDS 1998 12(4):447 8
Hood S, Evans J, Bond J, et al The treatment of oropharyngeal candidiasis in HIV-infected patients with oral amphotericin B suspension AIDS Patient Care & STDS 1998 12(8):625 7 15468434
Hood SV, Hollis S, Percy M, et al Assessment of therapeutic response of oropharyngeal and esophageal candidiasis in AIDS with use of a new clinical scoring system: Studies with D0870 Clin Infect Dis 1999 28(3):587 96 10194083
Hoppe J, Burr R, Ebeling H, et al Treatment of oropharyngeal candidiasis in immunocompetent infants: A randomized multicenter study of miconazole gel vs.nystatin suspension Pediatr Infect Dis J 1997 16(3):288 93 9076817
Hoppe JE Comparison of miconazole oral gen and two nystatin oral gels for oral thrush treatment in infants Sozialpadiatrie und Kinderarztliche Praxis 1996 18(2):73 4
Hoppe JE, Friess D, Niethammer D Orointestinal yeast colonization of paediatric oncologic patients during antifungal prophylaxis: Results of quantitative culture and Candida serology and comparison of three polyenes Mycoses 1995 38(1-2):41 9 7637681
Horning GM, Cohen ME Necrotizing ulcerative gingivitis, periodontitis, and stomatitis: Clinical staging and predisposing factors J Peridontol 1995 66(11):990 8
Horowitz BJ, Giaquinta D, Ito S Evolving pathogens in vulvovaginal candidiasis: Implications for patient care J Clin Pharmacol 1992 32(3):248 55 1564129
Horowitz BJ, Weisberg M, James JA, et al New directions in diagnosis and therapy of vulvovaginal candidiasis Curr Obstet Gynecol Fertil 1990 13(6):229 32
Horowitz LG Risk communication in dental practice: Responding assertively to AIDS, fear and infection control J Tenn Dent Assoc 1993 73(3):16 18, 65 8152236
Howell RB, Jandinski JJ, Palumbo P, et al Oral soft tissue manifestations and CD4 lymphocyte counts in HIV-infected children Pediatr Dent 1996 18(2):117 20 8710712
Hsia DC, Fleishman JA, East JA, et al Pediatric human immunodeficiency virus infection: Recent evidence on the utilization and costs of health services Arch Pediatr Adolesc Med 1995 149(5):489 96 7735400
Hu DJ, Kane MA, Heymann DL Transmission of HIV, hepatitis B virus, and other bloodborne pathogens in health care settings: A review of risk factors and guidelines for prevention Bull World Health Organ 1991 69(5):623 30 1959164
Huang TC, Chung WK Fluconazole in the treatment of Candida peritonitis in continuous ambulatory peritoneal dialysis: Report of a case J Formos Med Assoc 1993 92(2):190 1 8101752
Huber MA, Hall EH, Rathbun WA The role of the dentist in diagnosing infection in the AIDS patient Milit Med 1989 154(6):315 8
Hudson-Davies SC, Jones JH, Sarll DW Cross-infection control in general dental practice: Dentists' behaviour compared with their knowledge and opinions Br Dent J 1995 178(10):365 9 7779502
Humphris GM, Morrison T, Horne L Perception of risk of HIV infection from regular attenders to an industrial dental service Br Dent J 1993 174(10):371 8 8494667
Hundt W, Hofmann H In vitro susceptibility and sterol biosynthesis of Candida albicans strains after long-term treatment with azoles in HIV-infected patients Infection 1994 22(2):124 31 8070926
Hunter KD, Gibson J, Lockhart P, et al Fluconazole-resistant Candida species in the oral flora of fluconazole-exposed HIV-positive patients Oral Surg Oral Med Oral Pathol Oral Radiol Endod 1998 85(5):558 64 9619674
Hurley SF, Bond LM, Carlin JB, et al A method for estimating baseline health care costs J Epidemiol Community Health 1995 49(5):525 31 7499997
Husak R, Garbe C, Orfanos CE Oral hairy leukoplakia in 71 HIV-seropositive patients: Clinical symptoms, relation to immunologic status, and prognostic significance J Am Acad Dermatol 1996 35(6):928 34 8959952
Imam N, Carpenter CC, Mayer KH, et al Hierarchical pattern of mucosal Candida infections in HIV-seropositive women Am J Med 1990 89(2):142 6 1974383
Imbert-Bernard C, Valentin A, Reynes J, et al Relationship between fluconazole sensitivity of Candida albicans isolates from HIV positive patients and serotype, adherence and CD4+ lymphocyte count Eur J Clin Microbiol Infect Dis 1994 13(9):711 6 7843175
Inman W, Pearce G, Wilton L Safety of fluconazole in the treatment of vaginal candidiasis: A prescription-event monitoring study, with special reference to the outcome of pregnancy Eur J Clin Pharmacol 1994 46(2):115 8 8039528
Irigoyen M, Zepeda M, Lopez-Camara V Factors associated with Mexico City dentists' willingness to treat AIDS/HIV-positive patients Oral Surg Oral Med Oral Pathol Oral Radiol Endod 1998 86(2):169 74 9720091
Itescu S, Dalton J, Zhang HZ, et al Tissue infiltration in a CD8 lymphocytosis syndrome associated with human immunodeficiency virus-1 infection has the phenotypic appearance of an antigenically driven response J Clin Invest 1993 91(5):2216 25 288224 8486784
Itin P Oral hairy leukoplakia in HIV-negative immunosuppressed patients J Am Acad Dermatol 1990 23(5 Pt 1):957 8 2254496
Itin P, Rufli T, Rudlinger R, et al Oral hairy leukoplakia in a HIV-negative renal transplant patient: A marker for immunosuppression? Dermatologica 1988 177(2):126 8 2844612
Itula PF, Mackenzie SB, Lewis K, et al Orofacial manifestations and seroprevalence of HIV infection in Namibian dental patients Oral Dis 1997 3(Suppl 1):S51 3 9456657
Jabra-Rizk MA, Baqui AA, Kelley JI, et al Identification of Candida dubliniensis in a prospective study of patients in the United States J Clin Microbiol 1999 37(2):321 6 84296 9889211
Jacob LS, Flaitz CM, Nichols CM, et al Role of dentinal carious lesions in the pathogenesis of oral candidiasis in HIV infection J Am Dent Assoc 1998 129(2):187 94 9495050
Jaffe HW, McCurdy JM, Kalish ML, et al Lack of HIV transmission in the practice of a dentist with AIDS Ann Intern Med 1994 121(11):855 9 7978698
Jahn S, Busch HW, Altmeyer P Oral hairy leukoplakia in HIV-positive patients J Am Acad Dermatol 1998 38(2 Pt 1):284 6
Jandourek A, Vaishampayan JK, Vazquez JA Efficacy of melaleuca oral solution for the treatment of fluconazole refractory oral candidiasis in AIDS patients AIDS 1998 12(9):1033 7 9662200
Johnson EM, Warnock DW, Luker J, et al Emergence of azole drug resistance in Candida species from HIV-infected patients receiving prolonged fluconazole therapy for oral candidosis J Antimicrob Chemother 1995 35(1):103 14 7768758
Jones AC, Freedman PD, Phelan JA, et al Cytomegalovirus infections of the oral cavity: A report of six cases and review of the literature Oral Surg Oral Med Oral Pathol 1993 75(1):76 85 8380493
Jones DL, Rankin KV, Rees TD Factors that affect patient attitudes toward infection control measures J Dent Educ 1991 55(11):717 23 1744287
Jorge J, Jorge R, Almeida OP, et al Knowledge of and attitudes about blood-borne viruses and infection control in Brazilian dental practice Oral Dis 1996 2(1):41 4 8957936
Just-Nubling G, Gentschew G, Dohle M, et al Fluconazole in the treatment of oropharyngeal candidosis in HIV-positive patients Mycoses 1990 33(9-10):435 40 2093839
Just-Nubling G, Gentschew G, Meissner K, et al Fluconazole prophylaxis of recurrent oral candidiasis in HIV-positive patients Eur J Clin Microbiol Infect Dis 1991 10(11):917 21 1794360
Kabani S, Greenspan D, deSouza Y, et al Oral hairy leukoplakia with extensive oral mucosal involvement: Report of two cases Oral Surg Oral Med Oral Pathol 1989 67(4):411 5 2542859
Kaldenberg DO, Hallan JB, Becker BW Continued treatment of an AIDS patient J Dent Pract Adm 1990 7(3):103 7 2150078
Kanitakis J, Euvrard S, Lefrancois N, et al Oral hairy leukoplakia in a HIV-negative renal graft recipient Br J Dermatol 1991 124(5):483 6 1645582
Kao GD, Devine P, Mirza N Oral cavity and oropharyngeal tumors in human immunodeficiency virus-positive patients: Acute response to radiation therapy Arch Otolaryngol Head Neck Surg 1999 125(8):873 6 10448734
Kaplan B, Rabinerson D, Gibor Y Single-dose systemic oral fluconazole for the treatment of vaginal candidiasis Int J Gynecol Obstet 1997 57(3):281 6
Kaplan JE, Hanson DL, Navin TR, et al Risk factors for primary pneumocystis carinii pneumonia in human immunodeficiency virus-infected adolescents and adults in the United States: Reassessment of indications for chemoprophylaxis J Infect Dis 1998 178(4):1126 32 9806044
Karyotakis NC, Anaissie EJ, Hachem R, et al Comparison of the efficacy of polyenes and triazoles against hematogenous Candida krusei infection in neutropenic mice J Infect Dis 1993 168(5):1311 13 8228370
Kass N, Flynn C, Jacobson L, et al Effect of race on insurance coverage and health service use for HIV-infected gay men J Acquir Immune Defic Syndr 1999 20(1):85 92
Kass NE, Faden RR, Fox R, et al Homosexual and bisexual men's perceptions of discrimination in health services Am J Public Health 1992 82(9):1277 9 1503172 1694342
Kato Y, Hoshi Y, Akatsuka JI, et al The effects of antifungal chemoprophylaxis and empiric therapy on invasive fungal infection in neutropenic children with malignant neoplasms Pediatr Hematol Oncol 1995 12(1):1 18 7703034
Kauffman CA Itraconazole, fluconazole, and amphotericin B in antifungal therapy Curr Opinion Infect Dis 1991 4(6):764 8
Kauffman CA, Bradley SF, Vine AK Candida endophthalmitis associated with intraocular lens implantation: Efficacy of fluconazole therapy Mycoses 1993 36(1-2):13 7 8316256
Kauffman CA, Carver PL Antifungal agents in the 1990s: Current status and future developments Drugs 1997 53(4):539 49 9098658
Kawasaki K, Matsumura Y, Ogawa M, et al In vivo and in vitro antifungal activity of fluconazole Jpn J Antibiot 1991 44(5):552 61 1880935
Kay EJ, Murray K, Blinkhorn AS AIDS and human immunodeficiency virus: A preliminary investigation into Edinburgh general dental practitioners' views and behaviours Health Education Res 1990 5(3):321 5
Kearns G, Pogrel MA, Honda G Intraoral tertiary syphilis (gumma) in a human immunodeficiency virus-positive man: A case report J Oral Maxillofac Surg 1993 51(1):85 8 8419580
Kebede Y, Pickering J, McDonald JC, et al HIV infection in an Ethiopian prison Am J Public Health 1991 81(5):625 7 2014865 1405083
Kelly GE, Stanley BS, Weller IV The natural history of human immunodeficiency virus infection: A five year study in a London cohort of homosexual men Genitourin Med 1990 66(4):238 43 2133371
Kessler RC, Foster C, Joseph J, et al Stressful life events and symptom onset in HIV infection Am J Psychiatry 1991 148(6):733 8 1674646
Ketchem L, Berkowitz RJ, McIlveen L, et al Oral findings in HIV-seropositive children Pediatr Dent 1990 12(3):143 6 2077488
Keys GG HIV-testing of dental students and faculty: Benefits, detriments and implications Med Law 1990 9(3):918 29 2172686
Kharchenko OI, Pokrovsky VV The state of the oral cavity in persons infected by HIV Stomatologiya 1989 68(5):25 8
Kimbrell M, Thornburn KM Exogenous estrogen, gender dysphoria, and hairy leukoplakia Hawaii Med J 1988 47(7):
Kingsley LA, Armstrong J, Rahman A, et al No association between herpes simplex virus type-2 seropositivity or anogenital lesions and HIV seroconversion among homosexual men J Acquir Immune Defic Syndr 1990 3(8):773 9 2164082
Kirby AJ, Munoz A, Detels R, et al Thrush and fever as measures of immunocompetence in HIV-1-infected men J Acquir Immune Defic Syndr 1994 7(12):1242 9 7965635
Kirkpatrick CH Host factors in defense against fungal infections Am J Med 1984 77(4D):1 12 6388323
Kirtava Z, Blomberg J, Bredberg A, et al CD4+ T-lymphocytopenia without HIV infection: Increased prevalence among patients with primary Sjogren's syndrome Clin Exp Rheumatol 1995 13(5):609 16 8575139
Kirton CA AIDS: When your patient refuses HIV testing Am J Nurs 1994 94(11):48 53 quiz 53 4 7977507
Kisnisci R, Akal UK, Ozden N, et al Comparison of treatment modalities in chronic atrophic candidosis: A clinical and microbiologic study Turk J Med Sci 1997 27(4):337 40
Kitaura H, Adachi N, Kobayashi K, et al Knowledge and attitudes of Japanese dental health care workers towards HIV-related disease J Dent 1997 25(3-4):279 83 9175358
Kiyono H, Miller CJ, Lu Y, et al The common mucosal immune system for the reproductive tract: Basic principles applied toward an AIDS vaccine Adv Drug Deliv Rev 1995 18(1):23 51
Klein RS, Flanigan T, Schuman P, et al The effect of immunodeficiency on cutaneous delayed-type hypersensitivity testing in HIV-infected women without anergy: Implications for tuberculin testing. HIV Epidemiology Research Study (HERS) Group. HIV Epidemiology Research Int J Tuberc Lung Dis 1999 3(8):681 8 10460100
Klein RS, Phelan JA, Freeman K, et al Low occupational risk of human immunodeficiency virus infection among dental professionals N Engl J Med 1988 318(2):86 90 3422106
Klein RS, Quart AM, Small CB Periodontal disease in heterosexuals with acquired immunodeficiency syndrome J Peridontol 1991 62(8):535 40
Kleinman DV Building the capacity for the response of the dental profession to the global HIV pandemic: A case study in international collaboration J Public Health Dent 1994 54(4):234 7 7799299
Knobel GJ, Pitchford BN, Wilkinson D, et al Guidelines on HIV infection S Afr Med J 1992 81(3):169 71
Kochen MM, Hasford JC, Jager H, et al How do patients with HIV perceive their general practitioners? BMJ 1991 303(6814):1365 8 1760602 1671589
Koelbl JJ Patients with AIDS: Do we have a duty to treat? Part 1 Compendium 1991 12(9):
Koletar SL, Russell JA, Fass RJ, et al Comparison of oral fluconazole and clotrimazole troches as treatment for oral candidiasis in patients infected with human immunodeficiency virus Antimicrob Agents Chemother 1990 34(11):2267 8 172036 2073120
Kolokotronis A, Kioses V, Antoniades D, et al Immunologic status in patients infected with HIV with oral candidiasis and hairy leukoplakia Oral Surg Oral Med Oral Pathol 1994 78(1):41 6 8078662
Kolokotronis A, Kioses V, Antoniades D, et al Median rhomboid glossitis: An oral manifestation in patients infected with HIV Oral Surg Oral Med Oral Pathol 1994 78(1):36 40 8078660
Kooper DP, Leemans CR, Hulshof MC, et al Management of benign lymphoepithelial lesions of the parotid gland in human immunodeficiency virus-positive patients Eur Arch Otorhinolaryngol 1998 255(8):427 9 9801863
Kordossis T, Paikos S, Aroni K, et al Prevalence of Sjogren's-like syndrome in a cohort of HIV-1-positive patients: Descriptive pathology and immunopathology Br J Rheumatol 1998 37(6):691 5 9667626
Korn AP, Landers DV Gynecologic disease in women infected with human immunodeficiency virus type 1 J Acquir Immune Defic Syndr 1995 9(4):361 70
Korting HC, Blecher P, Froschl M, et al Quantitative assessment of the efficacy of oral ketoconazole for oral candidosis in HIV-infected patients Mycoses 1992 35(7-8):173 6 1287481
Kotogyan A, Harmanyeri Y, Tahsin Gunes A, et al Efficacy and safety of oral fluconazole in the treatment of patients with tinea corporis, cruris or pedis or cutaneous candidosis: A multicentre, open, noncomparative study Clin Drug Invest 1996 12(2):59 66
Kowalsky SF, Dixon DM Fluconazole: A new antifungal agent Clin Pharm 1991 10(3):179 94 2040125
Kratochvil FJ, Riordan GP, Auclair PL, et al Diagnosis of oral hairy leukoplakia by ultrastructural examination of exfoliative cytologic specimens Oral Surg Oral Med Oral Pathol 1990 70(5):613 8 2172887
Kromery V Jr, Koza I, Hornikova M, et al Fluconazole in the treatment of mycotic oropharyngeal stomatitis and esophagitis in neutropenic cancer patients Chemotherapy 1991 37(5):343 5 1804594
Kullberg BJ, Van't Wout JW, Poell RJM, et al Combined effect of fluconazole and recombinant human interleukin-1 on systemic candidiasis in neutropenic mice Antimicrob Agents Chemother 1992 36(6):1225 9 190322 1416821
Kunzel C, Sadowsky D Assessing HIV-related attitudes and orientations of male and female general dentists J Am Dent Assoc 1995 126(7):862 71 7629362
Kunzel C, Sadowsky D Predicting dentists' perceived occupational risk for HIV infection Soc Sci Med 1993 36(12):1579 86 8327921
Kunzel C, Sadowsky D, Tseng CL Comparing predictors of willingness to treat HIV+ patients for New York City male and female general practice dentists 50 years of age or younger J Public Health Dent 1997 57(3):159 62 9383754
Kura MM, Gharpure HM, Hira SK, et al "Delayed HIV sero-conversion" in an Indian male Natl Med J India 1998 11(4):201 2
Lacassin F, Damond F, Chochillon C, et al Response to fluconazole by 23 patients with human immunodeficiency virus infection and oral candidiasis: Pharmacological and mycological factors Antimicrob Agents Chemother 1996 40(8):1961 63 163452 8843316
Laguna F, Rodriguez-Tudela JL, Martinez-Suarez JV, et al Patterns of fluconazole susceptibility in isolates from human immunodeficiency virus-infected patients with oropharyngeal candidiasis due to Candida albicans Clin Infect Dis 1997 24(2):124 30 9114134
Laine L, Rabeneck L Prospective study of fluconazole suspension for the treatment of oesophageal candidiasis in patients with AIDS Aliment Pharmacol Ther 1995 9(5):553 6 8580277
Lake DE, Kunzweiler J, Beer M, et al Fluconazole versus amphotericin B in the treatment of esophageal candidiasis in cancer patients Chemotherapy 1996 42(4):308 14 8804799
Lakshmi N, Kumar AG, Subbarayudu S, et al HIV infection among dental patients J Indian Med Assoc 1998 96(9):
Lamey PJ, Nolan A, Follett EA, et al Anti-HIV antibody in saliva: An assessment of the role of the components of saliva, testing methodologies and collection systems J Oral Pathol Med 1996 25(3):104 7 9148035
Lampiris LN Managing the HIV-positive dental patient in the general dental office CDS Review 1996 89(2):28 36 9528474
Lamster IB, Begg MD, Mitchell-Lewis D, et al Oral manifestations of HIV infection in homosexual men and intravenous drug users: Study design and relationship of epidemiologic, clinical, and immunologic parameters to oral lesions Oral Surg Oral Med Oral Pathol 1994 78(2):163 74 7936584
Lamster IB, Grbic JT, Bucklan RS, et al Epidemiology and diagnosis of HIV-associated periodontal diseases Oral Dis 1997 3(Suppl 1):S141 8 9456678
Landman D, Saurina G, Quale JM Failure of all antifungal therapy for infection due to Candida albicans: A new AIDS-related problem? Clin Infect Dis 1998 26(1):183 4 9455530
Langford A, Kunze R, Schmelzer S, et al Immunocytochemical detection of herpes viruses in oral smears of HIV-infected patients J Oral Pathol Med 1992 21(2):49 57 1313501
Langford A, Langer R, Lobeck H, et al Human immunodeficiency virus-associated squamous cell carcinomas of the head and neck presenting as oral and primary intraosseous squamous cell carcinomas Quintessence Int 1995 26(9):635 54 8602445
Langford A, Pohle HD, Gelderblom H, et al Oral hyperpigmentation in HIV-infected patients Oral Surg Oral Med Oral Pathol 1989 67(3):301 7 2927925
Lapins J, Lindback S, Lidbrink P, et al Mucocutaneous manifestations in 22 consecutive cases of primary HIV-1 infection Br J Dermatol 1996 134(2):257 61 8746338
Laskaris G, Hadjivassiliou M, Stratigos J Oral signs and symptoms in 160 Greek HIV-infected patients J Oral Pathol Med 1992 21(3):120 3 1316436
Leen CL, Dunbar EM, Ellis ME, et al Once-weekly fluconazole to prevent recurrence of oropharyngeal candidiasis in patients with AIDS and AIDS-related complex: A double-blind placebo-controlled study [published erratum appears in J Infect 1990;21(2):183] J Infect 1990 21(1):55 60 2200826
Le Guennec R, Reynes J, Mallie M, et al Fluconazole- and itraconazole-resistant Candida albicans strains from AIDS patients: multilocus enzyme electrophoresis analysis and antifungal susceptibilities J Clin Microbiol 1995 33(10):2732 7 228565 8567915
Lehrnbecher T, Groll AH, Chanock SJ Treatment of fungal infections in neutropenic children Curr Opin Pediatr 1999 11(1):47 55 10084084
Leigh IM, Buchanan JA, Harwood CA, et al Role of human papillomaviruses in cutaneous and oral manifestations of immunosuppression J Acquir Immune Defic Syndr 1999 21(Suppl 1):S49 57 10430219
Leigh JE, Steele C, Wormley FLJ, et al Th1/Th2 cytokine expression in saliva of HIV-positive and HIV-negative individuals: A pilot study in HIV-positive individuals with oropharyngeal candidiasis J Acquir Immune Defic Syndr 1998 19(4):373 80
Lenker SL, Lubeck DP, Vosler A Planning community-wide services for persons with HIV infection in an area of moderate incidence Public Health Rep 1993 108(3):285 93 8497565 1403378
Lepage P, Van de Perre P, Van Vliet G, et al Clinical and endocrinologic manifestations in perinatally human immunodeficiency virus type 1-infected children aged 5 years or older Am J Dis Child 1991 145(11):1248 51 1951215
Levell NJ, Bewley AP, Chopra S, et al Bacillary angiomatosis with cutaneous and oral lesions in an HIV-infected patient from the U K. Br J Dermatol 1995 132(1):113 5
Levien TI, Baker DE Pharmacy and therapeutics review of Desflurane and Itraconazole Hosp Pharm 1993 28(5):420, 423 7, 431-2, 434-40
Lewis DA, Gallagher JE, Gelbier S An education and training initiative on dental care for the HIV-positive patient Prim Den Care 1996 3(1):28 35
Lewis DL, Arens M, Appleton SS, et al Cross-contamination potential with dental equipment Lancet 1992 340(8830):1252 4 1359320
Lewis DL, Jaffe HW, Liberti T Lack of HIV transmission in a dental practice Ann Intern Med 1995 122(12):
Lewis DL, Merey JH, Pepper DR The dental AIDS cases -- murder or an unsolvable mystery? JAMA 1994 271(13):
Lewis MA, Samaranyake LP, Lamey PJ Diagnosis and treatment of oral candidosis J Oral Maxillofac Surg 1991 49(9):996 1002 1653314
Lifson AR, Hessol NA, Buchbinder SP, et al The association of clinical conditions and serologic tests with CD4+ lymphocyte counts in HIV-infected subjects without AIDS AIDS 1991 5(10):1209 15 1686178
Lifson AR, Hilton JF, Westenhouse JL, et al Time from HIV seroconversion to oral candidiasis or hairy leukoplakia among homosexual and bisexual men enrolled in three prospective cohorts AIDS 1994 8(1):73 9 8011239
Lijmer JG, Mol BW, Heisterkamp S, et al Empirical evidence of design-related bias in studies of diagnostic tests JAMA 1999 282(11):1061 6 10493205
Lim SG, Lee CA, Hales M, et al Fluconazole for oropharyngeal candidiasis in anti-HIV positive haemophiliacs Aliment Pharmacol Ther 1991 5(2):199 205 1888820
Lin YG, Melchiono MW, Huba GJ, et al Evaluation of a linked service model of care for HIV-positive, homeless, and at-risk youths AIDS Patient Care & STDS 1998 12(10):787 96 11362024
Little JW. Dental Management of the Medically Compromised Patient. St. Louis: Mosby. 1997. [pmcid: 176006].
Little JW, Melnick SL, Rhame FS, et al Prevalence of oral lesions in symptomatic and asymptomatic HIV patients Gen Dent 1994 42(5):446 50 7489878
LiVolsi VA, Ciesielski CA, Berkelman RL, et al The mechanism of HIV infection in patients of the Florida dentist JAMA 1991 266(18):
Lo B, Steinbrook R Health care workers infected with the human immunodeficiency virus: The next steps JAMA 1992 267(8):1100 5 1310512
Loeliger A, Van Leeuwen M, Rozenberg-Arska M, et al Hepatosplenic candidiasis: A fatal disease? Infection 1992 20(6):336 8 1293053
Lohr KN, Carey TS Assessing "best evidence": issues in grading the quality of studies for systematic reviews Jt Comm J Qual Improv 1999 25(9):470 9 10481816
Longfield JN, Brundage J, Badger G, et al Look-back investigation after human immunodeficiency virus seroconversion in a pediatric dentist J Infect Dis 1994 169(1):1 8 8277171
Lopez N, Glick M, Berthold P Providing care in an infectious disease clinic: Why students volunteer Eur J Dent Educ 1998 2(3):138 42 9855811
Lopez-Dupla M, Mora Sanz P, Pintado Garcia V, et al Clinical, endoscopic, immunologic, and therapeutic aspects of oropharyngeal and esophageal candidiasis in HIV-infected patients: A survey of 114 cases Am J Gastroenterol 1992 87(12):1771 6 1449139
Lopez Olmos J, Parra I Vaginal candidiasis treatment: Prospective comparative study of three commercial products with a single dose Clinica e Investigacion en Ginecologia y Obstetricia 1994 21(7):300 6
Lot F, Seguier JC, Fegueux S, et al Probable transmission of HIV from an orthopedic surgeon to a patient in France Ann Intern Med 1999 130(1):1 6 9890844
Luangjamekorn L, Silverman S Jr, Gallo J, et al Findings in 50 AIDS virus-infected patients with positive oral Candida cultures J Dent Assoc Thai 1990 Jul-Aug 40(4):157 64 2074328
Lucatorto FM, Franker CK, Maza J Postscaling bacteremia in HIV-associated gingivitis and periodontitis Oral Surg Oral Med Oral Pathol 1992 73(5):550 4 1518641
Lucatorto F, Franker C, Hardy WD, et al Treatment of refractory oral candidiasis with fluconazole: A case report Oral Surg Oral Med Oral Pathol 1991 71(1):42 4 1994321
Lucena De Garcia A, Manotas S, Onatra W, et al Treatment of vaginal candidiasis with single oral dose of fluconazole Revista Colombiana de Obstetricia y Ginecologia 1993 44(2):146 50
Lucht E, Albert J, Linde A, et al Human immunodeficiency virus type 1 and cytomegalovirus in saliva J Med Virol 1993 39(2):156 62 8387571
Lucht E, Biberfeld P, Linde A Epstein-Barr virus (EBV) DNA in saliva and EBV serology of HIV-1-infected persons with and without hairy leukoplakia J Infect 1995 31(3):189 94 8586837
Lucht E, Evengard B, Skott J, et al Entamoeba gingivalis in human immunodeficiency virus type 1-infected patients with periodontal disease Clin Infect Dis 1998 27(3):471 3 9770142
Lumbreras C, Cuervas-Mons V, Jara P, et al Randomized trial of fluconazole versus nystatin for the prophylaxis of Candida infection following liver transplantation J Infect Dis 1996 174(3):583 8 8769617
Luttrull JK, Wan WL, Kubak BM, et al Treatment of ocular fungal infections with oral fluconazole Am J Ophthalmol 1995 119(4):477 81 7709972
Lynch DP Differential diagnosis in dentistry: HIV associated gingivitis J Houston Dist Dent Soc 1988 60(2):
Lynch DP, Grimes RM, Brimlow DL HIV infection and AIDS in Texas: A special report Tex Dent J 1993 110(2):5 13
Mabruk MJ, Flint SR, Coleman DC, et al A rapid microwave-in situ hybridization method for the definitive diagnosis of oral hairy leukoplakia: Comparison with immunohistochemistry J Oral Pathol Med 1996 25(4):170 6 8809685
Mabruk MJ, Flint SR, Toner M, et al In situ hybridization and the polymerase chain reaction (PCR) in the analysis of biopsies and exfoliative cytology specimens for definitive diagnosis of oral hairy leukoplakia (OHL) J Oral Pathol Med 1994 23(7):302 8 7965885
MacDonell KB, Chmiel JS, Goldsmith J, et al Prognostic usefulness of the Walter Reed staging classification for HIV infection J Acquir Immune Defic Syndr 1988 1(4):367 74 3216317
Macleod RI, Long LQ, Soames JV, et al Oral hairy leukoplakia in an HIV-negative renal transplant patient Br Dent J 1990 169(7):208 9 2171607
MacPhail LA, Greenspan D, Feigal DW, et al Recurrent aphthous ulcers in association with HIV infection: Description of ulcer types and analysis of T-lymphocyte subsets Oral Surg Oral Med Oral Pathol 1991 71(6):678 83 1676501
MacPhail LA, Greenspan JS Oral ulceration in HIV infection: Investigation and pathogenesis Oral Dis 1997 3(Suppl 1):S190 3 9456687
MacPhail LA, Hilton JF, Dodd CL, et al Prophylaxis with nystatin pastilles for HIV-associated oral candidiasis J Acquir Immune Defic Syndr 1996 12(5):470 6
MacPhail LA, Hilton JF, Heinic GS, et al Direct immunofluorescence vs. culture for detecting HSV in oral ulcers: A comparison J Am Dent Assoc 1995 126(1):74 8 7822648
Madeley CR Transmission of nosocomial virus infections by health care workers Curr Opinion Infect Dis 1993 6(4):511 4
Madigan A, Murray PA, Houpt M, et al Caries experience and cariogenic markers in HIV-positive children and their siblings Pediatr Dent 1996 18(2):129 36 8710715
Madinier I, Doglio A, Cagnon L, et al Epstein-Barr virus DNA detection in gingival tissues of patients undergoing surgical extractions British J Oral Maxillofac Surg 1992 30(4):237 43
Madinier I, Doglio A, Cagnon L, et al Southern blot detection of human papillomaviruses (HPVs) DNA sequences in gingival tissues J Peridontol 1992 63(8):667 73
Maenza JR, Keruly JC, Moore RD, et al Risk factors for fluconazole-resistant candidiasis in human immunodeficiency virus-infected patients J Infect Dis 1996 173(1):219 25 8537662
Maenza JR, Merz WG, Romagnoli MJ, et al Infection due to fluconazole-resistant Candida in patients with AIDS: Prevalence and microbiology Clin Infect Dis 1997 24(1):28 34 8994752
Magdic L, Drazancic A Fluconazole in the treatment of vaginal candidosis Gynaecologia et Perinatologia 1995 4(2):79 81
Maggon KK, Slee AM, Demos CH Development of antifungal agents by the pharmaceutical industry Drugs of Today 1991 27(5):317 30
Maiorano E, Favia G, Viale G Lymphoepithelial cysts of salivary glands: An immunohistochemical study of HIV-related and HIV-unrelated lesions Hum Pathol 1998 29(3):260 5 9496829
Manaloto CR, Perrault JG, Caringal LT, et al Natural history of HIV infection in Filipino female commercial sex workers J Acquir Immune Defic Syndr 1994 7(11):1157 68 7932083
Mandel ID, Barr CE, Turgeon L Longitudinal study of parotid saliva in HIV-1 infection J Oral Pathol Med 1992 21(5):209 13 1403836
Mandel L, Hong J HIV-associated parotid lymphoepithelial cysts J Am Dent Assoc 1999 130(4):528 32 10203903
Mandel L, Kim D, Uy C Parotid gland swelling in HIV diffuse infiltrative CD8 lymphocytosis syndrome Oral Surg Oral Med Oral Pathol Oral Radiol Endod 1998 85(5):565 8 9619675
Manz MC, Weyant RJ, Adelson R, et al Impact of HIV on VA dental services: Report of a survey J Public Health Dent 1994 54(4):197 204 7799293
Marcenes W, Pankhurst CL, Lewis DA Oral health behaviour and the prevalence of oral manifestations of HIV infection in a group of HIV positive adults Int Dent J 1998 48(6):557 62 9881289
Marchisio P, Principi N Treatment of oropharyngeal candidiasis in HIV-infected children with oral fluconazole. Multicentre Study Group [published erratum appears in Eur J Clin Microbiol Infect Dis 1994;13(8):694] Eur J Clin Microbiol Infect Dis 1994 13(4):338 40 8070442
Marcus M, Freed JR, Coulter ID, et al Perceived unmet need for oral treatment among a national population of HIV-positive medical patients: Social and clinical correlates Am J Public Health 2000 90(7):1059 63 10897183 1446293
Marder MZ AIDS: Control of the dental office situation N Y J Dent 1986 56(5):170 5 2945130
Margiotta V, Campisi G, Mancuso S, et al HIV infection: Oral lesions, CD4+ cell count and viral load in an Italian study population J Oral Pathol Med 1999 28(4):173 7 10235371
Markham A, Faulds D Roxithromycin: An update of its antimicrobial activity, pharmacokinetic properties and therapeutic use Drugs 1994 48(2):297 326 7527329
Markowitz N, Hansen NI, Hopewell PC, et al Incidence of tuberculosis in the United States among HIV-infected persons. The Pulmonary Complications of HIV Infection Study Group Ann Intern Med 1997 126(2):123 32 9005746
Marriott DJ, Jones PD, Hoy JF, et al Fluconazole once a week as secondary prophylaxis against oropharyngeal candidiasis in HIV-infected patients: A double-blind placebo-controlled study Med J Aust 1993 158(5):312 6 8097273
Marthy S, Richter M Human immunodeficiency virus activity in rib allografts J Oral Maxillofac Surg 1998 56(4):474 6 9541348
Martin MV The use of fluconazole and itraconazole in the treatment of Candida albicans infections: A review J Antimicrob Chemother 1999 44(4):429 37 10588302
Martinez P, Munoz J, Santamaria JM, et al [Acute symptomatic HIV infection. Report of 10 cases]. [Spanish] Enferm Infecc Microbiol 1992 10(4):205 10
Martinez-Canut P, Guarinos J, Bagan JV Periodontal disease in HIV seropositive patients and its relation to lymphocyte subsets J Peridontol 1996 67(1):33 6
Martinoli C, Pretolesi F, Del Bono V, et al Benign lymphoepithelial parotid lesions in HIV-positive patients: Spectrum of findings at gray-scale and Doppler sonography AJR 1995 165(4):975 9 7677004
Martins MD, Lozano-Chiu M, Rex JH Declining rates of oropharyngeal candidiasis and carriage of Candida albicans associated with trends toward reduced rates of carriage of fluconazole-resistant C. albicans in human immunodeficiency virus-infected patients Clin Infect Dis 1998 27(5):1291 4 9827284
Martins MD, Lozano-Chiu M, Rex JH Point prevalence of oropharyngeal carriage of fluconazole-resistant Candida in human immunodeficiency virus-infected patients Clin Infect Dis 1997 25(4):843 6 9356799
Marvan E, Firth N Focal epithelial hyperplasia in an HIV positive man: An illustrated case and review of the literature Aust Dent J 1998 43(5):305 10 9848979
Marx R, Katz MH, Park MS, et al Meeting the service needs of HIV-infected persons: Is the Ryan White CARE act succeeding? J Acquir Immune Defic Syndr 1997 14(1):44 55
Mascarenas CA, Hardin TC, Pennick GJ, et al Treatment of thrush with itraconazole solution: Evidence for topical effect Clin Infect Dis 1998 26(5):1242 3 9597271
Mascarenhas AK, Smith SR Factors associated with utilization of care for oral lesions in HIV disease Oral Surg Oral Med Oral Pathol Oral Radiol Endod 1999 87(6):708 13 10397663
Masouredis CM, Katz MH, Greenspan D, et al Prevalence of HIV-associated periodontitis and gingivitis in HIV-infected patients attending an AIDS clinic J Acquir Immune Defic Syndr 1992 5(5):479 83 1560345
Mastroianni A, Coronado O, Nanetti A, et al Pleural empyema due to Streptococcus intermedius in a patient with HIV infection Medecine et Maladies Infectieuses 1997 27(3):326 8
Masur H, Kaplan JE, Holmes KK, et al Preface to the 1997 USPHS/IDSA guidelines for the prevention of opportunistic infections in persons infected with human immunodeficiency virus Clin Infect Dis 1997 25(Suppl 3):S299 312 9356831
Mathaba LT, Davies G, Warmington JR The genotypic relationship of Candida albicans strains isolated from the oral cavity of patients with denture stomatitis J Med Microbiol 1995 42(5):372 9 7752218
Matis WL, Triana A, Shapiro R, et al Dermatologic findings associated with human immunodeficiency virus infection J Am Acad Dermatol 1987 17(5 Pt 1):746 51 3680653
Matsushima T, Ikeda H, Tomizawa S, et al Clinical evaluation of fluconazole in patients with mycotic infection Jpn J Antibiot 1989 42(1):153 63 2540361
Maupome G, Acosta-Gio E, Borges-Yanez SA, et al Survey on attitudes toward HIV-infected individuals and infection control practices among dentists in Mexico City Am J Infect Control 2000 28(1):21 24 10679133
Mauss S, Jablonowski H Efficacy, safety, and tolerance of low-dose, long-term interferon-alpha 2b and zidovudine in early-stage AIDS-associated Kaposi's sarcoma J Acquir Immune Defic Syndr 1995 10(2):157 62
May R, Migliorati CA Oral manifestations of AIDS: Part 3 Dent Manage 1991 31(6):33 7 1884823
Mazziotti F, Cirillo L, Arena V, et al Comparative clinical trial between a new imidazole molecule (fluconazole) and ketoconazole in the treatment of vulvovaginitis due to Candida albicans Minerva Ginecol 1992 44(12):653 9 1491774
McCartan BE, Samaranayake LP Oral care of HIV infected patients: The knowledge and attitudes of Irish dentists J Ir Dent Assoc 1991 37(2):41 3 1839995
McCarthy GM Host factors associated with HIV-related oral candidiasis: A review Oral Surg Oral Med Oral Pathol 1992 73(2):181 6 1532236
McCarthy GM, Haji FS, Mackie ID HIV-infected patients and dental care: Nondisclosure of HIV status and rejection for treatment Oral Surg Oral Med Oral Pathol Oral Radiol Endod 1995 80(6):655 9 8680970
McCarthy GM, Koval JJ Changes in dentists' infection control practices, knowledge, and attitudes about HIV over a 2-year period Oral Surg Oral Med Oral Pathol Oral Radiol Endod 1996 81(3):297 302 8653463
McCarthy GM, Koval JJ, MacDonald JK Factors associated with refusal to treat HIV-infected patients: The results of a national survey of dentists in Canada Am J Public Health 1999 89(4):541 5 10191798 1508900
McCarthy GM, Koval JJ, MacDonald JK Geographic differences in the attitudes, knowledge and infection control practices of Ontario dentists Can J Public Health 1996 87(2):119 24 8753641
McCarthy GM, Koval JJ, MacDonald JK Nonresponse bias in a survey of Ontario dentists' infection control and attitudes concerning HIV J Public Health Dent 1997 57(1):59 62 9150064
McCarthy GM, MacDonald JK Gender differences in characteristics, infection control practices, knowledge and attitudes related to HIV among Ontario dentists Community Dent Oral Epidemiol 1996 24(6):412 5 9007360
McCarthy GM, MacDonald JK Improved compliance with recommended infection control practices in the dental office between 1994 and 1995 Am J Infect Control 1998 26(1):24 8 9503109
McCarthy GM, Mackie ID, Koval J, et al Factors associated with increased frequency of HIV-related oral candidiasis J Oral Pathol Med 1991 20(7):332 6 1680189
McClellan KJ, Wiseman LR, Markham A Terbinafine: An update of its use in superficial mycoses Drugs 1999 58(1):179 202 10439936
McCormack-Brown KR Dental hygienist's attitudes towards AIDS: A descriptive survey J Dent Hyg 1991 65(8):373 8 1840275
McCormick SU Intralesional vinblastine injections for the treatment of oral Kaposi's sarcoma: Report of 10 patients with 2-year follow-up J Oral Maxillofac Surg 1996 54(5):583 7 discussion 588 9 8632242
McCreary C, Bergin C, Pilkington R, et al Clinical parameters associated with recalcitrant oral candidosis in HIV infection: A preliminary study Int J STD AIDS 1995 6(3):204 7 7647125
McCullough M, Ross B, Reade PC Oral Candida albicans from patients infected with the human immunodeficiency virus and characterization of a genetically distinct subgroup of Candida albicans Aust Dent J 1995 40(2):91 7 7786236
McKaig RG, Thomas JC, Patton LL, et al Prevalence of HIV-associated periodontitis and chronic periodontitis in a southeastern US study group J Public Health Dent 1998 58(4):294 300 10390712
McKindley DS, Rapp RP Selecting the right antifungal U.S. Pharmacist 1992 17(8):34 47
McMillan MD, Boyd NM, MacFadyen EE, et al Oral hairy leukoplakia-like lesions in an HIV-negative male: A case report N Z Dent J 1989 85(382):121 4 2552361
McMullan-Vogel CG, Jude HD, Ollert MW, et al Serotype distribution and secretory acid proteinase activity of Candida albicans isolated from the oral mucosa of patients with denture stomatitis Oral Microbiol 1999 14(3):183 9
Medical Economics. Drug Topics Red Book. Montvale, NJ: Medical Economics Co. 2000.
Mellanen L, Ingman T, Lahdevirta J, et al Matrix metalloproteinases-1, -3 and -8 and myeloperoxidase in saliva of patients with human immunodeficiency virus infection Oral Dis 1996 2(4):263 71 9171509
Mellanen L, Salo T, Ingman T, et al 72-kDa and 92-kDa gelatinases in saliva of patients with human immunodeficiency virus infection Acta Odontol Scand 1998 56(3):135 42 9688221
Melnick SL, Engel D, Truelove E, et al Oral mucosal lesions: Association with the presence of antibodies to the human immunodeficiency virus Oral Surg Oral Med Oral Pathol 1989 68(1):37 43 2755688
Melnick SL, Hannan P, Decher L, et al Increasing CD8+ T lymphocytes predict subsequent development of intraoral lesions among individuals in the early stages of infection by the human immunodeficiency virus J Acquir Immune Defic Syndr 1991 4(12):1199 1207 1682473
Metzgar D, van Belkum A, Field D, et al Random amplification of polymorphic DNA and microsatellite genotyping of pre- and posttreatment isolates of Candida spp. from human immunodeficiency virus-infected patients on different fluconazole regimens J Clin Microbiol 1998 36(8):2308 13 105037 9666011
Mijch AM, Quin J Recommendations for antimicrobial prophylaxis in HIV Med J Aust 1996 164(9):
Mikamo H, Kawazoe K, Sato Y, et al Comparative study on the effectiveness of antifungal agents in different regimens against vaginal candidiasis Chemotherapy 1998 44(5):364 8 9732153
Mikamo H, Kawazoe K, Sato Y, et al Penetration of oral fluconazole into gynecological tissues Antimicrob Agents Chemother 1999 43(1):148 51 89035 9869580
Miller EJJ, Dodson TB The risk of serious odontogenic infections in HIV-positive patients: A pilot study Oral Surg Oral Med Oral Pathol Oral Radiol Endod 1998 86(4):406 9 9798222
Millon L, Manteaux A, Reboux G, et al Fluconazole-resistant recurrent oral candidiasis in human immunodeficiency virus-positive patients: Persistence of Candida albicans strains with the same genotype J Clin Microbiol 1994 32(4):1115 8 267201 8027327
Mirowski GW, Hilton JF, Greenspan D, et al Association of cutaneous and oral diseases in HIV-infected men Oral Dis 1998 4(1):16 21 9655039
Mishu B, Schaffner W HIV-infected surgeons and dentists: Looking back and looking forward JAMA 1993 269(14):1843 4 8459519
Mito RS, Wahlers M Medically compromised patients, part II. Current trends in zidovudine chemoprophylaxis post HIV exposure J Calif Dent Assoc 1995 23(11):27 31
Miyauchi H, Kozuki K, Tanio T, et al Synthesis and antifungal activity of alkylthio and alkylsulfonyl derivatives of SM-8668 Bioorg Med Chem 1996 4(2):263 73 8814884
Mocroft A, Sabin CA, Youle M, et al Changes in AIDS-defining illnesses in a London Clinic, 1987-1998 J Acquir Immune Defic Syndr 1999 21(5):401 7 10458621
Molinari JA, Merchant VA, Barrett ED Acquired immune deficiency syndrome (AIDS): Disease manifestations and dental management J Mich Dent Assoc 1984 66(3):113 20 6233424
Molyneaux PJ, Mok JY, Burns SM, et al Measles, mumps and rubella immunisation in children at risk of infection with human immunodeficiency virus J Infect 1993 27(3):251 3 8308316
Momas I, Helal H, Pretet S, et al Demographic and behavioral predictors of knowledge and HIV seropositivity: Results of a survey conducted in three anonymous and free counselling and testing centers Eur J Epidemiol 1997 13(3):255 60 9258522
Moniaci D, Cavallari M, Greco D, et al Oral lesions in children born to HIV-1 positive women J Oral Pathol Med 1993 22(1):8 11 8419634
Moniaci D, Greco D, Flecchia G, et al Epidemiology, clinical features and prognostic value of HIV-1 related oral lesions J Oral Pathol Med 1990 19(10):477 81 1981079
Monteil RA, Michiels JF, Hofman P, et al Histological and ultrastructural study of one case of oral bacillary angiomatosis in HIV disease and review of the literature Eur J Cancer. Part B, Oral Oncology 1994 30B(1):65 71
Montella F, Pezzotti P, Di Sora F, et al Improving the prognostic value of CD4+ count using IgA and clinical signs in HIV-seropositive i. v. drug users Infection 1997 25(2):117 20 9108189
Montes LF Use of oral amphotericin B in humans for sites other than the mouth and GI tract J De Mycologie Medicale 1996 6(Suppl 2):42 7
Moore LV, Moore WE, Riley C, et al Periodontal microflora of HIV positive subjects with gingivitis or adult periodontitis J Peridontol 1993 64(1):48 56
Morfeldt-Manson L, Bottiger B, Nilsson B, et al Clinical signs and laboratory markers in predicting progression to AIDS in HIV-1 infected patients Scand J Infect Dis 1991 23(4):443 9 1683492
Mortin RA Now is the time Nebr Med J 1991 76(3):
Mosca NG, Sarubin D Treatment of the HIV-infected patient Part 1: Risk reduction. Miss Dent Assoc J 1996 52(1):20 2
Moshi AH, Jorgensen AF, Pallangyo K Treatment of oral candidiasis: A study to determine the clinical response of sodium benzoate compared with nystatin suspension AIDS 1998 12(16):2237 8 9833873
Moskowitz EM The treatment of dental patients with acquired immune deficiency syndrome (AIDS) N Y J Dent 1984 54(3):119 20 6584793
Mueller BA, Millheim ET, Farrington EA, et al Mucositis management practices for hospitalized patients: National survey results J Pain Symptom Manage 1995 10(7):510 20 8537693
Munoz P, Moreno S, Garau X, et al A multicentric study of fluconazole to treat oropharyngeal candidiasis in immunologically compromised patients Enferm Infecc Microbiol 1990 8(9):560 4
Murrah VA, Scholtes GA Antibody testing and counseling of dental patients at risk for human immunodeficiency virus (HIV) infection and associated clinical findings Oral Surg Oral Med Oral Pathol 1988 66(4):432 9 2972983
Murray PA HIV disease as a risk factor for periodontal disease Compendium 1994 15(8):1052, 1054 63 quiz
Murray PA, Grassi M, Winkler JR The microbiology of HIV-associated periodontal lesions J Clin Periodontol 1989 16(10):636 42 2693496
Murray PA, Koletar SL, Mallegol I, et al Itraconazole oral solution versus clotrimazole troches for the treatment of oropharyngeal candidiasis in immunocompromised patients Clin Ther 1997 19(3):471 80 9220211
Murray PA, Winkler JR, Peros WJ, et al DNA probe detection of periodontal pathogens in HIV-associated periodontal lesions Oral Microbiol Immunol 1991 6(1):34 40 1945481
Muzyka BC, Glick M Major aphthous ulcers in patients with HIV disease Oral Surg Oral Med Oral Pathol 1994 77(2):116 20 8139826
Myint M, Odden K, Schreurs O, et al The gingival plasma cell infiltrate in HIV-positive patients with periodontitis is disorganized J Clin Periodontol 1999 26(6):358 65 10382575
Myint MM, Steinsvoll S, Odden K, et al Salivary IgA responses to bacteria in dental plaque as related to periodontal and HIV infection status Eur J Oral Sci 1997 105(6):562 70 9469606
Mylonakis E, Flanigan TP Editorial response: Antifungal prophylaxis with weekly fluconazole for patients with AIDS Clin Infect Dis 1998 27(6):1376 8 9868645
Nair MK, Chien YW Development of anticandidal delivery systems: (I) anticandidal activities of antifungal agents and synergistic combination with other drugs Drug Dev Ind Pharm 1996 22(3):237 42
Nandwani R, Parnell A, Youle M, et al. Use of terbinafine in HIV-positive subjects: Pilot studies in onychomycosis and oral candidiasis. Br J Dermatol. 1996;134 Suppl 46:22-4.
Nathan A Treatment for women's conditions Pharm J 1996 257(6907):278 81
Nattress C AIDS in San Francisco Probe 1989 31(4):
Nattress CAn elective in San Francisco HIV infection: Comparing attitudes, knowledge and cross-infection control amongst dentists in San Francisco and Great Britain Br Dent J 1988 165(11):412 14 2974711
Ndiaye CF, Critchlow CW, Leggott PJ, et al Periodontal status of HIV-1 and HIV-2 seropositive and HIV seronegative female commercial sex workers in Senegal J Peridontol 1997 68(9):827 31
Nebavi F, Arnavielhe S, Le Guennec R, et al Oropharyngeal candidiasis in AIDS patients from Abidjan (Ivory Coast): Antifungal susceptibilities and multilocus enzyme electrophoresis analysis of Candida albicans isolates Pathol Biol 1998 46(5):307 14 9769890
Neiburger EJ Are latex gloves a contributing cause of percutaneous injury in dentists? Gen Dent 1998 46(5):467 72 10202492
Nenoff P, Taneva E, Pfeil B, et al In vitro activity of rilopirox against fluconazole-susceptible and fluconazole-resistant Candida isolates from patients with HIV infection Mycoses 1999 42(1-2):55 60
Newman SL, Flanigan TP, Fisher A, et al Clinically significant mucosal candidiasis resistant to fluconazole treatment in patients with AIDS Clin Infect Dis 1994 19(4):684 6 7803632
Niccolai I, Paolini P, Gironi A, et al Fluconazole for the management of candidiasis in intensive care Clin Ter 1991 139(1-2):17 26 1837762
Nielsen H, Bentsen KD, Hojtved L, et al Oral candidiasis and immune status of HIV-infected patients J Oral Pathol Med 1994 23(3):140 3 7912732
Niemcryk SJ, Bedros A, Marconi KM, et al Consistency in maintaining contact with HIV-related service providers: An analysis of the AIDS Cost and Services Utilization Study (ACSUS) J Community Health 1998 23(2):137 52 9591205
Nishanian P, Aziz N, Chung J, et al Oral fluids as an alternative to serum for measurement of markers of immune activation Clin Diagn Lab Immunol 1998 5(4):507 12 95609 9665958
Niwano Y, Kuzuhara N, Goto Y, et al Efficacy of NND-502, a novel imidazole antimycotic agent, in experimental models of Candida albicans and Aspergillus fumigatus infections Int J Antimicrob Agents 1999 12(3):221 8 10461840
Nolan A, Lamey PJ, MacFarlane TW, et al The effect of nebulised pentamidine on the concentration of intra-oral Candida albicans in HIV-infected patients J Med Microbiol 1994 41(2):95 7 8046740
Noriega FR, Scott DA, Edelman R Treatment of gastrointestinal infections Curr Opin Gastroenterol 1992 8(1):128 33
Noyer CM, Simon D Oral and esophageal disorders Gastroenterol Clin North Am 1997 26(2):241 57 9187924
Nozickova M, Koudelkova V, Kulikova Z, et al A comparison of the efficacy of oral fluconazole, 150 mg/week versus 50 mg/day, in the treatment of tinea corporis, tinea cruris, tinea pedis, and cutaneous candidosis Int J Dermatol 1998 37(9):703 5 9762826
Nunenmacher SJ, Holbert RD, Davidson EM HIV infection masquerading as Sjogren's disease: A clinical dilemma J Miss State Med Assoc 1996 37(7):645 6 8754932
Nuttall NM, Gilbert AD Assessing dental patients for their risk of being carriers of a blood-borne virus: The views of final year dental students [published erratum appears in J Dent 1993;21(4):215] J Dent 1993 21(2):99 104 8473599
Nyst MJ, Perriens JH, Kimputu L, et al Gentian violet, ketoconazole and nystatin in oropharyngeal and esophageal candidiasis in Zairian AIDS patients Ann Soc Belg Med Trop 1992 72(1):45 52 1567268
Odden K, Schenck K, Hurlen B High numbers of T cells in gingiva from patients with human immunodeficiency virus (HIV) infection J Oral Pathol Med 1995 24(9):413 9 8537915
Ogunwande SAB The prevalence of oral ailments that are common in HIV infection in a Nigerian dental practice J Acquir Immune Defic Syndr 1990 3(11):1117 8 2213516
O'Hehir TE ANUG data needs study RDH 1991 11(10):
Okabe K, Nakagawa K, Yamamoto E Factors affecting the occurrence of bacteremia associated with tooth extraction Int J Oral Maxillofac Surg 1995 24(3):239 42 7594761
Okuda T, Hatsuoka K, Tsuchiya N Yearly changes in infective cases in the operating room J Jpn Dent Soc Anesthesiol 1999 27(1):28 30
O-Prasertsawat P, Bourlert A Comparative study of fluconazole and clotrimazole for the treatment of vulvovaginal candidiasis Sex Transm Dis 1995 22(4):228 30 7482105
Osborn TP, Frederickson GJ, Small IA, et al A prospective study of complications related to mandibular third molar surgery J Oral Maxillofac Surg 1985 43(10):767 9 2995624
Ou CY, Ciesielski CA, Myers G, et al Molecular epidemiology of HIV transmission in a dental practice Science 1992 256(5060):1165 71 1589796
Overholser CD, Peterson DE, Bergman SA, et al Dental extractions in patients with acute nonlymphocytic leukemia J Oral Maxillofac Surg 1982 40(5):296 8 6211528
Padeh S, Theodor R, Jonas A, et al Severe malabsorption in autoimmune polyendocrinopathy-candidosis-ectodermal dystrophy syndrome successfully treated with immunosuppression Arch Dis Child 1997 76(6):532 4 9245854
Page RC, Beck JD Risk assessment for periodontal diseases Int Dent J 1997 47(2):61 87 9448791
Palacio H, Hilton JF, Canchola AJ, et al Effect of cigarette smoking on HIV-related oral lesions J Acquir Immune Defic Syndr 1997 14(4):338 42
Palenicek J, Nelson KE, Vlahov D, et al Comparison of clinical symptoms of human immunodeficiency virus disease between intravenous drug users and homosexual men Arch Intern Med 1993 153(15):1806 12 8101438
Palenik CJ, Miller CH Treating highly infectious patients in the dental office J Indiana Dent Assoc 1985 64(5):11 5
Palmer C. AIDS and dentistry: The governmental view. J Am Dent Assoc. 1989;Suppl:3S-8S. [pmid: 2592691].
Pankhurst CL, Lewis DA, Clark DT Prophylactic application of an intra-alveolar socket medicament to reduce postextraction complications in HIV-seropositive patients Oral Surg Oral Med Oral Pathol 1994 77(4):331 44 8015795
Papadopoulos J Hematogenous candidiasis in critically ill adult patients: Epidemiology, risk factors and management J Pharm Pract 1998 11(6):437 51
Parente F, Ardizzone S, Cernuschi M, et al Prevention of symptomatic recurrences of esophageal candidiasis in AIDS patients after the first episode: A prospective open study Am J Gastroenterol 1994 89(3):416 20 8122656
Park SS, D'Amico DJ, Paton B, et al Treatment of exogenous Candida endophthalmitis in rabbits with oral fluconazole Antimicrob Agents Chemother 1995 39(4):958 63 162661 7786003
Parmegiani RM, Loebenberg D, Cacciapuoti A, et al Sch 39304, a new antifungal agent: Oral and topical treatment of vaginal and superficial infections J Med Vet Mycol 1993 31(3):239 48 8360815
Parneix-Spake A, Bastuji-Garin S, Levy Y, et al Didanosine as probable cause of Stevens-Johnson syndrome Lancet 1992 340(8823):857 8
Parra B, Slots J Detection of human viruses in periodontal pockets using polymerase chain reaction Oral Microbiol Immunol 1996 11(5):289 93 9028252
Patel HS, Peters IIM, Smith CL Is there a role for fluconazole in the treatment of vulvovaginal candidiasis? Ann Pharmacother 1992 26(3):350 3 1554957
Patton LL Hematologic abnormalities among HIV-infected patients: Associations of significance for dentistry Oral Surg Oral Med Oral Pathol Oral Radiol Endod 1999 88(5):561 7 10556750
Patton LL, McKaig R, Strauss R, et al Changing prevalence of oral manifestations of human immuno-deficiency virus in the era of protease inhibitor therapy Oral Surg Oral Med Oral Pathol Oral Radiol Endod 2000 89(3):299 304 10710453
Patton LL, McKaig RG, Eron JJ, et al Oral hairy leukoplakia and oral candidiasis as predictors of HIV viral load AIDS 1999 13(15):2174 6 10546876
Patton LL, McKaig RG, Strauss RP, et al Oral manifestations of HIV in a southeast USA population Oral Dis 1998 4(3):164 9 9972166
Patton LL, Shugars DC Immunologic and viral markers of HIV-1 disease progression: Implications for dentistry J Am Dent Assoc 1999 130(9):1313 22 10492538
Patton LL, Van der Horst C Oral infections and other manifestations of HIV disease Infect Dis Clin North Am 1999 13(4):879 900 10579114
Payton C AIDS and health care workers Occup Health 1991 43(8):243 45
Pellicano S, Calzone R, Mandica D, et al Treatment of oral candidiasis with high dose of itraconazole in AIDS patients: Personal experience Gazz Medica Italiana 1999 158(2):37 9
Penn I Cancer is a complication of severe immunosuppression Surg Gynecol Obstet 1986 162(6):603 10 3520906
Penn I. Tumors of the immunocompromised patient. Annu Rev Med. 1988;39:63-73. [pmid: 3285791].
Perry CM, Whittington R, McTavish D Fluconazole: An update of its antimicrobial activity, pharmacokinetic properties, and therapeutic use in vaginal candidiasis Drugs 1995 49(6):984 1006 7641607
Persson RE, Hollender LG, Persson GR Alveolar bone levels in AIDS and HIV seropositive patients and in control subjects J Peridontol 1998 69(9):1056 61
Peter Z, Horvath Z, Makara M, et al Comparison of single-dose and 7-day fluconazole treatment of fungal esophagitis in alcoholic liver disease Zeitschrift fur Gastroenterologie 1996 34(6):361 4 8767824
Petrosillo N, Puro V, Ippolito G, et al Hepatitis B virus, hepatitis C virus and human immunodeficiency virus infection in health care workers: A multiple regression analysis of risk factors J Hosp Infect 1995 30(4):273 81 7499808
Pettifer A Oral candidiasis and HIV infection Nurs Stand 1992 6(42):34 5 1633087
Pfaller MA, Rhine-Chalberg J, Redding SW, et al Variations in fluconazole susceptibility and electrophoretic karyotype among oral isolates of Candida albicans from patients with AIDS and oral candidiasis J Clin Microbiol 1994 32(1):59 64 262970 7907345
Phair J, Munoz A, Detels R, et al The risk of pneumocystis carinii pneumonia among men infected with human immunodeficiency virus type 1. Multicenter AIDS Cohort Study Group N Engl J Med 1990 322(3):161 5 1967190
Phelan JA Dental lesions: Diagnosis and treatment Oral Dis 1997 3(Suppl 1):S235 7 9456696
Phelan JA, Begg MD, Lamster IB, et al Oral candidiasis in HIV infection: Predictive value and comparison of findings in injecting drug users and homosexual men J Oral Pathol Med 1997 26(5):237 43 9178176
Phillips P, De Beule K, Frechette G, et al A double-blind comparison of itraconazole oral solution and fluconazole capsules for the treatment of oropharyngeal candidiasis in patients with AIDS Clin Infect Dis 1998 26(6):1368 73 9636865
Phillips P, Zemcov J, Mahmood W, et al Itraconazole cyclodextrin solution for fluconazole-refractory oropharyngeal candidiasis in AIDS: Correlation of clinical response with in vitro susceptibility AIDS 1996 10(12):1369 73 8902066
Philpott-Howard JN, Wade JJ, Mufti GJ, et al Randomized comparison of oral fluconazole versus oral polyenes for the prevention of fungal infection in patients at risk of neutropenia J Antimicrob Chemother 1993 31(6):973 84 8360134
Piazza M, Chirianni A, Picciotto L, et al Blood in saliva of HIV seropositive drug abusers: Possible implication in AIDS transmission Boll Soc Ital Biol Sper 1991 67(12):1047 52 1840796
Piazza M, Chirianni A, Picciotto L, et al Blood in saliva of patients with acquired immunodeficiency syndrome: Possible implication in sexual transmission of the disease J Med Virol 1994 42(1):38 41 8308518
Piluso S, Di Lollo S, Baroni G, et al Unusual clinical aspects of oral non-Hodgkin's lymphomas in patients with HIV infection Eur J Cancer. Part B, Oral Oncology 1994 30B(1):61 4
Piluso S, Ficarra G, Lucatorto FM, et al Cause of oral ulcers in HIV-infected patients: A study of 19 cases Oral Surg Oral Med Oral Pathol Oral Radiol Endod 1996 82(2):166 72 8863306
Piluso S, Ficarra G, Orsi A, et al Clinical aspects and microbiology of HIV-associated periodontal lesions Minerva Stomatol 1993 42(6):301 9 8232138
Pindborg JJ Epidemiology and oral manifestations of HIV infection Ann R C Surg Engl 1993 75(2):111 4
Pitkin AD, Miller RF Clinical cases in AIDS. Part 2 Br J Hosp Med 1992 47(10):778 9 1318767
Plettenberg A, Stoehr A, Hoffken G, et al Fluconazole therapy of oral candidiasis in HIV-infected patients: Results of a multicentre study Infection 1994 22(2):118 23 7915254
Polak A Antifungal combination therapy in localized candidosis Mycoses 1990 33(7-8):353 8 2090935
Polak A Preclinical data and mode of action of Amorolfine Dermatology 1992 184(Suppl 1):3 7 1550968
Polsky B Treatment of thrush in oncology patients J de Mycologie Medicale 1996 6(Suppl 2):20 5
Pons V, Greenspan D, Debruin M Therapy for oropharyngeal candidiasis in HIV-infected patients: A randomized, prospective multicenter study of oral fluconazole versus clotrimazole troches. The Multicenter Study Group J Acquir Immune Defic Syndr 1993 6(12):1311 6 8254467
Pons V, Greenspan D, Lozada-Nur F, et al Oropharyngeal candidiasis in patients with AIDS: Randomized comparison of fluconazole versus nystatin oral suspensions Clin Infect Dis 1997 24(6):1204 7 9195083
Poroy A AIDS: Recommendations for prevention of the health care workers Adli Tip Dergisi 1988 4(1-2):67 71
Porter SR, El-Maaytah M, Scully C, et al Willingness of dentists to treat an HIV-infected patient AIDS 1995 9(4):402 3 7794550
Porter SR, Luker J, Scully C, et al Oral lesions in UK patients with or liable to HIV disease -- Ten years experience Med Oral 1999 4(3):455 69 11507520
Porter SR, Luker J, Scully C, et al Orofacial manifestations of a group of British patients infected with HIV-1 J Oral Pathol Med 1989 18(1):47 8 2746517
Porter SR, Peake G, Scully C, et al Attitudes to cross-infection measures of UK and Hong Kong patients Br Dent J 1993 175(7):254 7 8398467
Porter SR, Scully C HIV: The surgeon's perspective. Part 1. Update of pathogenesis, epidemiology and management and risk of nosocomial transmission Br J Oral Maxillofac Surg 1994 32(4):222 30 7947566
Porter SR, Scully C HIV topic update: Protease inhibitor therapy and oral health care Oral Dis 1998 4(3):159 63 9972165
Porter SR, Scully C, Cawson RA AIDS: Update and guidelines for general dental practice Dent Update 1987 14(1):9 10, 12, 15-7 2952535
Porter SR, Scully C, Luker J. Complications of dental surgery in persons with HIV disease. Oral Surg Oral Med Oral Pathol. 1993;75:165-7. [pmid: 8426715].
Portier S, El-Maaytah M, Afonso W, et al Attitudes of dentists to HIV-positive patients Lancet 1993 341(8851):
Potasman I, Castin A, Moskovitz B, et al Oral fluconazole for Candida urinary tract infection Urol Int 1997 59(4):252 6 9444745
Powderly WG, Gallant JE, Ghannoum MA, et al Oropharyngeal candidiasis in patients with HIV: Suggested guidelines for therapy Aids Res Hum Retroviruses 1999 16(18):1619 23
Powderly WG, Mayer KH, Perfect JR Diagnosis and treatment of oropharyngeal candidiasis in patients infected with HIV: A critical reassessment AIDS Res Hum Retroviruses 1999 15(16):1405 12 10555102
Prentice AG, Barnes RA, Rogers TRF, et al Therapy of deep fungal infection in haematological malignancy J Antimicrob Chemother 1997 40(6):779 88 9462428
Preston SL, Briceland LL Fluconazole for antifungal prophylaxis in chemotherapy-induced neutropenia Am J Health Syst Pharm 1995 52(2):164 73 12879543
Price P, Calder DM, Witt CS, et al Periodontal attachment loss in HIV-infected patients is associated with the major histocompatibility complex 8. 1 haplotype (HLA-A1,B8,DR3) Tissue Antigens 1999 54(4):391 9 10551423
Puelacher W, Hinteregger G, Nussbaumer W, et al Preoperative autologous blood donation in orthognathic surgery: A follow-up study of 179 patients J Craniomaxillofac Surg 1998 26(2):121 5 9617678
Quabeck K, Muller KD, Beelen DW, et al Prophylaxis and treatment of fungal infections with fluconazole in bone marrow transplant patients Mycoses 1992 35(9-10):221 4 1291872
Quale JM, Landman D, Zaman MM, et al In vitro activity of Cinnamomum zeylanicum against azole resistant and sensitive Candida species and a pilot study of cinnamon for oral candidiasis Am J Chin Med 1996 24(2):103 9 8874667
Quart A, Reich D Fungi in the gingival sulcus -- frequency and speciation in HIV+ and HIV- heterosexual patients Periodont Clin Investig 1995 17(1):10 12
Quart AM, Espinel-Ingroff A, Moore LS, et al Evaluation of fluconazole in the treatment of oropharyngeal candidiasis in patients with AIDS Infect Med 1996 13(8):708 13
Quart AM, Espinel-Ingroff A, Reich D, et al Fluconazole for refractory oropharyngeal candidiasis in aids patients AIDS Patient Care 1995 9(2):56 9
Quartey JB Impact of HIV on the practice of dentistry in Houston, Texas Tex Dent J 1998 115(11):45 56 9927954
Quereda C, Polanco AM, Giner C, et al Correlation between in vitro resistance to fluconazole and clinical outcome of oropharyngeal candidiasis in HIV-infected patients Eur J Clin Microbiol Infect Dis 1996 15(1):30 7 8641300
Rabeneck L, Laine L Esophageal candidiasis in patients infected with the human immunodeficiency virus: A decision analysis to assess cost-effectiveness of alternative management strategies Arch Intern Med 1994 154(23):2705 10 7993154
Rabeneck L, Popovic M, Gartner S, et al Acute HIV infection presenting with painful swallowing and esophageal ulcers JAMA 1990 263(17):2318 22 2325232
Rahn R Review presentation on povidone-iodine antisepsis in the oral cavity Postgrad Med J 1993 69(Suppl 3):S4 9 8290456
Rajnay ZW, Hochstetter RL Immediate placement of an endosseous root-form implant in an HIV-positive patient: Report of a case J Peridontol 1998 69(10):1167 71
Ramael M, Colebunders R, Colpaert C, et al The prevalence of hairy leukoplakia in HIV seropositive and HIV seronegative immunocompromised patients Int J STD AIDS 1992 3(4):251 4 1504155
Ramirez V, Gonzalez A, de la Rosa E, et al Oral lesions in Mexican HIV-infected patients J Oral Pathol Med 1990 19(10):482 5 1962816
Ramirez-Amador V, Esquivel-Pedraza L, Sierra-Madero J, et al Oral manifestations of HIV infection by gender and transmission category in Mexico City J Oral Pathol Med 1998 27(3):135 40 9563806
Ramirez-Amador V, Gonzalez M, de la Rosa E, et al Oral findings in Mexican AIDS patients with cancer J Oral Pathol Med 1993 22(2):87 91 8445548
Ramos-Gomez FJ, Flaitz C, Catapano P, et al Classification, diagnostic criteria, and treatment recommendations for orofacial manifestations in HIV-infected pediatric patients. Collaborative Workgroup on Oral Manifestations of Pediatric HIV Infection J Clin Pediatr Dent 1999 23(2):85 96 10204447
Ramos-Gomez FJ, Hilton JF, Canchola AJ, et al Risk factors for HIV-related orofacial soft-tissue manifestations in children Pediatr Dent 1996 18(2):121 6 8710713
Rams TE, Andriolo MJ, Feik D, et al Microbiological study of HIV-related periodontitis J Peridontol 1991 62(1):74 81
Raphael KG, Kunzel C, Sadowsky D Differences between Asian-American and white American dentists in attitudes toward treatment of HIV-positive patients AIDS Educ Prev 1996 8(2):155 64 8727655
Rarick MU, Burian P, De Guzman N, et al Intravenous immune globulin use in patients with human immunodeficiency virus-related thrombocytopenia who require dental extraction West J Med 1991 155(6):610 2 1812630 1003106
Ravera M, Reggiori A, Agliata AM, et al Evaluating diagnosis and treatment of oral and esophageal candidiasis in Ugandan AIDS patients Emerg Infect Dis 1999 5(2):274 7 10221882
Ravina A, Ficarra G, Chiodo M, et al Relationship of circulating CD4+ T-lymphocytes and p24 antigenemia to the risk of developing AIDS in HIV-infected subjects with oral hairy leukoplakia J Oral Pathol Med 1996 25(3):108 11 9148036
Redding S, Smith J, Farinacci G, et al Resistance of Candida albicans to fluconazole during treatment of oropharyngeal candidiasis in a patient with AIDS: Documentation by in vitro susceptibility testing and DNA subtype analysis Clin Infect Dis 1994 18(2):240 2 8161633
Redding SW, Pfaller MA, Messer SA, et al Variations in fluconazole susceptibility and DNA subtyping of multiple Candida albicans colonies from patients with AIDS and oral candidiasis suffering one or more episodes of infection J Clin Microbiol 1997 35(7):1761 5 229836 9196188
Reef SE, Levine WC, McNeil MM, et al Treatment options for vulvovaginal candidiasis, 1993 Clin Infect Dis 1995 20(Suppl 1):S80 90 7795112
Reents S, Goodwin SD, Singh V Antifungal prophylaxis in immunocompromised hosts Ann Pharmacother 1993 27(1):53 60 8431623
Rees T, Phillips R Multicenter comparison of one-day oral therapy with fluconazole or itraconazole in vaginal candidiasis Int J Gynecol Obstet 1992 37(Suppl 1):33 8
Regezi JA, Eversole LR, Barker BF, et al Herpes simplex and cytomegalovirus coinfected oral ulcers in HIV-positive patients Oral Surg Oral Med Oral Pathol Oral Radiol Endod 1996 81(1):55 62 8850485
Regezi JA, Greenspan D, Greenspan JS, et al HPV-associated epithelial atypia in oral warts in HIV+ patients J Cutan Pathol 1994 21(3):217 23 7962824
Regezi JA, MacPhail LA, Daniels TE, et al Oral Kaposi's sarcoma: A 10-year retrospective histopathologic study J Oral Pathol Med 1993 22(7):292 7 8229865
Regezi JA, Macphail LA, Richards DW, et al A study of macrophages, macrophage-related cells, and endothelial adhesion molecules in recurrent aphthous ulcers in HIV-positive patients J Dent Res 1993 72(12):1549 53 7504704
Regezi JA, McMillan A, Dekker N, et al Apoptosis-associated proteins in oral lymphomas from HIV-positive patients Oral Surg Oral Med Oral Pathol Oral Radiol Endod 1998 86(2):196 202 9720096
Reichart PA, Langford A, Gelderblom HR, et al Oral hairy leukoplakia: Observations in 95 cases and review of the literature J Oral Pathol Med 1989 18(7):410 5 2555478
Reichart PA, Luck A Dentists' attitudes to HIV infection in East and West Berlin AIDS-Forschung 1994 9(10):517 21
Reichart PA, Schiodt M Non-pigmented oral Kaposi's sarcoma (AIDS). Report of two cases Int J Oral Maxillofac Surg 1989 18(4):197 9 2507665
Reichart PA, Weigel D, Schmidt-Westhausen A, et al Exfoliative cheilitis (EC) in AIDS: Association with Candida infection J Oral Pathol Med 1997 26(6):290 3 9234190
Reinoso PC, Garcia JMA, Bermejo CL, et al Current treatment of candidemia in non-neutropenic patients. Amphotericin B or fluconazole? Retrospective study of 62 consecutive cases Rev Clin Esp 1997 197(12):799 803 9477669
Resnick L, Herbst JS, Ablashi DV, et al Regression of oral hairy leukoplakia after orally administered acyclovir therapy JAMA 1988 259(3):384 8 2826830
Restrepo MI, Najvar LK, Fothergill AW, et al Pradimicin therapy of disseminated Candida tropicalis infection in the mouse Medical Mycology 1998 36(3):181 4 9776832
Revankar SG, Kirkpatrick WR, McAtee RK, et al A randomized trial of continuous or intermittent therapy with fluconazole for oropharyngeal candidiasis in HIV-infected patients: Clinical outcomes and development of fluconazole resistance Am J Med 1998 105(1):7 11 9688014
Revankar SG, Sanche SE, Dib OP, et al Effect of highly active antiretroviral therapy on recurrent oropharyngeal candidiasis in HIV-infected patients AIDS 1998 12(18):2511 3 9875598
Reynes J, Raffi F, Joly V, et al Itraconazole oral solution for treatment of fluconazole resistant oral/esophageal candidosis in HIV-infected patients: Results of a prospective multicenter study. I. Clinical assessment J de Mycologie Medicale 1999 9(2):83 7
Rezabek GH, Friedman AD Superficial fungal infections of the skin: Diagnosis and current treatment recommendations Drugs 1992 43(5):674 82 1379146
Richards JM Notes on AIDS Br Dent J 1985 158(6):199 201 3159404
Richardson K Fluconazole: Fundamental aspects Reanimation Soins Intensifs Medecine D'Urgence 1990 6(Suppl S7 bis):623 4
Riley C, London JP, Burmeister JA Periodontal health in 200 HIV-positive patients J Oral Pathol Med 1992 21(3):124 7 1583595
Rindum JL, Holmstrup P, Pedersen M, et al Miconazole chewing gum for treatment of chronic oral candidosis Scand J Dent Res 1993 101(6):386 90 8290882
Robert LM, Chamberland ME, Cleveland JL, et al Investigations of patients of health care workers infected with HIV. The Centers for Disease Control and Prevention database Ann Intern Med 1995 122(9):653 7 7702226
Robinson EN Jr, De Bliek R The college student, the dentist, and the North Carolina senator: Risk analysis and risk management of HIV transmission from health care worker to patient Med Decis Making 1996 16(1):86 91 8717603
Robinson P, Croucher R The satisfaction of men with HIV infection attending a dedicated dental clinic: A controlled study AIDS Care 1994 6(1):39 48 8186276
Robinson P, Zakrzewska JM, Maini M, et al Dental visiting behaviour and experiences of men with HIV Br Dent J 1994 176(5):175 9 8136215
Robinson PG, Challacombe SJ, Sheiham A, et al Is erythematous candidiasis associated with advanced HIV disease? Oral Dis 1997 3(Suppl 1):S116 8 9456670
Robinson PG, Cooper H, Hatt J Healing after dental extractions in men with HIV infection Oral Surg Oral Med Oral Pathol 1992 74(4):426 30 1408013
Robinson PG, Croucher R Access to dental care -- experiences of men with HIV infection in the United Kingdom Community Dent Oral Epidemiol 1993 21(5):306 8 8222607
Robinson PG, Sheiham A, Challacombe SJ, et al Periodontal health and HIV infection Oral Dis 1997 3(Suppl 1):S149 52 9456679
Robinson PG, Sheiham A, Challacombe SJ, et al The periodontal health of homosexual men with HIV infection: A controlled study Oral Dis 1996 2(1):45 52 8957937
Robinson PG, Winkler JR, Palmer G, et al The diagnosis of periodontal conditions associated with HIV infection J Peridontol 1994 65(3):236 43
Rodilla Calvelo F, Orovitg Moreno F, Ferriols Lisart R, et al Domiciliary treatment with fluconazole for gastrointestinal candidiasis in AIDS patients Farmacia Hospitalaria 1995 19(3):145 7
Rodriguez Armas O, Bajares M, Kizer S, et al Efficacy and safety of a single oral dose of fluconazole (150 mg) in vulvovaginal candidiasis Revista de Obstetricia y Ginecologia de Venezuela 1992 52(4):231 5
Rodriguez-Tudela JL, Martinez-Suarez JV, Dronda F, et al Correlation of in-vitro susceptibility test results with clinical response: A study of azole therapy in AIDS patients J Antimicrob Chemother 1995 35(6):793 804 7559191
Rogasi PG, Vigano S, Pecile P, et al Lactobacillus casei pneumonia and sepsis in a patient with AIDS: Case report and review of the literature Ann Ital Med Int 1998 13(3):180 2 9859577
Rogers VC Dentistry and AIDS: Ethical and legal obligations in provision of care Med Law 1988 7(1):57 63 3339960
Rooney JF, Bryson Y, Mannix ML, et al Prevention of ultraviolet-light-induced herpes labialis by sunscreen Lancet 1991 338(8780):1419 22 1683420
Rosen T Tinea versicolor and candidiasis: An update on topical and systemic therapy Consultant 1997 37(6):1558 69
Rosenberg ZS, Joffe SA, Itescu S Spectrum of salivary gland disease in HIV-infected patients: Characterization with Ga-67 citrate imaging Radiology 1992 184(3):761 4 1509064
Rosenstein DI, Chiodo GT, Bartley MH Treating recurrent aphthous ulcers in patients with AIDS J Am Dent Assoc 1991 122(11):64, 67 8
Rosenstein DI, Riviere GR, Elott KS HIV-associated periodontal disease: New oral spirochete found J Am Dent Assoc 1993 124(7):76 80
Rosenstein DL, Ciodo GT, Bartley MH Unusual presentation of non-Hodgkin's lymphoma in a patient with HIV Gen Dent 1992 40(1):40 2 1628796
Rosner F, Sordillo PP, Wolpaw JR, et al Ethical considerations concerning the HIV-positive physician N Y State J Med 1992 92(4):151 5 1594147
Rowland RW, Escobar MR, Friedman RB, et al Painful gingivitis may be an early sign of infection with the human immunodeficiency virus Clin Infect Dis 1993 16(2):233 6 8095162
Ruhnke M, Eigler A, Engelmann E, et al Correlation between antifungal susceptibility testing of Candida isolates from patients with HIV infection and clinical results after treatment with fluconazole Infection 1994 22(2):132 6 8070927
Ruhnke M, Eigler A, Tennagen I, et al Emergence of fluconazole-resistant strains of Candida albicans in patients with recurrent oropharyngeal candidosis and human immunodeficiency virus infection J Clin Microbiol 1994 32(9):2092 8 263948 7814530
Ruhnke M, Schmidt-Westhausen A, Engelmann E, et al Comparative evaluation of three antifungal susceptibility test methods for Candida albicans isolates and correlation with response to fluconazole therapy J Clin Microbiol 1996 34(12):3208 11 229485 8940474
Ruhnke M, Schmidt-Westhausen A, Trautmann M In vitro activities of voriconazole (UK-109,496) against fluconazole-susceptible and -resistant Candida albicans isolates from oral cavities of patients with human immunodeficiency virus infection Antimicrob Agents Chemother 1997 41(3):575 7 163753 9055995
Ruskin JD, Wood RP, Bailey MR, et al Comparative trial of oral clotrimazole and nystatin for oropharyngeal candidiasis prophylaxis in orthotopic liver transplant patients Oral Surg Oral Med Oral Pathol 1992 74(5):567 71 1437059
Russell JG, Smithurst BA Implications of AIDS for teachers of medicine to dental students Med Educ 1989 23(6):534 7 2593885
Ryder MI. Periodontal considerations in the patient with HIV. Curr Opin Periodontol. 1993:43-51.
Ryder MI, Winkler JR, Weinreb RN Elevated phagocytosis, oxidative burst, and F-actin formation in PMNs from individuals with intraoral manifestations of HIV infection J Acquir Immune Defic Syndr 1988 1(4):346 53 3216315
Saag MS, Fessel WJ, Kaufman CA, et al Treatment of fluconazole-refractory oropharyngeal candidiasis with itraconazole oral solution in HIV-positive patients AIDS Res Hum Retroviruses 1999 15(16):1413 7 10555103
Sadowsky D, Kunzel C Continuing education and patients with HIV: Attitudes, perceived risk, and willingness to treat Gen Dent 1992 40(3):
Sadowsky D, Kunzel C Dentists' HIV-related ethicality: An empirical test J Am Coll Dent 1997 64(1):27 9 9130805
Sadowsky D, Kunzel C Measuring dentists' willingness to treat HIV-positive patients J Am Dent Assoc 1994 125(6):705 10 8014335
Sadowsky D, Kunzel C Predicting dentists' willingness to treat HIV-infected patients AIDS Care 1996 8(5):581 8 8893908
Safrin S, Crumpacker C, Chatis P, et al. A controlled trial comparing foscarnet with vidarabine for acyclovir-resistant mucocutaneous herpes simplex in the acquired immunodeficiency syndrome. N Engl J Med. 1991;325:551-5. [pmid: 1649971].
Salo T, Sorsa T, Lauhio A, et al. Matrix metalloproteinases, their endogenous inhibitors, and microbial activators in gingival crevicular fluid and saliva of HIV(+)-subjects. Ann N Y Acad Sci. 1994;732:476-8. [pmid: 7978843].
Salvi GE, Lawrence HP, Offenbacher S, et al. Influence of risk factors on the pathogenesis of periodontitis. Periodontol 2000. 1997;14:173-201. [pmid: 9567971].
Samandari T Photo quiz. Benign lymphoepithelial cysts Clin Infect Dis 1998 27(4):687, 884 5
Samaranayake LP Prevalence and nature of HIV Dent Update 1989 16(1):30 1 2599243
Samaranayake LP, McDonald KC Patient perception of cross-infection prevention in dentistry Oral Surg Oral Med Oral Pathol 1990 69(4):457 60 2326037
Sandvej K, Krenacs L, Hamilton-Dutoit SJ, et al Epstein-Barr virus latent and replicative gene expression in oral hairy leukoplakia Histopathology 1992 20(5):387 95 1316871
Sangeorzan JA, Bradley SF, He X, et al Epidemiology of oral candidiasis in HIV-infected patients: Colonization, infection, treatment, and emergence of fluconazole resistance Am J Med 1994 97(4):339 46 7942935
Sanguineti A, Carmichael JK, Campbell K Fluconazole-resistant Candida albicans after long-term suppressive therapy Arch Intern Med 1993 153(9):1122 4 8481078
Santolaria F, Castilla A, Gonzalez-Reimers E, et al Alcohol intake in a rural village: Physical signs and biological markers predicting excessive consumption in apparently healthy people Alcohol 1997 14(1):9 19 9014018
Sarris AH, Papadimitrakopoulou V, Dimopoulos MA, et al Primary parotid lymphoma: The effect of International Prognostic Index on outcome Leuk Lymphoma 1997 26(1-2):49 56 9250787
Satoh KI, Yokoyama K, Nishihara M, et al Investigation of autologous blood transfusion during operations at Kagoshima University Dental Hospital J Jpn Dent Soc Anesthesiol 1998 26(1):94 8
Sawyer RG, Adams RB, Rosenlof LK, et al Effectiveness of fluconazole in murine Candida albicans and bacterial C. albicans peritonitis and abscess formation J Med Vet Mycol 1995 33(2):131 6 7658305
Schafer-Korting M, Blechschmidt J, Korting HC Clinical use of oral nystatin in the prevention of systemic candidosis in patients at particular risk Mycoses 1996 39(9-10):329 39 9009654
Schaffner W Surgeons with HIV infection: The risk to patients J Hosp Infect 1991 18(Suppl A):191 6 1679783
Schaffner W, Mishu-Allos B Protecting patients when their surgeon or dentist is infected with a blood-borne virus J Hosp Infect 1995 30(Suppl):156 62 7560946
Scheutz F Dental care of HIV-infected patients: Attitudes and behavior among Danish dentists Community Dent Oral Epidemiol 1989 17(3):117 9 2525453
Scheutz F HIV infection and dental care: Views and experiences among HIV-seropositive patients AIDS Care 1990 2(1):37 42 2083259
Scheutz F, Langebaek J Dental care of infectious patients in Denmark, 1986-1993: Theoretical considerations and empirical findings Community Dent Oral Epidemiol 1995 23(4):226 31 7587144
Scheutz F, Matee MI, Andsager L, et al Is there an association between periodontal condition and HIV infection? J Clin Periodontol 1997 24(8):580 7 9266346
Scheutz F, Matee MI, Simon E, et al Association between carriage of oral yeasts, malnutrition and HIV-1 infection among Tanzanian children aged 18 months to 5 years Community Dent Oral Epidemiol 1997 25(3):193 8 9192146
Schiodt M HIV-associated salivary gland disease: A review Oral Surg Oral Med Oral Pathol 1992 73(2):164 7 1549310
Schiodt M, Bakilana PB, Hiza JF, et al Oral candidiasis and hairy leukoplakia correlate with HIV infection in Tanzania Oral Surg Oral Med Oral Pathol 1990 69(5):591 6 2185450
Schiodt M, Greenspan D, Daniels TE, et al Parotid gland enlargement and xerostomia associated with labial sialadenitis in HIV-infected patients J Autoimmun 1989 2(4):415 25 2789646
Schiodt M, Greenspan D, Greenspan JS HIV-related oral lesions: Bacterial infections J Respir Dis 1996 17(6):502 4
Schmidt A Systemic candidiasis in Sprague-Dawley rats J Med Vet Mycol 1996 34(2):99 104 8732354
Schmidt-Westhausen A, Gelderblom HR, Reichart PA Oral hairy leukoplakia in an HIV-seronegative heart transplant patient [published erratum appears in J Oral Pathol Med 1990;19(9):440] J Oral Pathol Med 1990 19(4):192 4 2164104
Schmidt-Westhausen A, Grunewald T, Reichart PA, et al Oral cryptococcosis in a patient with AIDS: A case report Oral Dis 1995 1(2):77 9 7553389
Schmidt-Westhausen A, Grunewald T, Reichart PA, et al Oral manifestations in 70 German HIV-infected women Oral Dis 1997 3(Suppl 1):S28 30 9456652
Schmidt-Westhausen A, Schiller RA, Pohle HD, et al Oral Candida and Enterobacteriaceae in HIV-1 infection: Correlation with clinical candidiasis and antimycotic therapy J Oral Pathol Med 1991 20(10):467 72 1753348
Schmidt-Westhausen AM, Priepke F, Bergmann FJ, et al Decline in the rate of oral opportunistic infections following introduction of highly active antiretroviral therapy J Oral Pathol Med 2000 29(7):336 41 10947250
Schneider DA, Hardwick KS, Marconi KM, et al Delivery of oral health care through the Ryan White CARE Act to people infected with HIV J Public Health Dent 1993 53(4):258 64 8258790
Schneider DA, Hardwick KS, Niemcryk SJ, et al A profile of patients in six dental schools J Dent Educ 1996 60(1):79 80 8594107
Schnetler JF Blood splashes to the eyes in oral and maxillofacial surgery, and the risks of HIV transmission Br J Oral Maxillofac Surg 1991 29(5):338 40 1742267
Schoenbaum EE, Davenny K, Holbrook K The management of HIV disease in pregnancy Baillieres Clin Obstet Gynaecol 1992 6(1):101 24 1633653
Schoofs AG, Odds FC, Colebunders R, et al Cross-sectional study of oral Candida carriage in a human immunodeficiency virus (HIV)-seropositive population: Predisposing factors, epidemiology and antifungal susceptibility Mycoses 1998 41(5-6):203 11 9715634
Schulman DI Point of view: Stigma, risk, and the Florida AIDS dental cases AIDS Patient Care 1992 6(1):3 4
Schulten E, Ten Kate RW, Van der Waal I Oral findings in HIV-infected patients attending a department of internal medicine: The contribution of intraoral examination towards the clinical management of HIV disease Q J Med 1990 76(279):741 5 2217677
Schulten EA, Ten Kate RW, Van der Waal I Oral manifestations of HIV infection in 75 Dutch patients J Oral Pathol Med 1989 18(1):42 6 2545871
Schuman P, Capps L, Peng G, et al Weekly fluconazole for the prevention of mucosal candidiasis in women with HIV infection. A randomized, double-blind, placebo-controlled trial. Terry Beirn Community Programs for Clinical Research on AIDS Ann Intern Med 1997 126(9):689 96 9139554
Schuman P, Christensen C, Sobel JD Aphthous vaginal ulceration in two women with acquired immunodeficiency syndrome Am J Obstet Gynecol 1996 174(5):1660 3 9065154
Schuman P, Ohmit SE, Sobel JD, et al Oral lesions among women living with or at risk for HIV infection. HIV Epidemiology Research Study (HERS) Group Am J Med 1998 104(6):559 64 9674719
Schuman P, Sobel JD, Ohmit SE, et al Mucosal candidal colonization and candidiasis in women with or at risk for human immunodeficiency virus infection. HIV Epidemiology Research Study (HERS) Group Clin Infect Dis 1998 27(5):1161 7 9827263
Schwarz B One year experience with self medication in vaginomycosis Pharmazeutische Zeitung 1995 140(45):44 7
Schwarze R, Penk A, Pittrow L Administration of fluconazole in children below 1 year of age Mycoses 1999 42(1-2):3 16 10394841
Sciacca A, Betta P, Cilauro S, et al Oral itraconazole therapy for neonatal hepatic candidiasis Ped Med Chir 1995 17(2):173 5
Scully C HIV topic update: Salivary testing for antibodies Oral Dis 1997 3(4):212 5 9643214
Scully C, Cawson RA, Porter S Acquired immune deficiency syndrome (AIDS) Br Dent J 1983 155(7):221 5 6227326
Scully C, McCarthy G Management of oral health in persons with HIV infection Oral Surg Oral Med Oral Pathol 1992 73(2):215 25 1312692
Scully C, Mortimer P Gnashings of HIV Lancet 1994 344(8927):
Scully C, Porter SR Infection control in dentistry Curr Opin Infect Dis 1994 7(4):488 92
Sears C The oral manifestations of AIDS AIDS Patient Care 1989 3(4):8 10
Seddon BM, Padley SP, Gazzard BG Differential diagnosis of parotid masses in HIV positive men: Report of five cases and review Int J STD AIDS 1996 7(3):224 7 8799787
Segal R, Trattner A, Alteras I, et al Once-weekly treatment with oral ketoconazole for superficial fungal infections J Am Acad Dermatol 1993 28(1):126 7 8425958
Seki H, Seno A, Sakazume S, et al Clinical study of fluconazole-injectable and -granules in pediatric patients Jpn J Antibiot 1994 47(3):289 95 8182900
Sereno Colo JA Efficacy and safety of single-dose fluconazole in the treatment of vaginal candidiasis Investigacion Medica Internacional 1991 17(4):181 4
Sesin GP, Miller J Itraconazole: A novel antifungal agent P & T 1993 18(10):952 4, 959-60
Shaoxi W, Ningru G, Wanqing L, et al A multicentre noncomparative study of fluconazole in the treatment of systemic fungal infections J Dermatol Treat 1995 6(3):171 2
Shearer BG MDR-TB: Another challenge from the microbial world J Am Dent Assoc 1994 125(1):42 9 8294663
Shen C, Grimaudo N, Marsh D, et al. Effectiveness of antifungal agent containing microspheres for controlling oral candidiasis. Proc Controlled Release Soc. 1996;23:517-8.
Shiboski CH, Neuhaus JM, Greenspan D, et al Effect of receptive oral sex and smoking on the incidence of hairy leukoplakia in HIV-positive gay men J Acquir Immune Defic Syndr 1999 21(3):236 42 10421248
Shiboski CH, Palacio H, Neuhaus JM, et al Dental care access and use among HIV-infected women Am J Public Health 1999 89(6):834 9 10358671 1508645
Shields JW, Mishu B, Schaffner W HIV-infected health care workers: Risk to patients JAMA 1993 270(13):1545 6 8371461
Ship JA, Wolff A AIDS and HIV-1 infection: Clinical entities in geriatric dentistry Gerodontology 1989 8(1):27 32 2534831
Shugar JM, Som PM, Jacobson AL, et al Multicentric parotid cysts and cervical adenopathy in AIDS patients. A newly recognized entity: CT and MR manifestations Laryngoscope 1988 98(7):772 5 3386385
Siegal MD, Garcia AI, Odom JG, et al Treating persons with AIDS: Report on a survey of Ohio dentists' knowledge, attitudes and practices in 1989 Ohio Dent J 1990 64(1):8 9, 11-3
Siew C, Gruninger SE, Hojvat SA Screening dentists for HIV and hepatitis B N Engl J Med 1988 318(21):1400 1
Silverman SJ, Gallo JW, McKnight ML, et al Clinical characteristics and management responses in 85 HIV-infected patients with oral candidiasis Oral Surg Oral Med Oral Pathol Oral Radiol Endod 1996 82(4):402 7 8899777
Silverman SJ, Kaugars GE, Gallo J, et al Clinical and lymphocyte responses to beta-carotene supplementation in 11 HIV-positive patients with chronic oral candidiasis Oral Surg Oral Med Oral Pathol 1994 78(4):442 7 7800374
Silverman SJ, Lozada F, Migliorati C, et al Current assessment: Dental risks and guidelines in the AIDS epidemic CDA Journal 1983 11(10):7 10 6233014
Sinicco A, Raiteri R, Flecchia G, et al Fluconazole versus ketoconazole in the treatment of oral candidiasis in HIV positive subjects G Mal Infett Parassit 1991 43(10):914 7
Sirois DA Oral manifestations of HIV disease Mt Sinai J Med 1998 65(5-6):322 32 9844359
Skott P, Lucht E, Julander I, et al Salivary sIgA response in HIV-1 infection J Acquir Immune Defic Syndr 1999 21(2):73 80 10360797
Slavin MB, Benrubi GI, Parker R, et al Single dose oral fluconazole vs intravaginal terconazole in treatment of Candida vaginitis: Comparison and pilot study J Fla Med Assoc 1992 79(10):693 6 1460451
Smith D, Gazzard B Treatment and prophylaxis of pneumocystis carinii pneumonia in AIDS patients Drugs 1991 42(4):628 39 1723365
Smith DE, Midgley J, Allan M, et al Itraconazole versus ketaconazole in the treatment of oral and oesophageal candidosis in patients infected with HIV AIDS 1991 5(11):1367 71 1662959
Smith GH Treatment of infections in the patient with acquired immunodeficiency syndrome Arch Intern Med 1994 154(9):949 73 8179453
Smith GL, Cross DL, Wray D Comparison of periodontal disease in HIV seropositive subjects and controls (I). Clinical features J Clin Periodontol 1995 22(7):558 68 7560240
Smith KJ, Nelson A, Angritt P, et al Kaposi's sarcoma in women: A clinicopathologic study J Cutan Med Surg 1999 3(3):132 9 10082593
Sobel JD Controversial aspects in the management of vulvovaginal candidiasis J Am Acad Dermatol 1994 31(3 Pt 2):S10 13 8077494
Sobel JD Limitations of antifungal agents in the treatment of Candida vaginitis: Future challenges Drug Resist Update 1999 2(3):148 52
Sobel JD Management of asymptomatic candiduria Int J Antimicrob Agents 1999 11(3-4):285 8 10394984
Soberman N, Leonidas JC, Berdon WE, et al Parotid enlargement in children seropositive for human immunodeficiency virus: Imaging findings AJR 1991 157(3):553 6 1651645
Somos P A new drug form for oral use (Klion-suspension) in the treatment of vaginal trichomoniasis Ther Hung 1992 40(3):127 9
Sote EO. HIV infection in children: A challenge to dental practice. Afr Dent J. 1993:711-9.
Soto JC, Levy MD, Allard R, et al Determinants of AIDS preventive behaviour among dental professionals Can J Public Health 1993 84(2):128 31 8334606
Soto-Ramirez LE, Hernandez-Gomez L, Sifuentes-Osornio J, et al Detection of specific antibodies in gingival crevicular transudate by enzyme-linked immunosorbent assay for diagnosis of human immunodeficiency virus type 1 infection J Clin Microbiol 1992 30(11):2780 3 270527 1452645
Southam JC, Felix DH, Cubie HA, et al Multifocal hairy leukoplakia associated with Kaposi's sarcoma Br Dent J 1992 172(1):21 3 1736946
Spector SL, Bernstein IL I. Executive summary of sinusitis practice parameters J Allergy Clin Immunol 1998 102(6 Pt 2):S108 44
Speller DCE, Shanson DC, Ayliffe GAJ, et al Acquired immune deficiency syndrome: Recommendations of a Working Party of the Hospital Infection Society J Hosp Infect 1990 15(1):7 34 1968481
Spinillo A, Colonna L, Piazzi G, et al Managing recurrent vulvovaginal candidiasis: Intermittent prevention with itraconazole J Reprod Med 1997 42(2):83 7 9058342
Sporri B, von Overbeck J, Brand CU, et al Reduced number of Langerhans cells in oral mucosal washings from HIV-1 seropositives J Oral Pathol Med 1994 23(9):399 402 7529837
Springer G Single oral fluconazole therapy in the treatment of vaginal mycosis Therapiewoche Osterreich 1991 6(4):217 24
Steidley KE, Thompson SH, McQuade MJ, et al A comparison of T4:T8 lymphocyte ratio in the periodontal lesion of healthy and HIV-positive patients J Peridontol 1992 63(9):753 6
Stein GE, Christensen S, Mummaw N Comparative study of fluconazole and clotrimazole in the treatment of vulvovaginal candidiasis DICP 1991 25(6):582 5 1877264
Steinsvoll S, Myint M, Odden K, et al Reduced serum IgG reactivities with bacteria from dental plaque in HIV-infected persons with periodontitis J Clin Periodontol 1997 24(11):823 9 9402504
Stellbrink HJ, Albrecht H, Fenske S, et al Candida krusei sepsis in HIV infection AIDS 1992 6(7):746 8 1503698
Stempel RR, Moulton JM, Moss AR Self-disclosure of HIV-1 antibody test results. The San Francisco General Hospital Cohort AIDS Educ Prev 1995 7(2):116 23 7619642
Stevens DA Oral amphotericin B in the treatment of oral candidiasis J de Mycologie Medicale 1996 6(Suppl 2):48 CIII
Stevens DA, Greene SI, Lang OS Thrush can be prevented in patients with acquired immunodeficiency syndrome and the acquired immunodeficiency syndrome-related complex: Randomized, double-blind, placebo-controlled study of 100-mg oral fluconazole daily Arch Intern Med 1991 151(12):2458 64 1747004
St.-Germain G, Dion C, Espinel-Ingroff A, et al Ketoconazole and itraconazole susceptibility of Candida albicans isolated from patients infected with HIV J Antimicrob Chemother 1995 36(1):109 18
Stolarski CR, Boguslaw BI, Hoffman CH, et al Small-cell noncleaved non-Hodgkin's lymphoma of the mandible in previously unrecognized human immunodeficiency virus infection: Report of a case J Oral Maxillofac Surg 1997 55(8):853 6 9251616
Stroner WF, Christensen C, Remeikis NA, et al Survey at urban college indicates compliance Today's FDA 1990 2(7):
Suchil P, Gei FM, Robles M, et al Once-weekly oral doses of fluconazole 150 mg in the treatment of tinea corporis/cruris and cutaneous candidiasis Clin Exp Dermatol 1992 17(6):397 401 1486705
Sugar AM Interactions of amphotericin B and SCH 39304 in the treatment of experimental murine candidiasis: Lack of antagonism of a polyene-azole combination Antimicrob Agents Chemother 1991 35(8):1669 71 245239 1929339
Sugar AM, Hitchcock CA, Troke PF, et al Combination therapy of murine invasive candidiasis with fluconazole and amphotericin B Antimicrob Agents Chemother 1995 39(3):598 601 162590 7793858
Sugar AM, McCaffrey RP Antifungal activity of 3'-deoxyadenosine (cordycepin) Antimicrob Agents Chemother 1998 42(6):1424 7 105616 9624488
Sugar AM, Salibian M, Goldani LZ Saperconazole therapy of murine disseminated candidiasis: Efficacy and interactions with amphotericin B Antimicrob Agents Chemother 1994 38(2):371 3 284460 8192469
Sugita K, Miyake M, Takitani K, et al Pharmacokinetic and clinical evaluations of fluconazole in pediatric patients Jpn J Antibiot 1994 47(3):296 303 8182901
Sullivan D, Bennett D, Henman M, et al Oligonucleotide fingerprinting of isolates of Candida species other than C. albicans and of atypical Candida species from human immunodeficiency virus-positive and AIDS patients J Clin Microbiol 1993 31(8):2124 33 265709 8103773
Sutherland DC. HIV -- Australasian experience: Current status of HIV infection in Australasia. Ann Royal Aust Coll Dent Surg. 1994;12:94-100.
Suzuki T, Tai H, Yoshie H, et al Characterization of HIV-related periodontitis in AIDS patients: HIV-infected macrophage exudate in gingival crevicular fluid as a hallmark of distinctive etiology Clin Exp Immunol 1997 108(2):254 9 9158094 1904660
Swindells S, Kleinschmidt DR, Hayes FA Pilot study of adjunctive GM-CSF (yeast-derived) for fluconazole- resistant oral candidiasis in HIV-1 infection Infect Dis Clin Pract 1997 6(4):278 9
Syndikus I, Vinall A, Rogers P, et al High dose rate Microselectron moulds for Kaposi sarcoma of the palate Radiother Oncol 1997 42(2):167 70 9106926
Syrjanen S, Laine P, Valle SL Demonstration of Epstein-Barr virus (EBV) DNA in oral hairy leukoplakia using in situ hybridization with biotinylated probe Proc Finn Dent Soc 1988 84(2):127 32 2839824
Syrjanen S, Valle SL, Antonen J, et al Oral candidal infection as a sign of HIV infection in homosexual men Oral Surg Oral Med Oral Pathol 1988 65(1):36 40 3422396
Syrjanen S, von Krogh G, Kellokoski J, et al Two different human papillomavirus (HPV) types associated with oral mucosal lesions in an HIV-seropositive man J Oral Pathol Med 1989 18(6):366 70 2553934
Szpirglas H HIV and dentistry Medecine et Maladies Infectieuses 1989 19(Spec Iss Apr):277 9
Tabata M, Langford A, Becker J, et al Distribution of immunocompetent cells in oral Kaposi's sarcoma (AIDS) Eur J Cancer. Part B, Oral Oncology 1993 29B(3):209 13
Takashima K, Oki T Azole antifungal agents Expert Opinion on Therapeutic Patents 1996 6(7):645 54
Takesaiko K, Kuroda H, Inoue T, et al Biological properties of aureobasidin A, a cyclic depsipeptide antifungal antibiotic J Antibiot 1993 46(9):1414 20 8226319
Talib SH, Singh J A study on opportunistic enteric parasites in 80 HIV seropositive patients Indian J Pathol Microbiol 1998 41(1):31 7 9581074
Talwar GP, Diwan M, Razvi F, et al The impact of new technologies on vaccines Natl Med J India 1999 12(6):274 80 10732430
Tanaka D Management of vaginal candidiasis: A review Pediatr Infect Dis J 1998 17(8):746 7 9726352
Tanner A, Stillman N Oral and dental infections with anaerobic bacteria: Clinical features, predominant pathogens, and treatment Clin Infect Dis 1993 16(Suppl 4):S304 9 8324136
Tavares Nunes Rego T, Barbosa Pinheiro AL Preventive aspects of periodontal diseases in Aids patients Rev Bras Med 1996 53(6):481 90
Taylor MN, Baddour LM, Alexander JR Disseminated histoplasmosis associated with the acquired immune deficiency syndrome Am J Med 1984 77(3):579 80 6332532
Teanpaisan R, Nittayananta W Prevalence of Candida species in AIDS patients and HIV-free subjects in Thailand J Oral Pathol Med 1998 27(1):4 7 9466727
Tenenbaum H, Elkaim R, Cuisinier F, et al Prevalence of six periodontal pathogens detected by DNA probe method in HIV vs non-HIV periodontitis Oral Dis 1997 3(Suppl 1):S153 5 9456680
Tenenbaum HC, Mock D, Simor AE Periodontitis as an early presentation of HIV infection CMAJ 1991 144(10):1265 9 2025822 1335180
Terrell CL Antifungal agents. Part II. The azoles Mayo Clin Proc 1999 74(1):78 100 9987539
Terry JH, Loree TR, Thomas MD, et al Major salivary gland lymphoepithelial lesions and the acquired immunodeficiency syndrome Am J Surg 1991 162(4):324 9 1951883
Terry SD, Jones JE, Brown RH Dental-care experiences of people living with HIV/AIDS in Aotearoa New Zealand N Z Dent J 1994 90(400):49 55 8058218
Thai L, Hart LL Boric acid vaginal suppositories Ann Pharmacother 1993 27(11):1355 7 8286810
Thaker HJ, Gobetti JP, Green TG Patient and dental student responses to a survey about AIDS in the dental setting J Mich Dent Assoc 1993 75(4):30 2, 34, 66
Thomas-Greber E, Korting HC, Bogner J, et al Fluconazole-resistant oral candidosis in a repeatedly treated female AIDS patient Mycoses 1994 37(1-2):35 8 7935590
Thompson AS, Blankenship KM, Selwyn PA, et al Evaluation of an innovative program to address the health and social service needs of drug-using women with or at risk for HIV infection J Community Health 1998 23(6):419 40 9824792
Thompson KA, Strayer DR, Salvato PD, et al Results of a double-blind placebo-controlled study of the double-stranded RNA drug polyI:polyC12U in the treatment of HIV infection Eur J Clin Microbiol Infect Dis 1996 15(7):580 7 8874076
Thompson SH, Charles GA, Craig DB Correlation of oral disease with the Walter Reed staging scheme for HIV-1-seropositive patients Oral Surg Oral Med Oral Pathol 1992 73(3):289 92 1532056
Thomson WM, Stewart JF, Carter KD, et al Public perception of cross-infection control in dentistry Aust Dent J 1997 42(5):291 6 9409043
Thorsen S, Mathiesen LR Fluconazole for ketoconazole-resistant oropharyngeal candidiasis in HIV-1 infected patients Scand J Infect Dis 1990 22(3):375 6 2371551
Tillmann HL, Manns MP Mode of hepatitis C virus infection, epidemiology, and chronicity rate in the general population and risk groups Dig Dis Sci 1996 41(12 Suppl):27 40S
Timonen H, Brusila P, Heikkinen J, et al Shorter treatment for vaginal candidosis: Comparison between single-dose oral fluconazole and three-day treatment with local miconazole Mycoses 1992 35(11-12):317 20 1302807
Tindall B, Cooper DA Primary HIV infection: Host responses and intervention strategies [editorial] [see comments] AIDS 1991 5(1):1 14 1812848
Tindall B, Hing M, Edwards P, et al Severe clinical manifestations of primary HIV infection AIDS 1989 3(11):747 9 2575913
Tobin JM, Loo P, Granger SE Treatment of vaginal candidosis: A comparative study of the efficacy and acceptability of itraconazole and clotrimazole Genitourin Med 1992 68(1):36 8 1312506
Tobin MJ Vulvovaginal candidiasis: Topical vs. oral therapy Am Fam Physician 1995 51(7):1715 20 7754931
Tollemar J Prophylaxis against fungal infections in transplant recipients: Possible approaches Biodrugs 1999 11(5):309 18 18031141
Tomar SL, Swango PA, Kleinman DV, et al Loss of periodontal attachment in HIV-seropositive military personnel J Peridontol 1995 66(6):421 8
Tomas Vecina S, Pedro-Botet Montoya J, Saballs Radresa P, et al Invasive candidiasis and malabsorption syndrome: Efficacy of oral fluconazole Rev Esp Quimioter 1990 3(4):377 8
Toriyama K, Yousukh A, Jiviriyawat Y, et al Seroepidemiological survey of human immunodeficiency virus (HIV), hepatitis B virus (HBV) and hepatitis C virus (HCV) infections among the hill tribes in northern Thailand Trop Med 1996 38(2):79 86
Tortorano AM, Viviani MA, Barchiesi F, et al Comparison of three methods for testing azole susceptibilities of Candida albicans strains isolated sequentially from oral cavities of AIDS patients J Clin Microbiol 1998 36(6):1578 83 104880 9620380
Tortorano AM, Viviani MA, Pagano A, et al Candida colonization in orthotopic liver transplantation: Fluconazole versus oral amphotericin B J de Mycologie Medicale 1995 5(1):21 4
Touraine RL, Bertrand Y, Nakache C, et al Candida arthritis during induction treatment for acute lymphoblastic leukemia Pediatrie 1991 46(12):791 5 1667033
Touyz L, Harel-Raviv M, Prosterman B, et al Candidal infection of the tongue together with candidal infection of the palate in patients with the human immunodeficiency virus Quintessence Int 1996 27(2):89 92 9063217
Triantos D, Leao JC, Porter SR, et al Tissue distribution of Epstein-Barr virus genotypes in hosts coinfected by HIV AIDS 1998 12(16):2141 6 9833854
Trieger N, Schlesinger N, Kaufman E, et al Israeli dentists: A survey of infection control office practices and care of medically compromised patients Spec Care Dentist 1993 13(3):117 21 8153853
Troke PF, Graninger W, Meunier F, et al Large-scale multicentre study of fluconazole in the treatment of hospitalised patients with fungal infections Eur J Clin Microbiol Infect Dis 1997 16(4):287 95 9177962
Tsang PC, Samaranayake LP Oral manifestations of HIV infection in a group of predominantly ethnic Chinese J Oral Pathol Med 1999 28(3):122 7 10069540
Tuffs A Germany: HIV tests for health workers Lancet 1991 338(8763):
Tukutuku K, Muyembe-Tamfum L, Kayembe K, et al Prevalence of dental caries, gingivitis, and oral hygiene in hospitalized AIDS cases in Kinshasa, Zaire J Oral Pathol Med 1990 19(6):271 2 2401961
Tulpule A, Joshi B, DeGuzman N, et al Interleukin-4 in the treatment of AIDS-related Kaposi's sarcoma Ann Oncol 1997 8(1):79 83
Tumbarello M, Caldarola G, Tacconelli E, et al Analysis of the risk factors associated with the emergence of azole resistant oral candidosis in the course of HIV infection J Antimicrob Chemother 1996 38(4):691 9 8937963
Tumbarello M, Tacconelli E, Caldarola G, et al Fluconazole resistant oral candidiasis in HIV-infected patients Oral Dis 1997 3(Suppl 1):S110 2 9456668
Tunkel DE, Loury MC, Fox CH, et al Bilateral parotid enlargement in HIV-seropositive patients Laryngoscope 1989 99(6 Pt 1):590 5 2725154
Uchida K, Yamaguchi H, Shibuya K The therapeutic effects of itraconazole, a new triazole antifungal agent, for experimental fungal infections Jpn J Antibiot 1991 44(5):588 99 1652657
Udasin IG, Gochfeld M Implications of the occupational safety and health administration's bloodborne pathogen standard for the occupational health professional J Occup Med 1994 36(5):548 55 8027880
Uriol PL, Gil A, Valencia ME, et al Secondary prophylaxis of esophageal candidiasis with fluconazole in acquired immunodeficiency syndrome Rev Clin Esp 1992 190(3):115 9 1561451
Urquiaga X, Pavia N, Vera L Treatment of vaginal candidiasis with single-dose fluconazole Investigacion Medica Internacional 1991 18(2):88 92
Ustianowski AP, Leake H, Evans S Outpatient therapy of HIV-associated oral and oesophageal candidosis Int J STD AIDS 1997 8(9):592 4 9292351
Valdez H, Gripshover BM, Salata RA, et al Resolution of azole-resistant oropharyngeal candidiasis after initiation of potent combination antiretroviral therapy AIDS 1998 12(5):
Van Cutsem J Prophylaxis of Candida and Aspergillus infections with oral administration of itraconazole Mycoses 1994 37(7-8):243 8 7739653
Van Cutsem J, Van Gerven F, Coremans G Oral therapy of vaginal candidosis in rats with itraconazole and fluconazole at various treatment schedules Int J Exp Clin Chemother 1991 4(4):195 200
Van Cutsem J, Van Gerven F, Oris M, et al Oral prophylaxis with itraconazole of experimental Aspergillus and Candida infections Chemotherapy 1992 38(Suppl 1):
Van den Anker JN, Melville C, Kempley ST Antifungal agents in neonatal systemic candidiasis Eur J Pediatr 1997 156(8):
Van der Waal I, Schulten EA, Pindborg JJ Oral manifestations of AIDS: An overview Int Dent J 1991 41(1):3 8 2004836
Vanhems P, Dassa C, Lambert J, et al Comprehensive classification of symptoms and signs reported among 218 patients with acute HIV-1 infection J Acquir Immune Defic Syndr 1999 21(2):99 106 10360800
Van Heusden AM, Merkus H, Corbeij R, et al Single-dose oral fluconazole versus single-dose topical miconazole for the treatment of acute vulvovaginal candidosis Acta Obstet Gynecol Scand 1990 69(5):417 22 2270767
Van Heusden AM, Merkus H, Euser R, et al A randomized, comparative study of a single oral dose of fluconazole versus a single topical dose of clotrimazole in the treatment of vaginal candidosis among general practitioners and gynaecologists Eur J Obstet Gynecol Reprod Biol 1994 55(2):123 7 7958150
Van Meter F, Gallo JW, Garcia-Rojas G, et al A study of oral candidiasis in HIV-positive patients J Dent Hyg 1994 68(1):30 4 8006694
Van Trigt L, Kreuger H, Westerman RF, et al Morbidity at an Amsterdam inner city clinic in relation to drug use Fam Pract 1989 6(4):299 302 2632308
Van't Wout JW Itraconazole in neutropenic patients Chemotherapy 1992 38(Suppl 1):23 6 1319311
Van't Wout JW Therapeutic indications for new triazoles and potential emergence of resistance Baillieres Clin Infect Dis 1995 2(1):111 26
Van't Wout JW, Novakova I, Verhagen CAH, et al The efficacy of itraconazole against systemic fungal infections in neutropenic patients: A randomized comparative study with amphotericin B Med Klin 1991 86(Suppl 1):11 13
Varthalitis J, Meunier F Prophylaxis of fungal infections Baillieres Clin Infect Dis 1995 2(1):157 77
Vazquez JA Options for the management of mucosal candidiasis in patients with AIDS and HIV infection Pharmacotherapy 1999 19(1):76 87 9917080
Vazquez JA, Gupta S, Villanueva A Potential utility of recombinant human GM-CSF as adjunctive treatment of refractory oropharyngeal candidiasis in AIDS patients Eur J Clin Microbiol Infect Dis 1998 17(11):781 83 9923519
Velandia M, Fridkin SK, Cardenas V, et al Transmission of HIV in dialysis centre Lancet 1995 345(8962):1417 22 7760615
Vena GA, Foti C, Filotico R, et al Sexually transmitted disease. V. Protozoal, fungal and parasite infections Ann Med Nav 1991 96(2 Suppl):49 56
Vernazza PL, Gilliam BL, Flepp M, et al Effect of antiviral treatment on the shedding of HIV-1 in semen AIDS 1997 11(10):1249 54 9256943
Viard JP, Hennequin C, Fortineau N, et al Fulminant cryptococcal infections in HIV-infected patients on oral fluconazole Lancet 1995 346(8967):
Vieira AR, de Souza IP, Modesto A, et al Gingival status of HIV+ children and the correlation with caries incidence and immunologic profile Pediatr Dent 1998 20(3):169 72 9635311
Vignarajah S, Eastmond VH, Ashraph A, et al An assessment of cross-infection control procedures among English-speaking Caribbean general dental practitioners: A regional preliminary study Int Dent J 1998 48(2):67 76 9779086
Vilmer C, Cavelier-Balloy B, Pinquier L, et al Focal epithelial hyperplasia and multifocal human papillomavirus infection in an HIV-seropositive man J Am Acad Dermatol 1994 30(3):497 8 8113468
Viscoli C, Castagnola E Emerging fungal pathogens, drug resistance and the role of lipid formulations of amphotericin B in the treatment of fungal infections in cancer patients: A review Int J Infect Dis 1998-1999 3(2):109 18
Viscoli C, Castagnola E, Fioredda F, et al Fluconazole in the treatment of candidiasis in immunocompromised children Antimicrob Agents Chemother 1991 35(2):365 7 245006 2024968
Viviani MA Opportunistic fungal infections in patients with acquired immune deficiency syndrome Chemotherapy 1992 38(Suppl 1):35 42 1319314
Volpe F, Schwimmer A, Barr C Oral manifestation of disseminated Mycobacterium avium intracellulare in a patient with AIDS Oral Surg Oral Med Oral Pathol 1985 60(6):567 70 3865126
Vreugdenhil G, Van Dijke BJ, Donnelly JP, et al Efficacy of itraconazole in the prevention of fungal infections among neutropenic patients with hematologic malignancies and intensive chemotherapy: A double blind, placebo controlled study Leuk Lymphoma 1993 11(5-6):353 8 8124207
Vuffray A, Durussel C, Boerlin P, et al Oropharyngeal candidiasis resistant to single-dose therapy with fluconazole in HIV-infected patients AIDS 1994 8(5):708 9 8060555
Waddell CE, Bennett CL, Davies JL Differences in the perceptions of HIV risk amongst dental care providers in Western Australian clinics Aust Dent J 1994 39(4):233 7 7945052
Wagman LM Condomania: A public education intervention Can J Public Health 1993 84(1):S62 5 8481875
Waldron JM Management of a carrier of infectious diseases: An overview of controls N Y State Dent J 1990 56(8):24 6
Wallace MR, Moss RB, Beecham HJ, et al Early clinical markers and CD4 percentage in subjects with human immunodeficiency virus infection J Acquir Immune Defic Syndr 1996 12(4):358 62
Walling DM, Perkins AG, Webster-Cyriaque J, et al The Epstein-Barr virus EBNA-2 gene in oral hairy leukoplakia: Strain variation, genetic recombination, and transcriptional expression J Virology 1994 68(12):7918 26 237254 7966582
Walling DM, Raab-Traub N Epstein-Barr virus intrastrain recombination in oral hairy leukoplakia J Virology 1994 68(12):7909 17 237253 7966581
Walsh T Mandatory HIV testing CDS Review 1991 84(9):12 13 1839969
Waltzing-Koudine L, Breville P, Rajzbaum G, et al Single drug therapy for Candida albicans spondylodiscitis with fluconazol Presse Med 1995 24(10):
Wanzala P, Manji F, Pindborg JJ, et al Low prevalence of oral mucosal lesions in HIV-1 seropositive African women J Oral Pathol Med 1989 18(7):416 8 2585305
Wargon O Cimetidine for mucosal warts in an HIV positive adult Aust J Dermatol 1996 37(3):149 50
Warnakulasuriya KA, Harrison JD, Johnson NW, et al Localised oral histoplasmosis lesions associated with HIV infection J Oral Pathol Med 1997 26(6):294 6 9234191
Watanabe K Clinical evaluation of antifungal agents used for deep-seated mycotic infections Jpn J Med Mycology 1996 37(4):217 22
Watt RG, Croucher R Dentists' perceptions of HIV/AIDS as an occupational hazard: A qualitative investigation Int Dent J 1991 41(5):259 64 1834577
Weers-Pothoff G, Havermans JF, Kamphuis J, et al Candida tropicalis arthritis in a patient with acute myeloid leukemia successfully treated with fluconazole: Case report and review of the literature Infection 1997 25(2):109 11 9108187
Weng S, Bulterys M, Chao A, et al Perinatal human immunodeficiency virus-1 transmission and intrauterine growth: A cohort study in Butare, Rwanda Pediatrics 1998 102(2):
Wensing EJ, Tonin PN, Mock D AIDS: Oral manifestations and risk factors Univ Tor Dent J 1987 1(1):20 4 3503754
Westrom L, Haglund A, Svensson L Fluconazole versus econazole in treating vaginal candidiasis Int J Gynecol Obstet 1992 37(Suppl 1):29 31
Weyant RJ, Bennett ME, Simon M, et al Desire to treat HIV-infected patients: Similarities and differences across health-care professions AIDS 1994 8(1):117 21 8011222
Whitby S, Madu EC, Bronze MS Case report: Candida zeylanoides infective endocarditis complicating infection with the human immunodeficiency virus Am J Med Sci 1996 312(3):138 9 8783683
White A, Goetz MB Azole-resistant Candida albicans: Report of two cases of resistance to fluconazole and review Clin Infect Dis 1994 19(4):687 92 7803633
White TC, Pfaller MA, Rinaldi MG, et al Stable azole drug resistance associated with a substrain of Candida albicans from an HIV-infected patient Oral Dis 1997 3(Suppl 1):S102 9 9456667
Wilcox CM, Darouiche RO, Laine L, et al A randomized, double-blind comparison of itraconazole oral solution and fluconazole tablets in the treatment of esophageal candidiasis J Infect Dis 1997 176(1):227 32 9207371
Wilcox CM, Monkemuller KE Review article: The therapy of gastrointestinal infections associated with the acquired immunodeficiency syndrome Aliment Pharmacol Ther 1997 11(3):425 43 9218066
Wilkins D, Woolcock AJ, Cossart YE Tuberculosis: Medical students at risk Med J Aust 1994 160(7):395 7 8007859
Willett NP Acquired immunodeficiency syndrome (AIDS): Epidemiology, biology and significance to the dental profession CDA Journal 1985 13(10):27 34 2934144
Williams BJ Modified orthodontic treatment goals in a patient with multiple complicating factors Spec Care Dentist 1992 12(6):251 4 1308324
Williams DM, Leigh IM, Greenspan D, et al Altered patterns of keratin expression in oral hairy leukoplakia: Prognostic implications J Oral Pathol Med 1991 20(4):167 71 1712044
Williams KV Dentists' willingness to treat high risk patients Br Dent J 1995 178(9):
Wilson DC Fluconazole failure in a child with burns and candidemia Clin Pharm 1992 11(10):883 4 1341996
Wilson NH, Burke FJ, Cheung SW Factors associated with dentists' willingness to treat high-risk patients Br Dent J 1995 178(4):145 8 7893547
Wingard JR The use of fluconazole prophylaxis in patients with chemotherapy-induced neutropenia Leuk Lymphoma 1992 8(4-5):353 9 1290959
Winn RE Antifungal therapy in critical care Probl Crit Care 1992 6(1):107 31
Winter M The practical management of haemophilia Blood Rev 1992 6(3):174 81 1422286
Wirima JJ, Harries AD Stevens-Johnson syndrome during anti-tuberculosis chemotherapy in HIV-seropositive patients: Report on six cases East Afr Med J 1991 68(1):64 6 2060484
Witte JJ Update: Investigations of persons treated by HIV-infected health-care workers?United States Arch Dermatol 1993 129(7):841 2
Wong CF, Hart LL Ketoconazole in vaginal candidiasis J Pharm Technol 1991 7(2):47 9
Woolley PD, Higgins SP Comparison of clotrimazole, fluconazole and itraconazole in vaginal candidiasis Br J Clin Pract 1995 49(2):65 6 7779645
Wormser GP, Krupp LB, Hanrahan JP, et al Acquired immunodeficiency syndrome in male prisoners: New insights into an emerging syndrome Ann Intern Med 1983 98(3):297 303 6338788
Yamac K, Senol E, Haznedar R Prophylactic use of fluconazole in neutropenic cancer patients Postgrad Med J 1995 71(835):284 6 7596933
Yamada H, Tsuda T, Watanabe T, et al Antifungal activity of D0870 against murine infections and its mechanism of action Chemotherapy 1998 44(2):112 20 9551242
Yamashita E, Kume H, Shionoya S, et al Therapeutic effect of fluconazole in patients with hematological disorders Jpn J Med Mycol 1993 34(3):331 41
Yeh CK, Fox PC, Ship JA, et al Oral defense mechanisms are impaired early in HIV-1 infected patients J Acquir Immune Defic Syndr 1988 1(4):361 6 3216316
Yeung SC, Kazazi F, Randle CG, et al Patients infected with human immunodeficiency virus type 1 have low levels of virus in saliva even in the presence of periodontal disease J Infect Dis 1993 167(4):803 9 8450244
Yeung SC, Stewart GJ, Cooper DA, et al Progression of periodontal disease in HIV seropositive patients J Peridontol 1993 64(7):651 7
Yosipovitch G, Weinberger A, Shochat B Negative seroactivity to HTLV-1 in Sephardic Jews and Arabs with Behcet's disease J Rheumatol 1992 19(11):1822 3 1362780
Youle M, Clarbour J, Farthing C, et al Treatment of resistant aphthous ulceration with thalidomide in patients positive for HIV antibody BMJ 1989 298(6671):
Young GAR, Bosly A, Gibbs DL, et al A double-blind comparison of fluconazole and nystatin in the prevention of candidiasis in patients with leukaemia Eur J Cancer 1999 35(8):1208 13 10615231
Young KL, Lange B, Dunning D Nebraska dental professional's procedures and opinions related to infectious diseases Nebr Med J 1991 76(3):55 62
Zabos GP Meeting primary oral health care needs of HIV-infected women Am J Public Health 1999 89(6):818 9 10358667 1508649
Zakarian AJ, McGivern AT, Andriolo M HIV-related ulcerative gingivitis and periodontitis J Macomb Dent Soc 1988 26(3):
Zakrzewska J, Robinson P, Croucher R Dental treatment and HIV positivity Lancet 1993 342(8863):
Zakrzewska JM, Robinson P, Williams IG Severe oral ulceration in patients with HIV infection: A case series Oral Dis 1997 3(Suppl 1):S194 6 9456688
Zambon JJ Rapid diagnosis of periodontal infections: Findings in AIDS patients Immunol Invest 1997 26(1-2):55 65 9037612
Zervos M, Meunier F Fluconazole (Diflucan(TM)): A review Int J Antimicrob Agents 1993 3(3):147 70 18611557
Ziegler C, Ganzinger U, Soltz-Szots J Treatment of acute and recurrent vaginal candidosis with fluconazole Mycoses 1992 35(Suppl 1):53 7 1406790
Zingman BS Resolution of refractory AIDS-related mucosal candidiasis after initiation of didanosine plus saquinavir N Engl J Med 1996 334(25):1674 5 8628377
Zingman BS Treatment of mucosal candidiasis in HIV-infected patients J de Mycologie Medicale 1996 6(Suppl 2):3 11
Zlatkov V, Karagiozov Il, Katsarova M Treatment of vaginal candidiasis with a single oral dose of fluconazole Akush Ginekol 1991 30(2):67 70
Zurita S, Costa C, Watts D, et al Prevalence of human retroviral infection in Quillabamba and Cuzco, Peru: A new endemic area for human T cell lymphotropic virus type 1 Am J Trop Med Hyg 1997 56(5):561 5 9180608