# References

1 Bader JD, Shugars DA, Rozier G, et al. Evidence Report: Diagnosis and Management of Dental Caries. Rockville, MD: Agency for Healthcare Research and Quality. 2000. [pmcid: 384376].
2 Pneumocystis Pneumonia -- Los Angeles MMWR 1996 45(34):729 33 8778581
3 Gallo RC, Salahuddin SZ, Popovic M, et al. Frequent detection and isolation of cytopathic retrovirus (HTLV-III) from patients with AIDS and at risk for AIDS. Science. 1984;224:500-3. [pmid: 6200936].
4 Fauci AS. Field Hearings on AIDS, Senate Appropriations Committee, Subcommittee on Labor, Heath and Human Services, and Education: San Francisco. July 9, 1999.
5 1993 revised classification system for HIV infection and expanded surveillance case definition for AIDS among adolescents and adults MMWR 1992 41(RR-17):1 19
6 Recommended infection-control practices for dentistry MMWR 1986 35(15):237 42 3083228
7 Recommendations for prevention of HIV transmission in health care settings MMWR 1987 36(SUO2):
8 Perspectives in disease prevention and health promotion update: Universal precautions for prevention of transmission of human immunodeficiency virus, hepatitis B virus, and other bloodborne pathogens in health care settings MMWR 1988 37(24):377 88 2836717
9 Recommended infection-control practices for dentistry, 1993 MMWR 1993 42(No. RR-8):1 20
10 Coulter ID, Marcus M, Freed JR, et al Use of dental care by HIV-infected medical patients J Dent Res 2000 79(6):1356 61 10890713
11 Marcus M, Freed JR, Coulter ID, et al Perceived unmet need for oral treatment among a national population of HIV-positive medical patients: Social and clinical correlates Am J Public Health 2000 90(7):1059 63 10897183 1446293
12 Update: trends in AIDS incidence, deaths, and prevalence -- United States 1996 MMWR 1997 46(08):165 73 9072676
13 HIV/AIDS Surveillance Report. 1999. [pmcid: 325679].
14 Moniaci D, Greco D, Flecchia G, et al Epidemiology, clinical features and prognostic value of HIV-1 related oral lesions J Oral Pathol Med 1990 19(10):477 81 1981079
15 Barr CE, Lopez MR, Rua-Dobles A, et al HIV-associated oral lesions: Immunologic, virologic and salivary parameters J Oral Pathol Med 1992 21(7):295 8 1355794
16 Greenspan JS Sentinels and signposts: The epidemiology and significance of the oral manifestations of HIV disease Oral Dis 1997 3(Suppl 1):13 7
17 Lifson AR, Hilton JF, Westenhouse JL, et al Time from HIV seroconversion to oral candidiasis or hairy leukoplakia among homosexual and bisexual men enrolled in three prospective cohorts AIDS 1994 8(1):73 9 8011239
18 Glick M, Muzyka BC, Lurie D, et al Oral manifestations associated with HIV-related disease as markers for immune suppression and AIDS Oral Surg Oral Med Oral Pathol 1994 77(4):344 9 8015797
19 Patton LL, McKaig R, Strauss R, et al Changing prevalence of oral manifestations of human immuno-deficiency virus in the era of protease inhibitor therapy Oral Surg Oral Med Oral Pathol Oral Radiol Endod 2000 89(3):299 304 10710453
20 Diz Dios P, Ocampo A, Miralles C, et al Frequency of oropharyngeal candidiasis in HIV-infected patients on protease inhibitor therapy Oral Surg Oral Med Oral Pathol Oral Radiol Endod 1999 87(4):437 41 10225625
21 Schmidt-Westhausen AM, Priepke F, Bergmann FJ, et al Decline in the rate of oral opportunistic infections following introduction of highly active antiretroviral therapy J Oral Pathol Med 2000 29(7):336 41 10947250
22 Tindall B, Cooper DA Primary HIV infection: Host responses and intervention strategies AIDS 1991 5(1):1 14 1812848
23 Tindall B, Hing M, Edwards P, et al Severe clinical manifestations of primary HIV infection AIDS 1989 3(11):747 9 2575913
24 Rabeneck L, Popovic M, Gartner S, et al Acute HIV infection presenting with painful swallowing and esophageal ulcers JAMA 1990 263(17):2318 22 2325232
25 Masouredis CM, Katz MH, Greenspan D, et al Prevalence of HIV-associated periodontitis and gingivitis in HIV-infected patients attending an AIDS clinic J Acquir Immune Defic Syndr 1992 5(5):479 83 1560345
26 Riley C, London JP, Burmeister JA Periodontal health in 200 HIV-positive patients J Oral Pathol Med 1992 21(3):124 7 1583595
27 McKaig RG, Thomas JC, Patton LL, et al Prevalence of HIV-associated periodontitis and chronic periodontitis in a southeastern US study group J Public Health Dent 1998 58(4):294 300 10390712
28 Melnick SL, Engel D, Truelove E, et al Oral mucosal lesions: Association with the presence of antibodies to the human immunodeficiency virus Oral Surg Oral Med Oral Pathol 1989 68(1):37 43 2755688
29 Robinson PG, Sheiham A, Challacombe SJ, et al Periodontal health and HIV infection Oral Dis 1997 3(Suppl 1):149 52
30 Madigan A, Murray PA, Houpt M, et al Caries experience and cariogenic markers in HIV-positive children and their siblings Pediatr Dent 1996 18(2):129 36 8710715
31 Coates E, Slade GD, Goss AN, et al Oral conditions and their social impact among HIV dental patients Aust Dent J 1996 41(1):33 6 8639112
32 Capilouto EI, Piette J, White BA, et al Perceived need for dental care among persons living with acquired immunodeficiency syndrome Med Care 1991 29(8):745 54 1875741
33 Greene VA, Chu SY, Diaz T, Schable B Oral health problems and use of dental services among HIV-infected adults. Supplement to HIV/AIDS Surveillance Project Group J Am Dent Assoc 1997 128(10):1417 22 9332143
34 Mascarenhas AK, Smith SR Factors associated with utilization of care for oral lesions in HIV disease Oral Surg Oral Med Oral Pathol Oral Radiol Endod 1999 87(6):708 13 10397663
35 Glick M, Abel SN, Muzyka BC, et al Dental complications after treating patients with AIDS J Am Dent Assoc 1994 125(3):296 301 8157842
36 Dodson TB Predictors of postextraction complications in HIV-positive patients Oral Surg Oral Med Oral Pathol Oral Radiol Endod 1997 84(5):474 9 9394376
37 Pankhurst CL, Lewis DA, Clark DT Prophylactic application of an intra-alveolar socket medicament to reduce postextraction complications in HIV-seropositive patients Oral Surg Oral Med Oral Pathol 1994 77(4):331 44 8015795
38 Okabe K, Nakagawa K, Yamamoto E Factors affecting the occurrence of bacteremia associated with tooth extraction Int J Oral Maxillofac Surg 1995 24(3):239 42 7594761
39 Conner HD, Haberman S, Collings CK, et al. Bacteremias following periodontal scaling in patients with healthy appearing gingiva. J Peridontol. 1967;38:466-72.
40 Dental management of the HIV-infected patient J Am Dent Assoc 1995Suppl:1 40
41 Patton LL Hematologic abnormalities among HIV-infected patients: Associations of significance for dentistry Oral Surg Oral Med Oral Pathol Oral Radiol Endod 1999 88(5):561 7 10556750
42 Hogg RS, Rhone SA, Yip B, et al Antiviral effect of double and triple drug combinations amongst HIV-infected adults: Lessons from the implementation of viral load-driven antiretroviral therapy AIDS 1998 12(3):279 84 9517990
43 Vernazza PL, Gilliam BL, Flepp M, et al Effect of antiviral treatment on the shedding of HIV-1 in semen AIDS 1997 11(10):1249 54 9256943
44 Martinez P, Munoz J, Santamaria JM, et al [Acute symptomatic HIV infection. Report of 10 cases]. [Spanish] Enferm Infecc Microbiol 1992 10(4):205 10
45 Vanhems P, Dassa C, Lambert J, et al Comprehensive classification of symptoms and signs reported among 218 patients with acute HIV-1 infection J Acquir Immune Defic Syndr 1999 21(2):99 106 10360800
46 Centers for Disease Control and Prevention 1993 revised classification system for HIV infection and expanded surveillance case definition for AIDS among adolescents and adults MMWR 1992 41(RR-17):1 19
47 Kolokotronis A, Kioses V, Antoniades D, et al Immunologic status in patients infected with HIV with oral candidiasis and hairy leukoplakia Oral Surg Oral Med Oral Pathol 1994 78(1):41 6 8078662
48 Hilton JF Functions of oral candidiasis episodes that are highly prognostic for AIDS Stat Med 2000 19(7):989 1004 10750064
49 Ravina A, Ficarra G, Chiodo M, et al Relationship of circulating CD4+ T-lymphocytes and p24 antigenemia to the risk of developing AIDS in HIV-infected subjects with oral hairy leukoplakia J Oral Pathol Med 1996 25(3):108 11 9148036
50 Feigal DW, Katz MH, Greenspan D, et al The prevalence of oral lesions in HIV-infected homosexual and bisexual men: Three San Francisco epidemiological cohorts AIDS 1991 5(5):519 25 1863403
51 Schuman P, Ohmit SE, Sobel JD, et al Oral lesions among women living with or at risk for HIV infection. HIV Epidemiology Research Study (HERS) Group Am J Med 1998 104(6):559 64 9674719
52 Begg MD, Panageas KS, Mitchell-Lewis D, et al Oral lesions as markers of severe immunosuppression in HIV-infected homosexual men and injection drug users Oral Surg Oral Med Oral Pathol Oral Radiol Endod 1996 82(3):276 83 8884825
53 MacPhail LA, Hilton JF, Dodd CL, et al Prophylaxis with nystatin pastilles for HIV-associated oral candidiasis J Acquir Immune Defic Syndr 1996 12(5):470 6
54 Stevens DA, Greene SI, Lang OS Thrush can be prevented in patients with acquired immunodeficiency syndrome and the acquired immunodeficiency syndrome-related complex: Randomized, double-blind, placebo-controlled study of 100-mg oral fluconazole daily Arch Intern Med 1991 151(12):2458 64 1747004
55 Schuman P, Capps L, Peng G, et al Weekly fluconazole for the prevention of mucosal candidiasis in women with HIV infection: A randomized, double-blind, placebo-controlled trial. Terry Beirn Community Programs for Clinical Research on AIDS Ann Intern Med 1997 126(9):689 96 9139554
56 Saag MS, Fessel WJ, Kaufman CA, et al Treatment of fluconazole-refractory oropharyngeal candidiasis with itraconazole oral solution in HIV-positive patients Aids Res Hum Retroviruses 1999 15(16):1413 7 10555103
57 Hunter KD, Gibson J, Lockhart P, et al Fluconazole-resistant Candida species in the oral flora of fluconazole-exposed HIV-positive patients Oral Surg Oral Med Oral Pathol Oral Radiol Endod 1998 85(5):558 64 9619674
58 Tumbarello M, Tacconelli E, Caldarola G, et al Fluconazole resistant oral candidiasis in HIV-infected patients Oral Dis 1997 3(Suppl 1):110 2
59 Sangeorzan JA, Bradley SF, He X, et al. Epidemiology of oral candidiasis in HIV-infected patients: Colonization, infection, treatment, and emergence of fluconazole resistance. Am J Med. 1994;97:339-46. [pmid: 7942935].
60 Maenza JR, Keruly JC, Moore RD, et al Risk factors for fluconazole-resistant candidiasis in human immunodeficiency virus-infected patients J Infect Dis 1996 173(1):219 25 8537662
61 Boken DJ, Swindells S, Rinaldi MG Fluconazole-resistant Candida albicans Clin Infect Dis 1993 17(6):1018 21 8110924
62 1999 USPHS/IDSA guidelines for the prevention of opportunistic infections in persons infected with human immunodeficiency virus. U.S. Public Health Service (USPHS) and Infectious Diseases Society of America (IDSA) MMWR 1999 48(RR-10):1 59, 61-6
63 Revankar SG, Kirkpatrick WR, McAtee RK, et al. A randomized trial of continuous or intermittent therapy with fluconazole for oropharyngeal candidiasis in HIV-infected patients: Clinical outcomes and development of fluconazole resistance. Am J Med. 1998;105:7-11. [pmid: 9688014].
64 Lohr KN, Carey TS Assessing 'best evidence': Issues in grading the quality of studies for systematic reviews Jt Comm J Qual Improv 1999 25(9):470 9 10481816
65 Begg C, Cho M, Eastwood S, et al Improving the quality of reporting of randomized controlled trials. The CONSORT statement JAMA 1996 276(8):637 9 8773637
66 Lijmer JG, Mol BW, Heisterkamp S, et al Empirical evidence of design-related bias in studies of diagnostic tests JAMA 1999 282(11):1061 6 10493205
67 Little JW. Dental management of the medically compromised patient. St. Louis: Mosby. 1997. [pmcid: 176006].
68 Scully C, McCarthy G Management of oral health in persons with HIV infection Oral Surg Oral Med Oral Pathol 1992 73(2):215 25 1312692
69 Glick M Clinical protocol for treating patients with HIV disease Gen Dent 1990 38(6):418 25 2151446
70 Cooper H Root canal treatment on patients with HIV infection Int Endod J 1993 26(6):369 71 8144247
71 Barr CE, Rua-Dobles A, Puig N Dental care for HIV-positive patients Spec Care Dentist 1989 9(6):191 4 2533728
72 Osborn TP, Frederickson GJ, Small IA, et al A prospective study of complications related to mandibular third molar surgery J Oral Maxillofac Surg 1985 43(10):767 9 2995624
73 Overholser CD, Peterson DE, Bergman SA, et al Dental extractions in patients with acute nonlymphocytic leukemia J Oral Maxillofac Surg 1982 40(5):296 8 6211528
74 Robinson PG, Cooper H, Hatt J Healing after dental extractions in men with HIV infection Oral Surg Oral Med Oral Pathol 1992 74(4):426 30 1408013
75 Porter SR, Scully C, Luker J. Complications of dental surgery in persons with HIV disease. Oral Surg Oral Med Oral Pathol. 1993;75:165-7. [pmid: 8426715].
76 Dodson TB HIV status and the risk of post-extraction complications J Dent Res 1997 76(10):1644 52 9326896
77 Dodson TB, Perrott DH, Gongloff RK, et al Human immunodeficiency virus serostatus and the risk of postextraction complications International J Oral Maxillofac Surg 1994 23(2):100 3
78 Colebunders R, Ryder R, Francis H, et al Seroconversion rate, mortality, and clinical manifestations associated with the receipt of a human immunodeficiency virus-infected blood transfusion in Kinshasa, Zaire J Infect Dis 1991 164(3):450 6 1869835
79 Margiotta V, Campisi G, Mancuso S, et al HIV nfection: Oral lesions, CD4+ cell count and viral load in an Italian study population J Oral Pathol Med 1999 28(4):173 7 10235371
80 Lamster IB, Begg MD, Mitchell-Lewis D, et al Oral manifestations of HIV infection in homosexual men and intravenous drug users. Study design and relationship of epidemiologic, clinical, and immunologic parameters to oral lesions Oral Surg Oral Med Oral Pathol 1994 78(2):163 74 7936584
81 Melnick SL, Hannan P, Decher L, et al. Increasing CD8+ T lymphocytes predict subsequent development of intraoral lesions among individuals in the early stages of infection by the human immunodeficiency virus. J Acquir Immune Defic Syndr. 1991;4:1199-1207. [pmid: 1682473].
82 Howell RB, Jandinski JJ, Palumbo P, et al Oral soft tissue manifestations and CD4 lymphocyte counts in HIV-infected children Pediatr Dent 1996 18(2):117 20 8710712
83 Kirby AJ, Munoz A, Detels R, et al Thrush and fever as measures of immunocompetence in HIV-1-infected men J Acquir Immune Defic Syndr 1994 7(12):1242 9 7965635
84 Schuman P, Sobel JD, Ohmit SE, et al Mucosal candidal colonization and candidiasis in women with or at risk for human immunodeficiency virus infection. HIV Epidemiology Research Study (HERS) Group Clin Infect Dis 1998 27(5):1161 7 9827263
85 Phelan JA, Begg MD, Lamster IB, et al Oral candidiasis in HIV infection: Predictive value and comparison of findings in injecting drug users and homosexual men J Oral Pathol Med 1997 26(5):237 43 9178176
86 Husak R, Garbe C, Orfanos CE Oral hairy leukoplakia in 71 HIV-seropositive patients: Clinical symptoms, relation to immunologic status, and prognostic significance J Am Acad Dermatol 1996 35(6):928 34 8959952
87 Chiang CP, Chueh LH, Lin SK, et al Oral manifestations of human immunodeficiency virus-infected patients in Taiwan J Formos Med Assoc 1998 97(9):600 5 9795527
88 Patton LL, McKaig RG, Strauss RP, et al Oral manifestations of HIV in a southeast USA population Oral Dis 1998 4(3):164 9 9972166
89 Patton LL, McKaig RG, Eron JJ, et al Oral hairy leukoplakia and oral candidiasis as predictors of HIV viral load AIDS 1999 13(15):2174 6 10546876
90 Marriott DJ, Jones PD, Hoy JF, et al Fluconazole once a week as secondary prophylaxis against oropharyngeal candidiasis in HIV-infected patients. A double-blind placebo-controlled study Med J Aust 1993 158(5):312 6 8097273
91 Leen CL, Dunbar EM, Ellis ME, et al Once-weekly fluconazole to prevent recurrence of oropharyngeal candidiasis in patients with AIDS and AIDS-related complex: A double-blind placebo-controlled study [published erratum appears in J Infect Dis 1990;21(2):183] J Infect 1990 21(1):55 60 2200826
92 Just-Nubling G, Gentschew G, Meissner K, et al Fluconazole prophylaxis of recurrent oral candidiasis in HIV-positive patients Eur J Clin Microbiol Infect Dis 1991 10(11):917 21 1794360
93 Cauda R, Tacconelli E, Tumbarello M, et al Role of protease inhibitors in preventing recurrent oral candidosis in patients with HIV infection: A prospective case-control study J Acquir Immune Defic Syndr 1999 21(1):20 5 10235510
94 Cassone A, De Bernardis F, Torosantucci A, et al In vitro and in vivo anticandidal activity of human immunodeficiency virus protease inhibitors J Infect Dis 1999 180(2):448 53 10395861
95 Freedberg KA, Scharfstein JA, Seage GR, et al The cost-effectiveness of preventing AIDS-related opportunistic infections [published erratum appears in JAMA 1999;281(21):1989] JAMA 1998 279(2):130 6 9440663
96 Phillips P, De Beule K, Frechette G, et al A double-blind comparison of itraconazole oral solution and fluconazole capsules for the treatment of oropharyngeal candidiasis in patients with AIDS Clin Infect Dis 1998 26(6):1368 73 9636865
97 De Wit S, Weerts D, Goossens H, Clumeck N Comparison of fluconazole and ketoconazole for oropharyngeal candidiasis in AIDS Lancet 1989 1(8641):746 8 2564563
98 De Repentigny L, Ratelle J, Baril JG, et al Comparison of itraconazole and ketoconazole in HIV-positive patients with oropharyngeal or esophageal candidiasis. Human Immunodeficiency Virus Itraconazole Ketoconazole Project Group Chemotherapy 1996 42(5):374 83 8874977
99 Graybill JR, Vazquez J, Darouiche RO, et al Randomized trial of itraconazole oral solution for oropharyngeal candidiasis in HIV/AIDS patients Am J Med 1998 104(1):33 9 9528717
100 Pons V, Greenspan D, Lozada-Nur F, et al Oropharyngeal candidiasis in patients with AIDS: Randomized comparison of fluconazole versus nystatin oral suspensions Clin Infect Dis 1997 24(6):1204 7 9195083
101 Pons V, Greenspan D, Debruin M. Therapy for oropharyngeal candidiasis in HIV-infected patients: A randomized, prospective multicenter study of oral fluconazole versus clotrimazole troches. The Multicenter Study Group. J Acquir Immune Defic Syndr. 1993;6:1311-6. [pmid: 8254467].
102 Murray PA, Koletar SL, Mallegol I, et al Itraconazole oral solution versus clotrimazole troches for the treatment of oropharyngeal candidiasis in immunocompromised patients Clin Ther 1997 19(3):471 80 9220211
103 Flynn PM, Cunningham CK, Kerkering T, et al Oropharyngeal candidiasis in immunocompromised children: A randomized, multicenter study of orally administered fluconazole suspension versus nystatin. The Multicenter Fluconazole Study Group J Pediatr 1995 127(2):322 8 7636666
104 Koletar SL, Russell JA, Fass RJ, et al Comparison of oral fluconazole and clotrimazole troches as treatment for oral candidiasis in patients infected with human immunodeficiency virus Antimicrob Agents Chemother 1990 34(11):2267 8 172036 2073120
105 De Wit S, O'Doherty E, Edwards J, et al Pharmacokinetics of two multiple-dosing regimens of D0870 in human immunodeficiency virus-positive patients: A phase I study Antimicrob Agents Chemother 1998 42(4):903 6 105564 9559805
106 Hernandez-Sampelayo T Fluconazole versus ketoconazole in the treatment of oropharyngeal candidiasis in HIV-infected children. Multicentre Study Group Eur J Clin Microbiol Infect Dis 1994 13(4):340 4 8070443
107 Nyst MJ, Perriens JH, Kimputu L, et al Gentian violet, ketoconazole and nystatin in oropharyngeal and esophageal candidiasis in Zairian AIDS patients Ann Soc Belg Med Trop 1992 72(1):45 52 1567268
108 De Wit S, O'Doherty E, De Vroey C, et al Safety and efficacy of single-dose fluconazole compared with a 7-day regimen of itraconazole in the treatment of AIDS-related oropharyngeal candidiasis J Intern Med Res 1998 26(3):159 70
109 European Community Clearinghouse on Oral Problems Related to HIV Infection and World Health Organization Collaborating Centre on Oral Manifestations of the Immunodeficiency Virus. Classification and diagnostic criteria for oral lesions in HIV infection. J Oral Pathol Med. 1993;22:289-91. [pmid: 8229864].
110 Greenspan JS, Barr CE, Sciubba JJ, et al Oral manifestations of HIV infection: Definitions, diagnostic criteria, and principles of therapy. The U.S.A. Oral AIDS Collaborative Group Oral Surg Oral Med Oral Pathol 1992 73(2):142 4 1532234
111 Ramos-Gomez FJ, Flaitz C, Catapano P, et al Classification, diagnostic criteria, and treatment recommendations for orofacial manifestations in HIV-infected pediatric patients. Collaborative workgroup on Oral Manifestations of Pediatric HIV Infection J Clin Pediatr Dent 1999 23(2):85 96 10204447