# Evidence Tables

## Glossary for Evidence Tables

adj./unadj.: adjusted/unadjusted

approx: approximately

ARC: AIDS-related complex

ART (HAART): antiretroviral therapy (highly active antiretroviral therapy)

AZT: Zidovudine

cfu: colony forming units

clin. effic.: clinical efficacy

compl. monitor: compliance monitor

DDI: didanosine

diffs: differences

dx: diagnosis

eso.cand.: esophageal candidiasis

F/U or FU: follow-up

grp: group

h/o: history of

hrs: hours

IDU: injectiondrug user

KOH: potassium hydroxide

md: median

mycol. effic.: mycologic efficacy

mn: mean

mos: months

MSM: men who have sex with men

MvProportHazard: Multivariate Proportional Hazard

NA: not applicable

neg: negative

neuro: neurological

NR: not reported

NPV: negative predictive value

Oralmuc cand.: oral mucosal candidiasis

pos: positive

PPV: positive predictive value

preop/postop: preoperative/postoperative

prev.: prevalence

RCT: randomized controlled trial

RR/OR (95% CI) p value: relative risk or odds ratio (95% confidence interval) probability value

SD: standard deviation

SE: standard error

tx: treatment

unk: unknown

VAMC: Veterans Affairs Medical Center

WB: Western Blot

yrs: years

Evidence Table 1. Increased Risk Associated with Selected Routine Dental ProceduresChapter 7. Evidence Tables

Study Description | | | | | | | | | | Study Group Characteristics | | | | | | | | Complication Outcomes
Author, Year | | Design | Type of Sample | Blinding | Setting | Study Period | Tx F/U Period | Total Sample Size | Examiner Standardization | Study Group Size | Age Mean/Median (Range or SD) | % Male | Race | Exposure Category | % ART (HAART) | % Patients Given Antibiotics | Overall | Systemic Infection | Dry Socket | Local Infection | Persistent Bleeding | Delayed Healing | Other | RR/OR (95% CI) p value | Quality Score Rating 100
| Endodontics | | | | | | | | | Endodontics | | | | | | | Endodontics
1 | Cooper, 1993 | retrospective cohort | patients treated in previous 24 mos; selection criteria not described | NR | London, U.K.-dedicated dental clinic | 9/90-8/92 | 1-3 mos | 48 patients; 57 teeth | NR | HIV-neg patients = 16; teeth = 17 | | | | NR | NA | 50% | NR | none | none | none | none | none | none | NR | 40
1 | Cooper, 1993 | retrospective cohort | patients treated in previous 24 mos; selection criteria not described | NR | London, U.K.-dedicated dental clinic | 9/90-8/92 | 1-3 mos | 48 patients; 57 teeth | NR | HIV-pos asymptomatic patients = 25; teeth = 31 | 34 yrs; range = 24-68 | 98% | NR | NR | NR | 24% | NR | none | none | 2% | none | none | none | NR | 40
1 | Cooper, 1993 | retrospective cohort | patients treated in previous 24 mos; selection criteria not described | NR | London, U.K.-dedicated dental clinic | 9/90-8/92 | 1-3 mos | 48 patients; 57 teeth | NR | AIDS patients = 7; teeth = 9 | | | | NR | NR | 42% | NR | none | none | none | none | none | none | NR | 40
| Extraction | | | | | | | | | Extraction | | | | | | | Extraction
2 | Robinson, Cooper, Hatt, 1992 | retrospective cohort | patients treated in a hospital clinic | NR | London, U.K.-dedicated dental clinic | 1/8/89-11/11/91 | 1-7 days | 116 patients; 233 teeth | Yes | HIV-neg patients = 36; teeth = 70 | mn = 32 yrs (SD = 7) | 100% | NR | NR | NA | all patients who had bone removed during extraction received antibiotics; numbers not reported | NR | NR | 4.3% overall 4.8% among those without antibiotics | NR | NR | NR | NR | NR | 50
2 | Robinson, Cooper, Hatt, 1992 | retrospective cohort | patients treated in a hospital clinic | NR | London, U.K.-dedicated dental clinic | 1/8/89-11/11/91 | 1-7 days | 116 patients; 233 teeth | Yes | HIV-pos patients = 80; teeth = 163 | mn = 35 yrs (SD = 7) | 100% | NR | NR | NR | all patients who had bone removed during extraction received antibiotics; numbers not reported | NR | NR | 3% overall 1.4% among those without antibiotics | NR | NR | NR | NR | NR | 50
| Extraction | | | | | | | | | Extraction | | | | | | | Extraction
3 | Dodson, Perrott, Gongloff, et al., 1994 | retrospective cohort | patients receiving extractions at a Veterans Administration Medical Center | NR | dental clinic in San Francisco, CA, U.S. | 1/1/88-12/31/89 | unk | 145 patients | NR | HIV-neg patients = 101 | mn = 57 yrs (SD = 18) | 100% | NR | NR | NA | preop 14% postop 20% | 3% unadjusted | NR | NR | NR | NR | NR | NR | unadjusted RR = 7.04 (2.0-25.0) p= 0.001 | 40
3 | Dodson, Perrott, Gongloff, et al., 1994 | retrospective cohort | patients receiving extractions at a Veterans Administration Medical Center | NR | dental clinic in San Francisco, CA, U.S. | 1/1/88-12/31/89 | unk | 145 patients | NR | HIV-pos patients = 44, broken down into: | mn = 42 yrs (SD = 9) | 100% | NR | NR | NR | preop 45% postop 36% | 21% unadjusted | NR | NR | NR | NR | NR | NR | adjusted RR = 4.3 (0.93-19.5) p = 0.06 adjusted for age, preop antibiotics, and tobacco use | 40
3 | Dodson, Perrott, Gongloff, et al., 1994 | retrospective cohort | patients receiving extractions at a Veterans Administration Medical Center | NR | dental clinic in San Francisco, CA, U.S. | 1/1/88-12/31/89 | unk | 145 patients | NR | asymptomatic n = 12 | NR | 100% | NR | NR | NR | NR | 18% unadjusted | NR | NR | NR | NR | NR | NR | adjusted RR = 4.3 (0.93-19.5) p = 0.06 adjusted for age, preop antibiotics, and tobacco use | 40
3 | Dodson, Perrott, Gongloff, et al., 1994 | retrospective cohort | patients receiving extractions at a Veterans Administration Medical Center | NR | dental clinic in San Francisco, CA, U.S. | 1/1/88-12/31/89 | unk | 145 patients | NR | Aids-related Complex n = 11 | NR | 100% | NR | NR | NR | NR | 18% unadjusted | NR | NR | NR | NR | NR | NR | adjusted RR = 4.3 (0.93-19.5) p = 0.06 adjusted for age, preop antibiotics, and tobacco use | 40
3 | Dodson, Perrott, Gongloff, et al., 1994 | retrospective cohort | patients receiving extractions at a Veterans Administration Medical Center | NR | dental clinic in San Francisco, CA, U.S. | 1/1/88-12/31/89 | unk | 145 patients | NR | AIDS n = 21 | NR | 100% | NR | NR | NR | NR | 24% unadjusted | NR | NR | NR | NR | NR | NR | adjusted RR = 4.3 (0.93-19.5) p = 0.06 adjusted for age, preop antibiotics, and tobacco use | 40
4 | Porter, Scully, Luker 1993 | prospective cohort | patients receiving extractions | surgeon not always aware of HIV status | university clinic in Bristol, U.K. | NR | NR | 64 patients | NR | HIV-neg patients = 26; teeth = 68 | md = 27 yrs | 96% | NR | 50% MSM 27% IDU 15% blood 4% MSM & IDU 4% other/unk | NA | preop 8% | 3% | NR | NR | NR | 0% | 3% | NR | NR | 55
4 | Porter, Scully, Luker 1993 | prospective cohort | patients receiving extractions | surgeon not always aware of HIV status | university clinic in Bristol, U.K. | NR | NR | 64 patients | NR | HIV-pos patients = 38; teeth = 100 | md = 29 yrs | 89% | NR | 53% MSM 18% IDU 8% blood 3% MSM & IDU 18% other/unk | NR | preop 24% | 4% | NR | NR | NR | 3% (1 patient with hemophillia) | 4% | NR | NR | 55
5 | Dodson, 1997 | prospective cohort | patients receiving extractions who met inclusion criteria | NR | dental clinic in Atlanta, GA, U.S. | 11/1/93-4/15/96 | 2, 7, 21 days | 151 patients | NR | HIV-neg patients n = 75 | mn = 40 yrs (SD = 13) | 65% | 21% white | NR | NA | preop 9% postop 9% | 13% (8% without pain) | NR | 3% | 3% | 0% | 7% | pain 12% | RR = 1.68 (0.82, 3.4) p= 0.15 | 75
5 | Dodson, 1997 | prospective cohort | patients receiving extractions who met inclusion criteria | NR | dental clinic in Atlanta, GA, U.S. | 11/1/93-4/15/96 | 2, 7, 21 days | 151 patients | NR | HIV-pos patients n = 76 | mn = 37 yrs (SD = 7) | 65% | 21% white | NR | NR | preop 63% postop 25% | 22% (12% without pain) | NR | 3% | 3% | 0% | 4% | pain 9% | without pain RR = 1.43 (0.55-3.95) p = 0.43 | 75

Evidence Table 2. Selected Oral Conditions as Markers of HIV SeroconversionChapter 7. Evidence Tables

Study Description | | | | | | | | | Study Group Characteristics | | | | | | | | | | Exposure Outcomes
Author, Year | | Design | Type of Sample | Blinding | Setting | Time of Exposure to HIV | Study Period | F/U Points | Total Sample Size | Examiner Standard-ization | HIV Test Intervals | Study Groups | Number Enrolled (Evaluable) | Age Mean/Median (Range) | % Male | Race | Exposure Category | Prior Dx of Oral Condition | Seroconversion Rate | F/U Status | Prev. of Oral Condition | Prev. of Sero-conversion | RR/OR (95% CI) p value | Sensitivity | Specificity | PPV | NPV | Quality Score Rating 100
| Oral Candidiasis (OC) | | | | | | | | Oral Candidiasis (OC) | | | | | | | | | | Oral Candidiasis (OC)
1 | Colebunders, Ryder, Francis, et al., 1991 | prospective design consisting of a cohort of infected and a cohort of uninfected transfusion patients matched for age, sex, time and number of transfusions, diagnosis, and severity of illness | cases represent all persons given transfusions of HIV-pos blood. controls are matched on case basis. | examiner blinded to HIV exposure status | Mama Yemo Hospital in Kinshasa, Zaire | known date of transfusion with HIV-pos blood | 1986-1987 | 1 week and 1, 2, 3, 6, and 12 months after transfusion | 180 (cases = 90; controls = 90) | NR | 1, 3, 6 and 12 mos after transfusion for cases; 12 mos after transfusion for controls | surgery patients given tranfusion with HIV-pos blood | 90 | md = 3 yrs (4 mos to 65 yrs) 60% of cases and controls < 5 yrs | 49% | NR | surgical transfusion patients | NR | 96% WB pos at 6 or 12 mos (94% at 0-1 mos; 96% at 2-3 mos; 96% at 4-6 mos; 95% at 7-12 mos) | alive = 38 dead = 39 lost = 13 at 12 mos | 8% at 3 mos after transfusion | 46% at 3 mos after transfusion | RR (CI) = 5.4 (1.4-20.0) p< 0.05 at 3 mos the relative risk of a person with OC being HIV pos is 5.4 times greater than for a person who does not have OC | 14%* | 97%* | 82%* | 57%* | 55%
1 | Colebunders, Ryder, Francis, et al., 1991 | prospective design consisting of a cohort of infected and a cohort of uninfected transfusion patients matched for age, sex, time and number of transfusions, diagnosis, and severity of illness | cases represent all persons given transfusions of HIV-pos blood. controls are matched on case basis. | examiner blinded to HIV exposure status | Mama Yemo Hospital in Kinshasa, Zaire | known date of transfusion with HIV-pos blood | 1986-1987 | 1 week and 1, 2, 3, 6, and 12 months after transfusion | 180 (cases = 90; controls = 90) | NR | 1, 3, 6 and 12 mos after transfusion for cases; 12 mos after transfusion for controls | surgery patients given transfusion with HIV-neg blood | 90 | md = 3 yrs (4 mos to 65 yrs) 60% of cases and controls < 5 yrs | 51% | NR | surgical transfusion patients | NR | 0% WB pos at 6 or 12 mos | alive = 67 dead = 14 lost = 9 at 12 mos | 8% at 3 mos after transfusion | 46% at 3 mos after transfusion | RR (CI) = 5.4 (1.4-20.0) p< 0.05 at 3 mos the relative risk of a person with OC being HIV pos is 5.4 times greater than for a person who does not have OC | 14%* | 97%* | 82%* | 57%* | 55%

* Number was calculated from data in the article and not reported in this form.

WB = positive Western Blot reaction

Evidence Table 3. Selected Oral Conditions as Indicators of Immune SuppressionChapter 7. Evidence Tables

Study Description | | | | | | | | | | Study Group Characteristics | | | | | | Outcomes
Author, Year | | Design | Type of Sample | Blinding | Setting | Study Period | Total Sample Size | Examiner Standard-ization | Recency of CD4 Cell Count | Number Enrolled | Age Mean/Median (Range) | % Male | Race | Exposure Category | % ART (HAART) | Prev. of Oral Condition | Prev. of CD4 <200 | RR/OR (95% CI) ± p value | Sensitivity | Specificity | PPV | NPV | Quality Score Rating 100
| Oral Candidiasis (OC) | | | | | | | | | Oral Candidiasis | | | | | | Oral Candidiasis (OC)
1 | Feigal, Katz, Greenspan, et al., 1991 | cross- sectional baseline of longitudinal cohort study | combination of 3 sample cohorts not drawn from dental clinics | examiners blinded to sero-status | San Francisco, CA, U.S. | 1987-1989 | 737 | NR | NR | 737 | mn = 38 yrs | 100% | 88% white | 100% MSM | NR | 8% | 17% | NR | 20%* | 94%* | 42%* | 85%* | 45
2 | Barr, Lopez, Rua-Dobles, et al., 1992 | case-control design with HIV-pos and HIV-neg gay/bisexual men as cases; none had presented for dental care and none were IDU | voluntary sample of men recruited from gay/bisexual community organizations | examiners blinded to sero-status | New York, NY, U.S. | NR | 102 | only one examiner | implied at time of oral exam | 101 (with oral exam and CD4 cell count) | md = 33 yrs (24-63) (of entire sample of 102 cases and 33 noninfected controls) | 100% | 85% white 4% black 11% Hispanic (of entire sample of 102 cases and 33 noninfected controls) | 100% MSM | 26% acyclovir 17% antifungals (of HIV-pos patients only) | 17% | 32% | OR = 23.4 ratio (2.8, 193.0) ratio of odds of person with CD4 <200 having OC to person with odds of CD4 >400 having OC | 41%* | 95%* | 76%* | 77%* | 50
3 | Glick, Muzyka, Lurie, et al., 1994 | cross- sectional design | sample of HIV-pos patients seeking regular dental care at university outpatient dental clinics | NR | Infectious Diseases Center at Temple University School of Dentistry, Philadelphia, PA, U.S. | 7/1988-6/1992 | 454 | NR | within 2 mos of oral exam | 454 | mn = 37 yrs | 89% | 59% white 34% black 7% Hispanic | 68% MSM 19% IDU 2% blood 5% MSM & IDU 7% heterosexual | NR | 54% | 53% | OR = 4.9 p = 0.001 of odds of CD4 <200 with lesion present to odds of CD4 >200 with lesion present (3.3, 7.3) | 77% | 66% | 70% | 68% | 20
4 | Kirby, Munoz, Detels, et al., 1994 | prospective cohort design (longitudinal multicenter AIDS cohort study) | AIDS-free gay and bisexual men recruited for study of transmission and progression of HIV negs who were HIV pos in study period | NA -- patient self-report | university medical centers in Baltimore, MD, Chicago, IL, Los Angeles, CA, and Pittsburgh, PA, U.S. | 9/1984-7/1991 | 2,568 HIV-pos persons with 20,632 visits | NA; patient self-report of thrush | within 3-6 mos of oral exam | 2,568 persons with visits | NR | 100% | NR | 100% MSM | NR | 9% | 13% | NR | 29%* | 94%* | 42%* | 90%* | 45
5 | | baseline of prospective cohort | sample of consecutive HIV-infected outpatients at infectious disease unit of a general hospital | examiners blind | Thessa-loniki, Greece | 1/1992 | 43 | dentists trained in the diagnosis of oral lesions of HIV infection | within 3-12 mos of baseline oral exam | 43 | mn = 33.3 yrs (18-56) | 77% | NR | NR | NR | 19% | 26% | chi-square = NR p = not significant | 64%* | 97%* | 88%* | 89%* | 25
6 | Begg, Panageas, Mitchell-Lewis, et al., 1996 | cross-sectional | sample of HIV-pos (MSM & IDU) persons in longitudinal study of HIV national history | no | New York, NY, U.S. | 3/1991-3/1992 | 164 | trained dentists | calibrated within 24 hrs of oral exam | 82 MSM | NR | 100% | NR | 51% MSM 49% IDU | 48% antiviral 51% antibiotic 34% acyclovir | 20% | 42% | OR = 1.5 ratio (0.5, 4.6) of odds of CD4 <200 with lesion present to odds of CD4 >200 with lesion present | 24% | 83% | 50% | 61% | 40
6 | Begg, Panageas, Mitchell-Lewis, et al., 1996 | cross-sectional | sample of HIV-pos (MSM & IDU) persons in longitudinal study of HIV national history | no | New York, NY, U.S. | 3/1991-3/1992 | 164 | trained dentists | calibrated within 24 hrs of oral exam | 79 IDU | NR | 65% | NR | | 62% antiviral 49% antibiotic 5% acyclovir | 44% | 28% | OR = 3.9 ratio (1.4, 11.3) of odds of CD4 <200 with lesion present to odds of CD4 >200 with lesion present | 68% | 65% | 43% | 84%
7 | Howell, Jandinski, Palumbo, et al., 1996 | cross-sectional design | sample of HIV-infected children consecutively enrolled in AIDS program | NR | Children's Hospital AIDS Program at NJ Medical School, U.S. | 1990 | 60 | two examiners; inter-rater reliablility of 96% | within 3 mos of oral exam | 60 | mn = 5.8 yrs (1-18) | 43% | 17% white 62% black 18% Hispanic 3% other | 92% perinatal 5% blood 3% other | NR | 32% | 37% | total = 2.82 p< 0.05 children with candidiasis have significantly lower CD4 cell counts | 50%* | 79%* | 58%* | 73%* | 25
8 | Phelan, Begg, Lamster 1997 | cross-sectional (baseline of prospective cohort study) | NR | NR | NY State Psychiatric Institute and Infectious Disease Clinic at Harlem Hospital, New York, NY, U.S. | NR | 163 | NR; training in calibration, colored slides used to calibrate] examiners trained in identification of oral candidiasis | NR | 82 MSM | NR | 100% | 87% white 9% Hispanic 2% black 2% other | 51% MSM 49% IDU | 34% acyclovir 48% antiviral 51% antibiotic 24% antifungal | 20% | NR | NR | NR* | NR* | 50%* | NR* | 45
8 | Phelan, Begg, Lamster 1997 | cross-sectional (baseline of prospective cohort study) | NR | NR | NY State Psychiatric Institute and Infectious Disease Clinic at Harlem Hospital, New York, NY, U.S. | NR | 163 | NR; training in calibration, colored slides used to calibrate] examiners trained in identification of oral candidiasis | NR | 81 IDU | NR | 100% | 74% black 7% white 17% Hispanic | 51% MSM 49% IDU | 5% acyclovir 62% antiviral 49% antibiotic 16% antifungal | 43% | NR | NR | NR* | NR* | 43%* | NR* | 45
9 | Schuman, Sobel, Ohmit, et al, 1998 | cross-sectional (baseline of multicenter prospective cohort study-HERS) | sample of women - half were recruited from medical care settings and half from community settings according to specific criteria | NR | university research centers in Detroit, MI, Providence, RI, New York, NY, and Batimore, MD, U.S. | 4/1992-1/1995 | 1,310 total: 871 HIV seropos and 439 seroneg women | centrally trained in diagnosis of oropharyngeal candidiasis, but at time of enrollment | at baseline exam | 871 | md = 35.1 yrs | 0% | 24% white 58% black 16% HIspanic | 52% IDU 48% heterosexual | 30% using antibiotics or 20% using Trimethoprim-sulfamethoxazole or Dapsone | 22% | 17% | NR | 40%* | 82%* | 85%* | 85%* | 25
10 | Schuman, Ohmit, Sobel, et al., 1998 | baseline of a multicenter prospective cohort design | sample of women recruited in 2 sites from community sources and 2 sites from medical care settings; no history of clinical AIDS;defining conditions reported were high-risk sex or IDU | NR | study centers in Bronx, NY, Baltimore, MD, Detroit, MI, and Providence, RI, U.S. | 4/1993-1/1995 | 1,310 total: 871 HIV seropos and 439 seroneg women | centrally trained nondental clinicians | at time of the baseline examination | 840 with oral exam and CD4 cell counts | md = 35 yrs | 0% | 24% white 58% black 16% Hispanic | 48% heterosexual contact 52% IDU | 30% antibiotic 10% antifungal 20% Trimethoprim-sulfamethoxazole or Dapsone 35% ART | 15% | 17% | NR | 30%* (27%* culture confirmed) | 88%* (89%* culture confirmed) | 34%* (34%* culture confirmed) | 86%* (86%* culture confirmed) | 45
| Oral Hairy Leukoplakia (OHL) | | | | | | | | | Oral Hairy Leukoplakia (OHL) | | | | | | Oral Hairy Leukoplakia (OHL)
1 | Feigal, Katz, Greenspan, et al., 1991 | cross-sectional baseline of longitudinal cohort study | combination of 3 sample cohorts not drawn from dental clinics | examiners blinded to sero-status | San Francisco, CA, U.S. | 1987-1989 | 737 | NR | NR | 737 | mn = 38 yrs | 100% | 88% white | 100% MSM | NR | 20% | 17% | NR | 34%* | 83%* | 29%* | 86%* | 45
2 | Barr, Lopez, Rua-Dobles, et al., 1992 | case-control design with HIV-pos and HIV-neg gay/bisexual men as cases; none had presented for dental care and none were IDU | voluntary sample of men recruited from gay/bisexual community organizations | examiners blinded to sero-status | New York, NY, U.S. | NR | 102 | only one examiner | implied at time of oral exam | 101 (with oral exam and CD4 cell count) | md = 33 yrs (24-63) (of entire sample of 102 cases and 33 noninfected controls) | 100% | 85% white 4% black 11% Hispanic (of entire sample of 102 cases and 33 noninfected controls) | 100% MSM | 26% acyclovir 17% antifungals (of HIV-pos cases only) | 8 | 32% | NR | 25%* | 83%* | 40%* | 70%* | 50
3 | Glick, Muzyka, Lurie, et al., 1994 | cross-sectional design | sample of HIV-pos patients seeking regular dental care at university outpatient dental clinics | NR | Infectious Diseases Center at Temple University School of Dentistry, Philadelphia, PA, U.S. | 7/1988-6/1992 | 454 | NR | within 2 mos of oral exam | 454 | mn = 37 yrs | 89% | 59% white 34% black 7% Hispanic | 68% MSM 19% IDU 2% blood 5% MSM & IDU 7% heterosexual | NR | 17% | 53% | OR = 2.4 (1.4, 4.1) p = 0.001 | 23% | 89% | 70% | 51% | 20
5 | Koloktronis, Kioses, Antoniades, et al., 1994 | baseline of prospective cohort | sample of consecutive HIV-infected outpatients at infectious disease unit of a general hospital | examiners blinded | Thessa-loniki, Greece | 1/1992 | 43 | dentists trained in the diagnosis of oral lesions of HIV infection | within 3-12 mos of baseline oral exam | 43 | mn = 33.3 yrs (18-56) | 77% | NR | NR | NR | 16% | 26% | chi-square = NR p= not significant | 18%* | 84%* | 29%* | 75%* | 25
6 | Begg, Panageas, Mitchell-Lewis, et al., 1996 | cross-sectional | sample of HIV-pos (MSM & IDU) persons in longitudinal study of HIV national history | no | New York, NY, U.S. | 3/1991-3/1992 | 164 | trained calibrated dentists | within 24 hrs of oral exam | 82 MSM | NR | 100% | NR | 51% MSM 49% IDU | 48% antiviral 51% antibiotic 34% acyclovir | 22% | 42% | OR = 2.1 (0.7, 6.0) | 29% | 83% | 56% | 63% | 40
6 | Begg, Panageas, Mitchell-Lewis, et al., 1996 | cross-sectional | sample of HIV-pos (MSM & IDU) persons in longitudinal study of HIV national history | no | New York, NY, U.S. | 3/1991-3/1992 | 164 | trained calibrated dentists | within 24 hrs of oral exam | 79 IDU | NR | 65% | NR | 51% MSM 49% IDU | 62% antiviral 49% antibiotic 5% acyclovir | 11% | 28% | OR = 3.9 (0.9, 16.2) | 23% | 93% | 56% | 76% | 40
10 | Schuman, Ohmit, Sobel, et al., 1998 | baseline of a multicenter prospective cohort design | sample of women recruited in 2 sites from community sources and 2 sites from medical care settings; no history of clinical AIDS; defining conditions reported were high-risk sex or IDU | NR | study centers in Bronx, NY, Baltimore, MD, Detroit, MI, and Providence, RI, U.S. | 4/1993-1/1995 | 1,310 total: 871 HIV seropos and 439 seroneg women | centrally trained nondental clinicians | at time of the baseline examination | 840 with oral exam and CD4 cell counts | md = 35 yrs | 0% | 24% white 58% black 16% Hispanic | 48% heterosexual contact 52% IDU | 30% antibiotic 10% antifungal 20% Trimethoprim-sulfamethoxazole or Dapsone 35% ART | 7% | 17% | NR | 13%* | 95%* | 35%* | 84%* | 45
| Necrotizing Ulcerative Periodontitis (NUP) | | | | | | | | | Necrotizing Ulcerative Periodontitis (NUP) | | | | | | Necrotizing Ulcerative Periodontitis (NUP)
3 | Glick, Muzyka, Lurie, et al., 1994 | cross-sectional design | sample of HIV-pos patients seeking regular dental care at university outpatient dental clinics | NR | Infectious Diseases Center at Temple University School of Dentistry, Philadelphia, PA, U.S. | 7/1988-6/1992 | 454 | NR | within 2 mos of oral exam | 454 | mn = 37 yrs | 89% | 59% white 34% black 7% Hispanic | 68% MSM 19% IDU 2% blood 5% MSM & IDU 7% heterosexual | NR | 9% | 53% | OR = 20.8 (15, 87.1) p = 0.001 | 16% | 99% | 95% | 52% | 20
6 | Begg, Panageas, Mitchell-Lewis, et al., 1996 | cross-sectional | sample of HIV-pos (MSM & IDU) persons in longitudinal study of HIV national history | no | New York, NY, U.S. | 3/1991-3/1992 | 164 | trained calibrated dentists | within 24 hrs of oral exam | 82 MSM | NR | 100% | NR | 51% MSM 49% IDU | 48% antiviral 51% antibiotic 34% acyclovir | 6% | 42% | OR = 6.3 (0.7, 58.8) | 11.8% | 97.9% | 80% | 61% | 40
6 | Begg, Panageas, Mitchell-Lewis, et al., 1996 | cross-sectional | sample of HIV-pos (MSM & IDU) persons in longitudinal study of HIV national history | no | New York, NY, U.S. | 3/1991-3/1992 | 164 | trained calibrated dentists | within 24 hrs of oral exam | 79 IDU | NR | 65% | NR | 51% MSM 49% IDU | 62% antiviral 49% antibiotic 5% acyclovir | 5% | 28% | OR = 0.9 (0.8, 1.0) | 0% | 91.7% | 0% | 69.8% | 40
| Oral Ulcers (OU) | | | | | | | | | Oral Ulcers (OU) | | | | | | Oral Ulcers (OU)
1 | Feigal, Katz, Greenspan, et al., 1991 | cross-sectional baseline of longitudinal cohort study | combination of 3 sample cohorts not drawn from dental clinics | examiners blinded to sero-status | San Francisco, CA, U.S. | 1987-1989 | 737 | NR | NR | 737 | mn = 38 yrs | 100% | 88% white | 100% MSM | NR | 2% | 17% | NR | 0%* | 97.7%* | 0%* | 82.6%* | 45
3 | Glick, Muzyka, Lurie, et al., 1994 | cross-sectional design | sample of HIV-pos patients seeking regular dental care at university outpatient dental clinics | NR | Infectious Diseases Center at Temple University School of Dentistry, Philadelphia, PA, U.S. | 7/1988-6/1992 | 454 | NR | within 2 mos of oral exam | 454 | mn = 37 yrs | 89% | 59% white 34% black 7% Hispanic | 68% MSM 19% IDU 2% blood 5% MSM & IDU 7% heterosexual | NR | 3% | 53% | NR | 6% | 100% | 100% | 52% | 20
6 | Begg, Panageas, Mitchell-Lewis, et al., 1996 | cross-sectional | sample of HIV-pos (MSM & IDU) persons in longitudinal study of HIV national history | no | New York, NY, U.S. | 3/1991-3/1992 | 164 | trained calibrated dentists | within 24 hrs of oral exam | 82 MSM | NR | 100% | NR | 51% MSM 49% IDU | 48% antiviral 51% antibiotic 34% acyclovir | 16% | 42% | OR = 1.8 (0.6, 6.0) | 20.6% | 87.5% | 53.9% | 60.9% | 40
6 | Begg, Panageas, Mitchell-Lewis, et al., 1996 | cross-sectional | sample of HIV-pos (MSM & IDU) persons in longitudinal study of HIV national history | no | New York, NY, U.S. | 3/1991-3/1992 | 164 | trained calibrated dentists | within 24 hrs of oral exam | 79 IDU | NR | 65% | NR | 51% MSM 49% IDU | 62% antiviral 49% antibiotic 5% acyclovir | 8% | 28% | OR = 1.3 (0.2, 7.8) | 9.1% | 93% | 33.3% | 72.6% | 40
10 | Schuman, Ohmit, Sobel, et al., 1998 | baseline of a multicenter prospective cohort design | sample of women recruited in 2 sites from community medical care settings; no history of clinical AIDS; defining conditions reported were high-risk sex or IDU | NR | study centers in Bronx, NY, Baltimore, MD, Detroit, MI, and Providence, RI, U.S. | 4/1993- 1/1995 | 1,310 total: 871 HIV seropos and 439 seroneg women | centrally trained nondental clinicians | at time of the baseline examination | 840 with oral exam and CD4 cell counts | md = 35 yrs | 0% | 24% white 58% black 16% Hispanic | 48% heterosexual contact 52% IDU | 30% antibiotic 10% antifungal 20% Trimethoprim-sulfamethoxazole or Dapsone 35% ART | 3% | 17% | NR | 6%* | 98%* | 38%* | 84%* | 45
| Linear Gingival Erythema (LGE) | | | | | | | | | Linear Gingival Erythema (LGE) | | | | | | Linear Gingival Erythema (LGE)
6 | Begg, Panageas, Mitchell-Lewis, et al., 1996 | cross-sectional | sample of HIV-pos (MSM & IDU) persons in longitudinal study of HIV national history | no | New York, NY, U.S. | 3/1991-3/1992 | 164 | trained calibrated dentists | within 24 hrs of oral exam | 82 MSM | NR | 100% | NR | 51% MSM 49% IDU | 48% antiviral 51% antibiotic 34% acyclovir | 13% | 42% | OR = 1.8 (0.5, 6.6) | 17.6% | 89.6% | 55% | 60.6% | 40
6 | Begg, Panageas, Mitchell-Lewis, et al., 1996 | cross-sectional | sample of HIV-pos (MSM & IDU) persons in longitudinal study of HIV national history | no | New York, NY, U.S. | 3/1991-3/1992 | 164 | trained calibrated dentists | within 24 hrs of oral exam | 79 IDU | NR | 65% | NR | 51% MSM 49% IDU | 62% antiviral 49% antibiotic 5% acyclovir | 30.4% | 28% | OR = 0.8 (0.2, 2.4) | 32% | 62.5% | 25% | 69.8% | 40
10 | Schuman, Ohmit, Sobel, et al., 1998 | baseline of a multicenter prospective cohort design | sample of women recruited in 2 sites from community medical care settings; no history of clinical AIDS; defining conditions reported were high-risk sex or IDU | NR | study centers in Bronx, NY, Baltimore, MD, Detroit, MI, and Providence, RI, U.S. | 4/1993-1/1995 | 1,310 total: 871 HIV seropos and 439 seroneg women | centrally trained nondental clinicians | at time of the baseline examination | 840 with oral exam and CD4 cell counts | md = 35 yrs | 0% | 24% white 58% black 16% Hispanic | 48% heterosexual contact 52% IDU | 30% antibiotic 10% antifungal 20% Trimethoprim-sulfamethoxazole or Dapsone 35% ART | 14% | 17% | NR | 13%* | 86%* | 18%* | 82%* | 45
| Kaposi's Sarcoma (KS) | | | | | | | | | Kaposi's Sarcoma (KS) | | | | | | Kaposi's Sarcoma (KS)
1 | Feigal, Katz, Greenspan, et al., 1991 | cross-sectional baseline of longitudinal cohort study | combination of 3 sample cohorts not drawn from dental clinics | examiners blinded to sero-status | San Francisco, CA, U.S. | 1987-1989 | 737 | NR | NR | 737 | mn = 38 yrs | 100% | 88% white | 100% MSM | NR | 1% | 17% | NR | 6.8%* | 99.5%* | 72.7%* | 83.7%* | 45
3 | Glick, Muzyka, Lurie, et al., 1994 | cross-sectional design | sample of HIV-pos patients seeking regular dental care at university outpatient dental clinics | NR | Infectious Diseases Center at Temple University School of Dentistry, Philadelphia, PA, U.S. | 7/1988-6/1992 | 454 | NR | within 2 mos of oral exam | 454 | mn = 37 yrs | 89% | 59% white 34% black 7% Hispanic | 68% MSM 19% IDU 2% blood 5% MSM & IDU 7% heterosexual | NR | 7% | 53% | OR = 14.7 (3.5, 62.4) p= 0.001 | 12% | 99% | 94% | 50% | 20
6 | Begg, Panageas, Mitchell-Lewis, et al., 1996 | cross-sectional | sample of HIV-pos (MSM & IDU) persons in longitudinal study of HIV national history | no | New York, NY, U.S. | 3/1991-3/1992 | 164 | trained calibrated dentists | within 24 hrs of oral exam | 82 MSM | NR | 100% | NR | 51% MSM 49% IDU | 48% antiviral 51% antibiotic 34% acyclovir | 4% | 42% | OR = 10.8 (0.5, 21.6) | 8.8% | 100% | 100% | 60.8% | 40
6 | Begg, Panageas, Mitchell-Lewis, et al., 1996 | cross-sectional | sample of HIV-pos (MSM & IDU) persons in longitudinal study of HIV national history | no | New York, NY, U.S. | 3/1991-3/1992 | 164 | trained calibrated dentists | within 24 hrs of oral exam | 79 IDU | NR | 65% | NR | 51% MSM 49% IDU | 62% antiviral 49% antibiotic 5% acyclovir | 0% | 28% | NA | NA | NA | NA | NA | 40

*Number was calculated from data in the article and not reported in this form.

Evidence Table 4. Efficacy of Anti-Fungal Agents Used to Prevent Oral CandidiasisChapter 7. Evidence Tables

Study Description | | | | | | | | | | Study Group Characteristics | | | | | | | | | | | | Treatment Outcomes | | Adverse Effects Experienced
Author, Year | | Design Blinding | Sample, Setting, Study Period | Drug Use Compli. Monitor. | Duration of Tx | F/U Points: Duration of Evaluation | Total Sample Size | Examiner Standard-ization | Dx Criteria Used | Drug Tx Group | Regimen | Number Enrolled (Evaluable) | Age Mean/Median (Range) | % Male | Race | Exposure Category | CD4 Cell Count Mean (Range) | % ART (HAART) | % Prior Oral Candidiasis Infection | % Infected at Enrollment | Test of Differences in Infected at Enrollment | % Reinfected Patients | Test of Differences in Reinfected Patients | Number Dropped Due to Adverse Effects | % Overall | % Gastro-intestinal | % Fever | % Rash | % Neuro-logical | % Other | % Resistant | Quality Score Rating 100
1 | Just-Nubling, Gent-schew, Meissner, et al., 1991 | RCT, open label (no blinding) | specific criteria: advanced HIV with CD4 count <100; at least 1 oral candidiasis episodein past 3 mos; 1 outpatient clinic, University Hospital, Frankfort, Germany | NR | 137-215 days, 6 mos minimum | every 2 weeks, more than 137-215 days, 6 mos minimum | 65 recruited, 7 dropped out, 58 evaluable | NR | new clinical sign (thrush, enanthema) and additional cfu of >1,000/mL in oral washings | group 1 - control | NA | NR (21) | NR | NR | NR | NR | <100 | NR | 100% | 0% | NR | 95.2% | 50 mg or 100 mg fluconazole resulted in significantly less frequent relapse than placebo (p < 0.01); 50 mg dose compared with 100 mg dose had no significant difference in relapse frequency (p = 0.66) (Fisher exact test) | 1 | 5% | 0% | NR | 5% | 0% | NR | NR | 64
1 | Just-Nubling, Gent-schew, Meissner, et al., 1991 | RCT, open label (no blinding) | study period: 5/89-8/90 | NR | 137-215 days, 6 mos minimum | every 2 weeks, more than 137-215 days, 6 mos minimum | 65 recruited, 7 dropped out, 58 evaluable | NR | new clinical sign (thrush, enanthema) and additional cfu of >1,000/mL in oral washings | group 2 - fluconazole | 50 mg/day fluconzaole cups | NR (18) | NR | NR | NR | NR | <100 | NR | 100% | 0% | NR | 11.1% | | 0 | 0% | 0% | NR | 0% | 0% | NR | NR | 64
1 | Just-Nubling, Gent-schew, Meissner, et al., 1991 | RCT, open label (no blinding) | study period: 5/89-8/90 | NR | 137-215 days, 6 mos minimum | every 2 weeks, more than 137-215 days, 6 mos minimum | 65 recruited, 7 dropped out, 58 evaluable | NR | new clinical sign (thrush, enanthema) and additional cfu of >1,000/mL in oral washings | group 3 - fluconazole | 100 mg/day fluconzaole cups | NR (19) | NR | NR | NR | NR | <100 | NR | 100% | 0% | NR | 21.1% | | 0 | 0% | 0% | NR | 0% | 0% | NR | NR | 64
2 | Stevens, Greene, Lang, 1991 | RCT, double blind (examiners and patients) | specific criteria: AIDS or ARC;at least 1 oral candidiasis episode | NR | 12 weeks | 4 times a week, then twice or more monthly, then when symptomatic or when at hospital for scheduled visits | 25 | NR | clinical signs, confirmed with blastospores and pseudo-hyphae on KOH and/or culture pos for Candidiasis albicans | group 1 - fluconazole | 100 mg/once daily | 12 (12) | mn = 34.5 (26-70) | 100% | 76% white 24% Hispanic | MSM: 76% MSM & IDU: 8% IDU: 8% heterosexual: 8% | 7/11 available <200 | 75% | 100% | 0% | NR | 0.0% | p = 0.002 (Fisher exact test) | 17% (2 subjects) | 83% | 67% | 8% | 8% | 42% | 67% | NR | 76
2 | Stevens, Greene, Lang, 1991 | RCT, double blind (examiners and patients) | 1 medical center, San Jose, CA study period: NR | NR | 12 weeks | 4 times a week, then twice or more monthly, then when symptomatic or when at hospital for scheduled visits | 25 | NR | clinical signs, confirmed with blastospores and pseudo-hyphae on KOH and/or culture pos for Candidiasis albicans | group 2 - placebo | 100 mg/once daily | 13 (13) | mn = 34.5 (26-70) | 100% | 76% white 24% Hispanic | MSM: 76% MSM & IDU: 8% IDU: 8% heterosexual: 8% | 7/11 available <200 | 77% | 100% | 0% | NR | 61.5% | p = 0.002 (Fisher exact test) | 15% (2 subjects) | 69% | 38% | 8% | 0% | 23% | 62% | NR | 76
3 | Marriott, Jones, Hoy, et al., 1993 | RCT, double blind (examiners and patients) | specific criteria: moderate to severe HIV; past fluconazole tx multicenter (3) hospitals in Australia study period: 1/89-9/90 | yes | 6 mos | every month for 6 mos | 84 | NR | new sign or symptom confirmed with pos culture or Gram stain | group 1 - fluconazole | 150 mg/week | 44 (31 clin effic; 25 mycol effic) | mn = 38 yrs (23-61) | 100% | NR | NR | mn = 18 (0-299) | 57% AZT | 100% | 44% culture pos | NR | 41.9% (13/31 evaluable) | NR; but chi-square p < 0.001 for analysis of those completing 6 mos tx without clinical relapse (18/31 fluconazole tx group vs. 1/26 placebo) | 1 due to maculopapular rash | 57% | NR | NR | NR | NR | NR | NR | 80
3 | Marriott, Jones, Hoy, et al., 1993 | RCT, double blind (examiners and patients) | specific criteria: moderate to severe HIV; past fluconazole tx multicenter (3) hospitals in Australia study period: 1/89-9/90 | yes | 6 mos | every month for 6 mos | 84 | NR | new sign or symptom confirmed with pos culture or Gram stain | group 2 - placebo | 150 mg/week | 40 (26 clin effic; 18 for mycol effic) | mn = 38 yrs (23-61) | 100% | NR | NR | mn = 38 (0-200) | 45% AZT | 100% | 58% culture pos | NR | 96.2% (25/26 evaluable) | NR; but chi-square p < 0.001 for analysis of those completing 6 mos tx without clinical relapse (18/31 fluconazole tx group vs. 1/26 placebo) | 0 | 13% | NR | NR | NR | NR | NR | NR | 80
4 | MacPhail, Hilton, Dodd, et al., 1996 | RCT, double blind (examiners and patients) | specific criteria: HIV/AIDS and CD4 <650; exclude esocand. | NR | 20 weeks | every 2 weeks for 20 weeks or until first recurrence | 128 | NR | clinical signs confirmed with KOH pos for hyphae and culture pos for fungal species | group 1 - 2 Nystatin pastilles | 400,000 U/day | 41 (41) | mn = 38 yrs (27-60) | 100% | NR | NR | >500: 17% 200-499: 44% <200: 39% | NR | 56% | 0% | NR | 49% reinfect or dropout | MvProportHazard model: after control for CD4 cell count, Candida carriage, h/o oral candidiasis, nystatin effective in delaying time to oral candidiasis, p<0.001. 1 nystatin reduced hazard to 60% placebo. 2 nystatin reduced hazard to 35% placebo | 0 | NR | NR | NR | NR | NR | NR | NR | 80
4 | MacPhail, Hilton, Dodd, et al., 1996 | RCT, double blind (examiners and patients) | 1 outpatient clinic: Oral AIDS Clinic at University of California at San Francisco, CA | NR | 20 weeks | every 2 weeks for 20 weeks or until first recurrence | 128 | NR | clinical signs confirmed with KOH pos for hyphae and culture pos for fungal species | group 2 - 1 nystatin pastille and 1 placebo pastille | 200,000 U/day | 44 (44) | mn = 38 yrs (27-60) | 100% | NR | NR | >500: 5% 200-499: 66% <200: 30% | NR | 55% | 0% | NR | 73% reinfect or dropout | | 0 | NR | NR | NR | NR | NR | NR | NR | 80
4 | MacPhail, Hilton, Dodd, et al., 1996 | RCT, double blind (examiners and patients) | study period: 11/87-3/90 | NR | 20 weeks | every 2 weeks for 20 weeks or until first recurrence | 128 | NR | clinical signs confirmed with KOH pos for hyphae and culture pos for fungal species | group 3 - 2 placebo pastilles | 200,000 U/day | 43 (43) | mn = 38 yrs (27-60) | 100% | NR | NR | >500: 12% 200-499: 49% <200: 44% | NR | 53% | 0% | NR | 70% reinfect or dropout | | 0 | NR | NR | NR | NR | NR | NR | NR | 80
5 | Schuman, Capps, Peng, et al., 1997 | RCT, double blind (examiners and patients) | specific criteria: CD4 <300; exclude eso. cand. | NR | median 17 mos fluconazole/10 mos placebo | every 3 mos, median F/U = 29 mos | 323 | NR | pos candida culture and 2+ signs and symptoms | group 1 -fluconazole | 200 mg/week | 162 (162) | mn = 37 yrs | 0% | 65% black 20% Hispanic 15% NR | IDU: 45% NR: 55% | mn = 172 | 85% | 48% | 0% | NR | 25.9% | RR = 0.50 (0.33-0.74); p < 0.001 | NR | 25% | NR | NR | NR | NR | NR | 3.70% | 84
5 | Schuman, Capps, Peng, et al., 1997 | RCT, double blind (examiners and patients) | 14 community clinics in U.S. study period: 5/92-11/95 | NR | median 17 mos fluconazole/10 mos placebo | every 3 mos, median F/U = 29 mos | 323 | NR | pos candida culture and 2+ signs and symptoms | group 2 - placebo | 200 mg/week | 161 (161) | mn = 37 yrs | 0% | 65% black 20% Hispanic 15% NR | IDU: 45% NR: 55% | mn = 186 | 75% | 47% | 0% | NR | 42.2% | RR = 0.50 (0.33-0.74); p < 0.001 | NR | 14% | NR | NR | NR | NR | NR | 4.30% | 84
6 | Leen, Dunbar, Ellis, et al., 1990 | RCT, double blind (examiners and patients) | specific criteria: AIDS/ARC dx; severe Oralmuc cand | NR | 24 weeks | every month for up to 6 mos | 14 | NR | "clinically unsuccessful and infection recurred" | group 1 - fluconazole | 150 mg/week | 9 (9) | NR | 100% | NR | NR | NR | NR | 100% | 0% | NR | 22.2% | p = 0.02 (Fisher exact test) | 0 | NR | NR | NR | NR | NR | NR | NR | 44
6 | Leen, Dunbar, Ellis, et al., 1990 | RCT, double blind (examiners and patients) | 1 center study period: NR | NR | 24 weeks | every month for up to 6 mos | 14 | NR | "clinically unsuccessful and infection recurred" | group 2 - placebo | 150 mg/week | 5 (5) | NR | 100% | NR | NR | NR | NR | 100% | 0% | NR | 100% | p = 0.02 (Fisher exact test) | 0 | NR | NR | NR | NR | NR | NR | NR | 44

Evidence Table 5. Effectiveness of Anti-Fungal Agents used to Treat Oral CandidiasisChapter 7. Evidence Tables

Study Description | | | | | | | | Study Group Characteristics | | | | | | | | Treatment Outcomes | | | | | Adverse Events Experienced | | | | | | | Results of Statistical Tests
Author, Year | | Design and Blinding | Sample, Setting, and Study Period | Drug Use Monitored | Evaluation Points | Total Sample Size | Dx Criteria Used for Oropharyngeal Candidiasis | Drug Tx Group and Regimen | Number Enrolled/(Evaluable) | Age Mean/Median (Range) | % Male and Race | Exposure Category | CD4 Cell Count Mean (Range/SE) | % ART (HAART) | % Albicans at Baseline | % Complete Clinical Response | % Clinical Relapse | % Negative Microscopy | % Negative Culture | % Albicans in Failures | Number Dropped Due to Adverse Effects | % Any Adverse Effects | % Gastro-intestinal | % Fever | % Rash | % Neurological | % Other | Differences in Clinical Response | Differences in Relapse | Differences in Adverse Effects | Quality Score Rating 100
1 | DeWit, Weerts, Goossens, et al., 1989 | randomized drug comparison trial; double blind (examiners and subjects) | convenience specific criteria: AIDS or ARC; exclude esophageal candidiasis setting: authorship implies university hospital, Brussels, Belgium study period: 11/1986-2/1988 | no | baseline, daily for inpatient on tx, weekly for outpatient on tx, end of tx, 30 days after tx | 37 enrolled; 33 evaluable for clinical response | clinical oropharyngeal lesions confirmed by yeast isolation by culture on throat/lesion swab | group 1 - fluconazole 50 mg capsule daily for 28 days (mean, 27; range, 2-42) | 18 (17) | mn = 32 yrs (24-53) | 56% male 83% white 17% black | NR | NR | NR | NR | 100% | 46% within 30 days of tx end | NR | 87% (of 15 evaluable) | NR | 1 | NR | NR | NR | NR | NR | transient liver enzyme increase: 6% | p = 0.0445 (Fisher exact) | NS | liver enzyme elevation: p = 0.1699 (Fisher exact) | 68
1 | DeWit, Weerts, Goossens, et al., 1989 | randomized drug comparison trial; double blind (examiners and subjects) | convenience specific criteria: AIDS or ARC; exclude esophageal candidiasis setting: authorship implies university hospital, Brussels, Belgium study period: 11/1986-2/1988 | no | baseline, daily for inpatient on tx, weekly for outpatient on tx, end of tx, 30 days after tx | 37 enrolled; 33 evaluable for clinical response | clinical oropharyngeal lesions confirmed by yeast isolation by culture on throat/lesion swab | group 2 - ketoconazole 200 mg capsule daily for 28 days (mean, 22; range, 2-28) | 19 (16) | mn = 38 yrs (25-68) | 89% male 95% white 5% black | NR | NR | NR | NR | 75% | 11% within 30 days of tx end | NR | 69% (of 13 evaluable) | NR | 0 | NR | NR | NR | NR | NR | transient liver enzyme increase: 21% | p = 0.0445 (Fisher exact) | NS | liver enzyme elevation: p = 0.1699 (Fisher exact) | 68
2 | Koletar, Russell, Fass, et al., 1990 | randomized drug comparison trial; no blinding | HIV-pos adults; esophageal status: NR setting: NR; authorship implies Ohio State University, U.S. study period: NR | Yes | baseline, days 3, 7, 14, 28, and 42 | 39 enrolled; 36 evaluable | clinical signs and symptoms of thrush, confirmed by KOH exam and fungal cultures | group 1 - 100 mg fluconazole capsule daily for 14 days | 19 (17) | mn = 33 yrs (22-43) | 100% male race NR | NR | 88% <200 12% 200-500 | 29% AZT | NR | 14 day: 100% | 28 day: 13% 42 day: 40% | NR | 14 day: 75% | NR | 0 | NR | 18% | NR | NR | NR | NR | 14 day: p = 0.018 (2-tailed Fisher exact) | 28 day: p = 0.014 42 day: p = 0.074 (2-tailed Fisher exact) | NR | 76
2 | Koletar, Russell, Fass, et al., 1990 | randomized drug comparison trial; no blinding | HIV-pos adults; esophageal status: NR setting: NR; authorship implies Ohio State University, U.S. study period: NR | Yes | baseline, days 3, 7, 14, 28, and 42 | 39 enrolled; 36 evaluable | clinical signs and symptoms of thrush, confirmed by KOH exam and fungal cultures | group 2 - clotrimazole troches 10 mg, 5 daily for 14 days | 20 (19) | mn = 33 yrs (22-43) | 84% male race NR | NR | 84% <200 16% 200-500 | 21% AZT | NR | 14 day: 65% | 28 day: 71% 42 day: 86% | NR | 14 day: 20% | NR | 2 | NR | 16% | NR | NR | NR | NR | 14 day: p = 0.018 (2-tailed Fisher exact) | 28 day: p = 0.014 42 day: p = 0.074 (2-tailed Fisher exact) | NR | 76
3 | Nyst, Periens, Kimputu, et al., 1992 | randomized drug comparison trial, open label, stratified by oropharyngeal candidiasis alone (3%) or with esophageal candidiasis (97%) no blinding | convenience; adult inpatients with AIDS; no antimycotic treatment within 2 weeks setting: 1 hospital in Kinshasa, Zaire study period: 5/1989-5/1990 | none | baseline; 14 days after starting treatment | 150 recruited, 141 enrolled; 72 evaluable 41.6% died within 14 days | clinical diagnosis of oropharyngeal candidiasis confirmed by microscopy of oral scrapings | group 1 - oral ketoconazole 200 mg daily for 10 days or longer until complete clearance of symptoms | 45 (23) | 37 yrs | 49% male race NR | NR | NR | NR | NR | 43% disappear (39% improve) | NR | at 14 days, 57% | NR | NR | 0 | 8% | 0% | 0% | 0% | 0% | 0% | group 1 vs. 2 p < 0.05 group 2 vs. 3 p < 0.05 group 1 vs. 3 p = not significant for lesions disappeared group 1 vs. 2 p < 0.05 group 2 vs. 3 p < 0.05 group 1 vs. 3 p = not significant for negative microscopy for mycelia chi-square and Fisher exact tests | NR | NR | 56
3 | Nyst, Periens, Kimputu, et al., 1992 | randomized drug comparison trial, open label, stratified by oropharyngeal candidiasis alone (3%) or with esophageal candidiasis (97%) no blinding | convenience; adult inpatients with AIDS; no antimycotic treatment within 2 weeks setting: 1 hospital in Kinshasa, Zaire study period: 5/1989-5/1990 | none | baseline; 14 days after starting treatment | 150 recruited, 141 enrolled; 72 evaluable 41.6% died within 14 days | clinical diagnosis of oropharyngeal candidiasis confirmed by microscopy of oral scrapings | group 2 - nystatin oral suspension 200,000 units 4 times daily for 10 days or longer until complete clearance of symptoms | 47 (23) | 35.4 yrs | 47% male race NR | NR | NR | NR | NR | 9% disappear (44% improve) | NR | at 14 days, 13% | NR | NR | 0 | 0% | 0% | 0% | 0% | 0% | 0% | | NR | NR | 56
3 | Nyst, Periens, Kimputu, et al., 1992 | randomized drug comparison trial, open label, stratified by oropharyngeal candidiasis alone (3%) or with esophageal candidiasis (97%) no blinding | convenience; adult inpatients with AIDS; no antimycotic treatment within 2 weeks setting: 1 hospital in Kinshasa, Zaire study period: 5/1989-5/1990 | none | baseline; 14 days after starting treatment | 150 recruited, 141 enrolled; 72 evaluable 41.6% died within 14 days | clinical diagnosis of oropharyngeal candidiasis confirmed by microscopy of oral scrapings | group 3 - 0.5% gentian violet aqueous solution 1.5 mL twice daily for 10 days or longer until complete clearance of symptoms | 49 (26) | 34.5 yrs | 45% male race NR | NR | NR | NR | NR | 42% disappear (39% improve) | NR | at 14 days, 62% | NR | NR | 0 | 0% | 0% | 0% | 0% | 0% | 8% small ulcers of oral mucosa; resolved | | NR | NR | 56
4 | Pons, Greenspan, Debruin, 1993 | randomized drug comparison trial examiners blind | convenience; adult HIV/AIDS; specific criteria; exclude esophageal candidiasis setting: 17 centers in the U.S. study period: NR | NR | baseline, 3, 7, 14, 28, and 42 days after beginning treatment | 334 enrolled; 288 evaluable clinically | signs and symptoms of oropharyngeal candidiasis confirmed by KOH smear and culture of candida within 48 hours of start of drug | group 1 - fluconazole capsules 100 mg, once daily for 14 days | 176 (152 for clinical, 136 for mycological) | 36.5 yrs (20-65) | 93% male 69% white 31% black | NR | NR 77% with AIDS | NR | 98% | 91% at day 14 (7% clinical improvement) | at 28 days, 18%; at 42 days, 34% | NR | at 14 days, 65% | 93% | 3 | 18% | 15% | NR | NR | NR | 9% | group 1 vs. 2 p = not significant mycologic response group 1 vs. 2 p = 0.005 (statistical test not given) | at 28 days, group 1 vs. 2 p < 0.001 at 42 days, group 1 vs. 2 p = not significant | NR | 88
4 | Pons, Greenspan, Debruin, 1993 | randomized drug comparison trial examiners blind | convenience; adult HIV/AIDS; specific criteria; exclude esophageal candidiasis setting: 17 centers in the U.S. study period: NR | NR | baseline, 3, 7, 14, 28, and 42 days after beginning treatment | 334 enrolled; 288 evaluable clinically | signs and symptoms of oropharyngeal candidiasis confirmed by KOH smear and culture of candida within 48 hours of start of drug | group 2 - clotrimazole 10 mg troche 5 times daily for 14 days | 158 (136 for clinical, 118 for mycological) | 36.9 yrs (21-62) | 91% male 76% white 23% black 1% other | NR | NR 74% with AIDS | NR | 98% | 85% at day 14 (9% clinical improvement) | at 28 days, 50%; at 42 days, 40% | NR | at 14 days, 48% | 93% | 7 | 19% | 14% | NR | NR | NR | 8% | group 1 vs. 2 p = not significant mycologic response group 1 vs. 2 p = 0.005 (statistical test not given) | at 28 days, group 1 vs. 2 p < 0.001 at 42 days, group 1 vs. 2 p = not significant | NR | 88
5 | Hernandez-Sampelayo, 1994 | open-label randomized drug comparison trial; no blinding | convenience; children with HIV/AIDS, inpatients and outpatients, not excluding esophageal candidiasis setting: 7 centers in 3 nations of Europe study period: 1/92-7/92 | NR | baseline, within 48 hrs of first dose; during tx 3 times weekly if inpatient and once weekly if outpatient; end of treatment; F/U: 2 and 4 weeks after last dose | 46 enrolled; 45 evaluable | white patches, erythema, and pain; dysphagia and ulceration; microscopic confirmation of lesion swabs by KOH prep and fungal culture in Sabouraud's agar | group 1- fluconazole oral suspension 10 mg/mL in a dose of 3 mg/kg body weight once daily mn = 14 days (6-33 days) | 24 (24) | mn = 4.6 yrs (0-14) | 64% male 79% white 21% black | NR | NR | NR | 75% | at end of therapy, 88%; at 4 weeks after tx, 44% | at 4 wks after tx, 50% | NR | at end of therapy, 71%; at 4 wks after tx, 41% | NR | 0 | 0% | 0% | 0% | 0% | 0% | 0% | NR | NR | NR | 60
5 | Hernandez-Sampelayo, 1994 | open-label randomized drug comparison trial; no blinding | convenience; children with HIV/AIDS, inpatients and outpatients, not excluding esophageal candidiasis setting: 7 centers in 3 nations of Europe study period: 1/92-7/92 | NR | baseline, within 48 hrs of first dose; during tx 3 times weekly if inpatient and once weekly if outpatient; end of treatment; F/U: 2 and 4 weeks after last dose | 46 enrolled; 45 evaluable | white patches, erythema, and pain; dysphagia and ulceration; microscopic confirmation of lesion swabs by KOH prep and fungal culture in Sabouraud's agar | group 2 - ketoconazole oral suspension 20 mg/mL in a dose of 7 mg/kg body weight once daily mn = 16 days (5-49 days) | 22 (21) | mn = 3.8 yrs (0-12) | 50% male 68% white 27% black 5% other | NR | NR | NR | 91% | at end of therapy, 81%; at 4 weeks after tx, 59% | at 4 weeks after tx, 41% | NR | at end of therapy, 57%; at 4 weeks after tx, 50% | 100% | 1 | 5% | 5% | 0% | 0% | 0% | 0% | NR | NR | NR | 60
6 | Flynn, Cunningham, Kerkering, et al., 1995 | randomized drug comparison trial; examiners blind | infants and children (5 mos to 14 yrs old) immuno-compromised; being evaluated or treated for malignant or immune disease (HIV) or immuno-suppressant drug use; esophagitis excluded setting: 32 U.S. centers; study period NR | Yes | baseline, after 3, 7, and 14 days; at tx and on days 28 and 42 | 186 total recruited (182 treated, 159 evaluable); 64 evaluable for HIV-pos and AIDS patients | signs of thrush, hyphae, or pseudohyphae in KOH or Gram-stained preparation of oral swabs or scrapings, confirmed by culture within 48 hrs of drug start | group 1 - fluconazole suspension 6 mg/kg loading dose, then 3 mg/kg daily for 13 days (changed from 4 to 6 and 2 to 3 during study) | 94 (86) total (35 for HIV pos) | NR | male NR race NR | NR | NR | NR | 91% total | cure: 91% total and 80% HIV pos improvement: 3% total | 18% at day 28; 38% at day 42 total no HIV subgroup analysis | NR | 76% at 14 days total; 83% HIV pos | NR | 2 | 7% total | 6% total | 0 | 1% | 1% | 0 | group 1 vs. 2 p < 0.001 total group 1 vs. 2 HIV pos p < 0.001 (group 1 vs. 2 p < 0.001 total group 1 vs. 2 p < 0.001 HIV pos) Cochran-Mantel-Haenszel test | group 1 vs. 2 p = not significant total at 28 days group 1 vs. 2 p = not significant total at 42 days HIV pos: NR | NR | 72
6 | Flynn, Cunningham, Kerkering, et al., 1995 | randomized drug comparison trial; examiners blind | | Yes | baseline, after 3, 7, and 14 days; at tx and on days 28 and 42 | 186 total recruited (182 treated, 159 evaluable); 64 evaluable for HIV-pos and AIDS patients | signs of thrush, hyphae, or pseudohyphae in KOH or Gram-stained preparation of oral swabs or scrapings, confirmed by culture within 48 hrs of drug start | group 2 - nystatin 400,000 units 4 times daily for 14 days | 88 (73) total (29 for HIV pos) | NR | male NR race NR | NR | NR | NR | 90% total | cure: 51% total and 29% HIV pos improvement: 27% total | 24% at day 28, 32% at day 42 total no HIV subgroup analysis | NR | 11% at 14 days total; 5% HIV pos | NR | 0 | 3% total | 3% total | 0 | 0 | 0 | 0 | group 1 vs. 2 p < 0.001 total group 1 vs. 2 HIV pos p < 0.001 (group 1 vs. 2 p < 0.001 total group 1 vs. 2 p < 0.001 HIV pos) Cochran-Mantel-Haenszel test | group 1 vs. 2 p = not significant total at 28 days group 1 vs. 2 p = not significant total at 42 days HIV pos: NR | NR | 72
7 | De Repentigny, Ratell, Baril, et al., 1996 | randomized drug comparison trial oropharyngeal candidiasis and/or esophageal candidiasis with results separately--report oropharyngeal candidiasis results only) double blind (examiners and patients) | Convenience, HIV-pos adults, specific criteria setting: 10 centers in Montreal, Canada, including University Hospital and Private Practice study period: NR | yes | baseline, week 1, week 2 (if cleared, then week 6 for F/U) | 106 enrolled in oral component (37 in esophageal component not reported here for total 143); 98 evaluable for efficacy in oral component | clinical signs and symptoms, confirmed by microscopy and mycologic culture | group 1 - Itraconazole 200 mg capsule daily for 14 days | 51 (46) | mn = 38.9 yrs | 93% male 98% white 2% black | NR | 87 | 56.6% on AZT and 7.7% on DDI | 98.40% | 21-day symptom resolution: 71% | mn days to relapse: 32.4 | NR | 14 days: 63% | NR | 2 adverse event given for entire 143 (oropharyngeal candidiasis and esophageal candidiasis) | NR | 17% | 0% | 4% | 14% | 22% | p = 0.0614 (Kaplan-Meier method, compared by log-rank test) | not significant (p = 0.3839) | not significant | 88
7 | De Repentigny, Ratell, Baril, et al., 1996 | randomized drug comparison trial oropharyngeal candidiasis and/or esophageal candidiasis with results separately--report oropharyngeal candidiasis results only) double blind (examiners and patients) | Convenience, HIV-pos adults, specific criteria setting: 10 centers in Montreal, Canada, including University Hospital and Private Practice study period: NR | yes | baseline, week 1, week 2 (if cleared, then week 6 for F/U) | 106 enrolled in oral component (37 in esophageal component not reported here for total 143); 98 evaluable for efficacy in oral component | clinical signs and symptoms, confirmed by microscopy and mycologic culture | group 2 - ketoconazole 100 mg tablet daily for 14 days | 55 (52) | mn = 36.7 yrs | 96% male 90% white 4% black 4% Hispanic 2% Asian | NR | 46 | 56.6% on AZT and 7.7% on DDI | 98.40% | 21-day symptom resolution: 60% | mn days to relapse: 28.9 | NR | 14 days: 62% | NR | 3 | NR | 15% | 0% | 5% | 5% | 31% | p = 0.0614 (Kaplan-Meier method, compared by log-rank test) | not significant (p = 0.3839) | not significant | 88
8 | Murray, Koletar, Mallegol, et al., 1997 | randomized drug comparison trial; open label; examiners blind | specific criteria; immunocom-promised adults; exclude esophageal candidiasis setting: 18 clinical centers in the U.S. study period: NR | NR | baseline, 3-4, 7-8, and 14-15 days of treatment; those responding to treatment again on days 28-29 and 42-43 | 162 total patients enrolled, of whom 123 were HIV pos or had AIDS; a total of 149 were evaluable; number with HIV/AIDS NR | signs and symptoms of oral candidiasis; culture, microscopic exam to confirm presence of candida species | group 1 - itraconazole oral solution 200 mg once daily for 14 days | 81 (75) total 61 (61) with HIV/AIDS | mn = 40 yrs (23-77) | 80% male 63% white 32% black 5% other | NR | NR | NR | 93% | global evaluation of clinical response (improvement or cure at end of treatment) = 77% | 46% md = 31 days | NR | 60% (HIV and AIDS 64%) | NR | 7 | NR | 26% | NR | 6% | NR | NR | clinical response - all: group 1 vs. 2 not significant p = 0.349 negative culture - all: group 1 vs. 2 p < 0.001 clinical response - HIV/AIDS: NR negative culture - HIV/AIDS: group 1 vs. 2 p < 0.01 HIV/AIDS clinical response and negative culture combined: group 1 vs. 2 p < 0.01 statistical test: NR | group 1 vs 2 p = not significant | NR | 84
8 | Murray, Koletar, Mallegol, et al., 1997 | randomized drug comparison trial; open label; examiners blind | specific criteria; immunocom-promised adults; exclude esophageal candidiasis setting: 18 clinical centers in the U.S. study period: NR | NR | baseline, 3-4, 7-8, and 14-15 days of treatment; those responding to treatment again on days 28-29 and 42-43 | 162 total patients enrolled, of whom 123 were HIV pos or had AIDS; a total of 149 were evaluable; number with HIV/AIDS NR | signs and symptoms of oral candidiasis; culture, microscopic exam to confirm presence of candida species | group 2 - clotrimazole troches; 2 10-mg troches 5 times daily for 14 days | 81 (74) total 62 (61) with HIV/AIDS | mn = 40 yrs (22-70) | 81% male 61% white 36% black 3% other | NR | NR | NR | 92% | global evaluation of clinical response (improvement or cure at end of treatment) = 70% | 60% md = 28 days | NR | 32% (HIV and AIDS 29%) | NR | 3 | NR | 25% | NR | 6% | NR | NR | | group 1 vs 2 p = not significant | NR | 84
9 | Pons, Greenspan, Lozada-Nur, et al., 1997 | randomized drug comparison trial; examiners blind | convenience, HIV/AIDS, specific criteria, exclude esophageal candidiasis setting: multicenter not specified; authorship implies San Francisco and Fresno, CA, Philadelphia, PA study period: NR | yes | baseline, then days 1, 3, 7, 14 (end of tx), 28, and 42 (F/U) | 167 enrolled; 138 evaluable for efficacy | clinical signs and symptoms of candidiasis and swab/scrape pos for hyphae or pseudohyphae confirmed by candida pos culture | group 1 - fluconazole liquid suspension swish and swallow 100 mg once daily for 14 days | 83 (69) | mn = 38 yrs | 86% male race NR | NR | NR | NR | 95% | complete cure: 87% improvement: 12% | day 28: 18% day 42: 27% | NR | day 14: 60% (of 68 evaluated) | 93% | 2 | NR | NR | NR | NR | NR | NR | for day 14 clinical cure p < 0.001 (Mantel-Haenszel chi-square adjusted for study site) | relapse day 28 p < 0.001; relapse day 42 p = 0.120 | NR | 84
9 | Pons, Greenspan, Lozada-Nur, et al., 1997 | randomized drug comparison trial; examiners blind | convenience, HIV/AIDS, specific criteria, exclude esophageal candidiasis setting: multicenter not specified; authorship implies San Francisco and Fresno, CA, Philadelphia, PA study period: NR | yes | baseline, then days 1, 3, 7, 14 (end of tx), 28, and 42 (F/U) | 167 enrolled; 138 evaluable for efficacy | clinical signs and symptoms of candidiasis and swab/scrape pos for hyphae or pseudohyphae confirmed by candida pos culture | group 2 - nystatin liquid swish and swallow 500,000 units 4 times daily for 14 days | 84 (69) | mn = 38 yrs | 86% male race NR | NR | NR | NR | 95% | complete cure: 52% improvement: 16% | day 28: 44% day 42: 11% | NR | day 14: 6% (of 66 evaluated) | 93% | 1 | NR | NR | NR | NR | NR | NR | for day 14 clinical cure p < 0.001 (Mantel-Haenszel chi-square adjusted for study site) | relapse day 28 p < 0.001; relapse day 42 p = 0.120 | NR | 84
10 | De Wit, O'Doherty, De Vroey, Clumeck, 1998 | randomized drug comparison with open label; no blinding | convenience, specific criteria: AIDS or ARC; exclude esophageal candidiasis setting: University Hospital, Brussels, Belgium study period: NR | NR | baseline, day 3, 8, and 30 (F/U) or relapse, whichever is first | 40 enrolled; 37 evaluable for clinical efficacy | clinical sign/symptom of oropharyngeal candidiasis; confirm by direct microscopy of oral swab and yeast counts | group 1 - fluconazole single 150 mg oral dose | 20 (20) | mn = 39.9 yrs (16-65) | 85% male race NR | NR | md = 22 | NR | 100% | day 8 cure: 75% (day 8 improvement: 15%) | day 30 failure: 11% relapse: 32% | NR | 6% (of 18 evaluable) | NR | 0 | 0% | 0% | 0% | 0% | 0% | 0% | p = 0.006 for cure plus improvement (Mann-Whitney U-test) | NR | NS | 44
10 | De Wit, O'Doherty, De Vroey, Clumeck, 1998 | randomized drug comparison with open label; no blinding | convenience, specific criteria: AIDS or ARC; exclude esophageal candidiasis setting: University Hospital, Brussels, Belgium study period: NR | NR | baseline, day 3, 8, and 30 (F/U) or relapse, whichever is first | 40 enrolled; 37 evaluable for clinical efficacy | clinical sign/symptom of oropharyngeal candidiasis; confirm by direct microscopy of oral swab and yeast counts | group 2 - itraconazole 100 mg oral dose, once daily for 7 days | 20 (17) | mn = 40.7 yrs (16-65) | 75% male race NR | NR | md = 38 | NR | 100% | day 8 cure: 24% (day 8 improvement: 12%) | day 30 failure: 65% relapse: 12% | NR | 8% (of 12 evaluable) | NR | 0 | 0% | 0% | 0% | 0% | 0% | 0% | p = 0.006 for cure plus improvement (Mann-Whitney U-test) | NR | NS | 44
11 | Graybill, Vasquez, Darouiche, et al., 1998 | randomized drug comparison trial; examiners blind | convenience, HIV pos; age 13 and above; exclude esophageal candidiasis; specific criteria -- assignments random setting: 12 centers in the U.S. study period: NR | yes | baseline, then day 3-4, 7-8, 14-15, 21-22, 35-36, 42-43 | 190 enrolled; 179 evaluable for efficacy | clinical signs of pseudo-membraneous or erythematous candidiasis and KOH smear pos for Candida spp., confirmed by mycologic culture | group 1 - 200 mg itraconazole oral solution once daily for 7 days | 64 (60) | md = 38 yrs (25-67) | 88% male 50% white 35% black 15% Hispanic | NR | mn = 141.7 (3-707) | NR | 91% | clinical symptoms: 93% lesion eradication: 86% | 59% | NR | 60% | NR | 4 | NR | approx 25% | NR | NR | NR | respiratory: 12.5% | group 1 and 2 equivalent to group 3 | NR | NR | 92
11 | Graybill, Vasquez, Darouiche, et al., 1998 | randomized drug comparison trial; examiners blind | convenience, HIV pos; age 13 and above; exclude esophageal candidiasis; specific criteria -- assignments random setting: 12 centers in the U.S. study period: NR | yes | baseline, then day 3-4, 7-8, 14-15, 21-22, 35-36, 42-43 | 190 enrolled; 179 evaluable for efficacy | clinical signs of pseudo-membraneous or erythematous candidiasis and KOH smear pos for Candida spp., confirmed by mycologic culture | group 2 - 200 mg itraconazole oral solution once daily for 14 days | 64 (59) | md = 38 yrs (21-67) | 97% male 42% white 39% black 19% Hispanic | NR | mn = 134.2 (5-600) | NR | 98% | clinical symptoms: 98% lesion eradication: 97% | 44% | NR | 76% | NR | 4 | NR | approx 25% | NR | NR | NR | respiratory:12.5% | group 1 and 2 equivalent to group 3 | NR | NR | 92
11 | Graybill, Vasquez, Darouiche, et al., 1998 | randomized drug comparison trial; examiners blind | convenience, HIV pos; age 13 and above; exclude esophageal candidiasis; specific criteria -- assignments random setting: 12 centers in the U.S. study period: NR | yes | baseline, then day 3-4, 7-8, 14-15, 21-22, 35-36, 42-43 | 190 enrolled; 179 evaluable for efficacy | clinical signs of pseudo-membraneous or erythematous candidiasis and KOH smear pos for Candida spp., confirmed by mycologic culture | group 3 - fluconazole 200 mg once, then 100 mg daily for 13 days | 62 (60) | md = 39 yrs (24-61) | 93% male 45% white 37% black 17% Hispanic 2% Asian/Pacific Islander | NR | mn = 162.3 (2-702) | NR | 98% | clinical symptoms: 92% lesion eradication: 87% | 48% | NR | 68% | NR | 1 | NR | approx 25% | NR | NR | NR | respiratory: 21% | group 1 and 2 equivalent to group 3 | NR | NR | 92
12 | Phillips, De Beule, Frechette, et al., 1998 | randomized drug comparison trial; assigned in blocks of 12; double blind (examiners and patients) | convenience, HIV pos CD4 <400 within 1 month, >19 yrs old, no antifungals in past 2 weeks; exclude esophageal candidiasis setting: 25 centers in 7 countries (Europe and Canada) study period: June 1993 to July 1994 | yes | baseline, 8, 15, 23, and 30 days after beginning treatment | 244 enrolled, 194 evaluable | clinical pseudo-membraneous candidiasis; mycologic assessment by microscopy (KOH, Gram or methylene blue stain); and culture (with Sabouraud's PS agar) | group 1 - itraconazole oral solution 100 mg twice daily for 7 days plus placebo capsules | 79 (62) | md = 36 yrs (25-64) | 91% male race NR | NR | mn = 151 (SE= 27) | NR | 95% | 82% (complete response or marked improvement) | at 18 days 37% | at 7 days 65%; at 14 days 53% | at 7 days 56%; at 14 days 44% | NR | NR | 33% | 19% | 0% | 0% | 5% | 0% | group 2 vs. 3: equivalent with p = 0.0024; group 1 vs. 3: not statistically equivalent; group 1 vs. 2: NR (Blackwelder test of equivalence) | NR | NR | 88
12 | Phillips, De Beule, Frechette, et al., 1998 | randomized drug comparison trial; assigned in blocks of 12; double blind (examiners and patients) | | yes | baseline, 8, 15, 23, and 30 days after beginning treatment | 244 enrolled, 194 evaluable | clinical pseudo-membraneous candidiasis; mycologic assessment by microscopy (KOH, Gram or methylene blue stain); and culture (with Sabouraud's PS agar) | group 2 - itraconazole oral solution 100 mg once daily for 14 days plus placebo capsules | 79 (60) | md = 35 yrs (24-58) | 89% male race NR | NR | mn = 160 (SE = 21) | NR | 93% | 90% (complete response or marked improvement) | at 18 days 35% | at 7 days 62%; at 14 days 60% | at 7 days 58%; at 14 days 57% | NR | NR | 48% | 34% | 4% | 5% | 6% | 0% | group 2 vs. 3: equivalent with p = 0.0024; group 1 vs. 3: not statistically equivalent; group 1 vs. 2: NR (Blackwelder test of equivalence) | NR | NR | 88
12 | Phillips, De Beule, Frechette, et al., 1998 | randomized drug comparison trial; assigned in blocks of 12; double blind (examiners and patients) | | yes | baseline, 8, 15, 23, and 30 days after beginning treatment | 244 enrolled, 194 evaluable | clinical pseudo-membraneous candidiasis; mycologic assessment by microscopy (KOH, Gram or methylene blue stain); and culture (with Sabouraud's PS agar) | group 3 - fluconazole capsules 100 mg once daily for 14 days plus placebo solution | 86 (72) | md = 38 yrs (21-65) | 92% male race NR | NR | mn = 136 (SE= 15) | NR | 97% | 90% (complete response or marked improvement) | at 18 days 34% | at 7 days 54%; at 14 days 60% | at 7 days 44%; at 14 days 53% | NR | NR | 43% | 33% | 2% | 6% | 2% | 2% | group 2 vs. 3: equivalent with p = 0.0024; group 1 vs. 3: not statistically equivalent; group 1 vs. 2: NR (Blackwelder test of equivalence) | NR | NR | 88