# Recommendations for Future Research

In this chapter, we address the limitations noted in our results for each of the key questions. It is primarily the lack of research that prevents us from being at all definitive with answers to the questions. Overall, the amount of research that we found to address the questions was inadequate. And the research we found did not address all of the elements in the questions. In addition, the results were inconsistent for the questions the research did address. Further, the research did not regularly take into account important characteristics of the study groups. Finally, the situation with respect to treatment for the human immunodeficiency virus (HIV) and the acquired immune deficiency syndrome (AIDS) has changed considerably since most of the studies reported in our review were conducted, and any impact this change may have still needs to be considered in arriving at answers to the questions.

## Future Research Needs Regarding Complications from Dental Procedures

To advance our understanding of differences in complication rates associated with dental patient HIV status, several considerations need to be kept in mind when future studies are designed and analyzed. The number of studies on extractions and endodontics must be increased, and the types of dental treatments that are studied need to be expanded beyond them to include the range of periodontal procedures, implants, orthognathic surgery, and oral prophylaxis. It is not possible to generalize to interventions whose risks are so unlike those of dental extractions or endodontics. Further, complication rates need to be reported according to clinical AIDS status, CD4 cell count, and level of plasma viral load. Patients whose immune systems are more compromised may well have a greater prevalence of complications.

There are important factors, such as administration of pre- or postoperative antibiotics, severity of the oral condition being treated, number of procedures, and other known risk factors such as diabetes and tobacco use, that should be routinely reported and included in any analysis of complications. Studies should routinely report the percentage of patients receiving antiretroviral therapy, especially highly active antiretroviral therapy (HAART). Patients receiving these highly active therapies may be receiving added protection against complications. The studies should also report rates for each specific type of complication, not just overall rates for all complications combined, and they should document compliance with postprocedure instructions.

In addition, study sample sizes need to be increased substantially to have the power to detect significant differences, in view of the relatively low rate of postoperative complications in the general population. Also, more sophisticated and rigorous research designs, such as prospective cohort studies, should be employed so as to control more rigorously the criteria for completeness and comparability in what is recorded as a complication. Additionally, more complex analysis of the complications using multivariate analytic techniques that statistically take into account potentially important differences within and between the study groups should be employed. Finally, with the changing demographic composition of the HIV-infected population, it will be increasingly important for future studies to determine whether complication outcomes differ by gender, race, or poverty status.

## Future Research Needs Regarding Oral Conditions as Markers of Recent HIV Seroconversion

There is very little research reported on the question of oral conditions as markers of recent HIV seroconversion. One of the major problems is establishing with some certainty when the exposure to HIV occurred so that the 3-month period of interest can be accurately specified. A presumptive diagnosis of acute retroviral syndrome can be based on a positive test for HIV ribonucleic acid (RNA) with a negative HIV antibody test, followed within months by a positive HIV antibody test signaling seroconversion and confirming the diagnosis. Unlike most longitudinal and cross-sectional studies in the literature, the one study^78^ that is reported in the Evidence Table is able to definitely establish the date of infection. This is essential if a statement is to be made about oral conditions occurring around the time of seroconversion, which typically occurs within 3 months of infection. It is fortunate that there will probably not be more opportunities to study oral conditions in the context of accidental infections surrounding use of unscreened blood products. However, such incidents are not unrepresentative of the usual sources of infection. This is particularly true of the study population in this report,^78^ which was predominantly young children with developing immune systems. Large doses of the HIV retrovirus injected directly into the circulatory system probably speed up the process of seroconversion and may cut out some of the sentinel disease processes that are more typical when the infection is acquired through means other than blood products (in such cases, it likely takes longer for seroconversion to occur). And whether the same disease processes have the same timing and frequency in adults remains to be established.

In the one article included in the evidence table, only oral candidiasis occurring around the time of seroconversion was examined.^78^ This condition and all of the oral conditions mentioned in the question need to be examined so that the question can be more fully answered. Clearly, prospective longitudinal designs using at-risk cohorts are best suited to answering this question. The two cohorts in this study were not truly both at risk for HIV infection because one was known to be transfused with infected blood and the other was known to be transfused with tested and untainted blood. The "cases" were known in advance to be 100 percent likely to seroconvert, and the "controls" were 100 percent unlikely. Following an at-risk cohort will mean committing a great deal of professional manpower and laboratory resources to frequent routine oral examinations and HIV testing at regular intervals.

## Future Research Needs Regarding Oral Conditions as Indicators of Severely Immunocompromised Status

To provide more conclusive evidence for the role of oral conditions as indicators of immunosuppression among HIV-positive persons, additional studies are needed. The areas that these studies should plan to address are listed below.

Additional studies are needed to examine the relationships between necrotizing ulcerative periodontitis, oral ulcers, linear gingival erythema, and parotid swelling and severe immunosuppression. Barely more than a handful of studies of oral conditions address the relationship between oral candidiasis and hairy leukoplakia and immunosuppression. Further, all of the studies were based on measures of CD4 cell count and not on measures of plasma HIV RNA level (viral load).

The studies that have been conducted have been on relatively homogeneous groups of HIV-infected persons, which may limit generalizability or external validity. More research is needed on how the prevalence of immunosuppression and the prevalence of oral lesions differ among HIV-positive subpopulations, such as women infected through heterosexual sex, homosexual men, injected drug users, children, and persons in other nations where different social conditions, endemic infections, resource constraints, and cultures prevail.

In addition, future studies should be explicit in the diagnostic criteria, both presumptive and definitive, used to determine the presence of oral lesions. We encourage use of established criteria, such as those for adults developed by the European Community Clearinghouse on Oral Problems Related to HIV Infection and the World Health Organization Collaborating Centre on Oral Health^109^ or the USA Oral AIDS Collaborative Group,^110^ and for children by the Collaborative Workgroup on Oral Manifestations of Pediatric HIV Infection.^111^ Such standardization of measurement will facilitate the comparison of data across centers and populations, as well as contribute to the plausibility of future meta-analysis. Because HIV epidemics in other countries (e.g., Thailand and much of sub-Saharan Africa) involve clades of HIV distinct from that predominant in the United States, the clade difference should also be a research issue when comparing U.S. and foreign populations.

The underlying causes of the list of oral conditions in the question are quite different, and the available evidence does not suggest that any one of them is particularly useful as an alternative to CD4 testing to indicate the level of immunosuppression. However, it may be more useful to conduct studies of the prevalence of selected combinations of oral lesions in an HIV-positive person over a relatively short period of time and to examine the ability of these combinations to predict the level of immunosuppression. In this regard, longitudinal studies that follow cohorts of immunocompetent HIV-positive persons over time are needed to get a better understanding of the temporal relationship between the development of various oral lesions (individually and in combination) and the degree of immunosuppression.

None of the studies address the implications of new therapies (i.e., HAART) for the development of these oral conditions. With the advent of such therapies that can so dramatically reduce the plasma viral load, the relationship between viral load, level of immunosuppression, and these oral conditions needs to be established.

## Future Research Needs Regarding Use of Antifungals for Oral Candidiasis Prevention

This evidence review indicates gaps in our knowledge about the efficacy of the three antifungal agents (i.e., clotrimazole, itraconazole, and amphotericin B oral solution) when used as prophylactic coverage against oropharyngeal candidiasis in HIV patients. Similarly, nystatin suspension has not been evaluated.

Future studies must follow cohorts that are well-defined and must control for the subject's immunologic (CD4 cell count) and clinical HIV disease stage, history of oropharyngeal candidiasis, past exposure to antifungal drugs, baseline oral Candida carriage, possible drug-drug interactions, HIV viral replication levels (HIV RNA quantity), and current antiretroviral drug therapy, including HAART regimens.

Compliance monitors, fungal speciation, and susceptibility testing of fungal isolates (from routine surveillance cultures and clinical infections) for resistance to the test drug must be included. This will allow more unbiased estimates of the relative risk for resistance that is associated with different prophylactic regimens. Future studies of prophylaxis should also address the issues of drug regimen convenience (administered once vs. up to five times daily) and acceptability of mode of administration (topical vs. systemic) because these may affect patient compliance with the drug therapy.

However, there may be less need for prophylaxis because improved antiretroviral therapy available in developed countries in the 21st century may have beneficial prophylactic effect on candidiasis, so monitoring for new or recurrent oropharyngeal candidiasis among patients who are enrolled in multicenter antiretroviral trials may prove useful. Successful HAART regimens, with their ability to reduce the patient's susceptibility to opportunistic infections, may decrease the incidence of candidiasis and thus the need for antifungal prophylaxis in compliant patients. However, patients who lack access to antiretroviral therapy, who have antiretroviral-resistant HIV strains, or who are not compliant with antiretroviral therapy regimens are likely to continue to be at risk for new or recurrent oropharyngeal candidiasis, especially as their HIV disease progresses.

## Future Research Needs Regarding Use of Antifungals to Treat Oral Candidiasis

This evidence review discusses gaps in our knowledge about the efficacy of amphotericin B oral suspension and intravenous amphotericin B when used to treat oropharyngeal candidiasis in HIV patients. Additional antifungal drugs are likely to be developed in the future and will require randomized clinical trials to demonstrate efficacy outcomes. It is likely that fluconazole will remain a commonly used comparison drug at a dose of 100 mg daily (often with a 200 mg loading dose) for 14 days or shorter times of administration.

As suggested for studies of prophylactic antifungal drug administration, future studies assessing the effectiveness of various antifungal drugs for the treatment of oropharyngeal candidiasis in patients with HIV/AIDS must follow cohorts that are well-defined and control for the subject's immunologic (CD4 cell count) and clinical HIV disease stage, history of oropharyngeal candidiasis, past exposure to antifungal drugs, baseline oral Candida carriage, possible drug-drug interactions, HIV viral replication levels (HIV RNA quantity), and current antiretroviral drug therapy, including HAART regimens. Compliance monitors, fungal speciation, and susceptibility testing of fungal isolates (from routine surveillance cultures and clinical infections) for resistance to the test drug should also be included. Studies using combinations of antifungal drugs may be warranted as well. This will allow more unbiased estimates of the relative risk for resistance associated with different treatment regimens. Future studies of drug therapies should also address issues of regimen convenience and acceptability to patients of the drug modality because these can have an impact on compliance with treatment. Additionally, studies should involve sufficiently large samples to allow adequate power to detect differences not only in clinical response, but also in mycological response and relapse rates. Research on the effectiveness of alternative and complementary medicine and therapies, for both the prophylaxis and treatment of oropharyngeal candidiasis, should be considered in the future as well. Finally, recognition and measurement of xerostomia that may predispose to candidal overgrowth in persons with HIV/AIDS needs to be considered.