# Conclusions

In this chapter, we discuss the overall conclusions and implications of our analysis of the data in the evidence tables in Chapter 7 and our results from the previous chapter. We begin, however, with a discussion of our system for grading the strength of the evidence we have collected and reviewed to address the key questions. Subsequent sections present our conclusions about each of the key questions separately.

## Grading the Evidence

Chapter 2 introduced the discussion of our grading system for articles in the literature we used to address the questions on management of dental patients who are HIV positive. Our approach for assigning overall categorical grades or ratings to the entire collection of evidence takes into account the overall quality of the individual articles included in the evidence tables as described in Chapter 2, the number of studies reported on a question, and the strength and consistency or homogeneity of the findings across the studies on a specific topic. The grades are defined as indicated below. We tried to make them general enough to apply to our conclusions on the questions about increased risk of complications from oral procedures, oral indicators of changes in HIV serostatus/immunosuppression, and the efficacy/effectiveness of antifungals.

We defined four basic grades for the literature. The first two indicate that the number of studies of acceptable quality and the quantity of data available are sufficient to make a judgment. They differ in that they judge the overall data as being good or fair in terms of supporting or rejecting the conclusion that the intervention, indicator, or drug of interest is meaningfully different from the comparison group, gold standard, or alternative intervention/placebo. The third grade, poor, indicates that the inconsistency of the outcome data makes it impossible to reach a conclusion about the intervention, indicator, or drug in question at this time. The fourth grade indicates that there is insufficient evidence bearing on a question. This grade is assigned when the quantity or quality of the data is insufficient to draw any conclusions, chiefly because of no or too few studies, small sample sizes, or poor methods in the studies reviewed. The specific category definitions are as follows:

### Good

The data are sufficient to assess the quality and strength of the findings. The outcome data are consistent and clearly support that the intervention, indicator, or drug in question does or does not demonstrate a significant or meaningful difference from the comparison group, gold standard, or alternative treatment/placebo.

### Fair

The data are sufficient to assess the quality and strength of the findings. The outcome data are not consistent and do not uniformly/strongly support that the intervention, indicator, or drug in question does or does not demonstrate a significant or meaningful difference from the comparison group, gold standard, or alternative treatment/placebo, but the weight of the evidence is in one direction.

### Poor

The data are not sufficient to assess the quality and strength of the findings. The outcome data are inconsistent, the study designs are not consistently strong, and there is no preponderance of evidence in one direction or the other to suggest whether or not the intervention, indicator, or drug is meaningfully different from the comparison group, gold standard, or alternative treatment/placebo.

### Insufficient

The data are not sufficient to assess the quality and strength of any findings about the intervention, indicator, or drug in question because of a limited number of studies, small sample sizes, or poor study methodologies.

## Increased Risk Associated with Selected Routine Dental Procedures

The key question for this topic was "Are HIV/AIDS patients at increased risk of complications (e.g., local infection, systemic infection, increased bleeding, delayed healing, or alveolitis) from intra-oral dental procedures (e.g., extractions, orthognathic surgery, periodontal therapy, endodontics, prophylaxis, scaling and root planing, and dental implants) compared with similar patients without HIV/AIDS?"

The literature available to address this question was very limited. Of the five articles that met the inclusion/exclusion criteria, only two dental therapies, endodontics and tooth extraction, were studied. Thus, there was insufficient evidence on increased complications among HIV-positive patients for orthognathic surgery, periodontal surgery, dental prophylaxis, scaling and root planing, or dental implants.

In the study of endodontic procedures, the immediate (1- to 3-month follow-up) postoperative complication rate was exceedingly low in the HIV-positive group and nonexistent in the control group.^70^ The authors did not detect a significant difference in complication rates between the two groups. However, because it is only one study, we conclude that the available evidence is insufficient for determining whether there are differences between HIV-positive and HIV-negative persons in complication rates associated with endodontic therapy.

Four studies met the inclusion criteria to examine the issue of postoperative complications associated with tooth extraction. Three studies in this review found no significant difference between complications in the HIV-positive and HIV-negative groups, although there was a consistent tendency for the HIV-positive patients to have more complications. The remaining study provided mixed results. An analysis similar to the other three studies comparing outcomes between the HIV-positive and HIV-negative groups demonstrated that the HIV-positive group had a statistically significant higher rate of postoperative complications. However, when the analysis was adjusted for other known risk factors (e.g., age, preoperative antibiotics, and tobacco use), the association was no longer statistically significant.^77^

Postextraction complications in these studies included persistent bleeding, persistent pain, localized alveolitis, local wound infection, and delayed wound healing. Nevertheless, across all studies, the postoperative complications that were experienced were rather minor and, when they occurred, were treated on an outpatient basis. Moreover, none of the four studies called for the need to take special precautions in the treatment of HIV-positive patients who do not have a coagulopathy and are sufficiently healthy to be seen on an outpatient basis. However, given the limited number of studies that addressed extraction, the low rate of complications generally, and the variability in the results when analytic approaches differ, we find the evidence is poor as a basis on which to rule in or out a meaningful relationship between HIV-positive status and postoperative complications following tooth extraction.

## Selected Oral Conditions as Markers of Recent HIV Seroconversion

The key question for this topic was "What are the sensitivity, specificity, and positive and negative predictive values of hairy leukoplakia, oral candidiasis, necrotizing ulcerative periodontitis, oral ulcers, and parotid swelling as markers of recent HIV seroconversion (within 12 weeks after exposure)?"

There is insufficient evidence to conclude anything about the ability of hairy leukoplakia, necrotizing ulcerative periodontitis, oral ulcers, and parotid swelling to serve as markers of recent HIV seroconversion because we could find no studies of those conditions that met our inclusion/exclusion criteria to review.

There was, however, one study of oral candidiasis that was reviewed.^78^ In this study, the prevalence rate of oral candidiasis in the total study sample was 8 percent and the prevalence of seroconversion was 46 percent. However, far more persons in the study who seroconverted did not have oral candidiasis than had it (i.e., low sensitivity [Sn] = 14 percent). Despite its high specificity (Sp = 97 percent), on the basis of this one study, oral candidiasis does not appear to be a very good marker for seroconversion, even in persons known to have been exposed to the retrovirus, if what is meant by marker is the ability to serve as a substitute for HIV testing.

On the other hand, looking only at persons who had oral candidiasis, a very large proportion of them had seroconverted (positive predictive value [PPV] = 82 percent). This is nearly twice the 46 percent seroconversion rate of the total sample. From this perspective, oral candidiasis may be an important marker for seroconversion among a population with known HIV exposure. Thus, from a clinical perspective, if a clinician finds oral candidiasis in a person known to have been exposed to HIV, it may well serve as a reasonable marker for seroconversion because the yield of true positives (seroconverters) will be considerably greater than expected by chance alone (82 percent vs. 46 percent).

There are several unusual aspects of this study that call for caution in interpretation and limit generalizability beyond the fact that it is a single study. The sample was a very unusual one in that half of the sample was infected with certainty by a transfusion of HIV-tainted blood, while the other half was transfused with blood known to be almost certainly HIV-free. Direct transfusion is not a common method of HIV transmission. With this form of transmission, the speed with which seroconversion occurs is undoubtedly very fast (especially in already ill children) as evidenced by the fact that all who were going to seroconvert had done so by the end of the first month. The fact that so many of the patients in the study were lost to follow-up by 3 months after the transfusion is also of concern, especially because most were lost due to death.

Because there is only a single study, a good but atypical one in many ways, we conclude that there is insufficient evidence to determine whether oral candidiasis is a marker for recent HIV seroconversion.

## Selected Oral Conditions as Indicators of Severe Immunosuppression

The key question for this topic was "What are the sensitivity, specificity, and positive and negative predictive values of hairy leukoplakia, oral candidiasis, necrotizing ulcerative periodontitis, oral ulcers, parotid swelling, linear gingival erythema, and Kaposi's sarcoma as indicators of severe immunosuppression as measured by CD4 lymphocyte cell count and plasma viral load of HIV in persons with HIV/AIDS?"

Because of the number of studies available for each of these oral conditions, our conclusions differ somewhat with respect to the specific oral conditions. Thus, we provide our conclusions for each condition separately, with the exception of parotid swelling. There were no studies and therefore insufficient evidence on which to base a judgment on parotid swelling as an indicator of severe immunosuppression.

Despite the reasonably large number of articles (10 on eight different populations), it is difficult to draw conclusions from such a diverse set of results derived from such different study groups about the overall usefulness of oral candidiasis as an indicator of severe immunosuppression. What is to be done if oral candidiasis is deemed an indicator will largely establish the criteria for deciding its usefulness. As we mentioned in the discussion of oral conditions as markers of recent seroconversion, if the intent is to use the presence of the condition as a substitute for testing, then a different criterion (i.e., high sensitivity) is necessary in clinical trials research or population-screening modes from the criterion that would be required in a clinical setting, where its disproportionate presence in members of a defined patient group (i.e., high PPV relative to the prevalence of immunosuppression) could be a cue to action (e.g., resetting or changing treatment).

The sensitivity of oral candidiasis in the studies reviewed ranges from low to moderately high (20 to 77 percent), with most falling in the moderate range at around 50 percent. It is clear that oral candidiasis is statistically associated with CD4 level in persons infected with HIV. As an indicator of CD4 cell count <200 cells/mm^3^ in a clinical trials research or population-screening setting, we judge the evidence to be fair that oral candidiasis is not a strong indicator of CD4 level based on its sensitivity. However, based on its moderate to high PPVs, which range from 34 to 88 percent, we rate the evidence as fair to conclude that in a clinical setting oral candidiasis may be a useful indicator of immunosuppression because the PPV is consistently much higher than the prevalence of CD4 cell count <200 cells/mm^3^ in the study populations.

The studies are fairly consistent in finding that among HIV-positive patients, the presence of hairy leukoplakia is not a highly sensitive indicator of a CD4 cell count <200 cells/mm^3^ (i.e., there are many false negatives). Further, four of the six studies indicated that the probability of a patient with hairy leukoplakia having a CD4 cell count <200 cells/mm^3^ was <50 percent and hardly different from the prevalence of CD4 <200 cells/mm^3^. Despite having moderate to moderately high specificity (i.e., the absence of hairy leukoplakia appears to be a fairly good indicator that the HIV-positive patient does not have a CD4 cell count <200 cells/mm^3^), we judge the available evidence to be good that hairy leukoplakia is not a useful indicator of severe immunosuppression as measured by CD4 cell count.

Because of the small number of studies reviewed and the small number of cases of necrotizing ulcerative periodontitis, we judge the evidence on this condition to be insufficient. For this reason, it is not possible to draw any definitive conclusions about necrotizing ulcerative periodontitis as an indicator of CD4 <200 cells/mm^3^. However, the studies reviewed do suggest that the presence of necrotizing ulcerative periodontitis is not very sensitive to a CD4 cell count <200 cells/mm^3^. On the other hand, if it were not for the fact that none of the injected drug user group in the Begg et al.^52^ study had necrotizing ulcerative periodontitis, its high PPVs in the other groups suggest it could be a useful predictor of immunosuppression in a clinical situation. Further studies are needed to examine the value of necrotizing ulcerative periodontitis as a predictor of CD4 cell count <200 cells/mm^3^.

We judge the evidence to be fair that oral ulcers are not sensitive enough to be used as an indicator of immunosuppression when measured by a CD4 cell count <200 cells/mm^3^. Based on its PPVs, the use of oral ulcers as an indicator of immunosuppression among HIV-infected persons in a clinical setting also does not seem to be of much use. When compared with the prevalence of a CD4 cell count <200 cells/mm^3^ in the study populations, the positive predictive values are no better than chance in predicting severe immunosuppression.

Because only two studies were reviewed, we judge the evidence to be insufficient regarding linear gingival erythema as an indicator of immunosuppression among HIV/AIDS patients. However, we do note that neither study gave any suggestion based on either sensitivity or PPV that linear gingival erythema would be a useful predictor of low CD4 cell count. The sensitivities are uniformly low and the PPV is not meaningfully higher than the prevalence of a CD4 cell count <200 cells/mm^3^, casting doubt on the potential usefulness of linear gingival erythema as an indicator of immunosuppression in a research, population screening, or clinical situation.

Because of its consistently low sensitivity in the three studies reviewed, we judge the evidence to be fair that the use of Kaposi's sarcoma as a predictor of a CD4 cell count <200 cells/mm^3^ is not warranted in a clinical trials research or population-screening situation because the rate of false negatives is so high. In a clinical situation, however, we believe the evidence is fair that the presence of Kaposi's sarcoma appears to be a good indicator of a CD4 cell count <200 cells/mm^3^, based on its high PPV.

## Efficacy of Antifungal Agents Used to Prevent Oral Candidiasis

The key question for this topic was "What is the efficacy of available antifungal agents -- nystatin formulations, clotrimazole, amphotericin B suspension, ketoconazole, fluconazole formulations, and itraconazole formulations -- as prophylactic measures for oral candidiasis in persons diagnosed with HIV/AIDS? (The question is intended to examine the prevention of both recurrences and first-time infections, although the primary focus is on recurrences.)"

There is insufficientevidence from which to draw conclusions about the efficacy of nystatin, clotrimazole, amphotericin B suspension, ketoconazole, and itraconazole with regard to oral candidiasis prophylaxis because nystatin was assessed in only one study reviewed and no studies were found that evaluated the other antifungal drugs. The one study of nystatin demonstrated that nystatin pastilles at 200,000 U/day and 400,000 U/day were effective in preventing new or recurrent oropharyngeal candidal infections, with the higher dose being more effective. Few side effects were reported for nystatin.

We consider the evidence to be good with respect to fluconazole. In five studies reviewed, fluconazole appears to be significantly more effective at preventing recurrences or new infections than was placebo over 3 to 17 months, when studied at doses ranging from 50 to 100 mg/day and 150 to 200 mg/week. Gastrointestinal disorders were the most common side effects, but were tolerable.

## Effectiveness of Antifungal Agents Used to Treat Oral Candidiasis

The key question for this topic was "What is the effectiveness of currently available drugs -- nystatin formulations, clotrimazole, amphotericin B suspension, ketoconazole, fluconazole formulations, and itraconazole formulations -- for the treatment of oral candidiasis in persons diagnosed with HIV/AIDS?"

There is insufficientevidence from which to draw conclusions about the effectiveness of amphotericin B suspension for treatment of oral candidiasis in patients with HIV/AIDS because it was not assessed in any studies reviewed. We judge the evidence to be good for the other drugs in question.

Fluconazole appears to be 88 to 100 percent effective in obtaining a complete clinical response after 14 days of therapy and 53 to 76 percent effective in obtaining a culture negative for Candida species. Itraconazole appears to be roughly equivalent to fluconazole, and ketoconazole achieved the same or slightly lower response rates. Fluconazole and itraconazole are more effective than nystatin or clotrimazole at managing oropharyngeal candidiasis, particularly when mycological response rates and relapse rates are taken into account. Although aqueous gentian violet oral rinse is not generally used in developed nations, it may be a cost-effective treatment for oropharyngeal candidiasis in developing countries.

For any given drug, not all individuals with complete clinical response (eradication of signs and symptoms) achieved a complete mycological response (negative culture). Relapse rates tended to be lower where mycological cure was obtained. Adverse events rarely resulted in discontinuation of therapy. Side effects were generally mild and typically involved the gastrointestinal system.

In addition to proven efficacy in randomized clinical trials, choice of antifungal drug and dose for the treatment of patients with oropharyngeal candidiasis will likely depend on a variety of individualized factors, such as level of immunosuppression, extent and severity of oral and esophageal candidiasis, need for topical versus systemic therapy, ease of administration of the drug, anticipated compliance with the regimen, clinical drug resistance patterns, changing or mutating Candida species, gastric acidity that may affect absorption of some drugs, drug-drug interactions, antiretroviral therapy and its success in controlling viral replication, whether treating a child or an adult patient, and medication costs.