# Results

This chapter reports the findings from a review of published literature to address key questions on the management of dental patients who are infected with the human immunodeficiency virus (HIV) or who are living with acquired immune deficiency syndrome (AIDS). The evidence tables presented in Chapter 7 contain the data from which these findings are derived. The discussion of results covers each of the questions and subquestions separately. It begins with a review of the potentially increased risks associated with specific dental procedures. This is followed by a review of selected oral conditions as markers or indicators for recent HIV seroconversion and severe immunosuppression. The discussion ends with a review of the efficacy or effectiveness of existing antifungal agents for the prevention and treatment of oral candidiasis.

## Increased Risk Associated with Selected Routine Dental Procedures: Key Question 1

### Overview

Some experts have suggested that special provisions are necessary to avoid postoperative complications among HIV-infected patients receiving dental treatment.^67 - 69^ This suggestion is based on the rationale that because patients with HIV infection are immunologically compromised, they are at increased risk for complications associated with dental treatment. It follows that those with substantial immunosuppression (e.g., CD4 cell count <200 cells/mm^3^) or severe neutropenia (absolute neutrophil count <500 cells/mm^3^) are at greater risk for complications. However, the extent to which HIV-positive and HIV-negative individuals experience different rates of postoperative complications following routine dental procedures remains unclear.

This review examined published studies to compare the complication rates associated with dental treatment in HIV-positive persons with the complication rates for similar dental treatment in individuals who are HIV negative. The review also explored any factors associated with differences in the complication rates. The data abstracted from the review of the five articles finally included in the review for Key Question 1 are shown in Evidence Table 1 in Chapter 7.

### Description of the Literature

Two of the seven dental procedures specifically mentioned to be of interest in Key Question 1 were the objects of study in the five articles. One article examined endodontic procedures (root canal treatment), and four studies examined tooth extraction. None reported on orthognathic surgery, periodontal surgery, prophylaxis, root planing and scaling, or implants.

The study of postoperative complications associated with endodontics employed a retrospective cohort design.^70^ Patient records were used to determine the course of dental treatment, and related medical records confirmed HIV status. The sample included 48 adults, with a mean age of 34 years, who were predominantly male. The 32 HIV-positive patients were further categorized according to presence or absence of AIDS-related symptoms. Including both the HIV-positive and the HIV-negative groups, a total of 57 teeth underwent endodontic treatment. Nine of the HIV-positive patients and eight of the HIV-negative controls received antibiotics for relief of presenting symptoms before endodontic treatment. Complications were assessed at recall examinations for up to 3 months after treatment.

Four studies examined postoperative complications associated with tooth extraction. Two studies in this review employed retrospective cohort designs, and the other two used prospective cohort designs. The four studies followed a total of nearly 300 patients, the vast majority of whom were males. Across the four studies, the HIV-negative groups had low rates of prophylactic antibiotics (8 to 14 percent), and in the HIV-positive groups preoperative antibiotic coverage ranged from 24 to 63 percent.

### Limitations in the Literature

One of our inclusion criteria required that studies used in this review have a concurrent HIV-negative control or comparison group receiving the same treatments in the same settings. Imposition of this criterion excluded studies^18^ that reported rather low rates of overall complications. Also excluded were studies that had a comparison group but that did not report complications separately for the two groups.^71^ The quality of the studies included in this review is variable. Only two studies employed a prospective study design. Two of the five studies looked at subgroups within the HIV-positive group. Only one study reported complication rates for subgroups under antibiotic therapy, and only one study of extraction complications included substantial numbers of female patients. Two of the five studies reported overall complication rates but no complication rates for individual types of complications. None controlled for severity of the presenting condition, and none adjusted for comorbid conditions, such as diabetes and periodontal disease. Finally, loss to follow-up was a concern in two studies.

### Results for Endodontic Procedures

In the study of endodontics, the immediate (1- to 3-month follow-up) postoperative complication rate was exceedingly low in the HIV-positive group and nonexistent in the control group.^70^ Only 1 of the 48 patients experienced any postoperative complications; an asymptomatic HIV-positive male was found to have pain and swelling following the initial root canal treatment. He received local debridement and antibiotics, and no further complications occurred. Otherwise, no complications associated with endodontic therapy were noted in any of the patients regardless of whether they did or did not receive prophylactic antibiotics. The authors did not detect a significant difference in complication rates between the two groups.

### Results for Extractions

Four studies met the inclusion criteria to examine the issue of postoperative complications associated with tooth extraction. By way of background, previous studies that had reported postoperative complication rates with the removal of third molars in non-HIV-infected individuals demonstrated that complication rates could vary from 3 to 10 percent.^72^ Some evidence also suggests that the complication rates increase in patients with immunocompromising diseases.^73^

Unadjusted complication rates overall ranged from 3 to 13 percent among HIV-negative subjects and 3 to 22 percent among HIV-positive patients. The study by Robinson and colleagues^74^ suggested a trend toward lower incidence of dry socket (i.e., alveolitis) among those with antibiotic treatment, but the researchers found no substantial difference in complication rates between the HIV-positive and HIV-negative groups.

Porter and associates^75^ reported no differences in delayed wound healing or postextraction dry socket. The only case of postextraction wound hemorrhage did occur in an HIV-infected patient but likely resulted from the patient's hemophilia. The authors concluded that postextraction complications are rare events in HIV-infected patients and do not recommend routine antibiotic prophylaxis before extractions.

In 1997, Dodson^76^ reported finding no difference in complication rates between the HIV-positive and HIV-negative groups, with a relative risk (RR) of 1.68 and a 95 percent confidence interval (CI) of 0.82 to 3.62. In contrast, the 1994 Dodson et al. retrospective study^77^ found that the groups differed significantly (RR = 7.04; 95 percent CI, 2.0 to 25.0; p = 0.001) and that the risk increased with increased levels of immunosuppression. When results were adjusted for age, preoperative antibiotics, and tobacco use, however, the difference was no longer statistically significant (RR = 4.3; 95 percent CI, 0.093 to 19.5; p = 0.06). Nevertheless, the authors suggested that biological and statistical evidence, while not overwhelming, does support the conclusion that HIV-positive patients are at increased risk of complications following extraction. They further asserted that because the complications are generally mild and managed conservatively, special measures such as determination of extent of immunosuppression or use of presurgical antibiotics are not recommended.

Three of the four studies in this review found no significant difference between complications in the HIV-positive and HIV-negative groups, although the HIV-positive groups tended to have more postoperative complications. The final study found that the HIV-positive groups had a statistically higher complication rate,^77^ but with the risk factor adjustment it was no longer significant. Postextraction complications included persistent bleeding, persistent pain, localized alveolitis, local wound infection, and delayed wound healing. Nevertheless, across all studies, the postoperative complications were rather minor and were treated on an outpatient basis. Finally, based on their findings, none of the four studies called for the need to take special precautions in HIV-positive patients who do not have a coagulopathy (e.g., hemophilia, thrombocytopenia, or other known bleeding disorders) and are sufficiently healthy to be seen on an outpatient basis.

## Selected Oral Conditions as Markers of Recent HIV Seroconversion: Key Question 2A

### Overview

It has been observed that persons who have recently HIV seroconverted have a higher than expected prevalence of selected oral conditions, especially oral candidiasis and hairy leukoplakia.^16^ If the presence of these conditions among persons at high risk for becoming infected with HIV is an accurate marker for recent seroconversion, then much valuable time can be saved and effort can be directed at persons with those conditions to have them tested sooner, influence their behavior so as to prevent spreading the infection to others, and initiate therapy to stave off opportunistic infections and full-blown AIDS. It would be especially time- and resource-saving for clinical trials research and in the resource-poor nations of the world if such oral markers were so strong that they made further testing for HIV (such as using dual enzyme-linked immunosorbent assays [ELISAs] and a confirmatory Western blot) unnecessary. Of course, any oral conditions would have to be extremely highly associated with recent seroconversion to be considered a substitute for HIV testing because the result of being wrong could be devastating to an individual, risky for the public, and biasing for research.

The question has dictated that the medical "testing" dimensions of sensitivity (Sn), specificity (Sp), positive predictive value (PPV), and negative predictive value (NPV) of the oral condition as a marker of recent seroconversion be used as the way of evaluating its usefulness. As a marker, sensitivity in this context is an indicator of how accurately the presence of an oral condition in a group of persons predicts recent seroconversion. Specificity, on the other hand, reflects how accurately the absence of the oral condition predicts that recent seroconversion has not occurred in a group of persons. Persons who have the oral condition but are not HIV positive are false positives and diminish specificity, whereas those who are HIV positive but do not have the oral condition are false negatives and diminish sensitivity. Because the cost and consequences of false positives and false negatives can be substantial in both screening and research applications, an oral condition used in place of conventional HIV testing would need to have high sensitivity and moderate to high specificity.

In a clinical setting, however, where a healthcare provider is faced with a particular patient, the provider is in a different situation. The provider must decide, on the basis of the presence or absence of an oral condition, whether this patient is likely to have HIV seroconverted. Help answering this question is to be found in the predictive values for the oral condition. PPV is the probability that a patient with the oral condition has seroconverted, and NPV is the probability that a person without the oral condition has not seroconverted. However, positive and negative predictive values are affected by the prevalence in the study population of the disease being predicted - - in this case, recent seroconversion. Thus, positive and negative predicted values must be viewed in a more relative perspective than sensitivity and specificity (i.e., in the context of the prevalence of recent seroconversion in the population under study). If the prevalence of recent seroconversion is greatly different from population to population, positive and negative predictive values of the same magnitude may not have the same meaning to clinicians.

### Description of the Literature

Only one study^78^ survived the inclusion and exclusion review process for Key Question 2A. Data abstracted from that study are contained in Evidence Table 2 in Chapter 7. The question asked for evidence on a set of specific oral conditions - - oral candidiasis, hairy leukoplakia, necrotizing ulcerative periodontitis, oral ulcers, and parotid swelling - - as markers for recent HIV seroconversion. Positive ELISAs and Western blot tests for HIV, obtained from patients confirmed previously seronegative for up to 3 months after the presumed time of infection and/or exposure, were considered evidence of recent seroconversion. No special conditions were imposed on the diagnosis of the oral conditions.

### Results for Oral Candidiasis

The study by Colebunders and colleagues^78^ used a prospective design to investigate the prevalence of a variety of signs and symptoms (including oral candidiasis) among two groups, each of 90 initially seronegative hospital patients in Zaire. All of the patients received blood transfusions for a variety of reasons between 1986 and 1987 before blood products were all routinely screened for HIV. The 90 "cases" consisted of all patients transfused with seropositive blood; the 90 "matched controls" received seronegative blood. More than 60 percent of the patients in the study were under 5 years of age. A large proportion of the patients in both groups were lost to follow-up and to death. No details were provided on the clinical determination of oral candidiasis. The controls were tested for HIV only at 12 months, and none of them had seroconverted, whereas 96 percent (all but two) of the available cases had seroconverted by the end of 3 months. While Sn, Sp, PPV, and NPV were not reported directly, data were reported that allowed us to calculate them.

The majority of patients with oral candidiasis had seroconverted by the end of 3 months (PPV = 82 percent), but only a small proportion of those who had seroconverted had oral candidiasis (Sn = 14 percent). Very few who did not seroconvert had oral candidiasis (Sp = 97 percent), and, as suggested above, most of those who did not have oral candidiasis did not seroconvert either (NPV = 57 percent).

## Selected Oral Conditions as Indicators of Severe Immunosuppression: Key Question 2B

### Overview

Key Question 2B involves the presentation of evidence supporting the use of selected individual oral conditions as indicators of the progression of HIV infection to the stage of severe immunosuppression and a diagnosis of AIDS. As formulated, the question suggests the use of measures of the CD4 cell count as an indicator of immunosuppression. The question emerges from an interest in achieving earlier identification of immunosuppression in persons being treated for HIV for the purposes of making changes in their antiretroviral therapy. It also raises the possibility of oral conditions serving as an alternative end point in clinical trial research or as a substitute for the CD4 blood tests to identify immunosuppression in poor nations where medical and financial resources are scarce or nonexistent.^16^ As with the previous question on recent seroconversion, Sn, Sp, PPV, and NPV are suggested as the basis for assessing the usefulness of the oral conditions as indicators of immunosuppression.

The original question identified the following five oral conditions of interest: hairy leukoplakia, oral candidiasis, necrotizing ulcerative periodontitis, oral ulcers, and parotid swelling. Two additional relevant conditions of interest were added at the recommendation of the Technical Expert Advisory Group - - linear gingival erythema and Kaposi's sarcoma. Articles that evaluated the predictive capability of combinations of some or all of these conditions have not been included in this review because they were not consistent in the number, mixture, or specific types of conditions they included.^79 - 81^

### Description of the Literature

The data from 10 articles^15,18,47,50 - 52,82 - 85^ have been abstracted and displayed in Evidence Table 3 in Chapter 7. Of these 10 articles, only two^18,52^ actually reported the sensitivity, specificity, positive predictive value, or negative predictive value; the remainder reported the data needed to calculate them for one or more of the oral conditions. All 10 articles reported a CD4 <200 cells/mm^3^ count alone as their measure of severe immunosuppression, and none reported viral load.

The 10 articles do not, however, represent 10 different study populations. There are two studies^84,85^ from which much if not all of the data reported are the same as for two other studies.^51,52^ Thus, the 10 articles represent only eight different study populations.

The study designs represented are a mixture of cross-sectional,^18, 82^ prospective cohort,^47,50 - 52,83 - 85^ and case-control.^15^ Only the data from the case portion of the case-control design is reported in the evidence table, and only data from the baselines of the prospective studies are included. This essentially reduces prospective designs to cross-sectional ones because the oral conditions and CD4 cell counts were assessed at the same or very similar points in time.

Nine out of 10 of the studies relied on clinical determination of candidiasis by means of an examination by dental or other health personnel (and sometimes by culture as well), and one of the articles was based solely on patient self-report of "thrush."^83^ All but one of the nine clinical studies^50^ mentioned training the examiners or reported having only one examiner.

It should be noted that the evidence table has been partitioned into multiple sections according to the type of oral condition that is being reported, so the same study may appear more than once in the evidence table, but under a different oral condition. For example, a study that reported on the presence of oral candidiasis according to CD4 level and separately on the presence of hairy leukoplakia according to CD4 level appears in two sections of the table, once for oral candidiasis and once for hairy leukoplakia. A study may appear as many times as it has relevant oral conditions on which it reported the necessary data. Table 10 at the end of this chapter lists the articles reviewed and included in Evidence Table 3. It also shows which oral conditions are reported on in each study.

Table 10. Articles in Evidence Table 3 Used to Report on Sensitivity, Specificity, Positive Predictive Value, and Negative Predictive Value of Oral Conditions as Indicators of Severe Immunosuppression

Authors and Year | Conditions ^a^
Authors and Year | OC | HL | NUP | OU | PS | LGE | KS
Feigal, Katz, Greenspan, et al., 1991^50^ | x | x | | x | | | x
Barr, Lopez, Rua-Dobles, et al., 1992^5^ | x | x
Kolokotronis, Kioses, Antoniades, et al., 1994^47^ | x | x
Glick, Muzyka, Lurie, et al., 1994^18^ | x | x | x | x | | | x
Kirby, Munoz, Detels, et al., 1994^83^ | x
Begg, Panageas, Mitchell-Lewis, et al., 1996^52^ | x | x | x | x | | x | x
Howell, Jandinski, Palumbo, et al., 1996^82^ | x
Phelan, Begg, Lamster, et al., 1997^85^ | x
Schuman, Sobel, Ohmit, et al., 1998^84^ | x
Schuman, Ohmit, Sobel, et al., 1998^51^ | x | x | | x | | x

a OC = oral candidiasis, HL = hairy leukoplakia, NUP = necrotizing ulcerative periodontitis, OU = oral ulcers, PS = parotid swelling, LGE = linear gingival erythema, KS = Kaposi's sarcoma

The conditions on which the studies reported are quite varied. It should be noted that none of the articles reported on parotid swelling. However, all 10 articles reported on oral candidiasis, 6 on hairy leukoplakia, and 4 on oral ulcers. These were the most commonly studied conditions in the studies reviewed. Only two studies reported on linear gingival erythema, two on necrotizing ulcerative periodontitis, and three on Kaposi's sarcoma. One article alone^52^ reported on six of the oral conditions. There was one article that only reported data to compute the positive predicted value for oral candidiasis^85^ and three other articles that reported on oral candidiasis alone.^82 - 84^

A number of studies that are cited in the literature as providing support for a relationship between the presence of one of these oral conditions and CD4 level or viral load have not been included in the review. They have not been included because they do not report the sensitivity, specificity, positive predictive value, or negative predictive value (or the data necessary to calculate them), but rather report the mean or median CD4 or viral load levels^49,86,87^ or a measure of association, such as an odds or likelihood ratio, without reporting the underlying distributions.^88,89^

As noted above, all 10 articles reported one or more of the parameters (Sp, Sn, PPV, or NPV) or the data to calculate them for the relationship between an oral condition and CD4 cell count. The study populations are quite different, however. One is a sample composed mostly of congenitally infected young children.^82^ Another study group (two articles) is composed only of women,^51,84^ three other studies are composed only of gay men,^15,50,83^ and one other consists mostly of gay men.^18^ One of the studies (two articles) reports results separately for two different study groups, one composed of gay men (most of whom were white) and the other of male and female injected drug users (most of whom were black).^52,85^ The studies also varied widely in the reported prevalence of oral candidiasis - - from 8 to 54 percent - - and in the prevalence of immunosuppression (CD4 <200 cells/mm^3^) - - from 13 to 53 percent.

The study patients were recruited from various settings. One study employed HIV-positive patients seeking dental care,^18^ others used patients in treatment for HIV,^47,82,83^ and some recruited from community organizations^15^ or sampled communities expected to have a large number of HIV-infected persons.^50^ The Schuman et al. study^51,84^ reported that the sample was recruited partly from community and partly from medical care settings.

### Limitations in the Literature

There are a number of obvious limitations associated with the evidence reviewed on oral lesions as indicators of immunosuppression in HIV-positive persons. First, the study populations in the studies reviewed may not be representative of the HIV-positive population generally. As discussed earlier, one study examined children only, two examined women only, and three examined only homosexual men. The prevalence of oral lesions and the prevalence of immunosuppression both varied widely among the studies. For clinical situations, the decision as to whether or not the presence of an oral lesion is a good indicator of a low CD4 cell count is based largely on the positive predictive value. However, the positive predictive value is a function of the prevalence of the disease in question, which in this case is immunosuppression as measured by CD4 cell count <200 cells/mm^3^. Because the prevalence of CD4 cell count may vary among different populations, results from these studies may not be generalizable to other populations. Second, the study by Glick et al.,^18^ a large study that reported on five of the oral conditions reviewed, examined HIV-positive patients referred for dental care. It is entirely possible that some of the patients went to the dentist because of the presence of oral lesions. If this occurred, it would likely increase the observed rate of true positives and false positives. Third, none of the studies reported on parotid swelling, a condition also suspected to be a consequence of immunosuppression, and none of the studies reported measured viral load. Fourth, the time interval between measurement of the CD4 cell count and the oral examination ranged from "within 24 hours" to "from 3 to 12 months" to not being reported. Long intervals may weaken or invalidate results. Because of new HIV highly active antiretroviral therapies (HAART) aimed at reducing viral load, viral load may be an even more important end point than CD4 cell count. Next, there was no agreement on the diagnostic criteria for the oral conditions to be included. In the case of oral candidiasis, for instance, they ranged from patient self-report to laboratory culture of Candida species to confirm a clinical diagnosis. Finally, although there were several studies investigating oral candidiasis and oral leukoplakia, there were far fewer investigating the other suspected indicators.

### Results for Oral Candidiasis

Table 11 presents the sensitivities (indicated by Xs) and the specificities (indicated by Os) of oral candidiasis relative to a CD4 cell count <200 cells/mm^3^ as an indicator of immunosuppression. There is little apparent consistency across the studies in sensitivities. They range from 20 to 77 percent (a range of 57 percentage points), with a small cluster of five study groups in the lower end of the range -- from 20 to 41 percent. This suggests that from 23 to 80 percent of the persons with CD4 cell counts <200 cells/mm^3^ did not present with oral candidiasis and were thus false negatives for this oral condition as an indicator of immunosuppression.

Table 11. Summary of Sensitivity and Specificity in Articles Using Oral Candidiasis as an Indicator of CD4 Cell Count <200 cells/mm3

Authors and Year | Percentages
Authors and Year | 0 | 5 | 10 | 15 | 20 | 25 | 30 | 35 | 40 | 45 | 50 | 55 | 60 | 65 | 70 | 75 | 80 | 85 | 90 | 95 | 100
Feigal, Katz, Greenspan, et al., 1991^50^ | | | | | X | | | | | | | | | | | | | O
Barr, Lopez, Rua-Dobles, et al., 1992^15^ | | | | | | | | | X | | | | | | | | | | | O
Glick, Muzyka, Lurie, et al., 1994^18^ | | | | | | | | | | | | | | | | X | | | O
Kirby, Munoz, Detels, et al., 1994^83^ | | | | | | | X | | | | | | | | | | | | | O
Kolokotronis, Kioses, Antoniades, et al., 1994^47^ | | | | | | | | | | | | | | X | | | | | | O
Begg, Panageas, Mitchell-Lewis, et al., 1996^52^ MSM ^a^ IDU ^a^ | | | | | | X | | | | | | | | O | X | | | O
Howell, Jandinski, Palumbo, et al., 1996^82^ | | | | | | | | | | | X | | | | | | O
Phelan, Begg, Lamster, et al., 1997^85^ MSM ^a^ IDU ^a^ | NR NR
Schuman, Sobel, Ohmit, et al., 1998^84^ | | | | | | | | | X | | | | | | | | O
Schuman, Ohmit, Sobel, et al., 1998^51^ | | | | | | | X | | | | | | | | | | | | O

a MSM = men who have sex with men; IDU = injected drug user

b NR = not reported; X = sensitivity; O = specificity

The situation with respect to specificity is somewhat more consistent. The specificities range from 65 to 97 percent, a range of 32 percentage points, with a cluster of eight study groups in the upper end of the range -- from 79 to 97 percent. This suggests that only 3 to 35 percent of the persons with CD4 cell counts of 200 cells/mm^3^ or higher presented with oral candidiasis and were thus false positives for this oral condition as an indicator of immunosuppression.

The positive and negative predictive values of oral candidiasis in the 10 articles relative to immunosuppression (CD4 cell count <200 cells/mm^3^) are presented in Table 12. Positive predictive values are indicated by Ps, and negative predictive values are indicated by Ns. The PPVs range from 34 to 88 percent (a range of 54 percentage points), with eight clustered at the low end of the range -- from 34 to 58 percent. This suggests that 12 to 66 percent of HIV-positive persons with oral candidiasis have CD4 cell counts <200 cells/mm^3^.

Table 12. Summary of Positive Predictive Values and Negative Predictive Values in Articles Using Oral Candidiasis as an Indicator of CD4 Cell Count <200 cells/mm3

Authors and Year | Percentages^b^
Authors and Year | 0 | 5 | 10 | 15 | 20 | 25 | 30 | 35 | 40 | 45 | 50 | 55 | 60 | 65 | 70 | 75 | 80 | 85 | 90 | 95 | 100
Feigal, Katz, Greenspan, et al., 1991^50^ | | | | | | | | | P | | | | | | | | | N
Barr, Lopez, Rua-Dobles, et al., 1992^15^ | | | | | | | | | | | | | | | | PN
Glick, Muzyka, Lurie, et al., 1994^18^ | | | | | | | | | | | | | | | NP
Kirby, Munoz, Detels, et al., 1994^83^ | | | | | | | | | P | | | | | | | | | | N
Kolokotronis, Kioses, Antoniades, et al., 1994^47^ | | | | | | | | | | | | | | | | | | | PN
Begg, Panageas, Mitchell-Lewis, et al., 1996^52^ MSM ^a^ IDU ^a^ | | | | | | | | | P | P | | N | | | | | N
Howell, Jandinski, Palumbo, et al., 1996^82^ | | | | | | | | | | | | | P | | | N
Phelan, Begg, Lamster, et al., 1997^85^ MSM ^a^ IDU ^a^ | | | | | | | | P | P
Schuman, Sobel, Ohmit, et al., 1998^84^ | | | | | | | | P | | | | | | | | | | N
Schuman, Ohmit, Sobel, et al., 1998^51^ | | | | | | | | P | | | | | | | | | | N

a MSM = men who have sex with men; IDU = injected drug user

b NR = not reported; X = sensitivity; O = specificity

The range of NPVs is from 61 to 90 percent (a 29 percentage point spread) and considerably smaller than for PPVs. However, all but four of the NPVs are clustered between 84 and 90 percent. This suggests that from 10 to 39 percent of HIV-positive persons with oral candidiasis have CD4 cell counts of 200 cells/mm^3^ or higher and are not yet severely immunosuppressed.

### Results for Hairy Leukoplakia

Six of the 10 studies reported on the association between hairy leukoplakia and CD4 cell count.^15,18,47,50 - 52^ One study^52^ reported sensitivity, specificity, and predictive values separately for homosexual men and intravenous drug users. The prevalence of hairy leukoplakia among the study populations ranged from 7 to 22 percent. The prevalence of CD4 cell counts <200 cells/mm^3^ ranged from 17 to 53 percent. Sensitivities, specificities, and predictive values were similar among the homosexual men and intravenous drug user groups reported in the Begg et al.^52^ study.

Table 13 shows the sensitivities and specificities for hairy leukoplakia as a predictor of CD4 cell count <200 cells/mm^3^. Across the six studies, sensitivities and specificities were fairly consistent. The sensitivities ranged from 13 to 34 percent, and the specificities ranged from 83 to 95 percent. Thus, a high percentage of persons who did not have CD4 cell counts <200 cells/mm^3^ did not have hairy leukoplakia, but a high percentage of persons who had CD4 cell counts <200 cells/mm^3^ did not have hairy leukoplakia. As a predictor of CD4 cell count <200 cells/mm^3^, hairy leukoplakia had a low percentage of true positives but a high percentage of true negatives.

Table 13. Summary of Sensitivity and Specificity in Articles Using Hairy Leukoplakia as an Indicator of CD4 Cell Count <200 cells/mm3

Authors and Year | Percentages ^b^
Authors and Year | 0 | 5 | 10 | 15 | 20 | 25 | 30 | 35 | 40 | 45 | 50 | 55 | 60 | 65 | 70 | 75 | 80 | 85 | 90 | 95 | 100
Feigal, Katz, Greenspan, et al., 1991^50^ | | | | | | | | X | | | | | | | | | | O
Barr, Lopez, Rua-Dobles, et al., 1992^15^ | | | | | | X | | | | | | | | | | | | O
Glick, Muzyka, Lurie, et al., 1994^18^ | | | | | | X | | | | | | | | | | | | | O
Kolokotronis, Kioses, Antoniades, et al., 1994^47^ | | | | | X | | | | | | | | | | | | | O
Begg, Panageas, Mitchell-Lewis, et al., 1996^52^ MSM^a^ IDU^a^ | | | | | X | X | | | | | | | | | | | | | O | O
Schuman, Ohmit, Sobel, et al., 1998^51^ | | | | X | | | | | | | | | | | | | | | | O

a MSM = men who have sex with men; IDU = injected drug user

b NR = not reported; X = sensitivity; O = specificity

Table 14 summarizes the positive and negative predictive values for hairy leukoplakia. PPVs ranged from 29 to 70 percent, with four of the values below 50 percent. NPVs ranged from 51 to 86 percent. Generally, NPVs were higher than PPVs.

Table 14. Summary of Positive and Negative Predictive Values in Articles Using Hairy Leukoplakia as an Indicator of CD4 Cell Count <200 cells/mm3

Authors and Year | Percentages ^b^
Authors and Year | 0 | 5 | 10 | 15 | 20 | 25 | 30 | 35 | 40 | 45 | 50 | 55 | 60 | 65 | 70 | 75 | 80 | 85 | 90 | 95 | 100
Feigal, Katz, Greenspan, et al., 1991^50^ | | | | | | | P | | | | | | | | | | | | N
Barr, Lopez, Rua-Dobles, et al., 1992^15^ | | | | | | | | | P | | | | | | N
Glick, Muzyka, Lurie, et al., 1994^18^ | | | | | | | | | | | | N | | | P
Kolokotronis, Kioses, Antoniades, et al., 1994^47^ | | | | | | | P | | | | | | | | | N
Begg, Panageas, Mitchell-Lewis, et al., 1996^52^ MSM ^a^ IDU ^a^ | | | | | | | | | | | | P P | N | | | N
Schuman, Ohmit, Sobel, et al., 1998^51^ | | | | | | | | P | | | | | | | | | | N

a MSM = men who have sex with men; IDU = injected drug user

b NR = not reported; X = sensitivity; O = specificity

### Results for Necrotizing Ulcerative Periodontitis

Two studies reported on necrotizing ulcerative periodontitis (NUP).^18,52^ The study by Begg et al.^52^ reported results separately for homosexual men and intravenous drug users. In the study by Glick et al.,^18^ 67 percent of the subjects were male homosexuals/bisexuals. The study by Begg et al. reported only four cases of NUP among the 82 homosexual men and only four cases among the intravenous drug users. No cases of NUP were reported among the 87 intravenous drug users with a CD4 cell count <200 cells/mm^3^. In the study by Glick et al., 41 of the 454 patients had NUP. The prevalence of a CD4 cell count <200 cells/mm^3^ was 41 percent in the study by Begg et al. and 53 percent in the study by Glick et al.

As shown in Table 15, the sensitivities reported in these studies were very low (0 to 16 percent), whereas the specificities were very high (92 to 99 percent). Only a few patients with a CD4 cell count <200 cells/mm^3^ had NUP, while most of the patients with a CD4 cell count equal to or greater than 200 cells/mm^3^ did not have NUP.

Table 15. Summary of Sensitivity and Specificity in Articles Using Necrotizing Ulcerative Periodontitis as an Indicator of CD4 Cell Count <200 cells/mm3

Authors and Year | Percentages ^b^
Authors and Year | 0 | 5 | 10 | 15 | 20 | 25 | 30 | 35 | 40 | 45 | 50 | 55 | 60 | 65 | 70 | 75 | 80 | 85 | 90 | 95 | 100
Glick, Muzyka, Lurie, et al., 1994^18^ | | | | | X | | | | | | | | | | | | | | | | O
Begg, Panageas, Mitchell-Lewis, et al., 1996^52^ MSM ^a^ IDU ^a^ | X | | | X | | | | | | | | | | | | | | | | O | O

a MSM = men who have sex with men; IDU = injected drug user

b NR = not reported; X = sensitivity; O = specificity

Predictive values are shown in Table 16. The probability that a patient with NUP had a CD4 cell count <200 cells/mm^3^ or PPV was 0.80 among the homosexual men in the study by Begg et al. and 0.95 among the patients in the study by Glick et al. Because none of the patients with CD4 <200 cells/mm^3^ among the intravenous drug users had NUP, the PPV for these patients was 0.^52^ The probability that a patient without NUP did not have a CD4 cell count <200 cells/mm^3^, or NPV, ranged from 0.52 to 0.70.

Table 16. Summary of Positive and Negative Predictive Values in Articles Using Necrotizing Ulcerative Periodontitis as an Indicator of CD4 Cell Count <200 cells/mm3

Authors and Year | Percentages ^b^
Authors and Year | 0 | 5 | 10 | 15 | 20 | 25 | 30 | 35 | 40 | 45 | 50 | 55 | 60 | 65 | 70 | 75 | 80 | 85 | 90 | 95 | 100
Glick, Muzyka, Lurie, et al., 1994^18^ | | | | | | | | | | | | N | | | | | | | | P
Begg, Panageas, Mitchell-Lewis, et al., 1996^52^ MSM ^a^ IDU ^a^ | P | | | | | | | | | | | | | N | N | | P

a MSM = men who have sex with men; IDU = injected drug user

b NR = not reported; X = sensitivity; O = specificity

### Results for Oral Ulcers

Four studies examined the association between oral ulcers and CD4 cell count.^18,50 - 52^ One study^52^ reported sensitivity, specificity, and predictive values separately for homosexual men and intravenous drug users. The prevalence of oral ulcers ranged from 2 to 18 percent in these studies. The prevalence of a CD4 cell count <200 cells/mm^3^ ranged from 17 to 53 percent.

Table 17 summarizes the sensitivities and specificities for oral ulcers as a predictor of a CD4 cell count <200 cells/mm^3^. Sensitivities were low, ranging from 0 to 21 percent, while the specificities were high, ranging from 88 to 100 percent. This indicates a high proportion of false negatives and a low proportion of false positives.

Table 17. Summary of Sensitivity and Specificity in Articles Using Oral Ulcers as an Indicator of CD4 Cell Count <200 cells/mm3

Authors and Year | Percentages ^b^
Authors and Year | 0 | 5 | 10 | 15 | 20 | 25 | 30 | 35 | 40 | 45 | 50 | 55 | 60 | 65 | 70 | 75 | 80 | 85 | 90 | 95 | 100
Feigal, Katz, Greenspan, et al., 1991^50^ | X | | | | | | | | | | | | | | | | | | | | O
Glick, Muzyka, Lurie, et al., 1994^18^ | | | X | | | | | | | | | | | | | | | | | | O
Begg, Panageas, Mitchell-Lewis, et al., 1996^52^ MSM ^a^ IDU ^a^ | | | X | | X | | | | | | | | | | | | | | O | O
Schuman, Ohmit, Sobel, et al., 1998^51^ | | | X | | | | | | | | | | | | | | | | | | O

a MSM = men who have sex with men; IDU = injected drug user

b NR = not reported; X = sensitivity; O = specificity

Table 18 shows the positive and negative predictive values. PPVs ranged from 0 to 100 percent, and NPVs ranged from 52 to 84 percent.

Table 18. Summary of Positive and Negative Predictive Values for Articles Using Oral Ulcers as an Indicator of CD4 Cell Count <200 cells/mm3

Authors and Year | Percentages ^b^
Authors and Year | 0 | 5 | 10 | 15 | 20 | 25 | 30 | 35 | 40 | 45 | 50 | 55 | 60 | 65 | 70 | 75 | 80 | 85 | 90 | 95 | 100
Feigal, Katz, Greenspan, et al., 1991^50^ | P | | | | | | | | | | | | | | | | | N
Glick, Muzyka, Lurie, et al., 1994^18^ | | | | | | | | | | | | N | | | | | | | | | P
Begg, Panageas, Mitchell-Lewis, et al., 1996^52^ MSM ^a^ IDU ^a^ | | | | | | | | P | | | | P | | N | | N
Schuman, Ohmit, Sobel, et al., 1998^51^ | | | | | | | | | P | | | | | | | | | N

a MSM = men who have sex with men; IDU = injected drug user

b NR = not reported; X = sensitivity; O = specificity

### Results for Linear Gingival Erythema

Studies by Begg and colleagues^52^ and Schuman and colleagues^51^ examined the association between linear gingival erythema (LGE) and CD4 cell count. In the former study, results are reported separately for homosexual men and intravenous drug users; the prevalence of LGE was 13 percent among the homosexual men and 34 percent among the intravenous drug users. The prevalence was 14 percent among the patients (all women) in the study by Schuman et al.

Table 19 shows the sensitivities and specificities for LGE as a predictor of CD4 cell count <200 cells/mm^3^. The sensitivities were low (13 to 34 percent), and the specificities were relatively high (62 to 90 percent). There was a high percentage of false negatives and a much lower proportion of false positives.

Table 19. Summary of Sensitivity and Specificity in Articles Using Linear Gingival Erythema as an Indicator of CD4 Cell Count <200 cells/mm3

Authors and Year | Percentages ^b^
Authors and Year | 0 | 5 | 10 | 15 | 20 | 25 | 30 | 35 | 40 | 45 | 50 | 55 | 60 | 65 | 70 | 75 | 80 | 85 | 90 | 95 | 100
Begg, Panageas, Mitchell-Lewis, et al., 1996^52^ MSM ^a^ IDU ^a^ | | | | | X | | | X | | | | | | O | | | | | O
Schuman, Ohmit, Sobel, et al., 1998^51^ | | | | X | | | | | | | | | | | | | | | O

a MSM = men who have sex with men; IDU = injected drug user

b NR = not reported; X = sensitivity; O = specificity

As shown in Table 20, the PPVs ranged from 18 to 55 percent, while the NPVs ranged from 61 to 82 percent.

Table 20. Summary of Positive and Negative Predictive Values in Articles Using Linear Gingival Erythema as an Indicator of CD4 Cell Count <200 cells/mm3

Authors and Year | Percentages ^b^
Authors and Year | 0 | 5 | 10 | 15 | 20 | 25 | 30 | 35 | 40 | 45 | 50 | 55 | 60 | 65 | 70 | 75 | 80 | 85 | 90 | 95 | 100
Begg, Panageas, Mitchell-Lewis, et al., 1996^52^ MSM ^a^ IDU ^a^ | | | | | P | | | | | | P | N | | N
Schuman, Ohmit, Sobel, et al., 1998^51^ | | | | | P | | | | | | | | | | | | N

a MSM = men who have sex with men; IDU = injected drug user

b NR = not reported; X = sensitivity; O = specificity

### Results for Kaposi's Sarcoma

Three articles examined the relationship between Kaposi's sarcoma and CD4 cell count.^18,50,52^ The study by Begg et al.^52^ reported results separately for homosexual men and intravenous drug users. Kaposi's sarcoma is a rare disease even among HIV-positive patients. The prevalence of Kaposi's sarcoma ranged from 0 to 7 percent. No cases were reported among the intravenous drug users in the study by Begg et al.

The sensitivities and specificities for these studies are shown in Table 21. Because Kaposi's sarcoma is so rare, few patients who had a CD4 cell count <200 cells/mm^3^ presented with the oral disease. This is evident in the low sensitivities, which ranged from 7 to 12 percent. However, as indicated by the perfect or near perfect specificities, which ranged from 99 to 100 percent, false positives essentially did not occur.

Table 21. Summary of Sensitivity and Specificity in Articles Using Kaposi's Sarcoma as an Indicator of CD4 Cell Count <200 cells/mm3

Authors and Year | Percentages ^b^
Authors and Year | 0 | 5 | 10 | 15 | 20 | 25 | 30 | 35 | 40 | 45 | 50 | 55 | 60 | 65 | 70 | 75 | 80 | 85 | 90 | 95 | 100
Feigal, Katz, Greenspan, et al., 1991^50^ | | | X | | | | | | | | | | | | | | | | | | O
Glick, Muzyka, Lurie, et al., 1994^18^ | | | | X | | | | | | | | | | | | | | | | | O
Begg, Panageas, Mitchell-Lewis, et al., 1996^52^ MSM ^a^ IDU ^a^ | n/a | | X | | | | | | | | | | | | | | | | | | O n/a

a MSM = men who have sex with men; IDU = injected drug user

b NR = not reported; X = sensitivity; O = specificity

The predictive values are summarized in Table 22. As indicated by the high PPVs (73 to 100 percent), if an HIV-positive patient presents with Kaposi's sarcoma, the probability of that patient having a CD4 cell count <200 cells/mm^3^ is very high. Also, if the person does not present with Kaposi's sarcoma, the probability of not having a CD4 cell count <200 cells/mm^3^ is also reasonably high, ranging from 61 to 84 percent.

Table 22. Summary of Sensitivity and Specificity in Articles Using Kaposi's Sarcoma as an Indicator of CD4 Cell Count <200 cells/mm3

Authors and Year | Percentages ^b^
Authors and Year | 0 | 5 | 10 | 15 | 20 | 25 | 30 | 35 | 40 | 45 | 50 | 55 | 60 | 65 | 70 | 75 | 80 | 85 | 90 | 95 | 100
Feigal, Katz, Greenspan, et al., 1991^50^ | | | | | | | | | | | | | | | | P | | N
Glick, Muzyka, Lurie, et al., 1994^18^ | | | | | | | | | | | | | | | | | | N | | P
Begg, Panageas, Mitchell-Lewis, et al., 1996^52^ MSM ^a^ IDU ^a^ | n/a | | | | | | | | | | | | | N | | | | | | | P n/a

a MSM = men who have sex with men; IDU = injected drug user

b NR = not reported; X = sensitivity; O = specificity

## Efficacy of Antifungal Agents Used to Prevent Oral Candidiasis: Key Question 3A

### Description of the Literature

Of the six clinical trials that evaluated the efficacy of antifungal medications used to prevent oral candidiasis in patients with HIV/AIDS, five were double-blind, placebo-controlled, randomized clinical trials,^53,54,55,90,91^ and one was an open-label, randomized clinical trial.^92^ The total sample size for each study ranged from a low of 14^91^ to a high of 323,^55^ with participants drawn from both community clinic and hospital settings. Men made up the entire subject pool in four studies,^53,54,90,91^ women were the entire subject population in one study,^55^ and the remaining study did not report the subjects' gender.^92^ Level of immunosuppression and use of antiretroviral therapy were fairly similar between active and placebo groups, where reported.

Prophylactic drug treatment lasted from 12 weeks^54^ to more than a year,^55^ with follow-up evaluation intervals varying by study. End points for new oral candidiasis diagnosis typically required new signs and/or symptoms of oral candidiasis, confirmed by such microbiologic evidence as positive Candida culture, positive potassium hydroxide fungal smear (KOH prep), or additional colony-forming units in oral washings. One study merely reported prophylactic failures as "unsuccessful clinical response and infection recurred".^91^

One study^53^ assessed the efficacy of two dose regimens of nystatin pastilles versus placebo, whereas varying doses of fluconazole were compared with placebo in the other five studies. Fluconazole dose regimens tested included 100 mg/week,^54^ 150 mg/week,^90,91^ 200 mg/week,^55^ 50 mg/day,^92^ and 100 mg/day.^92^ Four studies, in which all subjects had previously had oral candidiasis, evaluated prophylaxis against recurrence.^54,90-92^ The remaining two studies evaluated antifungal efficacy for prevention of first infections in approximately half of the subjects and against recurrent oral candidiasis in the other half.^53,55^

### Limitations in the Literature

Several issues and limitations were identified in the literature to address the question of the efficacy of antifungal prophylaxis for oral candidiasis.

None of the studies reported any assessment of compliance with the prescribed study regimen in either the drug arm or the placebo arm. Compliance is an important issue because prophylaxis failure may be due to the patients' inability or unwillingness to adhere to the drug regimen rather than a true reflection of drug efficacy.

None of the trials evaluated the efficacy of antifungal prophylaxis among patients using the newest protease inhibitors, which contain the highly active antiretroviral therapy (HAART), because even the most recent study^55^ was conducted during May 1992 and January 1994. During a 1-year follow-up in a case-control analysis of the effect of HAART on preventing oral candidiasis recurrences, oral candidiasis was diagnosed in 2 (7 percent) of 29 protease inhibitor-treated patients and 23 (36 percent) of 64 nonprotease inhibitor-treated patients (p < 0.001).^93^ It has been suggested that in addition to their effect on improving immunocompetence, the protease inhibitors in these newer therapies may have in vitro and in vivo anticandidal activity.^94^

Concern has arisen recently over the development of azole-resistant fungal strains as a consequence of the practice of chronic suppressive therapy. Few of the clinical trials involving fluconazole assessed the specific candidal species, such as proportion of C. albicans versus other non-C. albicans species, present in recurrent or new infections. Marriott and coworkers^90^ reported no significant difference between non-C. albicans relapse in the fluconazole-treated patients (27 percent) compared with placebo-treated patients (13 percent). In the Just-Nubling and coworkers^92^ study, C. albicans grew from oral washings in all relapses, and C. tropicalis, C. glabrata, or C. krusei also occurred, yielding pathogen counts of >1,000 in five patients in the control group, three in the 50 mg/day fluconazole group, and four in the 100 mg/day fluconazole group.

No studies reported results of drug resistance testing for oropharyngeal candidal species in cases of prophylactic failure. Although Schuman and coworkers^55^ provided vaginal speciation information and in vitro resistance data for vaginal species collected during a substudy examining in vitro resistance to fluconazole, neither species patterns nor their in vitro drug resistance characteristics were reported for oropharyngeal candidiasis recurrences.

No cost-effectiveness analyses for antifungal prophylaxis against oral candidiasis in HIV/AIDS patients were conducted. A recent analysis of the cost-effectiveness of preventing several AIDS-related opportunistic infections^95^ suggested that 100 mg/day fluconazole (even in patients at higher risk, with CD4 cell counts of <50 cells/mm^3^) is generally not recommended for primary prophylaxis against more serious fungal infections, including esophageal and systemic candidiasis, cryptococcus, histoplasmosis, and coccidiomycosis. In this analysis, to achieve a cost-effectiveness threshold of $50,000 per quality-adjusted life-year saved, the cost of fluconazole ($2,372/year, according to the AIDS Cost and Services Utilization Survey) would have to be reduced more than 50 percent, to approximately $100 per month.

No studies were identified that met inclusion criteria that evaluated the efficacy of clotrimazole, amphotericin B suspension, ketoconazole, or itraconazole formulations as prophylactic measures for oral candidiasis in persons with HIV/AIDS.

### Results for Antifungal Preventive Efficacy

MacPhail and coworkers^53^ found that over a 20-week follow-up period, a multivariate proportional hazards model based on 121 subjects, 48 of whom developed oral candidiasis during follow-up, indicated that (after controlling for CD4 cell counts, Candida carriage, and history of clinical oral candidiasis), nystatin is effective in delaying time to oral candidiasis (p < 0.001). On average, one nystatin pastille a day reduced the hazard of oral candidiasis to 60 percent of the hazard of the placebo group. Two nystatin pastilles per day (400,000 U/day) reduced the hazard to 35 percent of the hazard of the placebo group.

Stevens and coworkers^54^ assessed the effectiveness of 100 mg fluconazole per day compared with placebo in preventing recurrent oral candidiasis over 12 weeks among a small group of 25 men. They found that significantly fewer subjects on fluconazole (0 percent) than on placebo (61.5 percent) developed recurrences. Gastrointestinal and neurological side effects were slightly greater among fluconazole users than among the placebo group.

Marriott and coworkers^90^ assessed the efficacy of 150 mg fluconazole per week over 6 months in the prevention of oropharyngeal candidiasis relapse after successful treatment of an acute episode among 84 men with moderate to severe HIV infection. Of 73 evaluable patients, the median time to relapse was >168 days for the fluconazole group and 37 days for the placebo group. For those completing 6 months of prophylactic treatment, significantly fewer in the fluconazole group (42 percent) relapsed, compared with those in the placebo group (96 percent). Adverse event rates were reported as being 0.3 adverse events per patient-month for fluconazole versus 0.2 adverse events per patient-month for placebo.

Leen and coworkers^91^ examined the effectiveness of 150 mg fluconazole per week over 24 weeks in the prevention of oropharyngeal candidiasis in a maintenance phase following a demonstrated clinical cure with 50 mg/day fluconazole over 14 to 28 days. Randomization to placebo or fluconazole maintenance occurred 7 days after treatment ended (with evidence of clinical cure but no report of mycological status) for the acute phase. Patients were requested to inform their clinician immediately if symptoms of fungal infection recurred and to return monthly for study visits. All patients on placebo had a recurrence, four within 3 weeks and one at 18 weeks. Of patients on fluconazole, two relapsed at 4 and 5 weeks, two withdrew at 16 weeks with no recurrence, and five were clinically successful, with recurrence prevented to the end of the study at 24 weeks. Fluconazole resulted in a significant reduction in relapse rate over placebo.

Schuman and coworkers^55^ assessed the efficacy of 200 mg fluconazole weekly for a median of 17 months in the prevention of mucosal candidiasis in 323 women with HIV/AIDS. Although outcomes for vaginal and esophageal candidiasis were also included in this study, only the data for oropharyngeal candidiasis were reviewed. Weekly fluconazole was effective in preventing oropharyngeal candidiasis (relative risk [RR], 0.50; 95 percent confidence interval [CI], 0.33 to 0.74; p < 0.001). Confirmed oropharyngeal candidiasis recurrence occurred in 25.9 percent of the fluconazole group, compared with 42.2 percent of the placebo group. Infections that were considered confirmed or probably clinically resistant to fluconazole occurred in 3.7 percent of the fluconazole group and 4.3 percent of the placebo group. Of the 13 patients from both groups who had infections clinically resistant to fluconazole, 12 had oropharyngeal or esophageal candidiasis, with C. albicans isolated from 9 of 11 cultures that were available. Of the same 13 patients who developed resistant infections, 7 had CD4 cell counts <10 cells/mm^3^, 3 had CD4 cell counts between 10 and 50, and the remaining 3 had CD4 cell counts between 50 and 300. Although 25 percent of the patients receiving fluconazole and 14 percent of the patients on placebo had at least one adverse event, this was not significant. No specific toxicities were reported.

Just-Nubling and coworkers^92^ evaluated the efficacy in an open-label fashion of two different regimens of fluconazole (50 mg/day and 100 mg/day) in preventing oral candidiasis recurrences over a minimum of 6 months among 65 patients with advanced stages of HIV disease (CD4 <100 cells/mm^3^). Prophylaxis with fluconazole reduced the occurrence of oral candidiasis. In 20 (95.2 percent) of 21 placebo-treated patients, a total of 60 relapses occurred. In the 50 mg/day fluconazole group, 2 (11.1 percent) of 18 patients had four relapses. In the 100 mg/day fluconazole group, 4 (21.1 percent) of 19 had nine relapses. There were no significant differences in the relapse rate between the 50 and 100 mg/day dose regimens.

## Effectiveness of Antifungal Agents Used to Treat Oral Candidiasis: Key Question 3B

### Description of the Literature

Of the 12 clinical trials that evaluated the effectiveness of antifungal medications used to treat oral candidiasis in patients with HIV/AIDS, all were drug comparison trials. Three were double-blind, randomized clinical trials;^96-98^ 5 were examiner-blinded;^99 - 103^ and 4 were open-label, randomized clinical trials, using no blinding.^104 - 107^ Total sample sizes ranged from a low of 37^97^ to a high of 334,^101^ with participants drawn from a variety of settings, including private practice, community clinics, and hospitals. All studies but one,^107^ which was conducted in a hospital in Zaire among AIDS patients, were undertaken in developed nations, including the United States, Canada, or Europe. Men and women were included in all studies where reported. Two studies^103,106^ assessed drug efficacy in infants and children, whereas the remainder were conducted with adult populations. Levels of immunosuppression were fairly similar between groups, where reported.

Therapeutic drug regimens in most of the study arms lasted 14 days;some evaluated a 28-day course, some a 7-day course, and some a single dose. Evaluation intervals selected varied by study. End points for oral candidiasis cure included both clinical and mycologic cure. Clinical cure typically required absence of signs and/or symptoms of oral candidiasis. Mycologic cure required evidence such as negative Candida culture or negative KOH microscopic preparation. Topical and systemic antifungals were evaluated in the 12 studies that met the inclusion/exclusion criteria, as shown in Table 23. Fluconazole at varying doses in capsule form and as an oral suspension was the most commonly used drug for efficacy or equivalence comparisons. Other drugs assessed include aqueous gentian violet, nystatin, clotrimazole, amphotericin B, ketoconazole, and itraconazole.

Table 23. Randomized Clinical Trials of Antifungal Medications Used to Treat Oropharyngeal Candidiasis in Patients with HIV/AIDS

Antifungal Drugs ^a^
Authors and Year | Gentian Violet | Nystatin | Clotrimazole | Amphotericin B | Ketoconazole | Fluconazole | Itraconazole
Pons, Greenspan, Lozada-Nur, et al., 1997^100^ | | L | | | | L
Flynn, Cunningham, Kerkering, et al., 1995^103^ | | L | | | | L
Nyst, Perriens, Kimputu, et al., 1992^107^ | L | L | | | | X
Koletar, Russell, Fass, et al., 1990^104^ | | | T | | | C
Pons, Greenspan, Debruin, 1993^101^ | | | T | | | | C
Murray, Koletar, Mallegol, et al., 1997^102^ | | | T | | | | L
De Wit, Weerts, Goossens, et al., 1989^97^ | | | | | C | C
Hernandez-Sampelayo 1994^106^ | | | | | L | L
De Repentigny, Ratelle, Baril et al., 1996^98^ | | | | | C | | C
Phillips, De Beule, Frechette, et al., 1998^96^ | C | L | | | | C | L
Graybill, Vazquez, Darouiche, et al., 1998^99^ | C | L | | | | C | L
De Wit, O'Doherty, De Vroey, et al., 1998^108^ | | | | | | X | X

a C = capsule or table; L = liquid suspension or oral solution; T = troche (lozenge); X = unspecified oral dose.

### Limitations in the Literature

Several issues and limitations were identified in the literature to address the question of the effectiveness of various antifungal drugs used in the treatment of oral candidiasis.

HIV disease status (clinical disease and level of immunosuppression) was not reported in approximately half of the studies.

Antiretroviral therapy use was reported in only two studies,^98,104^ and in none involving the highly active antiretroviral therapy (HAART) protease inhibitors.

Assessment of compliance with the prescribed drug therapy was not universally undertaken and may have had an impact on effectiveness outcomes.

Several studies had low enrollment at randomization and subsequent attrition of subjects for clinical and mycological evaluation, creating underpowered studies and precluding statistical comparison of clinical and mycological cure rates between treatment arms. Relapse rate comparisons particularly may have been underpowered.

Speciation of candidal organisms in treatment failures was rare, and no drug resistance testing was undertaken. Flynn and coworkers^103^ reported that fungal isolates were saved but no susceptibility testing was done. They also reported that the seven fluconazole recipients in their study involving infants and children with non-C. albicans isolates were less likely to have successful outcomes compared with those with only C. albicans isolates (p < 0.001). In this study, no C. krusei was isolated at baseline; however, three patients receiving fluconazole had this isolate in cultures after 7 days of treatment.

No cost-effectiveness analyses for antifungal treatment of oral candidiasis in HIV/AIDS patients were conducted, although Nyst and coworkers^107^ report on costs associated with gentian violet, nystatin, and ketoconazole in Africa that could have a major impact on therapy selected.

No studies were identified that met inclusion criteria that evaluated the effectiveness of amphotericin B suspension or intravenous amphotericin B in persons with HIV/AIDS.

## Results for Antifungal Treatment Effectiveness

### Nystatin Versus Fluconazole

Pons and coworkers^100^ compared the efficacy of a 14-day regimen of either once daily 100 mg of fluconazole liquid suspension or four times daily 500,000 units of liquid nystatin in a randomized, examiner-blinded clinical trial involving 167 HIV-infected patients with oropharyngeal candidiasis. Fluconazole use resulted in significantly (p < 0.001) more clinical cures (87 percent vs. 5 percent), mycological eradication of Candida organisms (60 percent vs. 6 percent), and fewer relapses noted on day 28 (18 percent vs. 44 percent) than for nystatin users. Relapse rates were not significantly different by day 42 (fluconazole, 27 percent; nystatin, 11 percent). Subjects were matched for oropharyngeal candidiasis disease severity, but not HIV disease severity.

Flynn and coworkers^103^ compared a single daily dose of fluconazole oral suspension (2 - 3 mg/kg per day after loading dose) with 400,000 units four times a day of nystatin over 14 days in the treatment of oropharyngeal candidiasis in 182 immunocompromised infants and children, ages 5 months to 14 years, in a 32-center, randomized, observer-blinded trial. Efficacy results for the 64 HIV-infected subjects were reported as a subgroup analysis. Among these patients, fluconazole was superior to nystatin in achieving clinical cure (80 percent vs. 29 percent, respectively; p < 0.001). Higher rates of mycological eradication were also found for fluconazole among the HIV-infected subgroup (83 percent vs. 5 percent for nystatin; p < 0.001).

### Nystatin Versus Gentian Violet Versus Ketoconazole

Nyst and coworkers^107^ conducted an open-label, randomized study among 141 AIDS inpatients in a hospital in Zaire, of whom 41.6 percent died of AIDS during the 14-day course of therapy for oropharyngeal or oropharyngeal and esophageal candidiasis, leaving 72 evaluable patients. After 14 days of therapy, oropharyngeal lesions had disappeared in similar portions of patients treated with 0.5 percent aqueous solution gentian violet mouth rinse twice daily (42 percent) and 200 mg/day oral ketoconazole (43 percent), and in a significantly (p < 0.05) lower portion of patients treated with 200,000 units of nystatin mouth rinse four times daily (9 percent). Microscopy was conducted with KOH prep at baseline and after 14 days of therapy, indicating significantly (p < 0.05) more microscopic Candida clearance among users of gentian violet (62 percent) and ketoconazole (57 percent) than nystatin (13 percent).

### Clotrimazole Versus Fluconazole

Koletar and coworkers^104^ reported on a small, randomized, open-label trial comparing the efficacy of 100 mg fluconazole daily and 10 mg clotrimazole five times daily for 14 days among 39 HIV-infected subjects for the treatment of oropharyngeal candidiasis. Clinical resolution at the end of treatment was significantly (p = 0.018) better among fluconazole users (100 percent) than clotrimazole troche users (65 percent). Additionally, fluconazole produced significantly (p = 0.004) greater mycological eradication rates (75 percent) than did clotrimazole (20 percent). Fluconazole-treated patients were more likely to remain disease-free during follow-up than those treated with clotrimazole (p = 0.014 at 28 days and p = 0.074 at 42 days); prolonged clinical responses were correlated with mycological eradication. This study was an earlier single-center report of outcomes from the multicenter study of the same design reported by Pons and coworkers^101^ described below.

Pons and coworkers^101^ reported on a prospective multicenter, randomized, examiner-blinded comparison of 14 days of fluconazole 100 mg capsule daily and clotrimazole 10 mg troche five times daily among 334 HIV-infected adults with oropharyngeal candidiasis. Among patients fairly well-matched for age, gender, race, baseline severity of oral discomfort, lesions and erythema due to oral candidiasis, and previous diagnosis of AIDS, both treatments were clinically effective at 14 days (91 percent clinical cure for fluconazole and 85 percent clinical cure for clotrimazole). Mycological outcome (eradication of Candida) was significantly better (p = 0.005) for fluconazole (65 percent) than for clotrimazole (48 percent). Among patients evaluable for relapse at day 28, significantly more (p < 0.001) patients on clotrimazole (50 percent) had relapsed compared with patients on fluconazole (18 percent). With fewer patients remaining to evaluate at day 42, 34 percent and 40 percent, respectively, of fluconazole and clotrimazole groups had relapsed. C. albicans was found in 98 percent of baseline cultures, compared with 93 percent of relapse cultures. Adverse event rates at 18 percent and 19 percent, respectively, for fluconazole and clotrimazole were comparable.

### Clotrimazole Versus Itraconazole

Murray and coworkers^102^ reported on the results of a multicenter, examiner-blinded, randomized clinical trial of 14-day therapeutic courses of itraconazole oral solution 200 mg daily compared with clotrimazole troches five times daily for the treatment of oropharyngeal candidiasis in 162 immunocompromised patients, the majority of whom (123) were HIV-infected. Results are reported separately for the HIV-infected subjects. HIV/AIDS patients who received itraconazole oral solution had significantly greater rates of negative culture (64 percent vs. 29 percent, respectively) and clinical response plus negative culture (55 percent vs. 28 percent, respectively), compared with those who received clotrimazole (p < 0.01).

### Ketoconazole Versus Fluconazole

De Wit and coworkers^97^ conducted a double-blind, randomized comparison of the efficacy of 50 mg fluconazole daily versus 200 mg ketoconazole daily for 28 days to treat oropharyngeal candidiasis in a small population of 40 patients with AIDS-related complex (ARC) or an AIDS diagnosis in 1986 - 88. There was a significantly (p = 0.0445) better clinical response rate among patients on the fluconazole regimen (100 percent) than on the ketoconazole regimen (75 percent), although 46 percent of the fluconazole-treated patients relapsed within 30 days, compared with only 11 percent of ketoconazole-treated patients. Negative culture was obtained at the end of treatment in 87 percent of the evaluated patients in the fluconazole group and 69 percent of those evaluated in the ketoconazole group.

Hernandez-Sampelayo^106^ evaluated the clinical and mycologic response of oral candidiasis to fluconazole oral suspension (3 mg/kg per day; mean, 14 days; range, 6 to 33 days) and ketoconazole oral suspension (7 mg/kg per day; mean, 16 days; range, 5 to 49 days) in 46 pediatric patients with either HIV or AIDS. This small, multicenter, open-label, randomized controlled trial suggested comparable efficacy and safety of the two drugs in children, although fluconazole users had higher clinical and mycological cure rates (88 percent and 71 percent, respectively), at the end of treatment over variable periods of 5 to 49 days, than those treated with ketoconazole (81 percent and 57 percent, respectively). By 4 weeks post-treatment, 50 percent of fluconazole users had relapsed, compared with 41 percent of ketoconazole users.

### Ketoconazole Versus Itraconazole

De Repentigny and coworkers^98^ compared the efficacy of a 200 mg capsule of itraconazole daily with a 100 mg tablet of ketoconazole daily for 14 days in the treatment of oropharyngeal and/or esophageal candidiasis in a randomized, double-blind, multicenter clinical trial in Montreal that enrolled HIV-infected adults from hospitals and private practices. Outcomes for oropharyngeal candidiasis were reported for 98 evaluable subjects. Oropharyngeal infection was clinically cleared in 21 days in marginally more (p = 0.061) subjects on itraconazole (71 percent) than on ketoconazole (60 percent). At 14 days, cultures were negative in 62 to 63 percent of both groups. Relapse rates were similar, and adverse events for both drugs were mild.

### Itraconazole Versus Fluconazole

Phillips and coworkers^96^ conducted a multicenter, double-blind, randomized clinical trial that enrolled 244 HIV-infected adults with oropharyngeal candidiasis to compare antifungal drug efficacy using three arms: 100 mg of itraconazole oral solution twice daily for 7 days, 100 mg of itraconazole oral solution once daily for 14 days, and 100 mg of fluconazole once daily for 14 days. Among evaluable patients, a complete response (clearance of all signs and symptoms) or marked improvement was noted in 90 percent of those on once-daily itraconazole and 90 percent of the fluconazole-treated individuals at the end of 14 days of treatment, compared with 82 percent of those on a 7-day regimen of twice daily itraconazole. This study demonstrated equivalence (p = 0.0024) in terms of clinical response between the 14-day courses of fluconazole and itraconazole. Drug tolerability and early (within 18 days) relapse (34 to 37 percent) were comparable between study groups.

Graybill and coworkers^99^ reported on the outcomes of a multicenter, randomized, examiner-blinded equivalence trial among 179 HIV-infected patients with oropharyngeal candidiasis, treated in one of three arms: 200 mg of itraconazole oral solution daily for 7 days, 200 mg of itraconazole oral solution once daily for 14 days, and 100 mg of fluconazole once daily for 14 days. Both 14-day and 7-day regimens of itraconazole oral solution were equivalent to fluconazole for most efficacy parameters, with a clinical response rate (lesion eradication) of 97 percent for 14 days of itraconazole, 86 percent for 7 days of itraconazole, and 87 percent for 14 days of fluconazole. Approximately half of clinical responders in all groups had relapsed by 1 month after completion of treatment, with slight variations consistent with the drug regimen's ability to result in a culture negative status by the end of treatment.

De Wit and coworkers^108^ compared the efficacy of a single dose of 150 mg of fluconazole with a 7-day regimen of 100 mg daily of itraconazole in the treatment of oropharyngeal candidiasis in an open-label, randomized trial of 40 HIV-infected adults. The fluconazole group produced significantly (p = 0.006) more subjects who were clinically cured (75 percent) or improved (15 percent) on day 8 than did the itraconazole group (24 percent cured, 12 percent improved). Mycological eradication was documented in only one subject from each treatment group at day 8. By the end of 30 days, 30 percent of the fluconazole group had relapsed, compared with 12 percent of the itraconazole group. The authors recognized that one of the major limitations of this study is that 50 percent of the patients on itraconazole were on concomitant medications that potentially affect this drug's bioavailability. Additional limitations include a small number of subjects, short therapeutic courses, the relatively low dose of itraconazole in capsule form, and assessment of clinical and mycological outcomes after a mere 8 days.