# Methodology

## Overview

This chapter documents the procedures that the Research Triangle Institute-University of North Carolina Evidence-based Practice Center (RTI-UNC EPC) used to develop a comprehensive evidence report. The multidisciplinary team that led the preparation of this report consisted of Arthur J. Bonito, Ph.D. (Project Director), Daniel A. Shugars, D.D.S., Ph.D. (Clinical Director), and Lauren L. Patton, D.D.S. (Clinical Consultant). Other members contributing to the effort included James D. Bader, D.D.S., M.P.H. (Scientific Director); Lynn Whitener, Dr.P.H. (Information Specialist); Anne M. Jackman, M.S.W., and Jessica P. Nelson, B.A. (Project Managers); and Kathleen N. Lohr, Ph.D. (EPC Co-Director). Other persons who made important contributions to this effort have been named in the Acknowledgments (Appendix A).

The remainder of this chapter describes how the team reviewed the research currently available to address the key questions on the management of dental patients who are positive for the human immunodeficiency virus (HIV) or living with acquired immune deficiency syndrome (AIDS). To set the framework for the review, we present first the key questions and their underlying causal pathways. This is followed by a detailed description of the literature search process, which includes descriptions of the Medical Subject Headings (MeSH terms) used in the principal search, other search sources, the inclusion and exclusion criteria, and the application of these criteria to the results of the searches. Then we describe what happened once we determined that studies met the inclusion and exclusion criteria and were eligible for abstraction, how we abstracted the data onto data abstraction forms, and then how we transferred selected critical information to evidence tables. The abstraction forms are also described in this chapter.

The chapter also discusses quality issues -- in particular, the RTI-UNC EPC's quality control procedures with regard to determining the eligibility for inclusion, carrying out the data abstraction, and developing a quality-rating scheme for individual studies. An evidence report requires an extensive search of all types of literature. Because the criteria for quality may vary according to the types of study designs appropriate for particular key questions, the RTI-UNC EPC developed quality-rating forms specific to the studies included for each key question in this report. This chapter also describes the article rating systems and their use in the analysis.

## Key Questions and Causal Pathways

We address five key questions in this report and present causal pathways for each. They are based on the issues and concerns discussed briefly in Chapter 1. The questions were initially developed by National Institute of Dental and Craniofacial Research (NIDCR) staff and expert consultants and were refined through consultations with the Agency for Healthcare Research and Quality (AHRQ) Task Order Officer, NIDCR liaison, NIDCR staff involved in the planning of a State of the Science Workshop on management of HIV-positive dental patients that was held in December 2000, and the Technical Expert Advisory Group (TEAG) assembled for this particular topic area (Appendix B).

### Final Key Questions

This evidence report addresses three issues -- risks to HIV-positive patients of invasive oral procedures, oral conditions as markers or indicators of change in HIV status (seroconversion and immunosuppression), and the efficacy or effectiveness of antifungal treatments (prophylactic and curative) for oral candidiasis in HIV-positive patients. As noted in Chapter 1, the second and third topics have been split to cover each of the aspects in parentheses; thus, we focus on five specific key questions.

#### Key Question 1

Are HIV/AIDS patients at increased risk of complications (e.g., local infection, systemic infection, increased bleeding, delayed healing, or alveolitis) from intra-oral dental procedures (e.g., extractions, orthognathic surgery, periodontal therapy, endodontics, prophylaxis, root planing and scaling, and dental implants), compared with similar patients without HIV/AIDS?

#### Key Question 2A

What are the sensitivity, specificity, and positive and negative predictive values of hairy leukoplakia, oral candidiasis, necrotizing ulcerative periodontitis, oral ulcers, and parotid swelling as markers of recent HIV seroconversion (within 12 weeks after exposure)?

#### Key Question 2B

What are the sensitivity, specificity, and positive and negative predictive values of hairy leukoplakia, oral candidiasis, necrotizing ulcerative periodontitis, oral ulcers, parotid swelling, linear gingival erythema, and Kaposi's sarcoma as indicators of severe immunosuppression as measured by CD4 cellcount and plasma viral load in persons with HIV/AIDS?

#### Key Question 3A

What is the efficacy of available antifungal agents -- nystatin formulations, clotrimazole, amphotericin B suspension, ketoconazole, fluconazole formulations, itraconazole formulations -- as prophylactic measures for oral candidiasis in persons diagnosed with HIV/AIDS? This question is intended to examine the prevention of both recurrences and first-time infections, although the primary focus is on recurrences.

#### Key Question 3B

What is the effectiveness of currently available antifungal drugs -- nystatin formulations, clotrimazole, amphotericin B suspension, ketoconazole, fluconazole formulations, and itraconazole formulations -- for the treatment of oral candidiasis in persons diagnosed with HIV/AIDS?

The objective of Key Question 1 is to ascertain whether persons who are HIV positive are at greater risk of infection, excessive bleeding, delayed healing, or dry socket (alveolitis) as a result of their being HIV positive. Persons with a compromised immune system may be at greater risk for these complications than are uninfected persons. If they are, then such precautions as routine pre- or postsurgical medications may be needed.

Both parts of Key Question 2 focus on whether the presence of selected oral conditions is indicative of recent HIV infection or severe immunosuppression. In persons not known to be HIV-infected, and especially among persons in known exposure or risk categories, the presence of one of these oral conditions could be an indication to a health professional to have the person tested for HIV. Early identification, education, and risk reduction behavior changes, as well as initiation of antiretroviral therapy, could be advantageous to the recently seroconverted patient's health and the public's health.

These same oral conditions plus others may serve a similar purpose among persons who are known to be HIV positive but do not yet have symptomatic AIDS. Rather than indicating progression from HIV seronegative to seropositive status, such conditions may be signaling HIV disease progression to the stage of severe immunosuppression. In this regard, therefore, such an indicator may alert the healthcare providers of persons already participating in antiretroviral therapy that a change may be needed; for others, it may mark the start of therapy for a more advanced phase of the disease. Some experts also hope that oral conditions are such good predictors of immunosuppression that one or more of them may be used as a substitute for later end points in clinical trials and as alternatives to expensive tests in poor nations where resources and facilities for testing and treatment are particularly scarce or nonexistent.

Both parts of Key Question 3 involve the efficacy or effectiveness of currently available antifungal agents for the treatment of oral candidiasis. In one part, the issue is prevention of oral candidiasis among a group of HIV-infected persons who by virtue of their HIV infection are at increased risk for the condition; in the other, the topic is treatment among persons with HIV who actually have oral candidiasis. Questions have been raised about whether these drugs can be used to prevent candidiasis or be used to treat it routinely in persons with HIV disease and whether such uses are associated with increased resistance of the fungus to the drugs, especially as the HIV disease progresses.

### Causal Pathways

Our causal pathways lay out the major elements of the key questions by specifying the study groups, variables, and outcomes of interest and the causal direction or links underlying them. Despite similarities between the two parts of Key Questions 2 and 3, each is represented in a separate causal pathway because of differences in the study groups.

Figure 1 is the causal pathway for Key Question 1. It is concerned with establishing whether persons with HIV/AIDS are at higher risk for complications due to common invasive dental procedures than is true for persons without HIV infection. This causal pathway starts with dental patients in need of dental treatment. Characteristics of the patients that might be associated with complications include such basic demographics as age, gender, and race, as well as chronic disease status, whether they are receiving antibiotics, and whether they are infected with HIV. If they are HIV-infected, other important characteristics are how long they have been infected, to what stage their disease has progressed, whether they are receiving retroviral therapy and what kind, and what their exposure category is. The dental treatment procedures of interest for this question include periodontal surgery, root canal therapy, dental implants, orthognathic surgery, dental extraction, dental prophylaxis, and root planing and scaling. Characteristics of the provider that could influence the procedure include training, experience, and the clinical setting. At the end of the path is the rate of complications for the HIV/AIDS patients and for those who have undergone the same procedures but who are not infected with HIV. The complications of interest include local and system infections, increased bleeding, delayed healing, and dry socket (alveolitis).

Figure 1. Causal Pathway for Key Question 1: Are HIV/AIDS Patients at Increased Risk of Complications from Intra-Oral Dental Procedures as Compared with Similar Patients without HIV/AIDS?

The causal pathway for Key Question 2A (Figure 2) involves whether certain oral conditions can be used as markers of recent HIV infection (seroconversion). The pathway again starts with patients who, while they may be at risk for HIV infection or already exposed to infection, are known to not be HIV positive. Their demographic characteristics, antibiotic and antifungal use, chronic disease status, and risk or exposure group membership are indicated. The next point in time shown in the path is the occurrence of infection. This is followed by the presence of the oral conditions: hairy leukoplakia, oral candidiasis, necrotizing ulcerative periodontitis, oral ulcers, and parotid swelling. The final step in the path is blood test verification of HIV seroconversion (enzyme-linked immunosorbent assay [ELISA] and confirmatory Western blot) occurring within 3 months of the presumed point of infection.

Figure 2. Causal Pathway for Key Question 2A: What Are the Sensitivity, Specificity, and Positive and Negative Predictive Values of Oral Conditions as Markers of Recent HIV Seroconversion?

The causal pathway for Key Question 2B (Figure 3) concerns using oral conditions in the detection of changes in the CD4 cell count among persons who are already HIV positive. It starts with a group of patients who are already diagnosed HIV positive. It again characterizes them in terms of basic demographic characteristics, antibiotic and antifungal use, their exposure category, clinical AIDS status, and type of antiretroviral therapy. The next point in the path is the time of severe immunosuppression that is followed by the presence of the presumed oral indicators. The oral indicators this time are oral candidiasis, hairy leukoplakia, necrotizing ulcerative periodontitis, oral ulcers, parotid swelling, linear gingival erythema, and Kaposi's sarcoma. As with the previous question, a test is performed, this time to detect severe immunosuppression in the form of diminished CD4 cell counts.

Figure 3. Causal Pathway for Key Question 2B: What Are the Sensitivity, Specificity, and Positive and Negative Predictive Values of Oral Conditions as Indicators of Severe Immunosuppression?

The causal pathway for Key Question 3A (Figure 4) focuses on the prevention of oral candidiasis, both initial and recurrent, among persons with HIV/AIDS through the prophylactic use of an antifungal medication approved by the U.S. Food and Drug Administration (FDA). In addition to the demographic, HIV disease, exposure category, and treatment variables shown in Figure 4, past exposure to antifungals also needs to be considered. The FDA-approved antifungals are fluconazole, nystatin, itraconazole, clotrimazole, ketoconazole, and amphotericin B. In addition to knowing which medication is used, the path indicates that the dose, duration of use, and mode of administration are also important. The final step in the path is whether (or how long until) an oral candidal infection occurs (either a first one or a recurrence of one) and what species it is (i.e., one that is sensitive to the antifungal drug).

Figure 4. Causal Pathway for Key Question 3A: How Efficacious Is Antifungal Drug Prophylaxis Against Oral Candidiasis Infection in Persons with HIV/AIDS?

Figure 5, which shows the causal pathway for Key Question 3B, is centered on the effectiveness of available antifungal preparations as a treatment for oral candidiasis among persons with HIV/AIDS. The pathway starts with a group of persons diagnosed with HIV/AIDS and oral candidiasis. In addition to the demographic, HIV disease, and treatment variables shown in Figure 4, exposure category and past exposure to antifungals also need to be considered. The treatments for oral candidiasis consist of the same six available antifungals: fluconazole, nystatin, itraconazole, clotrimazole, ketoconazole, and amphotericin B. Dose, duration, and mode of administration are important factors as well. The end of the path is successful treatment as gauged by reports of symptom relief, negative culture results, eradication of visible infection, and no sign of developing resistance.

Figure 5. Causal Pathway for Key Question 3B: How Effective Are Available Antifungal Drugs for the Treatment of Oral Candidiasis in Persons with HIV/AIDS?

## Literature Searches

This portion of Chapter 2 documents the literature search process and outcomes. It discusses the terms used in our automated literature database searches, describes ancillary search strategies, and lists the inclusion or exclusion criteria used in our initial search and then in our review of studies identified. We searched two automated databases -- MEDLINE and EMBASE -- and manually reviewed the contents of the Cochrane Collaboration Library. Our clinical consultant also hand-searched the contents of the most recent 12 months (through spring 2000) of the five journals thought most likely to contain relevant articles -- Oral Surgery, Oral Medicine, Oral Pathology, Oral Radiology and Endodontics; Journal of Oral Pathology and Medicine; Oral Diseases; AIDS; and Journal of Acquired Immune Deficiency Syndromes and Human Retrovirology -- to be sure the lag in the automated searches did not omit eligible articles. Our review of the Cochrane materials indicated related topics under study but not currently available. We did not propose to search through the "gray" literature (i.e., unpublished materials).

We also describe the process used to select from among the identified articles those that would be included in the evidence tables. Our information specialist conducted the literature searches with collaboration from the project director and the clinical consultant on this report. Our goal was to be as inclusive and broad in the searches as possible so as not to miss relevant literature.

## Search Terms

We did separate MEDLINE searches for each of the five key questions, but all five searches began with the terms "HIV" or "HIV infection" or "acquired immunodeficiency syndrome" and were limited to humans and the English language. Beyond these similarities, the searches were customized except that the search terms for Key Questions 2A and 2B were similar to each other up to a point, as were the search terms for Key Questions 3A and 3B.

It is worth noting that restricting the searches to articles written in English probably caused us to miss some contributions published in other languages and thereby slightly biased the bibliography. However, it is very unlikely that important studies done outside of English-speaking nations would not have been published in an English-language journal given that English has become de facto the language of science and typically accords investigators a high measure of prestige in most nations.

The search terms and strategy for identifying research articles relevant to Key Question 1 from MEDLINE (the principal source for this report) are presented in Table 2 along with the results at each step. We did the searches without restriction on the year of publication, but we found no relevant publications dated before 1983. All five of the MEDLINE searches started with 83,962 articles on human HIV or AIDS in the English language. The search then included a variety of dental procedures to ensure that we captured all procedures of interest. The procedure descriptors specified a search that included any of the following terms: dental care, tooth extraction, dental procedure, gingivoplasty, periodontitis, periodontal surgery, dental implants, gingivectomy, oral surgical procedures, orthognathic surgery, dental scaling, dental prophylaxis, root scaling, root planing, root canal therapy, and pulpectomy. We identified 145,292 articles on these topics.

Table 2. Strategy and Results of Revised MEDLINE Search on Complications with Oral Procedures

Step | Search Terms | Number
1 | Explode HIV or explode HIV infections | 102,851
2 | Explode acquired immune deficiency syndrome | 48,987
3 | 1 or 2 | 102,851
4 | Limit 3 to human and English language | 83,962
5 | Explode dental care or explode tooth extraction or dental procedures | 23,445
6 | Explode gingivoplasty or explode periodontitis or periodontal surgery | 10,716
7 | Explode dental implants or explode gingivectomy or explode oral surgical procedures | 25,489
8 | Explode cephalometry or explode jaw or explode jaw abnormalities or explode malocclusion or explode mandible or explode maxilla or explode orthodontics, corrective or explode osteotomy or explode surgery, oral or explode emporomandibular joint disorders or orthognathic surgery | 96,635
9 | Explode dental scaling | 1,532
10 | Explode dental prophylaxis | 3,711
11 | Root scaling | 10
12 | Explode root planing | 401
13 | Explode root canal therapy or explode pulpectomy | 10,023
14 | 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 | 145,292
15 | 4 and 14 | 767
16 | Limit 15 to controlled clinical trial | 1
17 | Limit 15 to randomized controlled trial | 2
18 | Limit 14 to multicenter study | 3
19 | Explode epidemiologic methods or explode epidemiologic research design or explode epidemiologic study characteristics | 1,294,814
20 | 15 and 19 | 187
21 | Explode comparative study | 866,559
22 | 15 and 21 | 33
23 | Explode evaluation studies | 309,113
24 | 15 and 23 | 6
25 | Explode outcome and process assessment (healthcare) or explode outcome assessment (healthcare) or explode treatment outcome | 97,160
26 | 15 and 25 | 6
27 | 16 or 17 or 18 or 20 or 22 or 24 or 26 | 201

When crossed with the English-language articles on HIV/AIDS, 767 articles were common to both search results. We further winnowed these down to 201 articles by placing some methodological restrictions to eliminate nonresearch and clinical case report articles from the search results. We included studies that were described in terms of being controlled clinical trials, randomized controlled trials, multicenter study, epidemiologic research design, comparative study, evaluation study, outcome and process assessment, outcome assessment, or treatment outcome.

For Key Question 2A (Table 3), the departure point from the first search was to specify the oral conditions of interest. These terms included mouth diseases, periodontal diseases, oral infections, hairy leukoplakia, oral leukoplakia, oral candidiasis, necrotizing ulcerative gingivitis, oral ulcer, parotid diseases, parotid gland, parotitis, or parotid swelling. This step resulted in 1,719 articles when crossed with the English-language articles on HIV/AIDS. We reduced these further to 297 articles by restricting them to mention of HIV seropositivity, seroconversion, or AIDS serodiagnosis.

Table 3. Strategy and Results of Revised MEDLINE Search on Oral Conditions as Markers for HIV Seroconversion

Step | Search Terms | Number
1 | Explode HIV or explode HIV infections | 102,851
2 | Explode acquired immune deficiency syndrome | 48,987
3 | 1 or 2 | 102,851
4 | Limit 3 to human and English language | 83,962
5 | Explode mouth diseases or explode periodontal diseases or oral infections | 122,507
6 | Explode leukoplakia, hairy or explode leukoplakia, oral | 1,998
7 | Explode candidiasis, oral | 2,412
8 | Explode gingivitis, necrotizing ulcerative | 651
9 | Explode oral ulcer | 227
10 | Explode parotid diseases or explode parotid gland or explode parotitis or parotid swelling | 13,997
11 | 5 or 6 or 7 or 8 or 9 or 10 | 127,655
12 | 4 and 11 | 1,719
13 | Explode HIV seropositivity or seroconversion | 15,472
14 | Explode AIDS serodiagnosis | 2,374
15 | 13 or 14 | 17,399
16 | 12 and 15 | 297

Table 4 contains the search strategy and results for Key Question 2B. It included searching for the same oral condition as in Key Question 2A, but it restricted the studies to those mentioning immunosuppression or CD4 lymphocyte count. This yielded 133 articles.

Table 4. Strategy and Results of Revised MEDLINE Search on Oral Conditions as Indicators of Severe Immunosuppression

Step | Search Terms | Number
1 | Explode HIV or explode HIV infections | 102,851
2 | Explode acquired immune deficiency syndrome | 48,987
3 | 1 or 2 | 102,851
4 | Limit 3 to human and English language | 83,962
5 | Explode mouth diseases or explode periodontal
| diseases or oral infections | 122,507
6 | Explode leukoplakia, hairy or explode leukoplakia, oral | 1,998
7 | Explode candidiasis, oral | 2,412
8 | Explode gingivitis, necrotizing ulcerative | 651
9 | Explode oral ulcer | 227
10 | Explode parotid diseases or explode parotid gland or explode parotitis or parotid swelling | 13,997
11 | 5 or 6 or 7 or 8 or 9 or 10 | 127,655
12 | 4 and 11 | 1,719
13 | Explode immunosuppression | 27,915
14 | Explode CD4 lymphocyte count | 5,136
15 | 13 or 14 | 32,974
16 | 12 and 15 | 133

For Key Question 3A (Table 5), the search was limited to oral candidiasis and to the list of antifungal agents, fluconazole, ketoconazole, nystatin, itraconazole, clotrimazole, amphotericin B, or drug therapy. This resulted in 223 articles. As can be seen in Table 5, we further reduced this number to 18 studies by restricting the search with the following terms: primary prevention, prevention, preventive medicine, health promotion, disease prevention, dental prophylaxis, or prophylaxis.

Table 5. Strategy and Results of Revised MEDLINE Search on Efficacy of Antifungals to Prevent Oral Candidiasis

Step | Search Terms | Number
1 | Explode HIV or explode HIV infections | 102,851
2 | Explode acquired immune deficiency syndrome | 48,987
3 | 1 or 2 | 102,851
4 | Limit 3 to human and English language | 83,962
5 | Explode candidiasis, oral | 2,412
6 | 4 and 5 | 570
7 | Explode antifungal agents or fluconazole or ketoconazole or nystatin or antifungal prophylaxis | 68,818
8 | Explode itraconazole | 1,074
9 | Explode clotrimazole | 898
10 | Explode amphotericin B | 7,377
11 | Explode drug therapy | 129,950
12 | 7 or 8 or 9 or 10 or 11 | 196,195
13 | 6 and 12 | 223
14 | Explode primary prevention or prevention | 158,333
15 | Explode preventive medicine | 100,426
16 | Explode health promotion or disease prevention | 14,271
17 | Explode dental prophylaxis or prophylaxis | 31,348
18 | 14 or 15 or 16 or 17 | 236,746
19 | 13 and 18 | 18

Table 6 contains the search strategy and results for Key Question 3B. It was similar to the search done for Key Question 3A to the point of specifying the condition and the drugs. It then restricted the articles to those dealing with drug therapy, therapy, intervention studies, intervention, treatment outcome, or treatment, which yielded 143 articles.

Table 6. Strategy and Results of Revised MEDLINE Search on the Effectiveness of Antifungals to Treat Oral Candidiasis

Step | Search Terms | Number
1 | Explode HIV or explode HIV infections | 102,851
2 | Explode acquired immune deficiency syndrome | 48,987
3 | 1 or 2 | 102,851
4 | Limit 3 to human and English language | 83,962
5 | Explode candidiasis, oral | 2,412
6 | 4 and 5 | 570
7 | Explode antifungal agents or fluconazole or ketoconazole or nystatin or antifungal prophylaxis | 68,818
8 | Explode itraconazole | 1,074
9 | Explode clotrimazole | 898
10 | Explode amphotericin B | 7,377
11 | Explode drug therapy | 129,950
12 | 7 or 8 or 9 or 10 or 11 | 196,195
13 | 6 and 12 | 223
14 | Explode drug therapy or therapy | 519,566
15 | Explode intervention studies or intervention | 66,894
16 | Explode treatment outcome or treatment | 1,076,496
17 | 14 or 15 or 16 | 1,434,727
18 | 13 and 17 | 143

Subsequent to the MEDLINE searches, we conducted additional searches on EMBASE. EMBASE is somewhat more limited than MEDLINE in the time period covered (only since 1988) and in the search terms available to customize queries. For this latter reason, we did only three customized searches for the five questions: Key Questions 2A and 2B were combined into a single search, as were Key Questions 3A and 3B. The vast majority of articles uncovered in these searches were largely duplicative of those found in the MEDLINE searches. The search terms used in, and the number of articles resulting from, the EMBASE searches for Key Questions 1, 2A and B, and 3A and B appear in Tables 7, 8, and 9, respectively.

Table 7. Strategy and Results for EMBASE Search on Complications with Oral Procedures

Step | Search Terms | Number
1 | HIV or AIDS | 81,441
2 | Dental or dentist | 9,992
3 | 1 and 2 | 252
4 | Complications | 95,900
5 | Infection | 278,940
6 | 4 or 5 | 360,854
7 | 3 and 6 | 206

Table 8. Strategy and Results for EMBASE Search on Oral Conditions as Markers or Indicators of Seroconversion or Severe Immunosuppression

Step | Search Terms | Number
1 | Hairy leukoplakia | 300
2 | Oral candidiasis | 1,618
3 | Necrotizing ulcerative periodontitis | 18
4 | Oral ulcers | 146
5 | Parotid swelling | 73
6 | 1 or 2 or 3 or 4 or 5 | 2,106
7 | Immunosuppression | 1,197
8 | 6 and 7 | 10
9 | Plasma viral | 0
10 | Plasma viral load | 151
11 | 9 and 10 | 0
12 | Sensitivity or specificity or predictive value | 236,993
13 | 9 and 12 | 1
14 | 8 or 13 | 11

Table 9. Strategy and Results for EMBASE Search on Efficacy or Effectiveness of Antifungals to Prevent or Treat Oral Candidiasis

Step | Search Terms | Number
1 | Efficacy or effectiveness | 219,779
2 | Antifungal | 190
3 | Nystatin or clotrimazole or amphotericin or ketoconazole | 19,528
4 | Fluconazole or itraconazole | 7,393
5 | 2 or 3 or 4 | 22,332
6 | 1 and 5 | 3,411
7 | Oral candidiasis | 1,618
8 | 6 and 7 | 299

### Inclusion and Exclusion Criteria

The inclusion and exclusion criteria for the studies to be reviewed and abstracted evolved over time as we became more familiar with the relevant literature published on the five key questions. Fortunately, most of the literature was relatively recent (none published before the mid-1980s), so the article formats and materials presented were fairly standard, although far from completely. Reflecting the reality of the available articles, our original "ideal" standards on which studies to include were adjusted. This review represents the best of the research we identified to address these questions.

We tailored the criteria to the question as well as to the available literature. The basic screening criteria for inclusion and exclusion that applied to articles for all of the questions were as follows:

- Include: Only research manuscripts.
- Exclude: Literature reviews (except to check references for additional articles), letters, commentaries, editorials, clinical case reports, or practice or treatment guidelines.
- Include: Only articles published in English.
- Include: Only articles reporting on the human population.

For Key Question 1 on the differences in outcomes and complications of intra-oral procedures between HIV-positive and HIV-negative patients, the criteria used were as follows:

- Include: Studies reporting on complications of intra-oral surgical dental procedures, including orthognathic, periodontal, extractions, endodontics, prophylaxis, root planing and scaling, and implants.
- Exclude: Studies in which treatment is not rendered concurrently to HIV-positive and HIV-negative patients.
- Include: HIV status confirmed by test results.
- Exclude: Patient outcomes or complications not reported according to patient group and procedure.
- Include: Outcomes or complications reported are local infection, systemic infection, increased bleeding, dry socket (alveolitis), or delayed healing.

Because the nature of Key Questions 2A and 2B is so different from the nature of Key Question 1, which is more like a diagnostic question than an outcome difference question, the criteria for inclusion were different as well. For Key Question 2A on the use of oral lesions as markers for seroconversion, the criteria were as follows:

- Include: Reported presence of any of the following selected oral lesions within the 3-month primary HIV-infection window: hairy leukoplakia, oral candidiasis, necrotizing ulcerative periodontitis, oral ulcers, or parotid swelling.
- Include: Specificity, sensitivity, or positive or negative predictive values of the selected oral lesions as markers for seroconversion are reported, or information from which they can be calculated is presented.
- Exclude: No reasonable or firmly established time of exposure to HIV is reported.

The criteria for Key Question 2B addressing the use of selected oral lesions as indicators of change in immunosuppression were as follows:

- Include: Reported presence of any of the following oral lesions in HIV-positive patients: hairy leukoplakia, oral candidiasis, necrotizing ulcerative periodontitis, oral ulcers, parotid swelling, Kaposi's sarcoma, or linear gingival erythema.
- Include: HIV status of patients at time of oral lesion reported by CD4 cell count or plasma viral load.
- Include: Specificity, sensitivity, or positive or negative predictive values of the selected oral lesions as indicators of severe immunosuppression (CD4 <200 cells/mm^3^) are reported, or information from which they can be calculated is presented.

For Key Question 3A, addressing the use of available antifungal agents to prevent initial or recurrent oral candidiasis, the criteria were as follows:

- Include: Studies of the following available antifungal agents: nystatin formulations, clotrimazole, amphotericin B suspension, ketoconazole, fluconazole formulations, or itraconazole formulations.
- Include: Studies of the prevention of initial infection or recurrence of oropharyngeal candidiasis.
- Exclude: Studies without a concurrent control or comparison group.
- Include: Studies whose results are reported separately for initial infection or recurrence.
- Exclude: Studies on non-HIV/AIDS patients only or studies not reporting results separately for HIV/AIDS patients.
- Exclude: Studies without laboratory confirmation of oral candidiasis status at start of study period and after apparent infection.
- Exclude: Studies of mixed-site candidiasis where results are not reported separately for oropharyngeal candidiasis.

The criteria for Key Question 3B, on the effectiveness of available antifungal agents to treat oral candidiasis, were as follows:

- Include: Studies of treatment of oropharyngeal candidiasis.
- Include: Studies of available antifungal agents: nystatin formulations, clotrimazole, amphotericin B suspension, ketoconazole, fluconazole formulations, itraconazole formulations.
- Exclude: Studies comparing different formulations of the same drug.
- Exclude: Studies without a concurrent control or comparison group.
- Exclude: Studies on non-HIV/AIDS patients only or studies not reporting results separately for HIV/AIDS patients.
- Exclude: Studies without laboratory confirmation of oral candidiasis status at time of diagnosis and after treatment.
- Exclude: Studies of mixed-site candidiasis where results are not reported separately for oropharyngeal candidiasis.

## Title, Abstract, and Article Review

To narrow the literature identified through the MEDLINE search to research reports with evidence to bear on the key questions, the project director and the clinical director independently reviewed the titles and, when available, the abstracts obtained in the searches. The reviewers were not blinded in any way to authors or affiliations. After discussion of the inclusion and exclusion criteria, they reviewed the citations with the goal of retaining only research studies that were focused on the key questions. They also identified review articles that seemed relevant for the purpose of later hand-searching their lists of references.

In the review of the 201 citations for Key Question 1, the project director identified 9 articles to which the clinical director suggested adding 3 others, making a total of 12 articles for further review and possible abstraction; in addition, 5 review articles seemed relevant for reference review.

Dual review of the 297 citations titles and abstracts, where available, for Key Question 2A resulted in a total of 35 studies plus 6 seemingly relevant review articles. Similar review of the 133 citations for Key Question 2B led to a total of 31 studies plus 5 seemingly relevant review articles.

The project director and the clinical director also independently reviewed the citations turned up as part of the searches for Key Questions 3A and 3B. This process yielded 6 articles for Key Question 3A and 52 articles for Key Question 3B plus 9 reviews.

Much the same process was followed to review the articles identified through the EMBASE searches. The independent review of titles and abstracts, when available, was conducted by the project director and the clinical consultant. After deleting the duplications with the MEDLINE search and ineligible articles, they considered the following numbers of articles to be eligible or at least of potential value: Key Question 1, one article and four reviews; Key Questions 2A and 2B combined, one article; Key Questions 3A and 3B combined, one article and three reviews.

After the title review, independent dual reviews of the abstracts or articles identified as potentially relevant to each of the five key questions were performed. The clinical director and the clinical consultant for this report reviewed the abstracts or the complete articles of the preliminary list of articles identified for each question. After this review, and consideration of the sets of inclusion and exclusion criteria, an interim final list of articles was developed. The clinical consultant examined review articles and articles from her personal files to identify five additional publications to add to the list, and she hand-searched the past 12 months of issues of five journals that had contributed a large number of the articles identified in the searches to ensure that we did not miss important new material because of a possible lag in indexing them in the search databases.

The interim final list of article titles was sent to the TEAG members for their review and suggestions. In addition, the project director re-reviewed articles on the preliminary list of articles to abstract that had not been included on the final list, and several were reconsidered for the final list. In the end, the project director, the clinical consultant, and the clinical director reached a consensus that these articles should not be added. As a result of suggestions offered during the peer review process, an additional eight articles were added to the bibliography of materials reviewed or used in some way in the preparation of this report. None of these was abstracted or included in the evidence tables, however; all were used for background purposes only.

## Data Abstraction

Hard copies of the full articles for every entry on the interim final list were obtained. When most of the articles were available and some were reviewed, the clinical director developed headings for the columns of preliminary evidence tables. The clinical consultant created preliminary abstract forms based on the data planned for inclusion in the evidence table for each question. One or two articles were then abstracted for each question and entered into the preliminary evidence tables. After a conference call with the TEAG, the project director revised the abstract forms and the format of the evidence tables somewhat. The evidence tables were revised continuously within the scope of the abstraction form as the articles were being abstracted. Data items in the abstract form included study design information, descriptions of the sampling and characteristics of the study group, descriptions of interventions, and reported outcomes and statistics. Copies of the final abstract forms for each of the five questions are included in Appendix D.

Three abstractors assisted with the review. Two were dentists with additional training in managing medically compromised or HIV patients. The third was an experienced dental hygienist and researcher with a master's degree in education. At abstractor training, they reviewed specific examples and discussed how the abstract forms should be completed. After a discussion period and an opportunity to ask questions, the abstractors were assigned a series of articles and asked to return them on a flow basis as they were completed. Only single abstractions were performed. For quality control of the abstractors, and to ensure the reliability and validity of the abstracted data on the returned abstraction forms (or the entries in the evidence tables created from them), the clinical director, the clinical consultant, and the project director independently checked for accuracy and completeness against the original articles as they prepared their respective sections of the analysis in this evidence report.

## Quality Rating of Articles

We developed separate quality-rating forms for articles relating to each of the five key questions. The forms for the two oral conditions as markers or indicators (Key Questions 2A and 2B) consisted of very similar items. The forms for the antifungal prevention or treatment efficacy or effectiveness (Key Questions 3A and 3B) also contained very similar items. The set of items on each form were customized to the questions, but many of the component items were taken directly from or represent modifications of existing rating scales used by the RTI-UNC EPC. The items focus on the nature and size of the study sample, analysis issues, and validity concerns, among other design issues. In developing the quality-rating item sets, we were guided by the suggestions advanced by Lohr and Carey,^64^ both investigators in the RTI-UNC EPC. For the efficacy or effectiveness questions, consideration of CONSORT criteria^65^ figured prominently in our thinking, and for the marker or indicator questions, several items were included in response to issues raised by Lijmer and colleagues.^66^

Draft forms were pretested on several articles for each question, which resulted in some items being eliminated and others reworded. Articles were scored by summing the number (either 1 or 2) associated with items on the quality-rating form checked as "yes" and multiplying by five for the first key question and both parts of the second key question and by four for both parts of the third key question. The quality-rating forms and their scoring instructions for all parts of the three key questions are presented in Appendix E. Although not formally validated, our ratings of the articles provide a relative basis to assess the quality of the research available for each of the questions.