# Introduction

## Primary Objectives and Scope of This Evidence Report

This is the second in a series of systematic reviews of dental topics prepared for the Agency for Healthcare Research and Quality (AHRQ) with the support and collaboration of the National Institute of Dental and Craniofacial Research (NIDCR). The first was a review of dental caries diagnosis and management^1^ that cut across the entire population and stages of life. Rather than focusing on a specific dental disease condition or a particular treatment approach for the general population, this report focuses on several aspects of the treatment of a very special population subgroup -- persons infected with HIV and those living with acquired immune deficiency syndrome (AIDS). One of the main reasons for making this the second dental topic was NIDCR's intention to use this report as a major element of a State of the Science Workshop that it held in December 2000 on the management of dental patients with HIV/AIDS.

Being infected with HIV and having AIDS are phenomena that have been a part of the world's experience just since 1981.^2^ The retrovirus responsible for the HIV/AIDS infection was isolated in 1984.^3^ Despite the fact that HIV/AIDS still has no known cure, we are in the second generation of treatments for the infection. New highly active antiretroviral therapy (HAART) approaches involving the use of protease inhibitors and non-nucleoside reverse transcriptase inhibitors, guided by viral load and, at times, drug resistance testing, have greatly improved the lives and increased the longevity of persons living with HIV/AIDS.^4^ Thus, it is not surprising that, with an estimated 900,000 persons in the United States with HIV/AIDS living longer,^4^ many are seeking to obtain routine dental care. In addition, they are seeking relief from the discomfort and disability associated with concomitant oral lesions. Some belong to population groups who have traditionally had limited access to dental care and poor oral health, such as drug users, the poor, and the disabled. The questions assigned in this evidence report arise in part from the facts that persons with HIV infection can expect to live longer and that they want to do so with the highest available quality of life.

Very early in the infection's history, researchers recognized its route of transmission through exposure to bodily fluids and noted the association of its presence with infections of the oral mucosa. Today, episodes of some of these oral infections are still included in the Centers for Disease Control and Prevention's (CDC) official diagnostic criteria for symptomatic HIV and AIDS.^5^ For these reasons, members of the dental profession have been extremely anxious about risks associated with treatment of HIV-infected persons. Their initial concerns were primarily with the possible transmission of the HIV infection to staff and other patients in their practice. This led very early in the history of HIV/AIDS to the promulgation and adoption by dental practitioners of universal precautions.^6-9^ Over time, this initial reluctance to provide dental treatment to HIV-infected patients has been greatly reduced, but dental care remains one of these patients' greatest unmet needs.^10,11^ However, the focus of interest now has begun to shift to issues related to whether HIV-infected persons are at risk for excessive bleeding, the easy introduction of infection, and diminished healing of wounds when they obtain dental treatment, especially surgical procedures.

Despite recent advances in the medical management of HIV/AIDS, HIV continues to spread through at-risk populations, particularly women and poor people of color.^12,13^ The potential value of oral infections as markers of newly established HIV infection has been suggested. Such infections may provide clinical clues to support the need for HIV antibody testing and hence speed up the initiation of antiretroviral therapy when necessary. Oral conditions also may serve as indicators of HIV disease progression to AIDS and severe immunosuppression. If so, the presence of oral conditions could be a cue that current therapy needs to be reevaluated or changed.

Oral candidiasis is the most common, treatable oral mucosal infection seen in persons with HIV/AIDS. It causes considerable discomfort and morbidity in affected individuals. To date, six antifungal medications have been available in the United States for management of oral candidiasis. Prophylactic use of these antifungal medications has been suggested for some patients.

### Key Clinical Questions

The clinical questions to be addressed in this evidence report are based on the three issues mentioned briefly above. The actual questions were proposed by the NIDCR staff involved in the planning of the State of the Science Workshop on the management of HIV-positive dental patients. We subsequently refined the questions through discussions with the NIDCR staff and further clarified them through communication with the Technical Expert Advisory Group (TEAG) assembled for this particular topic area (see below). The questions reflect two common concerns: (1) that healthcare practitioners, and particularly dentists, may not be aware of the available research with respect to the treatment of persons who are HIV positive, and (2) that the research may not be as comprehensive or definitive as it should be. The questions cover three issues: (1) risks to HIV-positive patients of invasive oral procedures, (2) specific oral conditions as markers of change in HIV immune status, and (3) antifungal treatment of oral candidiasis in persons with HIV/AIDS. We then split the last two issues in two, so we actually address five questions in this report. (The five questions are discussed in greater detail in Chapter 2.)

The first main question addresses whether persons who are HIV positive run any greater risk of complications from selected invasive surgical dental procedures than do persons who are not HIV positive. The underlying issue concerns whether special precautions or measures -- expertise, facilities, medications -- not needed for seronegative dental patients are necessary to protect patients who are seropositive against such possible complications as systemic infection, delayed healing, or excessive bleeding because of their immunocompromised state. The answer to this question could certainly have an impact on the availability of routine dental services to persons with HIV/AIDS.

The second main question involves the usefulness and validity of using certain oral conditions commonly reported among persons with HIV/AIDS as markers or indicators of important changes in immune status. Two critical points, each represented by separate subquestions, come to the fore in this context. The first asks whether these oral conditions might be used as markers of the stage of seroconversion from HIV negative to positive. Some HIV researchers have suggested that during the period of seroconversion, the infected person is especially vulnerable to these oral conditions. Under these circumstances, the presence of the condition could be an indicator that HIV testing is warranted and that early intervention therapy might be justified. The second critical point occurs when HIV-infected persons become sufficiently immunocompromised to meet the definition of symptomatic AIDS. Again, experts have suggested that at this juncture of the infection, the person is particularly susceptible to these oral conditions. If so, and if the presence of the oral conditions is associated with this change in immune status as measured by available measures of the immune system (CD4 count) or level of viral load, it may be a signal to initiate different antiretroviral therapy.

The third main question concerns the effectiveness of available antifungal agents in the prevention and treatment of oral candidiasis in persons who are HIV positive. This question is actually two separate questions because we have no reason to assume that a given agent will be as effective in a prophylactic mode (preventing either initial or recurrent infection) as in a treatment capacity. The outcomes of interest, or end points, are quite different as well. In either case, side effects of the antifungal agents are a relevant concern. Moreover, the use of antifungal agents, especially in a prophylactic mode, raises the issue of increasing resistant strains of Candida species.

### Technical Expert Advisory Group (TEAG)

Guidelines from AHRQ required identification of technical experts in the specialized area of managing the oral conditions of dental patients with HIV/AIDS to serve as report advisers. A TEAG is expected to contribute to advancing AHRQ's broader goals of (a) creating and maintaining science partnerships and public-private partnerships and (b) meeting the needs of an array of potential consumers and users of its products. Thus, a TEAG is both an additional resource and a sounding board throughout the project.

Our TEAG consisted of six individuals who are acknowledged technical or clinical experts in this area. One member was nominated to serve as a representative of a patient advocacy group (the National Association of Persons with AIDS [NAPWA]), and another was chosen to represent the perspective of a potential user group (the American Dental Association [ADA]). Refer to Appendix B for a more complete description of the selection, role, and composition of the TEAG.

To ensure scientifically robust work, we asked the TEAG to provide reactions to work in progress and to advise on substantive issues or possibly overlooked areas of research. TEAG members participated in conference calls and e-mail communications at the beginning of the project to discuss the key clinical questions, initial drafts of causal pathways, and proposed inclusion and exclusion criteria for research articles; during the development of article abstraction forms to provide comments on the forms, the content proposed for inclusion in the evidence tables, and the final versions of the key clinical questions and causal pathways; and when the draft evidence tables were produced to discuss the content of the tables and the completeness of the search.

Because of their extensive knowledge of the literature and ongoing research in this specialized area of dentistry dealing with the management of patients who are HIV positive, as well as their active involvement in the associated professional societies, we also asked TEAG members to participate in the peer review process by commenting on the draft evidence report.

## Prevalence, Burden of Illness, and Variations in Practice in the United States

### Prevalence of HIV Infection and Oral Diseases in Patients with HIV/AIDS

The true prevalence of HIV infection in the United States is unknown because HIV case reporting through the CDC national surveillance mechanism is not universal among States and because not all HIV-infected individuals have been tested. By contrast, reporting of AIDS cases is required in the United States. Through the end of 1999, 733,374 persons had been reported with AIDS, and from the 34 States that report cases of HIV infections an additional 113,167 persons were determined to be living with diagnosed HIV infection (not AIDS).^13^

Oral mucosal opportunistic infections are common among individuals with HIV/AIDS, occurring in an estimated 20 to 50 percent of HIV-infected patients during the course of their disease.^14,15^ Oral candidiasis and oral hairy leukoplakia have been the most common oral mucosal lesions associated with HIV disease and may be markers of immunosuppression and/or disease progression.^16-18^ There is some evidence, however, to suggest that the success of new AIDS treatment regimens (HAART) may be changing the incidence and prevalence of oral diseases among persons with AIDS.^19-21^ Oral lesions may also give clues to primary acute HIV infection.^22-24^

In addition to high levels of chronic gingivitis and adult periodontitis,^25-27^ individuals with HIV are susceptible to rare and severe forms of necrotizing ulcerative gingival and periodontal breakdown.^28^ Compared with healthy adults, HIV-infected individuals have more prevalent, severe, and extensive conventional gingivitis and higher levels of periodontal pocketing and attachment loss, two clinical indicators of adult periodontitis.^29^ In a cross-sectional, masked study, children with perinatally acquired HIV were shown to be at greater risk for caries than their siblings, more so with advancing disease.^30^ A comparison of caries experience between HIV-positive and general patients did not reveal statistically significant differences between them.^31^ Also not yet documented are the prevalence, extent, and quality-of-life effects of xerostomia resulting either as a side effect of medication or HIV-induced salivary gland dysfunction, and the impact of this condition on dental caries rates among persons who are HIV positive.

### Burden of HIV Infection and Oral Disease in HIV Patients

The burden of newly diagnosed HIV/AIDS illness falls increasingly upon racial and ethnic minorities, women, adolescents, and the financially disadvantaged in the United States, and decreasingly upon men who have sex with men (MSM), although this group remains the largest single exposure group.^13^ Incident AIDS cases increasingly represent people who are not diagnosed until they develop opportunistic infections, those who do not obtain medical treatment once diagnosed, and those for whom antiretroviral drug treatments fail.^13^ Although AIDS incidence rates have been decreasing generally, these decreases are smaller among women, blacks, people infected through heterosexual contact, and those living in the South. However, there is recent evidence that AIDS incidence is actually increasing among young homosexual/bisexual men. Additionally, with the new HAART treatment, there has been improved survival and more limited disease progression to AIDS, resulting in more persons living with HIV as a chronic disease.

There are disparities in perceived dental needs and access to dental care among those who are HIV infected. A 1988 - 89 survey of individuals with symptomatic HIV disease in nine U.S. cities revealed a stronger perceived need for dental care (52 percent) than for any other service.^32^ Multivariate analysis showed that people who were white, were in low-income groups, used intravenous drugs, or had a history of oral opportunistic infections were more likely to report dental need. Forty-seven percent reported having an opportunistic oral infection, and these were significantly more prevalent among whites and the severely ill. In a 1994 multi-State interview of people who reported to local and State health departments through CDC's HIV/AIDS surveillance, 32 percent were not currently receiving dental care although dental needs were high, including 34 percent reporting current toothaches and 39 percent having painful or bleeding gums.^33^ A multivariate model of factors associated with persons who received dental care after they learned of HIV-positive status was significant in that these persons had dental insurance, 12 or more years of education, two or more oral conditions, and were white.^33^

Two recent reports from the 1996 HIV Cost and Services Utilization Study cohort, a nationally representative probability sample of 2,864 HIV-infected persons receiving medical care, have added further insight into dental need and utilization.^10,11^ Among subjects, 19.3 percent had a perceived unmet need for dental care in the previous 6 months.^11^ Unmet dental need was highest among those with no dental insurance, those on Medicaid in States without dental benefits, those with incomes under $5,000, and patients with less than a high school education.^11^ Forty-two percent of the sample had seen a dental health professional in the preceding 6 months; however, African Americans, persons whose exposure to HIV was via blood products, persons with less education, and those who were unemployed were less likely to get dental care.^10^ Availability of a regular source of care was associated with increased utilization.

Oral mucosal and periodontal diseases can result in morbidity and affect the quality of life for the HIV-infected patient.^31^ In a comparison of dental patients with HIV infection and general dental patients receiving publicly funded care in Adelaide, South Australia, HIV patients reported significantly greater levels of social impact. Social impact among HIV patients was frequent: 64.6 percent reported toothache, 43.7 percent avoided eating, and 16.7 percent avoided going out because of dental problems.^31^ Although the index of decayed, missing, and filled permanent teeth (DMFT) and its components did not differ significantly between HIV-infected and general dental patients, oral candidiasis was present among 32 percent of HIV patients.^31^

The most typical presentation of oral candidiasis is pseudomembraneous candidiasis, or thrush, which may be accompanied by pain during swallowing (odynophagia) that makes eating difficult, thus contributing to impaired nutritional intake and weight loss. Utilization of care for oral lesions, such as thrush and oral sores, as reported by participants in the national multisite AIDS Cost and Service Utilization Survey in 1991 - 92 was relatively low -- 9.1 percent in all -- and educational and racial differences existed among respondents who received care for HIV-associated oral lesions.^34^

### Variations in Practice for HIV-Positive Patients

#### Risk of Dental Treatment

Complications may result from dental treatment in any healthy individual. Risks of prolonged postoperative bleeding, delayed wound healing, oral wound or distant site infection, or dry socket (alveolitis) occur when surgical procedures are undertaken. Tooth extraction is a common surgical procedure performed on thousands of individuals every day, many of whom have HIV/AIDS. Patients with underlying medical disease, such as hemophilia, liver cirrhosis, or immune dysfunction from various causes, may be at higher risk than those with intact hemorrhagic and immune systems.

Whether HIV-infected patients have a greater propensity for complications from dental treatment has been controversial. Practitioners may empirically choose to place patients on either preoperative or postoperative antibiotics (or both) to prevent local wound or distant site infection. Required surgical treatment of HIV-infected patients may be denied or postponed because of concern about possible bleeding complications. Other providers may elect to use prophylactic extraction socket medications or antimicrobial rinses.

One retrospective review of common dental procedures (1,810 invasive procedures, including periodontal, restorative, endodontic, prosthodontic, and surgical procedures) performed mostly by general practitioners among 331 HIV-infected patients with suppressed immune systems (CD4 less than 200 cells/mm^3^) demonstrated an overall complication rate of 0.9 percent.^35^ Simple extractions resulted in a 4.1 percent complication rate, and surgical extractions resulted in an 11.8 percent rate, most being dry sockets following extractions.^35^ Another study of HIV-positive patients undergoing extractions reported a higher complication rate (22.4 percent); however, complications were minor and easily treated.^36^ This study also reported that in logistic regression models, out of numerous laboratory values, only low CB8 count was associated with high complication risk. The authors concluded that delaying treatment to obtain laboratory test results in situations of acute dental pain was of little value.^36^ Another study demonstrated that prophylactic socket medication may decrease the risk of dry and infected sockets.^37^

Dental surgical procedures or instrumentation involving periodontal structures are commonly associated with transient bacteremias.^38,39^ Expert consensus suggests that routine antibiotic coverage to prevent septicemia from bacteremias arising from dental procedures is not indicated solely on the basis of the patient's HIV status, but is recommended for severely neutropenic patients with absolute neutrophil counts below 500 cells/mm^3^.^40^ Fewer than 1 percent of HIV-infected dental patients have severe neutropenia.^41^ Chlorhexidine antimicrobial mouth rinse has been suggested for use before dental treatment to reduce the risk of postprocedural bacterial complications.^40^

Any surgical procedure in a patient with an underlying bleeding disorder, such as hemophilia, thrombocytopenia, or severe liver disease, places the patient at risk for bleeding complications. Individuals with hemophilia now constitute fewer than 1 percent of individuals with HIV/AIDS.^13^ Although 15 percent of all dental patients with HIV/AIDS may have thrombocytopenia (20 percent among those with AIDS or CD4 less than 200 cells/mm^3^), only 0.4 percent have severe thrombocytopenia (platelet count below 50,000), placing them at an elevated risk for postextraction bleeding.^41^

#### Use of Oral Indicators for Changes in HIV Serostatus

HIV infection remains a serious public health threat because undiagnosed seropositive individuals who continue risky behaviors may infect others in their social networks. Diagnosis at the time of HIV seroconversion would greatly facilitate national prevention efforts by providing early access to risk behavior counseling and initiation of antiretroviral therapy known to decrease HIV viral loads in blood and semen.^42,43^ Oral indicators of HIV infection that are well recognized and easily detected by patients and providers, if they occur in substantial numbers of patients during primary infection, may lead to HIV counseling and testing earlier in the disease when an individual is not otherwise suspicious of HIV infection.

Several reports have indicated that oral lesions may occur during HIV antibody seroconversion illness, also called primary or acute HIV infection. Ten patients of 1,110 admitted to a hospital internal medicine and infectious disease service over a 3-year period were identified retrospectively to have had symptomatic acute HIV infection.^44^ Of these 10 recent seroconverters, 4 had oral candidiasis. The largest study of HIV seroconverters observed in European and Australian cohorts (n = 218), reported oral ulcers among 28.9 percent and oral candidiasis among 17 percent during acute HIV-1 infection.^45^ Rabeneck and coworkers^24^ described 16 homosexual men presenting with acute HIV illness characterized by painful swallowing, rash, and palatal ulcers.

#### Use of Oral Indicators for Changes in Immune Status

Certain common and uncommon oral manifestations of HIV have been variably associated with immunosuppression identified by reduced CD4 counts, disease progression, and death. Two commonly occurring oral lesions, oral candidiasis and hairy leukoplakia, have been the subject of many reports. Oral lesions that are effective clinical indicators of a suppressed immune system could serve as risk markers of other more serious disease, such as Pneumocystis carinii pneumonia or esophageal candidiasis, which occur as a result of suppressed host defenses. They could serve as surrogate laboratory markers for absolute levels of the CD4 positive lymphocytes or CD4 to CD8 ratios among populations in developing nations without ready access to laboratory facilities. Oral lesions found in HIV-infected individuals that are not associated with immunosuppression may be associated with other risk factors.

It is generally held that oral candidiasis and hairy leukoplakia are signs of a depressed immune system because they are included in the CDC HIV case definition for symptomatic HIV disease.^46^ Kolokotronis and coworkers^47^ found that among 43 HIV-infected individuals, oral candidiasis, but not hairy leukoplakia, was associated with a CD4 count of less than 200 cells/mm^3^. Hilton^48^ recently reported that any history of candidiasis since HIV seroconversion and the recency of a candidiasis episode were the two candidiasis-related measures that were clinically and statistically significant in Cox regression models predicting time to AIDS diagnosis in two large cohorts of male seroconverters. Ravina and coworkers^49^ reported that although many HIV-infected patients with and without hairy leukoplakia had CD4 counts greater than 500 cells/mm^3^ at initial visit, in longitudinal analyses hairy leukoplakia was associated over time with a greater reduction in CD4 cell counts, a significant increase in P24 antigenemia, and a higher rate of progression to AIDS.

A large cohort of HIV-infected homosexual and bisexual men from San Francisco in the late 1980s,^50^ a large national cohort of women from the early to mid-1990s,^51^ and a mixed gender and transmission risk group of dental outpatients from Philadelphia in the late 1980s to early 1990s^18^ were evaluated for oral lesions and immunosuppression. Begg and coworkers^52^ described differences between the association of oral lesions with immunosuppression among homosexual men as compared with injected drug users in the late 1980s to early 1990s.

#### Antifungal Drug Management and Prophylaxis of Oral Candidiasis

Clinicians use a variety of drugs, in both topical and systemic delivery systems, to manage fungal infections, including oral candidiasis. Table 1 lists the six drug preparations approved for marketing in the United States by the Food and Drug Administration (FDA) that are used to manage fungal infections, along with a description of a typical course of treatment for oral candidiasis and the average wholesale price associated with such a course of treatment. For some of these antifungals, use for treating oral candidiasis may represent an "off-label" use.

Table 1. FDA-Approved Antifungal Drugs Used for the Management of Oropharyngeal Candidiasis^a^

Generic | Proprietary | Formulation ^b^ | Quantity | 2000 AWP ^c^ /Typical Treatment Course
amphotericin B | Fungizone | 100 mg/mL oral suspension | $70.56 / 56 mL | Rx: 100 mg QID for 14 days
clotrimazole | Mycelex | 10 mg troche | $62.43 / 50 | Rx: 10 mg 5x/day for 10 days
fluconazole | Diflucan | 100 mg tablet | $112.03 / 15 | Rx: 200 mg stat and 100 mg QD for 13 days
| | 10 mg/mL oral solution | $122.16 / 140 mL | Rx: 100 mg QD for 14 days
| | 40 mg/mL oral solution | $110.95 / 35 mL | Rx: 100 mg QD for 14 days
itraconazole | Sporanox | 100 mg capsule | $198.00 / 28 | Rx: 200 mg QD for 14 days
| | 10 mg/mL oral solution | $207.48 / 280 mL | Rx: 200 mg QD for 14 days
ketoconazole | Nizoral | 200 mg tablet | $52.66 / 15 | Rx: 400 mg stat and 200 mg QD for 13 days
nystatin | Mycostatin | 100,000 U/mL oral suspension | $69.85 / 200 mL | Rx: 500,000 U QID for 10 days
| | 200,000 U/oral pastille | $52.33 / 50 | Rx: 200,000 U 5x/day for 10 days
| | 500,000 U/oral tablet | $27.48 / 40 | Rx: 500,000 U QID for 10 days

a The following clarification is provided in a memo dated September 20, 2000, from Bernard A. Schwetz, D.V.M., Ph.D., acting deputy commissioner, U.S. Food and Drug Administration: "There are six antifungal drugs approved for marketing. These are fluconazole, itraconazole, clotrimazole, amphotericin B, nystatin, and ketoconazole. Of these, nystatin, itraconazole, and fluconazole are specifically indicated in approved labeling for treating oral candidiasis. Fluconazole (Diflucan®) is also indicated prophylactically 'to decrease the incidence of candidiasis in patients undergoing bone marrow transplantation who receive cytotoxic chemotherapy and/or radiation therapy.' Clotrimazole is indicated for treating candidiasis, but oral candidiasis is not specifically mentioned. Ketoconazole is approved for treating cutaneous candidiasis, and amphotericin B is not labeled for treating candidial infections."

b mg/mL = milligrams per milliliter, U/mL = units per milliliter

c AWP = average wholesale price

QID = four times a day, QD = every day, STAT = immediately

Source: Medical Economics. Drug Topics Red Book. Montvale, NJ: Medical Economics Co., Inc., 2000.

Several antifungal agents, including nystatin, itraconazole, ketoconazole, clotrimazole, and amphotericin B oral suspension, can be used topically. For topical agents, successful therapy depends on adequate contact time (2 minutes) between the agent and the oral mucosa. Treatment time varies from 7 to 14 days, with therapy minimally continued for 2 to 3 days beyond the last appearance of clinical signs and symptoms. Topical agents have the benefit of few side effects at normal therapeutic doses because of their lack of gastrointestinal absorption. However, sucrose-containing topical agents can be cariogenic when used over prolonged time periods, so adjunctive topical fluoride therapy may be needed.

Nystatin is a polyene antifungal administered topically. The general failure of the major fungal pathogen Candida albicans to develop resistance to nystatin, its negligible gastrointestinal absorption and thus relatively minor and infrequent side effects, and its topical mode of action make nystatin pastilles (lozenges) a potentially excellent choice for use as a prophylactic agent.^53^ Whereas the nystatin oral suspension used to "swish and swallow" has a high sucrose content, the pastille formulation requires adequate saliva. Clotrimazole, a topical imidazole, also requires adequate saliva to dissolve the troches (lozenges), but they contain dextrose rather than sucrose as a sweetening agent.

Systemic antifungals, including ketoconazole, fluconazole, and itraconazole, have the advantage of once-daily dosing and treatment of fungal infections at multiple body sites at once. However, these antifungals have more side effects and require consideration of important drug interactions.

Ketoconazole, an imidazole, may interfere with the metabolism of cyclosporine, tacrolimus, and warfarin, increasing toxicity. Its use is also contraindicated with isoniazid, phenytoin, and rifampin because they decrease its effect. Terfenadine and astemizole are also contraindicated while taking ketoconazole. Concomitant use of ketoconazole with protease inhibitors, which are normally metabolized through the cytochrome P450-34A enzyme system on which ketoconazole acts, may produce increased levels of the protease inhibitors. Absorption of ketoconazole requires gastric acidity, and that may necessitate the concomitant use of antacids, H_2_ antagonists, omeprazole, and sucralfate, which may reduce its bioavailability and result in treatment failure. Ketoconazole is to be taken with food. Periodic liver function tests are recommended to monitor for hepatotoxicity.

Fluconazole, a novel bis-triazole antifungal agent introduced in 1990, has systemic effects that may be beneficial for other fungal infections. Subjects in the fluconazole prophylactic arm of one antifungal placebo-controlled trial showed improvement of dermatophytoses, such as tinea pedis, onychomycosis, and tinea cruris.^54^ Additionally, systemic fluconazole prophylaxis may prevent esophageal and vaginal candidiasis,^55^ cryptococcemia, histoplasmosis, and other deep fungal infections. Unlike ketoconazole, fluconazole is not altered by changes in gastric acidity and carries less risk of hepatotoxicity; however, many of the same drug interactions are possible.

Itraconazole oral solution, also a triazole antifungal with systemic properties that is indicated for the treatment of oropharyngeal candidiasis, has demonstrated clinical improvement of fluconazole-refractory oropharyngeal candidiasis in HIV patients, allowing clinical response in 55 percent of patients in a median of 7 days.^56^ It carries the same drug interaction potential and the common azole antifungal side effects of nausea, headache, and abdominal pain, as well as reduced absorption under acidic stomach conditions.

Of the antifungal agents used to treat oral candidiasis in people with HIV/AIDS, fluconazole has consistently shown excellent clinical response, limited drug interactions, and mild toxicities, making it the likely drug of choice and thus the most widely prescribed. A newly raised concern about the widespread use of fluconazole as chronic suppressive therapy for oral candidiasis is the potential for development of azole-resistant Candida albicans and selection of non-albicans Candida species, which also increase in prevalence with immune-system decline and thus further complicate management of some individuals.^57-59^ Fluconazole resistance is most likely with substantial prior exposure to fluconazole and with severe immunosuppression (e.g., CD4 <50 cells/mm^3^).^60,61^

Because oral candidiasis can be a frequent and significant source of oral discomfort, pain, loss of taste, and aversion to food, it may lead to secondary complications, such as esophageal candidiasis, for some patients with HIV/AIDS. For this reason, it may justify consideration of antifungal prophylaxis in such patients. Although rarely used for primary prevention, it is sometimes considered for patients prone to multiple recurrences of oral candidiasis. Improved quality of life resulting from longer symptom-free periods is important to many patients. The possibility that resistance to antifungal agents will develop and consideration of the cost of the drug must also be weighed in the decision to attempt prophylaxis and in the selection of an antifungal agent.

Patients with CD4 counts of less than 200 cells/mm^3^ may be most at risk for oral candidiasis and thus may benefit most from antifungal prophylaxis. Candida albicans carriage and history of oral candidiasis are other significant predictors of time to oral candidiasis.^53^

Because of the effectiveness of antifungal therapy for the treatment of acute oropharyngeal candidiasis, the low mortality associated with mucosal candidiasis, the potential for resistant Candida organisms to develop, the possibility of drug interactions, and the cost of prophylaxis (e.g., annual average wholesale cost per patient of 200 mg of fluconazole per day in 1999 was $4,267), the U.S. Public Health Service and the Infectious Disease Society of America do not recommend routine primary prophylaxis.^62^ Expert opinion also recommends against chronic prophylaxis of recurrent oropharyngeal candidiasis for the same reason. When recurrences are frequent or severe, oral azoles (fluconazole, itraconazole, or ketoconazole) may be considered. Factors considered in decisions for prophylaxis against oral candidiasis include the following: the impact of oral fungal disease recurrences on the patient's quality of life and well-being, the need for prophylaxis for other fungal infections, cost, toxicities, drug interactions, and the potential to induce antifungal drug resistance. Among patients with frequent recurrences, continuous suppressive fluconazole therapy significantly reduces relapses and colonization, and it has tangential utility in preventing cryptococcosis and (in endemic areas) histoplasmosis, yet resistance remains a concern as it occurs with both intermittent and continuous therapy.^63^

## Organization of the Report

The remainder of this two-volume evidence report is organized in the following manner. Chapter 2 provides details about our literature search and review methodology. Specifically included are the analytical framework for our key clinical questions and our approaches to conducting the systematic review, abstracting data from articles, maintaining quality control, applying a quality rating system for individual articles, and similar details. Chapter 3 provides the results of our analyses. Chapter 4 provides the concluding discussion, and Chapter 5 notes gaps we found in the research and offers our recommendations for a research agenda related to the questions addressed on the management of dental patients who are HIV positive. Chapter 6 provides the references cited in the body of the evidence report.

In Volume 2, Chapter 7 contains the evidence tablesand supporting information. Finally, the complete bibliography of literature considered and used in developing the evidence report (including all articles reviewed in the literature search and all references cited in Chapters 1 to 5) appears in Chapter 8. The five appendices provide acknowledgments (Appendix A), information on the TEAG (Appendix B), identification of the peer reviewers for this report (Appendix C), our data abstraction forms (Appendix D), and the quality rating scales (Appendix E).