# Appendix E. Quality Rating Scales

Quality Rating Scale for Studies of Differences in Complication Rates (Question 1) (score = sum of "yes" answer points multiplied by 5)

## Research Design

1. | Is the design prospective | 1 Yes___ | 0 No___
2. | Is there a concurrent control/comparison group? | 2 Yes___ | 0 No___
3. | Is selection of cases for each study group made randomly from a pool of eligible cases? | 1 Yes___ | 0 No___
4. | If not, do they represent a continuous series of consecutive eligible patients? | 1 Yes___ | 0 No___
5. | Are "examiners/abstractors" blind to the group assignment of patients? | 2 Yes___ | 0 No___
6. | Were all groups treated the same with respect to prophylactic measures? | 1 Yes____ | 0 No____

## Data Analysis

7. | Is the analysis conducted and reported on all selected (intent to treat) or only completed? | 1 Selected____ | 0 Completed____
8. | Is the smallest study group at least 50 cases? | 1 Yes___ | 0 No___
9. | Was there a power analysis or some other basis noted for determining the adequacy of the study group sizes? | 1 Yes___ | 0 No___
10. | Was an effort made in the analysis to take into account initial differences between the study groups? | 1 Yes___ | 0 No___
11. | Was an effort made in the analysis to take into account differences in the complexity of the procedures between the study groups? | 1 Yes___ | 0 No___
12. | Was the study attrition less than 15% per study group? | 1 Yes___ | 0 No___

## Measurement and the Validity of the Results

13. | Are the results generally applicable or limited to one particular segment (level of immune suppression or exposure category) of the HIV-positive population? | 1 General___ | 0 Limited___
14. | Are the results generally applicable or limited to one particular healthcare delivery setting? | 1 General___ | 0 Limited___
15. | Is there an effort to ensure participant compliance with postoperative instructions? | 1 Yes___ | 0 No___
16. | Are the criteria used to define complications clinically relevant (are they what clinicians use in practice)? | 1 Yes___ | 0 No___
17. | Have the measures been shown to be reliable? | 1 Yes___ | 0 No___
18. | Is there evidence that the measures were applied reliably in the study? | 1 Yes____ | 0 No____
19. | If multiple examiners were used, was there a mention of being calibrated or trained to a standard? | 1 Yes____ | 0 No____
20. | If a single examiner, was the examiner different from the treatment provider? | 1 Yes___ | 0 No___

Quality Rating Scale for Studies of Oral Conditions as Markers of Recent Seroconversion (Question 2A) (score = sum of "yes" answer points multiplied by 5)

## RESEARCH DESIGN

1. | Were there 100 or more cases in the sample? | 1 Yes___ | 0 No___
2. | Were the sample cases randomly selected? | 2 Yes___ | 0 No___
3. | Was the prevalence of the oral condition being used as a marker less than 50% in the population from which the sample was selected? | 1 Yes___ | 0 No___
4. | Were the same patients followed over time to monitor the development of the oral conditions? | 2 Yes___ | 0 No___
5. | Were examiners blind to the exposure status of cases? | 1 Yes___ | 0 No___

## Measurement

6. | Were the criteria used for diagnosing the presence of the oral conditions specified? | 1 Yes___ | 0 No___
7. | Was the diagnosis of the oral condition based on reported symptoms, clinical observation, or periodic laboratory test results? | 2 Lab test___ | 0 Other___
8. | Was study attrition less than 15% in all study groups? | 1 Yes___ | 0 No___
9. | Was analysis reported on all cases selected or only on those who completed the study? | 1 All selected___ | 0 Only those completing___

## Validity of Results

10. | Were all patients confirmed (by testing) to be HIV negative before exposure to HIV? | 2 Yes___ | 0 No___
11. | Was the time of exposure to HIV known with a fair degree of certainty? | 1 Yes___ | 0 No___
12. | Were regular periodic tests conducted to detect seroconversion as soon as possible (as opposed to after some clinical sign is noticed or a symptom is reported)? | 1 Yes___ | 0 No___
13. | Was seroconversion established and confirmed by same test process as initial HIV status? | 1 Yes___ | 0 No___
14. | Were the patients selected from multiple exposure categories? | 1 Yes___ | 0 No___
15. | Was the presumed exposure from a single occasion? | 1 Yes___ | 0 No___
16. | Was history of the oral condition for the patients known? | 1 Yes___ | 0 No___

Quality Rating Scale for Studies of Oral Conditions as Indicators of Severe Immune Suppression (Question 2B) (score = sum of "yes" answer points multiplied by 5)

## RESEARCH DESIGN

1. | Were there 100 or more cases in the sample? | 1 Yes___ | 0 No___
2. | Were the sample cases randomly selected? | 2 Yes___ | 0 No___
3. | Was the prevalence of the oral condition being diagnosed less than 50% in the population from which the sample was selected? | 1 Yes___ | 0 No___
4. | Were the same patients followed over time to monitor the development of the oral conditions? | 2 Yes___ | 0 No___
5. | Were examiners blind to the CD4 cell count or viral load of cases? | 1 Yes___ | 0 No___

## MEASUREMENT

6. | Were the criteria used for diagnosing the presence of the oral conditions specified? | 1 Yes___ | 0 No___
7. | Was the diagnosis of the oral condition based on reported symptoms, clinical observation, or laboratory test results? | 2 Lab test___ | 0 Other___
8. | Was study attrition less than 15% in all study groups? | 1 Yes___ | 0 No___
9. | Was analysis reported on all cases selected or only on those who completed the study? | 1 All___ | 0 Only those completing___

## VALIDITY OF RESULTS

10. | Was the HIV status at the start of the study period established by CD4 cell count or viral load? | 2 Yes___ | 0 No___
11. | Were regular periodic tests conducted to detect immunosuppression for all patients (as opposed to only after some clinical sign is noticed or a symptom is reported)? | 1 Yes___ | 0 No___
12. | Was the immunocompromised state established and confirmed by the same test process as initial HIV status? | 1 Yes___ | 0 No___
13. | Was the retroviral treatment status of patients reported? | 1 Yes___ | 0 No___
14. | Was the time of seroconversion known? | 1 Yes___ | 0 No___
15. | Were the exposure categories of all patients known? | 1 Yes___ | 0 No___
16. | Was the history of the oral conditions for the patients known? | 1 Yes___ | 0 No___

Quality Rating Scale for Studies of Prophylactic Efficacy (Question 3A) (score = sum of "yes" answer points multiplied by 4)

## RESEARCH DESIGN

1. | Is the design prospective? | 2 Yes___ | 0 No___
2. | Is there a concurrent control/comparison group? | 2 Yes___ | 0 No___
3. | Is assignment made to study groups randomly? | 2 Yes___ | 0 No___
4. | Are examiners blinded to the intervention? | 2 Yes___ | 0 No___
5. | Are participants blinded to the intervention? | 2 Yes___ | 0 No___

## DATA ANALYSIS

6. | Is the analysis conducted and reported on all selected (intent to treat) or only completed cases? | 1 Selected____ | 0 Completed____
7. | Is the smallest study group at least 50 cases? | 1 Yes___ | 0 No___
8. | Was there a power analysis or some other basis noted for determining the adequacy of the study group sizes? | 1 Yes___ | 0 No___
9. | Was an effort made in the analysis to take into account initial differences between the study groups? | 1 Yes___ | 0 No___
10 | Was the study attrition less than 15% per study group? | 1 Yes___ | 0 No___

## MEASUREMENT AND THE VALIDITY OF THE RESULTS

11 | Are the results generally applicable or limited to one particular segment of the HIV-positive population? | 1 General___ | 0 Limited___
12 | Are the results generally applicable or limited to one particular healthcare delivery setting? | 1 General___ | 0 Limited___
13. | Is there an effort to ensure participant compliance? | 1 Yes___ | 0 No___
14. | Did the study run long enough to show an effect (could the clinical change have occurred in the time allowed)? | 1 Yes___ | 0 No___
15. | Are there before and after treatment measures of whatever will be used to gauge change due to exposure? | 1 Yes___ | 0 No___
16. | Are the criteria for measuring whatever will be used to gauge change due to treatment clearly stated? | 1 Yes___ | 0 No___
17. | Are the same criteria used for both before and after? | 1 Yes___ | 0 No___
18. | Are the criteria used clinically relevant (are they what clinicians use in practice)? | 1 Yes___ | 0 No___
19. | Have the measures used been shown to be reliable? | 1 Yes___ | 0 No___
20. | Is there evidence that the measures were applied reliably in the study? | 1 Yes___ | 0 No___

Quality Rating Scale for Studies of Treatment Effectiveness (Question 3B) (score = sum of "yes" answer points multiplied by 4)

## RESEARCH DESIGN

1. | Is the design prospective? | 2 Yes___ | 0 No___
2. | Is there a concurrent control/comparison group? | 2 Yes___ | 0 No___
3. | Is assignment made to study groups randomly? | 2 Yes___ | 0 No___
4. | Are examiners blinded to the intervention? | 2 Yes___ | 0 No___
5. | Are participants blinded to the intervention? | 2 Yes___ | 0 No___

## DATA ANALYSIS

6. | Is the analysis conducted and reported on all selected (intent to treat) or only completed cases? | 1 Selected____ | 0 Completed____
7. | Is the smallest study group at least 50 cases? | 1 Yes___ | 0 No___
8 | Was there a power analysis or some other basis noted for determining the adequacy of the study group sizes? | 1 Yes___ | 0 No___
9. | Was an effort made in the analysis to take into account initial differences between the study groups? | 1 Yes___ | 0 No___
10 | Was the study attrition less than 15% per study group? | 1 Yes___ | 0 No___

## MEASUREMENT AND THE VALIDITY OF THE RESULTS

11. | Are the results generally applicable or limited to one particular segment of the HIV-positive population? | 1 General___ | 0 Limited___
12. | Are the results generally applicable or limited to one particular healthcare delivery setting? | 1 General___ | 0 Limited___
13. | Is there an effort to ensure participant compliance? | 1 Yes___ | 0 No___
14. | Did the study run long enough to show an effect (could the clinical change have occurred in the time allowed)? | 1 Yes___ | 0 No___
15. | Are there before and after treatment measures of whatever will be used to gauge change due to exposure? | 1 Yes___ | 0 No___
16. | Are the criteria for measuring whatever will be used to gauge change due to treatment clearly stated? | 1 Yes___ | 0 No___
17. | Are the same criteria used for both before and after? | 1 Yes___ | 0 No___
18. | Are the criteria used clinically relevant (are they what clinicians use in practice)? | 1 Yes___ | 0 No___
19. | Have the measures used been shown to be reliable? | 1 Yes___ | 0 No___
20. | Is there evidence that the measures were applied reliably in the study? | 1 Yes___ | 0 No___