# Appendix D. Data Abstraction Forms

## Question 1: HIV Evidence Report Abstraction Form: Dental Treatment Complication Risk

### Administrative Information

1 | Abstractor:___________________________
2 | Date:________________
3 | Abbreviated study citation:_________________________________________________
  | first author | journal abbr. | year | volume pages

### Study Information

1. | Study design: randomized controlled trial, nonrandomized controlled trial, case-control, prospective cohort, retrospective cohort, cross-sectional, other_____________________________(circle one)
2. | Study period: (specify years in which conducted)_____________________
3. | Study/treatment site (include nation): hospital dental clinic, graduate program university clinic, undergraduate, dental school clinic, health department dental clinic, private dental practice, general hospital, medical, clinic, private medical office, other__________________ (circle one)
4. | Duration of evaluation/follow-up period:_____ days or _______ weeks or ______ months
5. | Number of evaluation time points: ______ and interval __________ (e.g., 4 times, every month)
6. | Dental intervention: dental prophylaxis, scaling and root planning, dental extraction(s), periodontal surgery, root canal therapy, dental implants, orthognathic surgery, other:____________________ (circle all that apply)
7. | Examiners blind to HIV status: yes no not reported (circle one)

### Sample Information

1. | Description of population sampled: _________________________________________________ __________________________________________________________________________________
2. | Sample size: _____________= total subjects selected _____________= HIV/AIDS (case) subjects selected _____________= non-HIV (control) subjects selected
3. | Subject sample selection: random, systematic, cluster, convenience, specific criteria, unknown (circle one) (If specific criteria, describe inclusion and exclusion) _______________________________________________________ ________________________________________________________________________________________________________________ _______________________________________________________________________________

### Group Characteristics

Cases (or total if not reported by group)
1. | Age: | mean:_______ median: ______ range: ______________________
2. | Gender: | number (%) male:_______________ | | number (%) female:______________
3. | Race: | number (%) white: ______________ | | number (%) black: ______________
| | number (%) Hispanic: ___________ | | number (%) Asian/Pacific Islander: _________
| | number (%) other or unknown:_________________
4. | Chronic disease state:
| hepatitis/cirrhosis | hemophilia/bleeding disorder | diabetes | chronic steroid therapy | chemotherapy | other:_____________
5. | Number (%) having multiple procedures (e.g., multiple extractions):_____________________
6. | Number (%) having more complex procedures (e.g., surgical extraction rather than simple extraction) _________________________________________________________________________________
7. | HIV exposure category:
| number (%) MSM: __________________ | | | number (%) IDU: ______________
| number (%) MSM& IDU: _____________ | | | number (%)heterosexual: ________
| number (%) blood exposure: ___________ | | | number (%) perinatal: ___________
| number (%) other or unknown:_________
8. | Number of years infected (circle one: since known seroconversion or since first HIV + antibody test):
| mean: ________ | | median: ________ | | range: ________
9. | HIV disease stage (Centers for Disease Control case definition): ___________________________________
| Number (%) AIDS: ______ | | number (%) symptomatic:________ | | number (%) asymptomatic: _______
| Number (%)CD4 <200:_______ | | number (%) CD4 200-499:________ | | number (%) CD4 >500:______
10. | CD4 mean:_____________ SD:_____________ range: ____________________
11. | Antiretroviral therapy: number (%) none: ______ number (%) non-HAART (all study pre-1996): ____
| Number (%) HAART (+protease inhibitor): ______ number (%) unknown: _______
12. | Viral load data: unknown or describe: _____________________________________________
13. | Antibiotic administered (number [%] receiving preoperative, postoperative, combined, not reported): _______________________________________________________________________________

### Control/Comparison Group

1. | Age: | mean:_______ median: ______ range: _____________
2. | Gender: | number (%) male:_______________ | number (%) female:______________
3. | Race: | number (%) white: ______________ | number (%) black: ______________
| | number (%) Hispanic: ___________ | number (%) Asian/Pacific Islander: _________
| | number (%) other or unknown:_________________
4. | Chronic disease state: hepatitis/cirrhosis, hemophilia/bleeding disorder, diabetes, chronic steroid therapy, chemotherapy, other: _________________________ (circle any that apply)
5. | Number (%) having multiple procedures (e.g., multiple extractions):_____________________
6. | Number (%) having more complex procedures (e.g., surgical extraction rather than simple extraction): ___________________________________________________________________________________
7. | Antibiotic administered (number [%] receiving preoperative, postoperative, combined, not reported): __________________________________________________________________

### Provider/Examiner information

1. | Number of examiners: | _________
2. | Number of treatment providers: | _________
3. | Treatment provider professional training: student, resident/graduate student, dental hygienist, general dentist, ADA-recognized specialist, not reported, other ___________________ (circle one)
4. | Examiner standardization received: training, calibration, standardization, none, not reported (circle one)

### Analysis Information

1. | Type of analysis reported: intent to treat/observe, all with follow-up, only full participants (circle one)
2. | Exclusion from analysis criteria: _____________________________________________
3. | Tests of differences in complications reported: (give comparisons made, OR or RR, CI, and p value) ___________________________________________________________________________

### Complications Information

1. | Rates of complications (%): systemic infection: HIV/AIDS case: _____________ control:_____________________________________ list different rates if given by HIV disease stage: ________________________________________________ localized (wound) infection: HIV/AIDS case: _____________ control: ______________________________ list different rates if given by HIV disease stage: ________________________________________________ increased/delayed/persistent bleeding: HIV/AIDS case: _____________ control: _____________________ list different rates if given by HIV disease stage: ________________________________________________ delayed healing: HIV/AIDS case: _____________ control: _______________________________________ list different rates if given by HIV disease stage: ________________________________________________ dry socket: HIV/AIDS case: _____________ control: ___________________________________________ list different rates if given by HIV disease stage: ________________________________________________ other complication #1_______________: HIV/AIDS case: _____________ control: ___________________ list different rates if given by HIV disease stage: ________________________________________________ other complication #2_______________: HIV/AIDS case: _____________ control: ___________________ list different rates if given by HIV disease stage: ________________________________________________
2. | Criteria for systemic infection:____________________________________________________________ ____________________________________________________________________________________
3. | Criteria for localized wound infection:_______________________________________________________ ____________________________________________________________________________________
4. | Criteria for increased/delayed/persistent bleeding:_____________________________________________ ____________________________________________________________________________________
5. | Criteria for delayed healing:______________________________________________________________ ____________________________________________________________________________________
6. | Criteria for dry socket:__________________________________________________________________ ____________________________________________________________________________________
7. | Criteria or other complication #1:__________________________________________________________ ____________________________________________________________________________________
8. | Criteria for other complication #2:_________________________________________________________ ____________________________________________________________________________________
9. | Comments about relative morbidity of complications:____________________________________________ ____________________________________________________________________________________
10. | Other comments about limitations of study or analysis:__________________________________________ ____________________________________________________________________________________

## Question 2A: HIV Evidence Report abstraction form: Sensitivity, Specificity, PPV, and NPV of Oral Lesions as Markers of seroconversion (Recent HIV infection 6-12 weeks, aka primary infection, acute HIV)

### Administrative Information

1. | Abstractor:___________________________
2. | Date:________________
3. | Abbreviated study citation:_____________________________________________________________
  | first author | journal abbr. | year | volume pages

### Study Information

1. | Study design: multiple case reports, prospective seroconverter cohort, case-control, retrospective cohort, cross-sectional, other _____________________________ (circle one)
2. | Study period: (specify years in which conducted) _____________________
3. | Study/treatment site (include nation): hospital dental clinic, graduate program university clinic, undergraduate dental school clinic, health department dental clinic, private dental practice, general hospital, medical, clinic, private medical office, other__________________ (circle one)
4. | Examiners blind to HIV seroconversion status: yes no not reported (circle one)
5. | Time of HIV exposure known: definitely from records, reported by subject, estimated, not known, not reported (circle one)
6. | Time from HIV seroconversion to lesion diagnosis:< 1 month, < 2 months, < 3 months, > 3 months, unknown, other: _________________________________ (circle one)
7. | Criteria for recent seroconversion: ________________________________________________
8. | Frequency of periodic testing for seroconversion:____________________________________
9. | Prior HIV sero-status established for cases and controls: yes no not reported (circle one)

### Sample Information

1. | Description of population sampled: _________________________________________________ __________________________________________________________________________________
2. | Sample size: size of total sample selected: _______________________ size of case (HIV-exposed, acute HIV, seroconverters) sample selected: _________________ size of control (non-HIV-exposed, non-seroconverters) sample selected: ____________________
3. | Subject sample selection: random, systematic, cluster, convenience, specific criteria, not reported (circle one) (If specific criteria) ______________________________________________________________________________________________________________________________________________________________________________________________________________________________________________________

### Group Characteristics

#### Cases (or total if not reported by group)

1. | Age: | mean:_______ median: ______ range: ______________________
2. | Gender: | number (%) male:_______________ | number (%) female:______________
3. | Race: | number (%) white: ______________ | number (%) black: ______________
| | number (%) Hispanic: ___________ | number (%) Asian/Pacific Islander: _________
| | number (%) other or unknown:_________________
4. | HIV exposure category:
4. | number (%) MSM: __________________ | | number (%) IDU: ______________
4. | number (%) MSM& IDU: _____________ | | number (%)heterosexual: ________
4. | number (%) blood exposure: ___________ | | number (%) perinatal: ___________
4. | number (%) other or unknown:_________

### Controls

1. | Age: | mean:_______ median: ______ range: _____________
2. | Gender: | number (%) male:_______________ | number (%) female:______________
3. | Race: | number (%) white: ______________ | number (%) black: ______________
| | number (%) Hispanic: ___________ | number (%) Asian/Pacific Islander: _________
| | number (%) other or unknown:_________________
4. | HIV exposure category:
4. | number (%) MSM: __________________ | | number (%) IDU: ______________
4. | number (%) MSM& IDU: _____________ | | number (%)heterosexual: ________
4. | number (%) blood exposure: ___________ | | number (%) perinatal: ___________
4. | number (%) other or unknown:_________

### Provider/Examiner Information

1. | Number of examiners: _________
2. | Examiner professional training: dentist, physician, nurse, dental hygienist, not reported, other ___________________ (circle all that apply)
3. | Examiner standardization received: training, calibration, standardization, none, not reported (circle one)

#### Oral Lesion Diagnostic Criteria

1. | Hairy leukoplakia: clinical, standard criteria (EC-Clearinghouse/WHO and/or US Oral AIDS Collaborative Group), histological, microbiological, response to treatment, not reported, other: _____________________ (circle all that apply)
2. | Oral candidiasis: clinical, standard criteria (EC-Clearinghouse/WHO and/or US Oral AIDS Collaborative Group), histological, microbiological, response to treatment, unknown, other: _____________________ (circle all that apply)
3. | Necrotizing ulcerative periodontitis: clinical, standard criteria (EC-Clearinghouse/WHO and/or US Oral AIDS Collaborative Group), histological, microbiological, response to treatment, unknown, other: _____________________ (circle all that apply)
4. | Oral ulcers: clinical, standard criteria (EC-Clearinghouse/WHO and/or US Oral AIDS Collaborative Group), histological, microbiological, response to treatment, unknown, other: _____________________ (circle all that apply)
5. | Parotid swelling: clinical, standard criteria (EC-Clearinghouse/WHO and/or US Oral AIDS Collaborative Group), histological, microbiological, response to treatment, unknown, other: _____________________ (circle all that apply)
6. | Linear gingival erythema:_________________: clinical, standard criteria (EC-Clearinghouse/WHO and/or US Oral AIDS Collaborative Group), histological, microbiological, response to treatment, unknown, other: _____________________ (circle all that apply)
7. | Other # 1 specify: _________________: clinical, standard criteria (EC-Clearinghouse/WHO and/or US Oral AIDS Collaborative Group), histological, microbiological, response to treatment, unknown, other: _____________________ (circle all that apply)
8. | Other # 2 specify:_________________: clinical, standard criteria (EC-Clearinghouse/WHO and/or US Oral AIDS Collaborative Group), histological, microbiological response to treatment, unknown, other: _____________________ (circle all that apply)

### Reported Results

| Hairy Leuko-plakia | Oral Candid-iasis | Necro-tizing Ulcera-tive Perio-dontitis | Oral Ulcers | Parotid Swelling | Linear Gingival Erythema | Other 1 (specify) | Other 2 (specify)
# of lesions in sero-converting cases | ______ | ______ | ______ | ______ | ______ | ______ | ______ | ______
% of sero-converting cases with lesions | ______ | ______ | ______ | ______ | ______ | ______ | ______ | ______
# of lesions in non-seroconverting controls | ______ | ______ | ______ | ______ | ______ | ______ | ______ | ______
% of non-seroconverting controls with lesions | ______ | ______ | ______ | ______ | ______ | ______ | ______ | ______
OR/RR (HIV AB +) | ______ | ______ | ______ | ______ | ______ | ______ | ______ | ______
95% CI | ______ | ______ | ______ | ______ | ______ | ______ | ______ | ______
p value | ______ | ______ | ______ | ______ | ______ | ______ | ______ | ______
Sensitivity (HIV AB +) | ______ | ______ | ______ | ______ | ______ | ______ | ______ | ______
Specificity (HIV AB +) | ______ | ______ | ______ | ______ | ______ | ______ | ______ | ______
PPV (HIV AB +) | ______ | ______ | ______ | ______ | ______ | ______ | ______ | ______
NPV (HIV AB +) | ______ | ______ | ______ | ______ | ______ | ______ | ______ | ______

## Question 2B: HIV Evidence Report Abstraction Form: Sensitivity, Specificity, PPV, and NPV of Oral Lesions for Immune Suppression and Viral Load

### Administrative Information

1. | Abstractor:___________________________
2. | Date:________________
3. | Abbreviated study citation:__________________________________________________________
| | first author | journal abbr. | year | volume | pages

### Study Information

1. | Study design: multiple case reports, prospective cohort, retrospective cohort, case-control, cross-sectional, other_____________________________ (circle one)
2. | Study period: (specify years in which conducted)_____________________
3. | Study/treatment site (include nation): hospital dental clinic, graduate program university clinic, undergraduate dental school clinic, health department dental clinic, private dental practice, other__________________ (circle one)
4. | Examiners blind to immune suppression/viral load: yes no not reported (circle one)
5. | CD4/viral load testing time interval from lesion diagnosis: same day, < 1 month, 32 days to 2 months, 64 days to 3 months, >3 months, not reported, other:______________________________ (circle one)

### Sample Information

1. | Description of population sampled: _________________________________________________ ________________________________________________________________________________
2. | Sample size: total sample size: _______________________ more immunosuppressed sample size: ______________________ less immunosuppressed sample size: _______________________
3. | Subject sample selection: random, systematic, cluster, convenience, specific criteria, not reported (circle one) (If specific criteria, describe) ___________________________________________________________________________________ ___________________________________________________________________________________ __________________________________________________________

### Group Characteristics

Cases (or total if not reported by group)

1. | Age: | mean:_______ median: ______ range: ______________________
2. | Gender: | number (%) male:_______________ | number (%) female:_____________
3. | Race: | number (%) white: ______________ | number (%) black: _____________
3. | Race: | number (%) Hispanic: ___________ | number (%) Asian/Pacific Islander: _________
3. | Race: | number (%) other or unknown:_________________
4. | HIV transmission risk behavior:
4. | number (%) MSM: _______________ | | number (%) IDU: ___________
4. | number (%) MSM& IDU: __________ | | number (%)heterosexual: _____
4. | number (%) blood exposure: ________ | | number (%) perinatal: ________
4. | number (%) other or unknown:______
5. | HIV disease stage (Centers for Disease Control case definition): __________________________________
5. | number (%) AIDS: _______ | number (%) symptomatic: _______ | number (%) asymptomatic: _______
5. | number (%) CD4 <200: _______ | number (%) CD4 200-499 _______ | number (%) CD4 >500: _______
6. | Recent CDR Data: CD4 mean:_____________ SD:_____________ range: ____________________
7. | Plasma viral load data: HIV RNA mean: __________ median: __________ CD4 range: ____________
8. | Viral load parameter used: describe: ______________________________________________
9. | Antiretroviral therapy: | number (%) none: | __________
9. | Antiretroviral therapy: | number (%) non-HAART (all study pre-1996): | __________
9. | Antiretroviral therapy: | number ($) HAART (+protease inhibitor): | __________

### Controls

1. | Age: | mean:_______ median: ______ range: _____________
2. | Gender: | number (%) male:_______________ | number (%) female:______________
3. | Race: | number (%) white: ______________ | number (%) black: ______________
3. | Race: | number (%) Hispanic: ___________ | number (%) Asian/Pacific Islander: _________
3. | Race: | number (%) other or unknown:_________________
4. | HIV transmission risk behavior:
4. | number (%) MSM: __________________ | | number (%) IDU: ______________
4. | number (%) MSM& IDU: _____________ | | number (%)heterosexual: ________
4. | number (%) blood exposure: ___________ | | number (%) perinatal: ___________
4. | number (%) other or unknown:_________
5. | HIV disease stage (Centers for Disease Control case definition): ___________________________________
5. | number (%) AIDS: ________ | number (%) symptomatic: ________ | number (%) asymptomatic: ________
5. | number (%) CD4 <200: ________ | number (%) CD4 200-499 ________ | number (%) CD4 >500: ________
6. | Recent CD4 Data: CD4 mean:_____________ SD:_____________ range: ____________________
7. | Plasma viral load data: HIV RNA mean: __________ median: __________ CD4 range: ____________
8. | Viral load parameter used: describe: ______________________________________________
9. | Antiretroviral therapy: | number (%) none: | __________
9. | Antiretroviral therapy: | number (%) non-HAART (all study pre-1996): | __________
9. | Antiretroviral therapy: | number (%) HAART (+protease inhibitor): | __________
9. | Antiretroviral therapy: | number (%) unknown: | __________

### Provider/Examiner information

1. | Number of examiners:_________
2. | Examiner professional training: dentist, physician, nurse, dental hygienist, not reported, other ___________________ (circle all that apply)
3. | Examiner standardization received: training, calibration, standardization, none, not reported (circle one)

#### Oral Lesion Diagnostic Criteria

1. | Hairy leukoplakia: clinical, standard criteria (EC-Clearinghouse/WHO and/or US Oral AIDS Collaborative Group), histological, microbiological, response to treatment, unknown, other: _____________________ (circle all)
2. | Oral candidiasis: clinical, standard criteria (EC-Clearinghouse/WHO and/or US Oral AIDS Collaborative Group), histological, microbiological, response to treatment, unknown, other: _____________________ (circle all)
3. | Necrotizing ulcerative periodontitis: clinical, standard criteria (EC-Clearinghouse/WHO and/or US Oral AIDS Collaborative Group), histological, microbiological, response to treatment, unknown, other: _____________________ (circle all that apply)
4. | Oral ulcers: clinical, standard criteria (EC-Clearinghouse/WHO and/or US Oral AIDS Collaborative Group), histological, microbiological, response to treatment, unknown, other: _____________________ (circle all that apply)
5. | Parotid swelling: clinical, standard criteria (EC-Clearinghouse/WHO and/or US Oral AIDS Collaborative Group), histological, microbiological, response to treatment, unknown, other: _____________________ (circle all that apply)
6. | Kaposi's sarcoma: clinical, standard criteria (EC-Clearinghouse/WHO and/or US Oral AIDS Collaborative Group), histological, microbiological, response to treatment, unknown, other: _____________________ (circle all that apply)
7. | Linear gingival erythema: clinical, standard criteria (EC-Clearinghouse/WHO and/or US Oral AIDS Collaborative Group), histological, microbiological, response to treatment, unknown, other: _____________________ (circle all that apply)
8. | Other # 1 specify: _________________: clinical, standard criteria (EC-Clearinghouse/WHO and/or US Oral AIDS Collaborative Group), histological, microbiological, response to treatment, unknown, other: _____________________ (circle all that apply)
9. | Other # 2 specify:_________________: clinical, standard criteria (EC-Clearinghouse/WHO and/or US Oral AIDS Collaborative Group), histological, microbiological response to treatment, unknown, other: _____________________ (circle all that apply)

### Reported Results

| Hairy Leukoplakia | Oral Candidiasis | Necrotizing Ulcerative Periodontitis | Oral Ulcers | Parotid Swelling | Kaposi's Sarcoma | Linear Gingival Erythema | Other 1 (specify) | Other 2 (specify)
# of lesions in more immuno-compromised | _______ | _______ | _______ | _______ | _______ | _______ | _______ | _______ | _______
% more immuno-compromised cases with lesions | _______ | _______ | _______ | _______ | _______ | _______ | _______ | _______ | _______
# of lesions in less immuno-compromised | _______ | _______ | _______ | _______ | _______ | _______ | _______ | _______ | _______
% less immuno-compromised cases with lesions | _______ | _______ | _______ | _______ | _______ | _______ | _______ | _______ | _______
OR/RR (CD4<200) | _______ | _______ | _______ | _______ | _______ | _______ | _______ | _______ | _______
95% CI | _______ | _______ | _______ | _______ | _______ | _______ | _______ | _______ | _______
p value | _______ | _______ | _______ | _______ | _______ | _______ | _______ | _______ | _______
Sensitivity (CD4<200) | _______ | _______ | _______ | _______ | _______ | _______ | _______ | _______ | _______
Specificity (CD4<200) | _______ | _______ | _______ | _______ | _______ | _______ | _______ | _______ | _______
PPV (CD4<200) | _______ | _______ | _______ | _______ | _______ | _______ | _______ | _______ | _______
NPV (CD4<200) | _______ | _______ | _______ | _______ | _______ | _______ | _______ | _______ | _______
OR/RR (Hi VL) | _______ | _______ | _______ | _______ | _______ | _______ | _______ | _______ | _______
95% CI | _______ | _______ | _______ | _______ | _______ | _______ | _______ | _______ | _______
p value | _______ | _______ | _______ | _______ | _______ | _______ | _______ | _______ | _______
Sensitivity (Hi VL) | _______ | _______ | _______ | _______ | _______ | _______ | _______ | _______ | _______
Specificity (Hi VL) | _______ | _______ | _______ | _______ | _______ | _______ | _______ | _______ | _______
PPV (Hi VL) | _______ | _______ | _______ | _______ | _______ | _______ | _______ | _______ | _______
NPV (Hi VL) | _______ | _______ | _______ | _______ | _______ | _______ | _______ | _______ | _______

## Question 3A: HIV Evidence Report Abstraction Form: Efficacy of Antifungal Prophylaxis For Oral Candidiasis in HIV Patients

### Administrative Information

1. | Abstractor:___________________________
2. | Date:________________
3. | Abbreviated study citation:_____________________________________________________________
| | first author | journal abbr. | year | volume # | pages

### Study Information

1. | Study design: randomized controlled trial (RCT), nonrandomized controlled trial, RCT with crossover, other_____________________________ (circle one)
2. | Placebo used yes no (circle one)
3. | Number of active groups: _______
4. | Study period: (specify years in which conducted)_____________________
5. | Study/treatment site (include nation): hospital dental clinic, graduate program university clinic, undergraduate dental clinic, health department dental clinic, private dental practice, other__________________ (circle one)
6. | Duration of prophylactic treatment:_____ days or _______ weeks or ______ months
7. | Dose and schedule of treatment group(s) (XX mgs., Y times / day, week, month)
  Group 1 or only group:________________________ | Group 2:_____________________________
8. | Duration of evaluation period:_____ days or _______ weeks or ______ months
9. | Drug use compliance monitoring: yes no not reported (circle one)
10. | Number of evaluation time points ______ and interval __________ (e.g. 4 times, every month)
11. | Blinding to active drug: examiners blind, patient blind, patients and examiners blind, no blinding, not reported (circle one)

### Sample Information

1. | Description of population sampled: _________________________________________________ __________________________________________________________________________________
2. | Sample size:
2. | _____ = total subjects
2. | _____ = group 1 (or only active drug 1 group subjects)
2. | _____ = group 2 (active drug 2 group) subjects
2. | _____ = placebo
3. | Subject sample selection: random, systematic, cluster, convenience, specific criteria, unknown (circle one) (If specific criteria, describe inclusion and exclusion) ______________________________________________________________________________________________________________________________________________________________________________________________________________________________________________________

### Group Characteristics

#### Group 1 (or total if not reported by group)

1. | Subject Age: | mean:_______ median: ______ range: ______________________
2. | Subject Gender: | number (%) male:_______________ | number (%) female:______________
3. | Subject Race: | number (%) white: ______________ | number (%) black: ______________
3. | Subject Race: | number (%) Hispanic: ___________ | number (%) Asian/Pacific Islander: _______
3. | Subject Race: | number (%) other or unknown: ___________
4. | HIV transmission risk behavior:
4. | number (%) MSM: __________________ | | number (%) IDU: ______________
4. | number (%) MSM& IDU: _____________ | | number (%)heterosexual: ________
4. | number (%) blood exposure: ___________ | | number (%) perinatal: ___________
4. | number (%) other or unknown:_________
5. | HIV disease stage (Centers for Disease Control case definition): ___________________________________
5. | number (%) AIDS:_____ | number (%) symptomatic (ARC):_____ | number (%) asymptomatic:_____
5. | number (%) CD4 <200:_____ | number (%) CD4 200-499 _____ | number (%) CD4 >500:_____
6. | Antiretroviral therapy: | number (%) none: | __________
6. | Antiretroviral therapy: | number (%) non-HAART (all study pre-1996): | __________
6. | Antiretroviral therapy: | number (%) HAART (+protease inhibitor): | __________
6. | Antiretroviral therapy: | number (%) unknown: | ___________
7. | Viral load data: unknown or describe: _____________________________________________
8. | Previous oral candidiasis experience: number (%) with >1 episode or recurrent candidiasis________ frequency of oral candidiasis episodes or recurrences____________

#### Group 2

1. | Age: | mean:_______ median: ______ range: ______________________
2. | Gender: | number (%) male:_______________ | number (%) female:______________
3. | Race: | number (%) white: ______________ | number (%) black: ______________
3. | Race: | number (%) Hispanic: ___________ | number (%) Asian/Pacific Islander: _________
3. | Race: | number (%) other or unknown:_________________
4. | HIV transmission risk behavior:
4. | number (%) MSM: __________________ | | number (%) IDU: ______________
4. | number (%) MSM& IDU: _____________ | | number (%)heterosexual: ________
4. | number (%) blood exposure: ___________ | | number (%) perinatal: ___________
4. | number (%) other or unknown:_________
5. | HIV disease stage (Centers for Disease Control case definition): ___________________________________
5. | number (%) AIDS: ______ | number (%) symptomatic (ARC): ______ | number (%) asymptomatic: ______
5. | number (%) CD4 <200: ______ | number (%) CD4 200-499 ______ | number (%) CD4 >500: ______
6. | Antiretroviral therapy: | number (%) none: | __________
6. | Antiretroviral therapy: | number (%) non-HAART (all study pre-1996): | __________
6. | Antiretroviral therapy: | number (%) HAART (+protease inhibitor): | __________
6. | Antiretroviral therapy: | number (%) unknown: ___________
7. | Viral load data: unknown or describe: _____________________________________________
8. | Previous oral candidiasis experience: number (%) with >1 episode or recurrent candidiasis________ frequency of oral candidiasis episodes or recurrences____________

#### Placebo Group

1. | Subject Age: | mean:_______ median: ______ range: ______________________
2. | Subject Gender: | number (%) male:_______________ | number (%) female:______________
3. | Subject Race: | number (%) white: ______________ | number (%) black: ______________
3. | number (%) Hispanic: ___________ | number (%) Asian/Pacific Islander: _________
3. | number (%) other or unknown:_________________
4. | HIV transmission risk behavior:
4. | number (%) MSM: __________________ | | number (%) IDU: ______________
4. | number (%) MSM& IDU: _____________ | | number (%)heterosexual: ________
4. | number (%) blood exposure: ___________ | | number (%) perinatal: ___________
4. | number (%) other or unknown:_________
5. | HIV disease stage (Centers for Disease Control case definition): ___________________________________
5. | number (%) AIDS: ______ | number (%) symptomatic (ARC): ______ | number (%) asymptomatic: ______
5. | number (%) CD4 <200: ______ | number (%) CD4 200-499 ______ | number (%) CD4 >500: ______
6. | Antiretroviral therapy: | number (%) none: | __________
6. | Antiretroviral therapy: | number (%) non-HAART (all study pre-1996): | __________
6. | Antiretroviral therapy: | number (%) HAART (+protease inhibitor): | __________
6. | Antiretroviral therapy: | number (%) unknown: ___________
7. | Viral load data: unknown or describe: _____________________________________________
8. | Previous oral candidiasis experience: number (%) with >1 episode or recurrent candidiasis________ frequency of oral candidiasis episodes or recurrences____________

### Provider/Examiner Information

1. | Number of examiners: _________
2. | Examiners received: training, calibration, standardization, none, not reported(circle one)

### Analysis Information

1. | Type of analysis reported: intent to treat, all with follow-up, only full participants (circle one)
2. | Exclusion from analysis criteria: _____________________________________________

### Outcome Information

1. | Variant of oral candidiasis targeted for prevention: oral candidiasis variant not specified, pseudomembraneous candidiasis (thrush), erythematous candidiasis, angular cheilitis, other _________________ (circle all that apply)
3. | Antifungal resistance testing: yes no not reported (circle one)
  a. | Drug:___________________ | Outcome: _________________________________
  b. | Drug:___________________ | Outcome: _________________________________
4. | Criteria for Clinical Endpoints/Harms: (define criteria) be sure these are endpoints for oral or oropharyngeal candidiasis only, and not vaginal, esophageal, or other site candidiasis
  a. | Clinical Success: ____________________________________________________________
  b. | Clinical Failure: _____________________________________________________________
  c. | Mycologic Relapse:__________________________________________________________
  d. | Mycologic Cure:______________________________________________________________
  e. | Mycologic Colonization: _______________________________________________________
  f. | Drug Resistance: _____________________________________________________________
  g. | Other Endpoint #1:____________________________________________________________
  h. | Other Endpoint #2:____________________________________________________________
  i. | Other Endpoint #3:____________________________________________________________
5. | Criteria for oral candidiasis diagnosis: positive candidal culture, positive swab KOH prep, positive swab from Gram stain, clinical signs (e.g., white plaques, inflammation,___________________________), clinical symptoms (e.g., pain, burning, dysphagia,____________________), response to antifungal treatment, other________________________________ (circle all that apply)
6. | Adverse effects (type, number, %, drug group)_____________________________________________ ______________________________________________________________________________________

## Question 3B: HIV Evidence Report Abstraction Form: Effectiveness of Available Antifungal Agents for Treatment of Oral Candidiasis in HIV/AIDS patients

### Administrative Information

1. | Abstractor:___________________________
2. | Date:________________
3. | Abbreviated study citation:_____________________________________________________________
| | first author | journal abbr. | year | volume # | pages

### Study Information

1. | Type of design: randomized controlled trial (RCT), nonrandomized controlled trial, RCT with crossover, other_____________________________ (circle one)
2. | Placebo used yes no (circle one)
3. | Number of active groups: _______
4. | Study period: (specify years in which conducted)_____________________
5. | Study/treatment site (include nation): hospital dental clinic, graduate program university clinic, undergraduate dental clinic, health department dental clinic, private dental practice, other__________________ (circle one)
6. | Duration of treatment:_____ days or _______ weeks or ______ months
7. | Dose and schedule of treatment group(s) (XX mgs., Y times / day, week, month)
  Group 1 or only group:________________________
  Group 2:_____________________________
  Group 3:_____________________________ Placebo: _____________________________
8. | Duration of evaluation period:_____ days or _______ weeks or ______ months
9. | Drug use compliance monitoring: yes no not reported (circle one)
10. | Number of evaluation time points ______ and interval __________ (e.g. 4 times, every month)
11. | Blinding to active drug: examiners blind, patient blind, patients and examiners blind, no blinding, not reported (circle one)

### Sample Information

1. | Description of population sampled: _________________________________________________ __________________________________________________________________________________
2. | Sample size: _____________= total subjects _____________= Group 1 or only active drug group subjects _____________= Group 2 (active drug) subjects _____________= Group 3 (active drug) subjects _____________= placebo (control) subjects
3. | Subject selection: random, systematic, cluster, convenience, specific criteria, unknown (circle one) (If specific criteria, describe inclusion and exclusion) _______________________________________________________________________________________________________________________________________________________________________________________________________________________________________________________________________________________

### Group Characteristics

#### Group 1

1. | Subject Age: | mean:_______ median: ______ range: __________
2. | Subject Gender: | number (%) male:_______________ | number (%) female:______________
3. | Subject Race: | number (%) white: ______________ | number (%) black: ______________
3. | Subject Race: | number (%) Hispanic: ___________ | number (%) Asian/Pacific Islander: _________
3. | Subject Race: | number (%) other or unknown:_________________
4. | HIV exposure category number:
4. | number (%) MSM: __________________ | | number (%) IDU: ______________
4. | number (%) MSM& IDU: _____________ | | number (%)heterosexual: ________
4. | number (%) blood exposure: ___________ | | number (%) perinatal: ___________
4. | number (%) other or unknown:_________
5. | Number of years infected (circle one: since known seroconversion or since first HIV + antibody test):
5. | mean: ________ | median: ________ | range: ________
6. | HIV disease stage (Centers for Disease Control case definition): ___________________________________
  number (%) AIDS: ______ | number (%) symptomatic (ARC): ______ | number (%) asymptomatic: ______
  number (%) CD4 <200: ______ | number (%) CD4 200-499 ______ | number (%) CD4 >500: ______
7. | Antiretroviral therapy: | number (%) none: | __________
7. | Antiretroviral therapy: | number (%) non-HAART (all study pre-1996): | __________
7. | Antiretroviral therapy: | number (%) HAART (+protease inhibitor): | __________
7. | Antiretroviral therapy: | number (%) unknown: | __________
8. | Viral load data: describe: _____________________________________________
9. | Previous oral candidiasis experience: number (%) with >1 episode or recurrent candidiasis________ frequency of oral candidiasis episodes or recurrences____________

#### Group 2

1. | Subject Age: | mean:_______ median: ______ range: __________
2. | Subject Gender: | number (%) male:_______________ | number (%) female:______________
3. | Subject Race: | number (%) white: ______________ | number (%) black: ______________
3. | Subject Race: | number (%) Hispanic: ___________ | number (%) Asian/Pacific Islander: _________
3. | Subject Race: | number (%) other or unknown:_________________
4. | HIV exposure category number:
4. | number (%) MSM: __________________ | | number (%) IDU: ______________
4. | number (%) MSM& IDU: _____________ | | number (%) heterosexual: ________
4. | number (%) blood exposure: ___________ | | number (%) perinatal: ___________
4. | number (%) other or unknown:_________
5. | Number of years infected (circle one: since known seroconversion or since first HIV + antibody test):
5. | mean: ________ | median: ________ | range: ________
6. | HIV disease stage (Centers for Disease Control case definition): ___________________________________
6. | number (%) AIDS: ______ | number (%) symptomatic (ARC): ______ | number (%) asymptomatic: ______
6. | number (%) CD4 <200: ______ | number (%) CD4 200-499 ______ | number (%) CD4 >500: ______
7. | Antiretroviral therapy: | number (%) none: | __________
7. | Antiretroviral therapy: | number (%) non-HAART (all study pre-1996): | __________
7. | Antiretroviral therapy: | number (%) HAART (+protease inhibitor): | __________
7. | Antiretroviral therapy: | number (%) unknown: | __________
8. | Viral load data: describe: _____________________________________________
9. | Previous oral candidiasis experience: number (%) with >1 episode or recurrent candidiasis________ frequency of oral candidiasis episodes or recurrences____________

#### Group 3

1. | Subject Age: | mean:_______ median: ______ range: ______
2. | Subject Gender: | number (%) male:_______________ | number (%) female:______________
3. | Subject Race: | number (%) white: ______________ | number (%) black: ______________
3. | Subject Race: | number (%) Hispanic: ___________ | number (%) Asian/Pacific Islander: _________
3. | Subject Race: | number (%) other or unknown:_________________
4. | HIV exposure category number:
4. | number (%) MSM: __________________ | | number (%) IDU: ______________
4. | number (%) MSM& IDU: _____________ | | number (%)heterosexual: ________
4. | number (%) blood exposure: ___________ | | number (%) perinatal: ___________
4. | number (%) other or unknown:_________
5. | Number of years infected (circle one: since known seroconversion or since first HIV + antibody test):
5. | mean: ________ | median: ________ | range: ________
6. | HIV disease stage (Centers for Disease Control case definition): ___________________________________
  number (%) AIDS: ______ | number (%) symptomatic (ARC): ______ | number (%) asymptomatic: ______
  number (%) CD4 <200: ______ | number (%) CD4 200-499 ______ | number (%) CD4 >500: ______
7. | Antiretroviral therapy: | number (%) none: | __________
7. | Antiretroviral therapy: | number (%) non-HAART (all study pre-1996): | __________
7. | Antiretroviral therapy: | number (%) HAART (+protease inhibitor): | __________
7. | Antiretroviral therapy: | number (%) unknown: | __________
8. | Viral load data: describe: _____________________________________________
9. | Previous oral candidiasis experience:number (%) with >1 episode or recurrent candidiasis________ frequency of oral candidiasis episodes or recurrences____________

### Placebo Group

1. | Subject Age: | mean:_______ median: ______ range: ______________________
2. | Subject Gender: | number (%) male:_______________ | number (%) female:______________
3. | Subject Race: | number (%) white: ______________ | number (%) black: ______________
3. | Subject Race: | number (%) Hispanic: ___________ | number (%) Asian/Pacific Islander: _________
3. | Subject Race: | number (%) other or unknown:_________________
4. | HIV exposure category number:
4. | number (%) MSM: __________________ | | number (%) IDU: ______________
4. | number (%) MSM& IDU: _____________ | | number (%)heterosexual: ________
4. | number (%) blood exposure: ___________ | | number (%) perinatal: ___________
4. | number (%) other or unknown:_________
5. | Number of years infected (circle one: since known seroconversion or since first HIV + antibody test):
5. | mean: ________ | median: ________ | range: ________
6. | HIV disease stage (Centers for Disease Control case definition): ___________________________________
  number (%) AIDS: ______ | number (%) symptomatic (ARC): ______ | number (%) asymptomatic: ______
  number (%) CD4 <200: ______ | number (%) CD4 200-499 ______ | number (%) CD4 >500: ______
7. | Antiretroviral therapy: | number (%) none: | __________
7. | Antiretroviral therapy: | number (%) non-HAART (all study pre-1996): | __________
7. | Antiretroviral therapy: | number (%) HAART (+protease inhibitor): | __________
7. | Antiretroviral therapy: | number (%) unknown: | __________
8. | Viral load data: describe: _____________________________________________
9. | Previous oral candidiasis experience: number (%) with >1 episode or recurrent candidiasis________ frequency of oral candidiasis episodes or recurrences____________

### Provider/Examiner Information

1. | Number of examiners:_________
2. | Examiners received: training, calibration, standardization, none, not reported(circle one)

### Analysis Information

1. | Type of analysis reported: intent to treat/observe, all with follow-up, only full participants (circle one)
2. | Exclusion from analysis criteria: _____________________________________________

### Outcome Information

1. | Variant of oral candidiasis targeted for treatment: oral candidiasis variant not specified, pseudomembraneous candidiasis (thrush), erythematous candidiasis, angular cheilitis, other _________________ (circle all that apply)
3. | Antifungal resistance testing: yes no not reported (circle one)
  c. | Drug:___________________ | Outcome: _________________________________
  d. | Drug:___________________ | Outcome: _________________________________
4. | Criteria for Clinical Endpoints/Harms: (define criteria) be sure these are endpoints for oral or oropharyngeal candidiasis only, and not vaginal, esophageal, or other site candidiasis
  a. | Clinical Success: ______________________________________________________________
  b. | Clinical Failure: _______________________________________________________________
  c. | Mycologic Relapse:____________________________________________________________
  d. | Mycologic Cure:______________________________________________________________
  e. | Mycologic Colonization: _______________________________________________________
  f. | Fungal Speciation: : ___________________________________________________________
  g. | Drug Resistance: _____________________________________________________________
  h. | Other Endpoint #1:____________________________________________________________
  i. | Other Endpoint #2:____________________________________________________________
  j. | Other Endpoint #3:____________________________________________________________
5. | Criteria for oral candidiasis diagnosis: positive candidal culture, positive swab KOH prep, positive swab from Gram stain, clinical signs (e.g., white plaques, inflammation,___________________________), clinical symptoms (e.g., pain, burning, dysphagia,____________________), response to antifungal treatment, other________________________________ (circle all that apply)
6. | Adverse effects (type, number, %, drug group)_____________________________________________ ______________________________________________________________________________________