# Appendix B. Selection, Composition, and Role of the Technical Expert Advisory Group

We gratefully acknowledge the substantial involvement of and assistance from the Technical Expert Advisory Group (TEAG). TEAG members are listed at the end of this Appendix. The TEAG was meant in part to contribute to (a) advancing AHRQ's broader goals of creating and maintaining "science partnerships" and "public-private partnerships" and (b) meeting the needs of a broad array of potential consumers and users of its products. Thus, it was both a substantial resource and a sounding board throughout the study, and it is the body from whom expert inputs were formally sought at several points through the project.

We constituted our TEAG from three types of technical experts and other partners. These types are (1) technical/clinical experts, (2) patients or representatives of organizations whose mission concerns the interests and perspectives of patients and the public generally, and (3) potential users of the final evidence report, including explicitly a representative of the primary dental professional organization in the United States -- the American Dental Association (ADA). All in all, we had four clinical/technical experts, one individual representing persons with HIV, and one individual representing potential user groups, for a total of six persons on the TEAG.

The final decision about TEAG membership was based on candidates' availability for scheduled conference calls and other input, willingness to review materials and provide advice and assistance within a short turnaround time, and approval by the Task Order Officer of the Agency for Healthcare Research and Quality.

The RTI-UNC Center team solicited the views of TEAG members from the start of the project. Among other issues, TEAG members provided insights and reactions to key clinical questions, input to the literature review process (by ensuring that we included all known published research meeting our inclusion criteria), review of our data abstraction forms, and review of our draft evidence tables. TEAG members also provided valuable input on problems of focusing a literature search on treatments and specifying appropriate outcomes for a clinical topic as complex as the management of HIV-positive patients.

In keeping with AHRQ's standards for employing a multidisciplinary approach to the development of evidence reports, we called on our TEAG for input at two key points during this task. First, the members of the group were asked to comment on the literature synthesis and to give us feedback on our overall plans at that stage of the analysis, which included approaches to developing evidence tables and to summarizing information about outcomes associated with the options being studied in our review of the management of dental patients who are HIV positive. Second, they were asked to review the draft evidence report for completeness, correctness, and clarity.

## TEAG Members

- Dental Researcher
- Charles Barr, D.D.S., M.S.
- Division of Oral Medicine
- Department of Oral Diagnosis
- School of Dental Medicine
- University of Connecticut Health Center

- Clinical Experts
- John G. Bartlett, M.D.
- Chief, Division of Infectious Diseases
- School of Medicine
- Johns Hopkins University
- Michael Glick, D.M.D., B.MD.Sc.
- Programs for Medically Complex Patients
- University of Pennsylvania
- Lisa Kaplowitz, M.D.
- Director, HIV/AIDS Center
- Virginia Commonwealth University

- Consumer Organization
- Deborah Greenspan, B.D.S., L.D.S., R.C.S., D.Sc.
- Department of Stomatology
- School of Dentistry
- University of California - San Francisco
- Representing National Association of Persons with AIDS (NAPWA)

- User Group
- Sol Silverman, Jr., D.D.S., M.A.
- Department of Stomatology
- School of Dentistry
- University of California at San Francisco
- Representing American Dental Association (ADA)