# Appendix A. Acknowledgments

This study was supported by Contract No. 290-97-0011, Task Number 6, from the Agency for Healthcare Research and Quality (AHRQ), formerly the Agency for Health Care Policy and Research (AHCPR). We acknowledge the assistance of Jacqueline Besteman, J.D., M.A., the AHRQ Task Order Officer for the Evidence-based Practice Center Program, and Ernestine W. Murray, R.N., M.A.S., the AHRQ Task Order Officer for this report. The cooperation and support of Isabel Garcia, D.D.S., M.P.H., the National Institute of Dental and Craniofacial Research (NIDCR) liaison with AHRQ, has been greatly appreciated. The help of NIDCR staff Drs. Louis DePaula and Jim Lipton, who were involved in the planning of the State of the Science Workshop on the management of HIV-positive dental patients that was held in December 2000, is gratefully acknowledged.

We recognize the role that the Technical Expert Advisory Group (TEAG) has played in shaping and producing this evidence report. In addition, the Research Triangle Institute-University of North Carolina at Chapel Hill Evidence-based Practice Center (RTI-UNC EPC) thanks its Scientific Advisers --- Samuel J. Arbes, Jr., D.D.S., Ph.D., M.P.H.; Amid Ismail, B.D.S., M.P.H., Dr.P.H.; Jan Clarkson, B.D.S., Ph.D.; and Alex White, D.D.S., Dr.P.H., M.S. -- for providing their expertise throughout the project.

The investigators appreciate the time and assistance of the data abstractors. The clinical data abstractors were Sally Maurellio, M.Ed.; Alison Lohman, D.D.S.; and Dena Fischer, D.D.S. The automated search expertise of Lynn Whitener, Dr.P.H., M.S.L.S., and the administrative assistance of Donna Curasi also contributed to the data collection phase of the project.

We thank the following individuals from the University of North Carolina at Chapel Hill: Gordon DeFriese, Ph.D., Co-Director of the RTI-UNC EPC, Timothy S. Carey, M.D., M.P.H., Scientific Adviser to the RTI-UNC EPC, and John Stamm, D.D.S., M.Sc.D., D.D.P.H, Dean of the School of Dentistry. Finally, we also thank our RTI colleagues Nancy Berkman, Ph.D., Anjolie Idicula, B.A., and Cristina Garces, B.A., for guidance in preparing this report, Terri Kissiah for her outstanding word processing skills and logistical support, and Richard Strowd, J.D., and Tim Weinzapfel, C.A.C.M., for their contracting assistance.