# Evidence Tables

## Acronyms and Abbreviations Used in the Evidence Tables

Abbr. | Definition
ANCOVA | analysis of covariance
APF | acidulated phosphate fluoride
ca | caries-active
CFU | colony-forming unit
CHX | chlorhexidine
com | comparison
conc | concentration
CV | coefficient of variation
DEJ | dentoenamel junction
DMF | decayed, missing, and filled permanent teeth
dmfs | decayed, missing, and filled surfaces on primary teeth
DMFS | decayed, missing, and filled surfaces on permanent teeth
DMFT | decayed, missing, and filled permanent teeth
EC | electrical conductance
ECM | brand name of electronic caries meter
exp | experimental
FOTI | fiberoptic tranillumination
F=f | community water fluoridated
F=nf | community water not fluoridated
G-RCT | controlled trial with group randomization
Gy | grays
ICC | intraclass correlation coefficient
ITT | intention to treat
mol | molar
mS | mutans Streptococcus
n/a | not applicable
NaF | sodium fluoride
nf | not fluoridated
NNT | number needed to treat
NR | not reported
ns | not significant
non-RCT | clinical trial without individuals randomized to treatment
occ | occlusal
OHI | oral hygiene instruction
perm | permanent
pre | premolar
prev | prevalence
prophy | prophylaxis
prox | proximal
RCI | root caries index
RCT | randomized controlled trial
RS | root surface
SnF, SnF_2_ | stannous fluoride
sub | subanalysis of caries-active
surf | surface
train | training
TiF | titanium tetrafluoride
Tx | treatment

Evidence Table 1. Diagnosis of dental caries -- in vivo

Author, Year | | Diagnostic Method | Teeth and Surfaces | No. of Sites | Validation Method | Validator Reliability | Caries Prev. | No. of Examiners | Train. of Examiners | Subj. Age | Selection Criteria | Criteria for Caries | Interrater Reliability | Mean Intrarater Reliability | Sensitivity | Specificity | Quality Score
Radiographic Methods-Permanent Posterior Teeth-Proximal Surfaces-Cavitated Lesions
1 S1 | Rugg-Gunn, 1972^ 37 ^ | D-speed bitewing film, read x1.5 | permanent posterior proximals out of out of contact <1 year | 370 | visual/tactile inspection | NR | 9% | NR | NR | mean=13.9 years | NR | radiolucency in enamel and outer 1/2 of dentin | NR | NR | 0.35 | 1.00 | 60
2 S2 | Downer & O'Mullane, 1975b^ 35 ^ | D-speed bitewing film, read x1.5 | permanent posterior proximals | 185 | microscopy 200m sections, read x2.5 | NR | 36% | NR | NR | teenaged donors | teeth extracted during trial | radiolucency reaching DEJ or beyond | NR | r=0.97 | 0.73 | 0.97 | 70
3 S3 | Mejare, Grondahl, Carlstedt, et al., 1985^ 38 ^ | D-speed bitewing film | permanent posterior proximal surfaces | 598 | visual inspection | consensus of 3 examiners | 5% | 3 -- all calls based on consensus (assume 1) | NR | mean=14.9 years | all where extraction permits direct insp. | radiolucency extending to 2/3 enamel thickness | NR | NR | 0.36 | 0.98 | 65
4 S4 | Pitts & Rimmer, 1992^ 63 ^ | D-speed bitewing film, read x2.0 | permanent posterior proximals | 1,468 | visual inspection after separation | NR | 1% | 1 | NR | 5-15 years | NR | radiolucency into dentin | n/a | dice score=0.85 | 0.87 | 0.99 | 60
5 S5 | Hintze, Wenzel, Danielsen, et al., 1998^ 36 ^ | E-speed bitewing film | permanent posterior proximals surfaces | 338 | visual exam after separation | k = 0.68 | 6% | 4 | calibration | mean=24.7 years (21-38) | no proximal restoration selected site | radiolucency into dentin | k = 0.55 | NR | 0.63^1^ | 0.93^1^ | 70
Radiographic Methods-Primary Posterior Teeth-Proximal Surfaces-Cavitated Lesions
6 S4 | Pitts & Rimmer, 1992^ 63 ^ | D-speed bitewing film, read x2.0 | primary posterior proximals | 755 | visual inspection after separation | NR | 14% | 1 | NR | 5-15 years | regular attenders | radiolucency into dentin | n/a | dice score=0.85 | 0.99 | 0.87 | 60
Visual Tactile Methods-Permanent Posterior Teeth-Proximal Surfaces-Cavitated Lesions
7 S3 | Mejare, Grondahl, Carlstedt, et al., 1985^ 38 ^ | visual/tactile | permanent posterior proximal surfaces | 598 | visual inspection and probing | consensus of 3 examiners | 5% | 3 | NR | mean=14.9 years | NR | manifest caries with cavity | NR | NR | 0.29 | 0.99 | 65
8 S5 | Hintze, Wenzel, Danielsen, et al., 1998^ 36 ^ | visual probe used to explore contour | permanent posterior proximal surfaces | 338 | visual exam after separation | k = 0.68 | 6% | 4 | calibration | mean=24.7 years (21-38) | no proximal restoration at selected site | cavitated caries | k = 0.45 | NR | 0.34^1^ | 0.99^1^ | 70
Visual Methods-Permanent Posterior Teeth-Occlusal Surfaces-Cavitated Lesions
9 S2 | Downer & O'Mullane, 1975b^ 35 ^ | visual | permanent posterior pit and fissure sites | 230 | Microscopy 200m sections, read x2.5 | NR | 74% | 1 | NR | teenaged donors | teeth extracted during RCT | break in enamel of fissure wall, or shadow under enamel | NR | r=0.97 | 0.84 | 0.78 | 60
Visual Methods-Permanent Posterior Teeth-Occlusal Surfaces-Lesions Involving Dentin
10 S6 | Ricketts, Kidd, & Wilson, 1995^ 46 ^ | visual | 3^rd^ molar occ. sites, 1 1^st^ mol. & 1 pre. | 100 | magnified radiographs of 600m sections | NR | 30% | NR | NR | NR | no visible sign of cavitation | undermining stain | n/a | NR | 0.03 | 0.97 | 45
Visual Methods-Permanent Posterior Teeth-Occlusal Surfaces-Any Lesions
11 S6 | Ricketts, Kidd, & Wilson, 1995^ 46 ^ | visual | 3^rd^ molar occ. sites, 1 1^st^ mol. & 1 pre. | 100 | magnified radiographs of 600m sections | NR | 64% | NR | NR | NR | no visible sign of cavitation | white/brown spot or undermining stain | n/a | NR | 0.27 | 0.89 | 40
EC-Permanent Posterior Teeth-Occlusal Surfaces-Lesions Involving Dentin
12 S7 | Lussi, Firestone, Schoenberg, et al., 1995^ 47 ^ | electrical conductance (ECM) | 3^rd^ molar occlusal sites | 41 | photographs of stained sections, confirmed with Knoop hardness measures | NR | 37% | 1 | NR | mean=28.7 years ±10 | either caries free or visual signs of caries, no cavitation | manufacturer's designation of instrument reading | NR | NR | 0.93 | 0.77 | 40
13 S6 | Ricketts, Kidd, & Wilson, 1995^ 46 ^ | electrical conductance (Vanguard) | 3^rd^ molar occ. sites, 1 1^st^ mol. & 1 pre. | 100 | magnified radiographs of 600m sections | NR | 30% | 1 | NR | NR | no visible sign of cavitation | instrument reading of 4-9 | n/a | NR | 0.97 | 0.56 | 45
EC Permanent Posterior Teeth-Occlusal Surfaces-Any Lesions
14 S6 | Ricketts, Kidd, & Wilson, 1995^ 46 ^ | electrical conductance (Vanguard) | 3^rd^ molar occ. sites, 1 1^st^ mol. & 1 pre. | 100 | magnified radiographs of 600m sections | NR | 64% | 1 | NR | NR | no visible sign of cavitation | instrument reading of 4-9 | n/a | NR | 0.81 | 0.78 | 40
FOTI Methods-Permanent Posterior Teeth-Proximal Surfaces-Cavitated Lesions
15 S5 | Hintze, Wenzel, Danielsen, et al., 1998^ 36 ^ | FOTI, 2 mm tip | permanent posterior proximal surfaces | 338 | visual exam of separated teeth | k = 0.68 | 6% | 4 | calibration | mean=24.7 years (21-38) | no proximal restoration selected site | shadow in dentin | NR | NR | 0.04^1^ | 1.0^1^ | 70

1 No overall validation no cavitation status available. Each examiner compared only to his/her personal validation results.

Explanations for Selected Column Headings: The first column contains both the entry number and the study number. There are multiple entries for some studies. Teeth and Surfaces: Tooth types and surfaces on which diagnoses were made. Number of Sites: Total number of sites evaluated for presence/absence of lesions. Validation Method: Method for determining the "gold standard" or reference criterion for the presence/absence of a carious lesion. Validator Reliability: Reliability of the reference criterion determination; notation if multiple examiners were involved in the determination. Caries Prevalence: Percent of sites evaluated that were carious according to the reference criterion. Number of Examiners: Number of individual examiners or observers whose diagnoses were analyzed in determining the performance of the method being evaluated. Training of Examiners: Specific training or calibration performed for the study. Subject Age: Information about the age of examination subjects, with mean, range, and/or standard deviation, if reported. Selection Criteria: Specific criteria used in selecting subjects. Criteria for Caries: Specific criteria applied by the examiners to determine the presence of a carious lesion. Interrater Reliability: Statistic and value for any such determination. Mean Intrarater Reliability: Statistic and mean value for any such determination. Sensitivity: Mean sensitivity across all examiners. Specificity: Mean specificity across all examiners. Quality Score: Evaluation of the quality of the study on a 0 to 100 scale (see Figure 2 for the scoring instrument).

Evidence Table 2. Diagnosis of dental caries -- in vitro

Author, Year | | Diagnostic Method | Teeth and Surfaces | No. of Sites | Validation Method | Validator Reliability | Caries Prev. | No. of Examiners | Train. of Examiners | Subj. Age | Selection Criteria | Criteria for Caries | Interrater Reliability | Mean Intrarater Reliability | Sensitivity | Specificity | Quality Score
Radiographic Methods-Permanent Posterior Teeth-Proximal Surfaces-Cavitated Lesions
1 S1 | Espelid & Tveit, 1986^ 110 ^ | D-speed film read x2.0 | permanent posterior proximals | 151 | consensus visual exam -any break in enamel | NR | 19% | 7 | NR | NR | no hypoplasia or noncarious defects | radiolucency involving DEJ | NR | NR | 0.69 | 0.89 | 55
Radiographic Methods-Permanent Posterior Teeth-Proximal Surfaces-Lesions Involving Dentin
2 S2 | Mileman & van der Weele, 1990^ 39 ^ | duplicate D-speed bitewing films | permanent posterior proximals | 105 | microradiography of sections | NR | 43% | 276 | NR | NR | sound and carious | caries into outer 1/2 of dentin | κ = 0.53 | NR | 0.54 | 0.97 | 60
3 S3 | Verdonschot, van de Rijke, Brouwer, et al., 1991^ 41 ^ | D-speed film | mandibular premolar proximals | 21 | microradiography of 80 µm sections | NR | NR | 3 | NR | NR | sound or initial proximal decay, no large cavities | lesion reaching DEJ | r=0.93 | NR | 0.50 | 0.94 | 35
4 S4 | Russell & Pitts, 1993^ 42 ^ | digital imaging (Radio-visiography) | permanent posterior proximal surfaces | 240 | microscopy x10 of sections | NR | NR | 3 | familiarization, no calibration | NR | no restorations | radiolucency penetrating beyond DEJ | not reported for individual methods | NR | 0.16 | 0.96 | 50
4 S4 | Russell & Pitts, 1993^ 42 ^ | D-speed bitewing film | permanent posterior proximal surfaces | 240 | microscopy x10 of sections | NR | NR | 3 | familiarization, no calibration | NR | no restorations | radiolucency penetrating beyond DEJ | not reported for individual methods | NR | 0.29 | 0.92 | 50
4 S4 | Russell & Pitts, 1993^ 42 ^ | E-speed bitewing film | permanent posterior proximal surfaces | 240 | microscopy x10 of sections | NR | NR | 3 | familiarization, no calibration | NR | no restorations | radiolucency penetrating beyond DEJ | not reported for individual methods | NR | 0.30 | 0.96 | 50
5 S5 | Ricketts, Whaites, Kidd, et al., 1997d^ 40 ^ | D-speed bitewing film | permanent posterior proximal surfaces | NR (96 teeth) | magnified x3 600 µm sections | 94% agreement | 13% | 5 | NR | NR | unrestored, wide range of caries status | radiolucency into dentin | NR | 91% agreement | 0.16 | 0.99 | 60
Radiographic Methods-Permanent Posterior Teeth-Proximal Surfaces-Any Lesions
6 S6 | Heaven, Firestone, & Feagin, 1992^ 43 ^ | automatic image analysis of digitized D-speed film | premolar proximal surfaces | 16 | microradiography of ground sections | NR | 75% | 1 | n/a | NR | NR | NR | n/a | 0.0 CV | 1.0 | 1.0 | 20
7 S4 | Russell & Pitts, 1993^ 42 ^ | E-speed bitewing film | permanent posterior proximal surfaces | 240 | microscopy x10 of sections | NR | NR | 3 | familiarization, no calibration | NR | no restorations | any radiolucency | not reported for individual methods | NR | 0.25 | 0.90 | 50
7 S4 | Russell & Pitts, 1993^ 42 ^ | D-speed bitewing film | permanent posterior proximal surfaces | 240 | microscopy x10 of sections | NR | NR | 3 | familiarization, no calibration | NR | no restorations | any radiolucency | not reported for individual methods | NR | 0.26 | 0.90 | 50
7 S4 | Russell & Pitts, 1993^ 42 ^ | digital imaging (Radio-visiography) | permanent posterior proximal surfaces | 240 | microscopy x10 of sections | NR | NR | 3 | familiarization, no calibration | NR | no restorations | any radiolucency | not reported for individual methods | NR | 0.15 | 0.92 | 50
8 S5 | Ricketts, Whaites, Kidd, et al., 1997d^ 40 ^ | D-speed bitewing film | permanent posterior proximal surfaces | NR (96 teeth) | magnified x3 600 µm sections | 94% agreement | 37% | 5 | NR | NR | unrestored, wide range of caries status | any radiolucency in enamel or dentin | NR | 91% agreement | 0.27 | 0.97 | 60
9 S7 | Firestone, Sema, Heaven, et al., 1998^ 44 ^ | image analysis system (Caries Finder) | permanent posterior proximal surfaces, 49 premolar, 2 molar | 102 | "thin section microrad-iography" | NR | 66% | 1 | written and verbal instruction | NR | no mechanical damage | NR | κ = 1.0 | NR | 0.78 | 0.74 | 40
9 S7 | Firestone, Sema, Heaven, et al., 1998^ 44 ^ | D-speed bitewing film | permanent posterior proximal surfaces, 49 premolar, 2 molar | 102 | "thin section microrad-iography" | NR | 66% | 16 | written and verbal instruction | NR | no mechanical damage | NR | κ = 0.52 | NR | 0.61 | 0.86 | 50
9 S7 | Firestone, Sema, Heaven, et al., 1998^ 44 ^ | digital imaging x8 (Sens-A-Ray) with results of image analysis system displayed (Caries Finder) | permanent posterior proximal surfaces, 49 premolar, 2 molar | 102 | "thin section microrad-iography" | NR | 66% | 16 | written and verbal instruction | NR | no mechanical damage | NR | κ = 0.54 | NR | 0.73 | 0.82 | 50
Radiographic Methods-Permanent Posterior Teeth-Occlusal Surfaces-Lesions Involving Dentin
10 S8 | Wenzel, Fejerskov, Kidd, et al., 1990^ 49 ^ | D-speed film | permanent posterior occlusal surfaces | 46 | enlarged x23 color photos of hemi-sections | NR | 72% | 4 | none | NR | no restorations, range of caries status | caries into dentin | κ=0.40 | NR | 0.63 | 0.94 | 40
10 S8 | Wenzel, Fejerskov, Kidd, et al., 1990^ 49 ^ | digitized D-speed film with edge enhancement and contrast stretch | permanent posterior occlusal surfaces | 46 | enlarged x23 color photos of hemi-sections | NR | 72% | 2 | none | NR | no restorations, range of caries status | caries into dentin | κ=0.82 | NR | 0.68 | 0.98 | 40
11 S9 | Wenzel, Hintze, Mikkelsen, et al., 1991^ 50 ^ | E-speed film | 3rd molar occlusal surfaces | 81 | stereo-microscopy x10 of 600 µm sections | NR | 67% | 4 | NR | 18-20 years, male donors | no visible occlusal macroscopic cavitation | caries into dentin | NR | NR | 0.63 | 0.85 | 45
11 S9 | Wenzel, Hintze, Mikkelsen, et al., 1991^ 50 ^ | digitized image of E-speed film | 3rd molar occlusal surfaces | 81 | stereo-microscopy x10 of 600 µm sections | NR | 67% | 4 | NR | 18-20 years, male donors | no visible occlusal macroscopic cavitation | caries into dentin | NR | NR | 0.72 | 0.83 | 45
11 S9 | Wenzel, Hintze, Mikkelsen, et al., 1991^ 50 ^ | E-speed film digitized - edge enhanced | 3rd molar occlusal surfaces | 81 | stereo-microscopy x10 of 600 µm sections | NR | 67% | 4 | NR | 18-20 years, male donors | no visible occlusal macroscopic cavitation | caries into dentin | NR | NR | 0.62 | 0.83 | 45
11 S9 | Wenzel, Hintze, Mikkelsen, et al., 1991^ 50 ^ | RVG digital image with contrast manipulation | 3rd molar occlusal surfaces | 81 | stereo-microscopy x10 of 600 µm sections | NR | 67% | 4 | NR | 18-20 years, male donors | no visible occlusal macroscopic cavitation | caries into dentin | NR | NR | 0.69 | 0.84 | 45
11 S9 | Wenzel, Hintze, Mikkelsen, et al., 1991^ 50 ^ | RVG digitized with density saturation manipulation | 3rd molar occlusal surfaces | 81 | stereo-microscopy x10 of 600 µm sections | NR | 67% | 4 | NR | 18-20 years, male donors | no visible occlusal macroscopic cavitation | caries into dentin | NR | NR | 0.64 | 0.82 | 45
12 S10 | Wenzel & Fejerskov, 1992^ 51 ^ | E-speed film | 3rd molar occlusal surfaces | 78 | stereo-microscopy x10 of 600 µm sections | NR | 67% | 1 | NR | 18-20 years | no macro-scopic occlusal cavitation | caries reaching dentin | n/a | NR | 0.48 | 0.81 | 45
12 S10 | Wenzel & Fejerskov, 1992^ 51 ^ | digitized images of E-speed film | 3rd molar occlusal surfaces | 78 | stereo-microscopy x10 of 600 µm sections | NR | 67% | 1 | NR | 18-20 years | no macro-scopic occlusal cavitation | caries reaching dentin | n/a | NR | 0.71 | 0.85 | 45
12 S10 | Wenzel & Fejerskov, 1992^ 51 ^ | digitized image of E-speed film with edge enhancement | 3rd molar occlusal surfaces | 78 | stereo-microscopy x10 of 600 µm sections | NR | 67% | 1 | NR | 18-20 years | no macro-scopic occlusal cavitation | caries reaching dentin | n/a | NR | 0.54 | 0.77 | 45
13 S11 | Nytun, Raadal, & Espelid, 1992^ 48 ^ | radiographic film (speed NR) read x2.0 | permanent molar occlusal surfaces | 30 | stereo-microscopy x4 of 350 µm sections | consensus of 2 examiners | 77% | 10 | NR | NR | no proximal or smooth surface caries | radiolucency involving dentin | NR | NR | 0.66 | 0.50 | 40
14 S12 | Keltey & Holt, 1993^ 45 ^ | D-speed bitewing film | permanent 1st molar occlusal fissure sites | 100 | visual inspection of dried sections | NR | 51% | 1 | standardization | child donors | no restoration or carious destruction | radiolucency into dentin | n/a | κ=0.92 | 0.67 | 0.92 | 35
15 S4 | Russell & Pitts, 1993^ 42 ^ | digital imaging (Radio-visiography) | permanent posterior occlusal surfaces | 120 | microscopy x10 of sections | NR | 28% | 3 | familiarization, no calibration | NR | no restorations | radiolucency penetrating beyond DEJ | not reported for individual methods | NR | 0.21 | 0.97 | 50
15 S4 | Russell & Pitts, 1993^ 42 ^ | D-speed bitewing film | permanent posterior occlusal surfaces | 120 | microscopy x10 of sections | NR | 28% | 3 | familiarization, no calibration | NR | no restorations | radiolucency penetrating beyond DEJ | not reported for individual methods | NR | 0.18 | 0.98 | 50
15 S4 | Russell & Pitts, 1993^ 42 ^ | E-speed bitewing film | permanent posterior occlusal surfaces | 120 | microscopy x10 of sections | NR | 28% | 3 | familiarization, no calibration | NR | no restorations | radiolucency penetrating beyond DEJ | not reported for individual methods | NR | 0.21 | 0.99 | 50
16 S13 | Lussi, 1993^ 55 ^ | D-speed bitewing film read x2.0 | permanent posterior occlusal sites | 63 | photographs of stained sections x6.4 and Knoop hardness | NR | 44% | 24 | none | NR | no caries on smooth surfaces, no cavitated lesions on occlusal | caries into dentin | κ=0.46 | κ=0.56 | 0.45 | 0.83 | 45
17 S14 | Verdonschot, Wenzel, Truin, et al., 1993^ 56 ^ | E-speed film read x2.0 | 3rd molar pit & fissure sites | 81 | stereo-microscopy x10 of 600 µm sections | NR | 67% | 4 | NR | 18-20 years | no macroscopic cavitation | dentinal caries | NR | NR | 0.61 | 0.79 | 30
18 S15 | Lussi, Firestone, Schoenburg, et al., 1995^ 47 ^ | D-speed bitewing film, read x2.0 | 3rd molar occlusal surfaces | 26 | photographs of stained sections x6.4 and Knoop hardness measures | NR | 42% | 6 | NR | mean= 28.7±10 years | either caries free or visual signs of caries, no cavitation | caries beyond the DEJ | NR | NR | 0.62 | 0.77 | 50
19 S16 | Ricketts, Kidd, Smith, et al., 1994^ 111 ^ | D-speed bitewing film | permanent molar occlusal | 48 | macroscopic inspection of hemisections | NR | 67% | 12 | NR | NR | NR | dentine caries | NR | NR | 0.62 | 0.76 | 40
20 S18 | Ekstrand, Ricketts, & Kidd, 1997^ 57 ^ | E-speed film | permanent posterior pit & fissure sites | 100 | stereo-microscopy x5 of hemisections | >95% agreement between 2 raters | 39% | 3 | 1 hour training | NR | unrestored with no large smooth surface lesions | radiolucency to middle 1/3 of dentin | κ=0.55 | κ=0.79 | 0.54 | 1.0 | 60
21 S20 | Huysmans, Hintze, & Wenzel, 1997^ 112 ^ | digital imaging (Digora) | permanent posterior occlusal surfaces | 189 | stereo-microscopy x25 of 800 µm sections | NR | 55% | 3 | NR | NR | range of caries status | caries into dentin | κ between 0.67 and 0.73 | NR | 0.60 | 0.94 | 65
22 S5 | Ricketts, Whaites, Kidd, et al., 1997^d^ ^ 40 ^ | D-speed bitewing film | permanent posterior occlusal surfaces | 96 | magnified x3 600 µm sections | 88% agreement | 39% | 5 | NR | NR | unrestored, wide range of caries status | radiolucency into dentin | NR | 95% agreement | 0.14 | 0.95 | 60
23 S19 | Ashley, Blinkhorn, & Davies, 1998^ 52 ^ | E-speed film | permanent posterior occlusal surfaces | 103 | stereo-microscopy x100 of 400 µm sections | 97% agreement | 36% | 1 | NR | NR | no restorations, sealants, or cavitation | radiolucency into dentin | n/a | κ=0.45 | 0.24 | 0.89 | 60
23 S19 | Ashley, Blinkhorn, & Davies, 1998^ 52 ^ | digital imaging (Digora) | permanent posterior occlusal surfaces | 103 | stereo-microscopy x100 of 400 µm sections | 97% agreement | 36% | 1 | NR | NR | no restorations, sealants, or cavitation | radiolucency into dentin | n/a | κ=0.44 | 0.19 | 0.89 | 60
24 S17 | Huysmans, Longbotton, & Pitts, 1998^ 53 ^ | E-speed film, read x2.0 | permanent posterior occlusal surfaces | 107 | stereo-microscopy x12 of 120 µm sections | consensus of examiners | 41% | 2 | NR | NR | no restorations verifying occlusal caries | radiolucency into dentin | κ=0.57 | NR | 0.58 | 0.87 | 60
Radiographic Methods-Permanent Posterior Teeth-Occlusal Surfaces-Any Lesions
25 S8 | Wenzel, Fejerskov, Kidd, et al., 1990^ 49 ^ | digitized D-speed film with edge enhancement and contrast stretch | permanent posterior occlusal surfaces | 46 | enlarged x23 color photos of hemi-sections | NR | 89% | 2 | none | NR | no restorations, range of caries status | caries in enamel or dentin | κ=0.82 | NR | 0.79 | 0.90 | 40
25 S8 | Wenzel, Fejerskov, Kidd, et al., 1990^ 49 ^ | D-speed film | permanent posterior occlusal surfaces | 46 | enlarged x23 color photos of hemi-sections | NR | 89% | 4 | none | NR | no restorations, range of caries status | caries in enamel or dentin | κ=0.40 | NR | 0.73 | 0.80 | 40
26 S4 | Russell & Pitts, 1993^ 42 ^ | E-speed bitewing film | permanent posterior occlusal surfaces | 120 | microscopy x10 of sections | NR | NR | 3 | familiarization, no calibration | NR | no restorations | caries in enamel or dentin | not reported for individual methods | NR | 0.12 | 0.96 | 50
26 S4 | Russell & Pitts, 1993^ 42 ^ | D-speed bitewing film | permanent posterior occlusal surfaces | 120 | microscopy x10 of sections | NR | NR | 3 | familiarization, no calibration | NR | no restorations | caries in enamel or dentin | not reported for individual methods | NR | 0.12 | 0.95 | 50
26 S4 | Russell & Pitts, 1993^ 42 ^ | digital imaging (Radio-visiography) | permanent posterior occlusal surfaces | 120 | microscopy x10 of sections | NR | NR | 3 | familiarization, no calibration | NR | no restorations | caries in enamel or dentin | not reported for individual methods | NR | 0.15 | 0.97 | 50
27 S20 | Lazarchik, Firestone, Heaven, et al., 1995^ 113 ^ | D-speed bitewing film | permanent posterior occlusal surfaces | 100 | photographs x6.4 of stained sections | NR | 79% | 15 | NR | NR | no smooth surface caries | caries present | κ=0.53 | NR | 0.58 | 0.79 | 50
28 S5 | Ricketts, Whaites, Kidd, et al., 1997d^ 40 ^ | D-speed bitewing film | permanent posterior occlusal surfaces | 96 | magnified x3 600 µm sections | 88% agreement | 70% | 5 | NR | NR | unrestored, wide range of caries status | radiolucency into enamel or dentin | NR | 95% agreement | 0.27 | 0.97 | 60
Radiographic Methods-Permanent Posterior Teeth-Occlusal Surfaces-Enamel Only Lesions
29 S8 | Wenzel, Fejerskov, Kidd, et al., 1990^ 49 ^ | D-speed film | permanent posterior occlusal surfaces | 46 | enlarged x23 color photos of hemisections | NR | 17% | 4 | none | NR | no restorations, range of caries status | caries limited to enamel | κ=0.40 | NR | 0.44 | 0.70 | 40
29 S8 | Wenzel, Fejerskov, Kidd, et al., 1990^ 49 ^ | digitized D-speed film with edge enhancement and contrast stretch | permanent posterior occlusal surfaces | 46 | enlarged x23 color photos of hemisections | NR | 17% | 2 | none | NR | no restorations, range of caries status | caries limited to enamel | κ=0.82 | NR | 0.31 | 0.72 | 40
30 S19 | Ashley, Blinkhorn, & Davies, 1998^ 52 ^ | digital imaging (Digora) | permanent posterior occlusal surfaces | 103 | stereo-microscopy x100 of 400 µm sections | 97% agreement | 24% | 1 | NR | NR | no restorations, sealants, or cavitation | any radiolucent area confined to enamel | n/a | κ=0.44 | 0.24 | 0.80 | 55
30 S19 | Ashley, Blinkhorn, & Davies, 1998^ 52 ^ | E-speed film | permanent posterior occlusal surfaces | 103 | stereo-microscopy x100 of 400 µm sections | 97% agreement | 24% | 1 | NR | NR | no restorations, sealants, or cavitation | any radiolucent area confined to enamel | n/a | κ=0.45 | 0.19 | 0.80 | 55
Radiographic Methods-Permanent Anterior & Posterior Teeth-Proximal Surfaces-Lesions Involving Dentin
31 S21 | White & Yoon, 1997^ 64 ^ | digital imaging (Shick CDD) | permanent anterior and posterior teeth | 320 | visual x30 tactile exam of hemisections | NR | 25% | 10 for anterior/11 for posterior | NR | NR | selected after validation for distribution of lesions | lesion penetrates dentin | NR | NR | 0.52 | 0.95 | 60
31 S21 | White & Yoon, 1997^ 64 ^ | E-speed film, magnified if desired | permanent anterior and posterior teeth | 320 | visual x30 tactile exam of hemisections | NR | 25% | 10 for anterior/11 for posterior | NR | NR | selected after validation for distribution of lesions | lesion penetrates dentin | NR | NR | 0.58 | 0.94 | 60
Radiographic Methods-Permanent Anterior & Posterior Teeth-Proximal Surfaces-Any Lesions
32 S21 | White & Yoon, 1997^ 64 ^ | digital imaging (Shick CDD) | permanent anterior and posterior teeth | 320 | visual x30 tactile exam of hemisections | NR | 75% | 10 for anterior/11 for posterior | NR | NR | selected after validation for distribution of lesions | any evidence of a lesion | NR | NR | 0.49 | 0.80 | 55
32 S21 | White & Yoon, 1997^ 64 ^ | E-speed film, magnified if desired | permanent anterior and posterior teeth | 320 | visual x30 tactile exam of hemisections | NR | 75% | 10 for anterior/11 for posterior | NR | NR | selected after validation for distribution of lesions | any evidence of a lesion | NR | NR | 0.58 | 0.76 | 55
33 S16 | Huysmans, Hintze, & Wenzel, 1997^ 112 ^ | digital imaging (Digora) | permanent canine and posterior proximal surfaces | 410 | stereo-microscopy x25 of 800 µm sections | NR | 36% | 3 | NR | NR | range of caries status | "presence of caries" | κ between 0.53 and 0.69 | NR | 0.33 | 0.95 | 70
Radiographic Methods-Permanent Anterior & Posterior Teeth-Proximal Surfaces-Enamel-Only Lesions
34 S21 | White & Yoon, 1997^ 64 ^ | digital imaging (Shick CDD) | permanent anterior and posterior teeth | 320 | visual x30 tactile exam of hemi-sections | NR | 50% | 10 for anterior/11 for posterior | NR | NR | selected after validation for distribution of lesions | any evidence of a lesion not penetrating dentin | NR | NR | 0.35 | 0.80 | 55
34 S21 | White & Yoon, 1997^ 64 ^ | E-speed film, magnified if desired | permanent anterior and posterior teeth | 320 | visual x30 tactile exam of hemi-sections | NR | 50% | 10 for anterior/11 for posterior | NR | NR | selected after validation for distribution of lesions | any evidence of a lesion not penetrating dentin | NR | NR | 0.46 | 0.76 | 55
Radiographic Methods-Primary Teeth-Occlusal Surfaces-Lesions Involving Dentin
35 S12 | Keltey & Holt, 1993^ 45 ^ | D-speed bitewing film | primary 2nd molar occlusal fissure sites | 100 | visual inspection of dried sections | NR | 44% | 1 | standardization | child donors | no restoration or carious destruction | radiolucency into dentin | n/a | κ=0.92 | 0.93 | 0.89 | 35
Visual/Tactile Methods-Permanent Posterior Teeth-Proximal Surfaces-Cavitated Lesions
36 S22 | Downer & O'Mullane, 1975b^ 35 ^ | visual/tactile, probe used sparingly | permanent posterior proximals | 185 | microscopy x2.5 of 200 µm sections | NR | NR | 1 | NR | teenage donors | NR | break in smooth surface or shadow beneath enamel-probe enters lesion | n/a | NR | 0.93 | 0.97 | 50
Visual/Tactile Methods-Permanent Posterior Teeth-Proximal Surfaces-Lesions Involving Dentin
37 S3 | Verdonschot, van de Rijke, Brouwer, et al, 1991^ 41 ^ | visual/tactile | mandibular premolar proximals | 21 | microradiography of 80 µm sections | NR | NR | 3 | NR | NR | sound or initial proximal decay, no large cavities | limited cavitation or greater | NR | NR | 0.50 | 0.71 | 35
Visual/Tactile Methods-Permanent Posterior Teeth-Occlusal Surfaces-Cavitated Lesions
38 S22 | Downer & O'Mullane, 1975b^ 35 ^ | visual/tactile, probe used sparingly | permanent posterior pit & fissure sites | 230 | microscopy x2.5 of 200 µm sections | NR | NR | 1 | NR | teenage donors | NR | break in fissure wall or shadow beneath enamel-probe enters lesion | n/a | NR | 0.92 | 0.85 | 50
Visual/Tactile Methods-Permanent Posterior Teeth-Occlusal Surfaces-Lesions Involving Dentin
39 S23 | Penning, van Amerongen, Seef, et al., 1992^ 54 ^ | standardized pressure probing | sites in permanent molar occlusal fissures | 1,140 sites in 3 teeth | micro-radiography of 720 µm sections | consensus of 3 examiners | 13% | 1 | NR | NR | fissure discoloration without cavitation | 30-40 g tugback upon 500 g probing | n/a | NR | 0.24 | 1.0 | 45
Visual/Tactile Methods-Permanent Posterior Teeth-Occlusal Surfaces-Lesions Involving Dentin
40 S13 | Lussi, 1993^ 55 ^ | visual/tactile (light pressure) | permanent posterior occlusal sites | 63 | photographs of stained sections x6.4 and Knoop hardness | NR | 44% | 23 | none | NR | no caries on smooth surfaces, no cavitated lesions on occlusal | caries into dentin | κ=0.27 | NR | 0.14 | 0.93 | 45
Visual/Tactile Methods-Permanent Posterior Teeth-Occlusal Surfaces-Any Lesions
41 S23 | Penning, van Amerongen, Seef, et al, 1992^ 54 ^ | standardized pressure probing | sites in permanent molar occlusal fissures | 1,140 sites in 3 teeth | microradiography of 720 µm sections | consensus of 3 examiners | 19% | 1 | NR | NR | fissure discoloration without cavitation | 30-40 g tugback upon 500 g probing | n/a | NR | 0.17 | 1.0 | 45
42 S24 | Lussi, 1991^ 114 ^ | visual/tactile (light pressure) | permanent posterior pit and fissure sites | 61 | slide of stained section | NR | 61% | 8 | none | NR | no caries on smooth surfaces | enamel or dentin caries, but not "subsurface lesions" | NR | NR | 0.61 | 0.87 | 45
Visual Methods-Permanent Posterior Teeth-Proximal Surfaces-Cavitated Lesions
43 S21 | Downer & O'Mullane, 1975b^ 35 ^ | visual | permanent posterior proximals | 185 | microscopy x2.5 of 200 µ sections | NR | NR | 1 | NR | teenage donors | NR | break in smooth surface or shadow beneath enamel | n/a | NR | 0.94 | 0.92 | 50
Visual Methods-Permanent Posterior Teeth-Occlusal Surfaces-Cavitated Lesions
44 S22 | Downer & O'Mullane, 1975b^ 35 ^ | visual | permanent posterior pit & fissure sites | 230 | microscopy x2.5 of 200 µ sections | NR | NR | 1 | NR | teenage donors | NR | break in smooth surface or shadow beneath enamel | n/a | NR | 0.91 | 0.81 | 50
45 S12 | Ketley & Holt, 1993^ 45 ^ | visual | permanent 1st molar occlusal fissure sites | 100 | visual inspection of dried sections | NR | 51% | 1 | standardization | child donors | no restoration or carious destruction | break in enamel or shadow/ opacity beneath enamel < 1.5 mm across fissure (Downer and O'Mullane, 1975b^ 35 ^) | n/a | κ=0.77 | 0.31 | 0.98 | 35
Visual Methods-Permanent Posterior Teeth-Occlusal Surfaces-Lesions Involving Dentin
46 S11 | Nytun, Raadal, & Espelid, 1992^ 48 ^ | visual | permanent molar occlusal surfaces | 30 | stereo-microscopy x4 of 350 µ sections | consensus of 2 examiners | 77% | 10 | NR | NR | no prox. or smooth surf. caries, signs of fissure caries | caries beneath DEJ - cavitation, or discoloration | NR | NR | 0.72 | 0.41 | 40
47 S10 | Wenzel & Fejerskov, 1992^ 51 ^ | visual | 3rd molar occlusal surfaces | 78 | stereo-microscopy x10 of 600 µ sections | NR | 67% | 1 | NR | 18-20 years | no macroscopic occlusal cavitation | chalky and dark-stained fissure and a greyish "shadow" | n/a | NR | 0.54 | 0.81 | 45
48 S13 | Lussi, 1993^ 55 ^ | visual visual (with magnification) | permanent posterior occlusal sites | 63 | photographs of stained sections x6.4 and Knoop hardness | NR | 44% | 26 | none | NR | no caries on smooth surfaces, no cavitated lesions on occlusal | caries into dentin | κ=0.22 | κ=0.48 | 0.12 | 0.93 | 45
48 S13 | Lussi, 1993^ 55 ^ | visual visual (with magnification) | permanent posterior occlusal sites | 63 | photographs of stained sections x6.4 and Knoop hardness | NR | 44% | 26 | none | NR | no caries on smooth surfaces, no cavitated lesions on occlusal | caries into dentin | κ=0.19 | NR | 0.20 | 0.89 | 45
49 S14 | Verdonschot, Wenzel, Truin, et al., 1993^ 56 ^ | visual | 3rd molar pit & fissure sites | 81 | stereo-microscopy x10 of 600 µ sections | NR | 67% | 4 | NR | 18-20 years | no macroscopic cavitation | dental caries | NR | NR | 0.48 | 0.89 | 30
50 S25 | Deery, Fyffe, Nugent, et al., 1995^ 62 ^ | visual | permanent molar occlusal surfaces | 112 | microscopy x2.5 of sections | consensus of 2 examiners | 54% | 7 | none | NR | no restorations-range of lesions | caries extending into dentin | NR | κ=0.87 | 0.12 | 0.97 | 65
51 S18 | Ekstrand, Ricketts, & Kidd, 1997^ 57 ^ | visual | permanent posterior pit & fissure sites | 100 | stereo-microscopy x5 of hemi-sections | > 95% agreement between 2 raters | 39% | 3 | none | NR | unrestored with no large surface lesions | opaque/colored enamel/greyish dentin | κ=0.61 | κ=0.80 | 0.95 | 0.90 | 60
52 S19 | Ashley, Blinkhorn, & Davies, 1998^ 52 ^ | visual | permanent posterior occlusal surfaces | 103 | stereo-microscopy x100 of 400 µ sections | 97% agreement | 36% | 1 | NR | NR | NR | break in enamel or shadow/opacity under enamel | n/a | κ=0.42 | 0.24 | 0.97 | 60
53 S26 | Huysmans, Longbotton, & Pitts, 1998^ 53 ^ | visual | permanent posterior occlusal fissures | 107 | stereo-microscopy x12 of 120 µ sections | consensus of examiners | 41% | 2 | NR | NR | no restorations verifying occlusal caries | appearance of dentinal involvement or cavity into dentin | κ=0.27 | NR | 0.27 | 1.0 | 60
Visual Methods-Permanent Posterior Teeth-Occlusal Surfaces-Any Lesions
54 S8 | Wenzel, Fejerskov, Kidd, et al., 1990^ 49 ^ | inspection of x10 photographs | permanent posterior occlusal surfaces | 45 | enlarged x23 color photos of hemisections | NR | 89% | 4 | none | NR | no restorations | caries in enamel or dentin | κ=0.40 | NR | 0.89 | 0.65 | 40
55 S24 | Lussi, 1991^ 114 ^ | visual | permanent posterior pit and fissure sites | 61 | slide of stained section | NR | 61% | 26 | none | NR | no caries on smooth surfaces | enamel or dentin caries, but not "subsurface lesions" | NR | NR | 0.63 | 0.83 | 45
56 S25 | Deery, Fyffe, Nugent, et al., 1995^ 62 ^ | visual | permanent molar occlusal surfaces | 112 | microscopy x2.5 of sections | consensus of 2 examiners | 97% | 7 | none | NR | NR | staining, discoloration, loss of tooth structure | NR | κ = 0.60 | 0.60 | 0.50 | 65
Visual Methods-Permanent Posterior Teeth-Occlusal Surfaces-Enamel-Only Lesions
57 S8 | Wenzel, Fejerskov, Kidd, et al., 1990^ 49 ^ | inspection of x10 photographs | permanent posterior occlusal surfaces | 46 | enlarged x23 color photos of hemisections | NR | 17% | 4 | none | NR | no restorations | caries in enamel | κ = 0.40 | NR | 0.72 | 0.66 | 40
58 S19 | Ashley, Blinkhorn, & Davies, 1998^ 52 ^ | visual | permanent posterior occlusal surfaces | 103 | stereo-microscopy x100 of 400 µ sections | 97% agreement | 24% | 1 | NR | NR | no restorations, sealants, or cavitation | dark line at fissure base or white opaque changes in fissure walls | n/a | κ=0.42 | 0.60 | 0.73 | 55
Visual Methods-Primary Teeth-Occlusal Surfaces-Cavitated Lesions
59 S12 | Keltey & Holt, 1993^ 45 ^ | visual | primary 2nd molar occlusal fissure sites | 100 | visual inspection of dried sections | NR | 44% | 1 | standardization | child donors | no restoration or carious destruction | break in enamel or shadow/opacity beneath enamel <1.5 mm across fissure | n/a | κ=0.77 | 0.45 | 1.0 | 35
EC-Permanent Posterior Teeth-Occlusal Surfaces-Lesions Involving Dentin
60 S14 | Verdonschot, Wenzel, Truin, et al. 1993^ 56 ^ | electrical conductance (Vanguard), self-selected site | 3rd molar pit & fissure sites | 81 | stereo-microscopy x10 of 600 µ sections | NR | 67% | 4 | NR | 18-20 years | no macroscopic cavitation | instrument reading >8.0 | NR | NR | 0.67 | 0.82 | 30
61 S27 | Ricketts, Kidd, & Wilson, 1995^ 46 ^ | electrical conductance (Vanguard) | 3rd molar occ. sites, 1 1st mol. & 1 pre. | 100 | magnified radiographs of 600 µ sections | NR | 30% | 1 | NR | NR | no visible cavitation | instrument reading of 4-9 | n/a | NR | 0.93 | 0.63 | 45
61 S27 | Ricketts, Kidd, & Wilson, 1995^ 46 ^ | electrical conductance (Caries Meter L) | 3rd molar occ. sites, 1 1st mol. & 1 pre. | 100 | magnified radiographs of 600 µ sections | NR | 30% | 1 | NR | NR | no visible cavitation | manufacturer's designation of instrument reading | n/a | NR | 0.96 | 0.62 | 45
62 S29 | Ricketts, Kidd, & Wilson, 1997a^ 58 ^ | electrical conductance (ECMII) airflow=10 l/min. | 30 3rd mol., 1 1st mol. premol. occ. sites | 76 | digitized macro-radiographs of 600 µ sections | NR | 32% | 1 | NR | NR | no visible cavitation | post hoc determination of optimal instrument reading | n/a | κ=0.85 | 0.92 | 0.89 | 20
63 S30 | Ricketts, Kidd, & Wilson, 1997b^ 59 ^ | electrical conductance (ECMII), stable reading | 30 3rd mol., 1 1st mol. premol. occ. sites | 76 | digitized macro-radiographs of 600 µ sections | NR | 32% | 1 | NR | NR | no visible cavitation | post hoc determination of optimal instrument reading | n/a | κ=0.92 | 0.92 | 0.87 | 25
64 S31 | Ricketts, Kidd, & Wilson, 1997c^ 60 ^ | electrical conductance (ECMII), with gel coating occlusal surface | permanent posterior occlusal surfaces | 96 | magnification x3.0 of 1000 µ sections | NR | 39% | 1 | NR | NR | NR | post hoc determination of optimal instrument reading | n/a | κ = 0.55 | 0.76 | 0.76 | 40
65 S18 | Ekstrand, Ricketts, & Kidd, 1997^ 57 ^ | electric conductance (ECM) | permanent posterior pit & fissure sites | 100 | stereo-microscopy x5 of hemisections | >95% agreement between 2 raters | 39% | 3 | 1 hour training | NR | unrestored with no large surface lesions | instrument reading >9.0 | κ=0.54 | κ=0.73 | 0.90 | 0.85 | 60
66 S17 | Huysmans, Longbotton, & Pitts, 1998^ 53 ^ | electrical conductance (ECM) | permanent posterior occlusal fissures | 107 | stereo-microscopy x12 of 120 µ sections | consensus of examiners | 41% | 2 | NR | NR | no restorations verifying occlusal caries | instrument reading <7.0 | κ=0.53 | NR | 0.58 | 0.94 | 50
66 S17 | Huysmans, Longbotton, & Pitts, 1998^ 53 ^ | electrical conductance (ECM)-with gel coating surface | permanent posterior occlusal fissures | 107 | stereo-microscopy x12 of 120 µ sections | consensus of examiners | 41% | 2 | NR | NR | no restorations verifying occlusal caries | instrument reading <11.5 | κ=0.89 | NR | 0.76 | 0.90 | 55
66 S17 | Huysmans, Longbotton, & Pitts, 1998^ 53 ^ | electrical conductance (Caries Meter L) | permanent posterior occlusal fissures | 107 | stereo-microscopy x12 of 120 µ sections | consensus of examiners | 41% | 2 | NR | NR | no restorations verifying occlusal caries | manufacturer's categorization of instrument reading | κ=0.47 | NR | 0.78 | 0.79 | 60
67 S19 | Ashley, Blinkhorn, & Davies, 1998^ 52 ^ | electrical conductance (ECM) | permanent posterior occlusal surfaces | 103 | stereo-microscopy x100 of 400 µ sections | 97% agreement | 36% | 1 | NR | NR | no restorations, sealants, or cavitation | post hoc determination of optimal instrument reading | n/a | κ=0.63 | 0.78 | 0.80 | 55
68 S32 | Lussi, Imwinkelried, Pitts, et al., 1999^ 61 ^ | electrical conductance (ECMIIb) | permanent posterior occlusal pits & fissures | 105 | photographs x3.2 of stained sections | NR | 36% | 1 | NR | NR | no visible smooth surface caries | manufacturer's designation of instrument reading | NR | NR | 0.92 | 0.78 | 35
EC-Permanent Posterior Teeth-Occlusal Surfaces-Any Lesions
69 S33 | Rock & Kidd, 1988^ 115 ^ | electrical conductance (Vanguard) | permanent posterior fissure surfaces | 50 | photographs of sections | NR | 74% | 1 | NR | 11-13 years | NR | manufacturer's designation of instrument reading | n/a | NR | 0.70 | 0.85 | 35
70 S27 | Ricketts, Kidd, & Wilson, 1995^ 46 ^ | electrical conductance (Vanguard) | 3rd molar occ. sites, 1 1st mol. & 1 pre. | 100 | magnified radiographs of 600 µ sections | NR | 64% | 1 | NR | NR | no visible cavitation | instrument reading of 4-9 | n/a | NR | 0.70 | 0.83 | 40
70 S27 | Ricketts, Kidd, & Wilson, 1995^ 46 ^ | electrical conductance (Caries Meter L) | 3rd molar occ. sites, 1 1st mol. & 1 pre. | 100 | magnified radiographs of 600 µ sections | NR | 64% | 1 | NR | NR | no visible cavitation | manufacturer's designation of instrument reading | n/a | NR | 0.74 | 0.74 | 40
71 S28 | Ricketts, Kidd, Liepins, et al., 1996^ 116 ^ | electrical conductance (ECM) | 3rd molar pit & fissure sites | 30 | digitized macro-radiographs of 670 µ sections | NR | 80% | 1 | NR | young adult donors | NR | post hoc determination of optimal instrument reading | n/a | NR | 0.92 | 1.0 | 5
72 S29 | Ricketts, Kidd, & Wilson, 1997a^ 58 ^ | electrical conductance (ECMII) | 30 3rd mol., 1 1st mol. pre. occ. sites | 76 | digitized macro-radiographs of 600 µ sections | NR | 64% | 1 | NR | NR | no visible cavitation | post hoc determination of optimal instrument reading | n/a | κ=0.69 | 0.71 | 0.78 | 15
73 S29 | Ricketts, Kidd, & Wilson, 1997b^ 59 ^ | electrical conductance (ECMII) | 30 3rd mol., 1 1st mol. pre. occ. sites | 76 | digitized macroradio-graphs of 600 µ sections | NR | 64% | 1 | NR | NR | NR | post hoc determination of optimal instrument reading | n/a | κ = 0.92 | 0.61 | 0.96 | 20
74 S31 | Ricketts, Kidd, & Wilson, 1997c^ 60 ^ | electrical conductance (ECMII), with gel coating occlusal surface | permanent posterior occlusal surfaces | 96 | magnification x3.0 of 1000 µ sections | NR | 78% | 1 | NR | NR | NR | post hoc determination of optimal instrument reading | n/a | κ = 0.76 | 0.61 | 0.86 | 40
EC-Permanent Posterior Teeth-Occlusal Surfaces-Enamel-Only Lesions
75 S19 | Ashley, Blinkhorn, & Davies, 1998^ 52 ^ | electrical conductance (EC) | permanent posterior occlusal surfaces | 103 | stereo-microscopy x100 of 400 µ sections | 97% agreement | 24% | 1 | NR | NR | no restorations, sealants, or cavitation | post hoc determination of optimal instrument reading | n/a | κ = 0.63 | 0.65 | 0.73 | 50
FOTI Methods-Permanent Posterior Teeth-Occlusal Surfaces-Lesions Involving Dentin
76 S19 | Ashley, Blinkhorn, & Davies, 1998^ 52 ^ | FOTI 0.05 mm | permanent posterior occlusal surfaces | 103 | stereo-microscopy x100 of 400 µ sections | 97% agreement | 36% | 1 | NR | NR | no restorations, sealants, or cavitation | gray/yellow discoloration into dentin | n/a | κ = 0.51 | 0.14 | 0.95 | 60
FOTI Methods-Permanent Posterior Teeth-Occlusal Surfaces-Enamel-Only Lesions
77 S19 | Ashley, Blinkhorn, & Davies, 1998^ 52 ^ | FOTI 0.05 mm | permanent posterior occlusal surfaces | 103 | stereo-microscopy x100 of 400 µ sections | 97% agreement | 24% | 1 | NR | NR | no restorations, sealants, or cavitation | gray/yellow discoloration in enamel only | n/a | κ = 0.51 | 0.21 | 0.88 | 55
Laser Fluorescence Methods-Permanent Posterior Teeth-Occlusal Surfaces-Lesions Involving Dentin
78 S32 | Lussi, Imwinkelried, Pitts, et al., 1999^ 61 ^ | laser fluorescence (DIAGNODent) -- moist teeth | permanent posterior occlusal pits & fissures | 105 | photographs x3.2 of stained sections | NR | 36% | 1 | NR | NR | no visible smooth surface caries | post hoc determination of optimal instrument reading | NR | NR | 0.76 | 0.87 | 30
79 S32 | Lussi, Imwinkelried, Pitts, et al., 1999^ 61 ^ | laser fluorescence (DIAGNODent) -- dry teeth | permanent posterior occlusal pits & fissures | 105 | photographs x3.2 of stained sections | NR | 36% | 1 | NR | NR | no visible smooth surface caries | post hoc determination of optimal instrument reading | NR | NR | 0.84 | 0.79 | 30
Combination Methods-Permanent Posterior Teeth-Occlusal Surfaces-Lesions Involving Dentin
80 S11 | Nytun, Raadal, & Espelid, 1992^ 48 ^ | visual and radiographic, film speed NR | permanent molar occlusal surfaces | 30 | stereo-microscopy x4 of 350 µ sections | consensus of 2 examiners | 77% | 10 | NR | NR | no proximal or smooth surface caries | radiolucency into dentin and caries beneath DEJ - cavity or discoloration | NR | NR | 0.86 | 0.64 | 40
81 S13 | Lussi, 1993^ 55 ^ | visual and radiographic | permanent posterior occlusal sites | 63 | photographs of stained sections x6.4 and Knoop hardness | NR | 44% | 10 | none | NR | no caries on smooth surfaces, no cavitated lesions on occlusal | caries into dentin | κ = 0.46 | NR | 0.49 | 0.87 | 45
82 S33 | Cayley & Holt, 1997^ 65 ^ | visual and bitewing radiographs | permanent molar occlusal sites | 60 | visual inspection of sections | κ = 0.93 | NR | 11 | none | NR | no cavitation or restoration | none given | κ = 0.30 | κ = 0.49 | 0.65 | 0.74 | 55

Explanations for Selected Column Headings: The first column contains both the entry number and the study number. There are multiple entries for some studies. Teeth and Surfaces: Tooth types and surfaces on which diagnoses were made. Number of Sites: Total number of sites evaluated for presence/absence of lesions. Validation Method: Method for determining the "gold standard" or reference criterion for the presence/absence of a carious lesion. Validator Reliability: Reliability of the reference criterion determination; notation if multiple examiners were involved in the determination. Caries Prevalence: Percent of sites evaluated that were carious according to the reference criterion. Number of Examiners: Number of individual examiners or observers whose diagnoses were analyzed in determining the performance of the method being evaluated. Training of Examiners: Specific training or calibration performed for the study. Donor Age: Information about the age(s) of the donors of the sample of teeth used in the study. Selection Criteria: Specific criteria used in selecting subjects. Criteria for Caries: Specific criteria applied by the examiners to determine the presence of a carious lesion. Interrater Reliability: Statistic and value for any such determination. Mean Intrarater Reliability: Statistic and value for any such determination. Sensitivity: Mean sensitivity across all examiners. Specificity: Mean specificity across all examiners. Quality Score: Evaluation of the quality of the study on a 0 to 100 scale (see Figure 2 for the scoring instrument).

Evidence Table 3. Treatment of noncavitated carious lesions

Author, Year | | Type of Design | Duration | Country and F Status | Experimental Agent | Frequency | Comparison Agent | Subj. Age | N of Subj. in Analyses | Tooth Type | Surface | Exp. Lesion N | Com. Lesion N | Criteria for Noncavitated Lesion at Baseline | Criteria for Progression | Criteria for Reversal | No. of Examiners | Interexaminer Reliability | Mean Intra-examiner Reliability | Type of Analysis | Compliance Estimate | Attrition from Baseline | Percent of Lesions Progressing | | | Percent of Lesions Reversing | | | Quality Score
Author, Year | | Type of Design | Duration | Country and F Status | Experimental Agent | Frequency | Comparison Agent | Subj. Age | N of Subj. in Analyses | Tooth Type | Surface | Exp. Lesion N | Com. Lesion N | Criteria for Noncavitated Lesion at Baseline | Criteria for Progression | Criteria for Reversal | No. of Examiners | Interexaminer Reliability | Mean Intra-examiner Reliability | Type of Analysis | Compliance Estimate | Attrition from Baseline | exp. | com. | p value | exp. | com. | p value
Fluoride Rinse/Solution
1 | Hyde, 1973^ 69 ^ | RCT | 24 mo | Canada F= "practically none" | APF solution, concentration NR | one application at baseline | placebo | children in mixed dentition, no age reported | 377 | perm 1st molar | mesial | 92 | 100 | diagnosed as "incipient" radiographically -- no criteria reported | lesion progresses radiographically to DEJ | NR | "at least 2" | n/a | NR | all at final exam | n/a | 12% for all analysis groups | 51% | 82% | <0.001 | NR | NR | NR | 60
1 | Hyde, 1973^ 69 ^ | RCT | 24 mo | Canada F= "practically none" | 8% stannous fluoride | one application at baseline | placebo | children in mixed dentition, no age reported | 377 | perm 1st molar | mesial | 89 | | diagnosed as "incipient" radiographically -- no criteria reported | lesion progresses radiographically to DEJ | NR | "at least 2" | n/a | NR | all at final exam | n/a | 12% for all analysis groups | 67% | | <0.001 | NR | NR | NR | 60
1 | Hyde, 1973^ 69 ^ | RCT | 24 mo | Canada F= "practically none" | ammoniacal silver nitrate | one application at baseline | placebo | children in mixed dentition, no age reported | 377 | perm 1st molar | mesial | 96 | | diagnosed as "incipient" radiographically -- no criteria reported | lesion progresses radiographically to DEJ | NR | "at least 2" | n/a | NR | all at final exam | n/a | 12% for all analysis groups | 69% | | <0.001 | NR | NR | NR | 60
2 | Hollender & Koch, 1976^ 72 ^ | non-RCT | 36 mo | Sweden F= NR | 0.5% NaF rinse | twice per month during school terms | placebo | children 9-11 years | 28 | perm maxillary anterior | labial | 59 | 31 | chalky spots in enamel w/o breakdown in surface (cavitation) | area of lesion larger than baseline upon direct comparison of photos | area of lesion smaller than baseline upon direct comparison of photos | 2 | 92% agreement | 85% agreement | all at final exam | NR, absences followed up | 17% for exp & control | 24% | 16% | NR | 25% | 32% | NR | 55
3 | de Liefde, 1987^ 71 ^ | prospective cohort | 20-32 mo | New Zealand F= mixed | 2% NaF solution | once per week for 3 weeks, with pattern repeated once at 3 months | 2% NaF solution, every 6 months | children <10 years | 444 | perm molars | occlusal | 497 | 374 | color change (chalky white, yellow, light brown) surface roughness, visible minor loss of enamel from fissure walls but no enamel break at fissure base | visible break in enamel with softening at the base, with or without surrounding softening, or marked shadowing of enamel with no visible break | NR | NR (all exams by School Dental Service) | NR | NR | only full participants | NR | NR | 33% | 36% | ns | NR | NR | NR | 40
Varnish
4 | Modeer, Twetman,& Bergstrand, 1984^ 70 ^ | RCT | 36 mo | Sweden F= 0.24 ppm | 5% NaF varnish (Duraphat) 0.2% NaF rinse 2/month | varnish every 3 months, rinse 2/month | 0.2% NaF rinse 2/month | 14 years | 194 | perm posterior | proximal | 212 | 306 | lesion in outer half of enamel, radiographically | caries more than half way through enamel | NR | 2 simultaneously | n/a | 89% agreement | only full participants | NR | 18% for exp & control | 60% | 61% | NR | 7% | 7% | NR | 65
Sealant
5 | Heller, Reed, Bruner, et al., 1995^ 68 ^ | subanal of retrospective cohort | 60 mo | USA F = fluoridated | sealant (Delton) | repairs as necessary at annual exams | nil | 1st grade children, no age reported | 113 | perm 1st molars K5 | occlusal and pit and fissure | 380 | 56 | dark staining, chalky appearance, slight explorer stick, without enamel surface defects | restoration, or surface defect, or definite softness upon probing | NR | 1 | n/a | NR | all at final exam | NR | 76% for exp & control | 11% | 52% | <0.001 | NR | NR | NR | 45

Explanations for Selected Column Headings Type of Design: Study design of main study; subsets represent reported analyses of selected lesions in experimental and control groups that meet review criteria. Duration: Months from baseline to final examination. Country and F Status: Location of study; community water fluoridation status of participants. Subject Age: Mean, range, and/or standard deviation of the participants at baseline if reported. Number of Subjects in Analysis: Number of subjects contributing lesions to the final analysis. Exp. Lesion N: Number of lesions in the experimental group included in the final analysis. Comp. Lesion N: Number of lesions in the comparison group included in the final analysis. Criteria for Progression: Criteria used to determine that a lesion had progressed from its baseline status. Criteria for Reversal: Criteria used to determine that a lesion had reversed or regressed from its baseline status. Interexaminer Reliability: Statistic and value for any such determination. Mean Intraexaminer Reliability: Statistic and value for any such determination. Type of Analysis: Approach to including subjects in the analysis, either analyses that include all subjects with baseline and final examinations, or analyses that also demand "full participation." Compliance Estimate: Information presented about subject compliance with study protocols. Quality Score: Evaluation of the quality of the study on a 0 to 100 scale (see Figure 3 for the scoring instrument).

Evidence Table 4. Prevention for caries-active individuals

Author, Year | | Type of Design | Duration | Country and F Status | Preventive Agent | Comparison Agent | Other Professional Prevention | Subj. Age | Selection Criteria for CA Designation | CA as % of Population/ Sample | Baseline CA Sample N | Criteria for Caries | Teeth | Type of Exam | Examiner N | Reliability | Type of Analysis | Compliance Estimate | Attrition from Baseline | Final N (exp; com) | Baseline Caries Level | Δ Caries | Percent Reduct., Signif., & NNT | Quality Score
Fluoride Studies
1 S1 | Luoma, Murtomaa, Nuuja, et al., 1978^ 73 ^ | RCT | 24 mo | Finland F = NR | 0.04% NaF rinse 1/day; toothpaste 0.047. 2/day | placebo | 0.02% NaF topical+ OHI 1/yr | 11-15 years | "high DMF scores" | NR | exp=41; com=41 | Moller & Poulsen, 1973^ 117 ^ (no grade 1) | all permanent | visual/tactile, bitewing radio (proximal only) | 2 | inter=NR; intra=NR | all with final exam | 87% | exp = 22%; com = 2% | 32; 40 | exp=29.2 DMFS; com= 28.0 DMFS | exp=4.3 DMFS; com=5.1 DMFS | 15%; p>0.05 NNT=2.5 | 60
2 S2 | Seppä, Tuutti, & Luoma, 1982^ 74 ^ | half-mouth | 36 mo | Finland F = 1-1.2 ppm | 2.2% F varnish (Duraphat) 2/yr | nil | "ordinary dental care" | 11-13 years | "above average DMFS values" | NR | exp=NR; com=NR approx. 95 each | Moller & Poulsen, 1973^ 117 ^ (no grade 1) | all permanent | visual/tactile, bitewing radio | 2 | inter=NR; intra= 0.93 κ | full participation | 100% | exp=NR; com=NR | 62; 62 | exp = 9.10 DMFS; com=8.58 DMFS (1/2 mouth) | exp=4.32 DMFS; com=6.16 DMFS (1/2 mouth) | 30%; p<0.001 NNT=1.6 | 50
2 S2 | Seppä, Tuutti, & Luoma, 1982^ 74 ^ | half-mouth | 36 mo | Finland F = 1-1.2 ppm | 0.7% F varnish (Fluor Protector) 2/yr | nil | "ordinary dental care" | 11-13 years | "above average DMFS values" | NR | exp=NR; com=NR approx. 95 each | Moller & Poulsen, 1973^ 117 ^ (no grade 1) | all permanent | visual/tactile, bitewing radio | 2 | inter=NR; intra= 0.93 κ | full participation | 100% | exp=NR; com=NR | 70; 70 | exp=8.60 DMFS; com=8.69 DMFS (1/2 mouth) | exp=4.37 DMFS; com=4.93 DMFS (1/2 mouth) | 11%; p=ns NNT=5.4 | 50
3 S3 | Lindquist, Edward, Torell, et al., 1989^ 75 ^ | RCT | 24 mo | Sweden F <0.1 ppm | F varnish (Duraphat) 4/yr | nil | NaF rinse 2/mo | 12-14 years | mS >10^6^ CFU/ml | 23% | exp=64; com=64 | Gustafsson, 1954^ 118 ^ (clinical, including incipient caries), Grondahl, et al., 1977^ 119 ^ (radio) | all permanent | visual/tactile, bitewing radio (post proximal only) | 1 | intra=NR | all with final exam | NR | exp=34%; com=22% | 42; 50 | exp=24.3 DFS; com=22.9 DFS | exp=5.88 DFS; com=6.34 DFS | 7%; p>0.05 NNT=4.3 | 55
3 S3 | Lindquist, Edward, Torell, et al., 1989^ 75 ^ | RCT | 24 mo | Sweden F <0.1 ppm | Ferric Aluminum F (0.2%F) topical 4/yr | nil | NaF rinse 2/mo | 12-14 years | mS >10^6^ CFU/ml | 23% | exp=64; com=64 | Gustafsson, 1954^ 118 ^ (clinical, including incipient caries), Grondahl, et al., 1977^ 119 ^ (radio) | all permanent | visual/tactile, bitewing radio (post proximal only) | 1 | intra=NR | all with final exam | NR | exp=27%; com=22% | 47; 50 | exp=25.1 DFS; com=22.9 DFS | exp=5.53 DFS; com=6.34 DFS | 13%; p>0.05 NNT=2.5 | 55
4 S4 | Olivier, Brodeur, & Simard, 1992^ 76 ^ | RCT | 24 mo | Canada F = nf | 1.23% APF gel 2/yr | placebo | usual care, including other routine prevention | 6 years | >3 dfs on primary proximals | NR | exp=248; com=240 | WHO, 1979^ 120 ^ | all permanent | visual/tactile, radio (approx only) | 5 | mean inter and intra > 0.96 ICC | all with final exam | 80% complete | exp=10%; com=14% | 224; 207 | exp=0.59; com=0.74 | exp=2.94 DMFS; com=3.24 DMFS | 9%; p>0.05 NNT=6.7 | 80
5 S5 | Seppä, Pöllanen, & Hausen, 1994^ 77 ^ | RCT | 36 mo | Finland F = 1.0 ppm | 1.13% Duraphat varnish (1/2 strength) 3/yr | 2.26% Duraphat varnish (full strength) 3/yr | sealants | 12-14 years | "highest DMFS & initial caries scores in community" | "about 20%" | exp=NR; com=NR, total=274 | Moller & Poulsen, 1973^ 117 ^ (no grade 1) | all permanent | visual/tactile, bitewing radio | 1 clinical, 1 radio | NR | all with final exam | NR | exp=NR; com=NR 10% overall | 127; 122 | exp=8.5 DMFS; com=8.9 DMFS | exp=4.2 DMFS; com=4.2 DMFS | 0% | 55
6 S6 | Brambilla, Gagliani, Felloni, et al., 1999^ 79 ^ | RCT | 60 mo | Italy F = 0.2 ppm | 1% AmineF rinse 2/year | placebo | 1 mg F tablet/school day; OHI/6 mo | 6 years | mS >10^5^ CFU/ml | 32% (among full participants) | exp=NR; com=NR | WHO, 1987^ 121 ^ | all permanent teeth | visual/tactile | 2 | inter=NR; intra=NR | full participants only | NR | exp=NR; com=NR | 48; 43 | exp=0.62 DMFT; com=0.66 DMFT | exp=1.55 DMFT; com=2.04 DMFT | 24%; p=NR ^1^ NNT=10.2 | 60
Chlorhexedine studies
7 S7 | Lundstrom & Krasse, 1987^ 80 ^ | RCT | 22 mo | Sweden F = NR | 1% CHX gel whenever mS > 5*10^5^ CFU/ml | nil | annual F varnish and/or 2/mo F rinse | 11-15 years | mS >5*10^5^ CFU/ml, ortho Tx | NR | exp=20; com=20 | Gustafsson, 1954^ 119 ^ | all permanent | visual/tactile, bitewing radio | baseline NR; final 1 | inter=0.66-0.90 coef. rel.; intra=NR | all with final exam | NR | exp=30%; com=15% | 14; 17 | exp=9.8 DFS; com=9.9 DFS | exp=2.6 DFS; com=3.5 DFS | 26%; p=ns NNT=2.0 | 40
8 S8 | Gisselsson, Birkhed, & Björn, 1988^ 81 ^ | sub of G-RCT, by class-room, n=6 | 36 mo | Sweden F = 0.3 ppm | 1% CHX gel, 4/yr | placebo | 0.2% NaF rinse 1/wk | 11 years | mS >10^6^ CFU/ml | 49% | exp=NR; com=NR | NR | all permanent proximals | posterior = radio anterior = visual/tactile | posterior=1; anterior=10 | intra=92.5% agreement on radio | only full participants | NR | exp=NR; com=NR | 35; 34 | exp=NR; com=NR | exp=2.5 prox. DFS; com=4.5 prox. DFS | 44%; p=NR NNT=1.5 | 60
9 S3 | Lindquist, Edward, Torell, et al., 1989^ 75 ^ | RCT | 24 mo | Sweden F <0.1 ppm | 1% CHX gel 4/day for 2 days, repeated as needed to get mS<2.5*10^5^ − mean=5 treatments | nil | NaF rinse 2/mo | 12-14 years | mS >10^6^ CFU/ml | 23% | exp=64; com=64 | Gustafsson, 1954^ 118 ^ (clinical, including incipient caries), Grondahl, et al. 1977^ 119 ^ (radio) | all permanent | visual/tactile, bitewing radio (posterior proximal only) | 1 | intra=NR | all with final exam | NR | exp=22%; com=22% | 50; 50 | exp=26.8 DFS; com=22.9 DFS | exp=3.06 DFS; com=6.34 DFS | 52%; p<0.001 NNT=0.6 | 55
10 S9 | Spets-Happonen, Luoma, Forss, et al., 1991^ 82 ^ | RCT | 33 mo | Finland F = NR | 0.05% CHX rinse 2/day for 5 days, every 3rd wk | nil | F varnish (Duraphat) 1/yr | 11 years | >1 DMFS in previous 2 yr | 13% | exp=NR; com=NR | Moller & Poulsen, 1973^ 117 ^ (no grade 1) | all permanent | visual/tactile, FOTI, bitewing radio (proximal only) | 2 | inter=0.70 k ; intra=0.79 k | all with final exam | NR | exp=NR; com=NR 17% overall | 54; 62 | exp=NR; com=NR | exp=3.4 DMFS; com=3.5 DMFS | 3%; p=ns NNT=27.5 | 70
11 S10 | Fennis-le, Verdonschot, Burgersdijk, et al., 1998^ 84 ^ | sub of RCT | 30 mo | Nether-lands F=NR | CHX varnish (40% w/w CHX diacetate in sandrac resin) 2/yr | placebo | F topical 2/yr | 5-6 years and 11-12 years | mS>10^6^ CFU/ml | 15% | exp=NR; com=NR | stained fissures validated by removal of enamel | occlusals of all 1st or 2nd perm molars depending on subject age | visual, with removal of tissue in stained fissures | 1 | intra=NR | all with final exam | 68% ^2^ | exp=NR; com=NR 5% overall | 25; 22 | exp=NR; com=NR | exp=1.8 DFS-molar occ; com=2.7 DFS molar occ | 33%; p<0.05 NNT=2.8 | 55
11 S10 | Fennis-le, Verdonschot, Burgersdijk, et al., 1998^ 84 ^ | sub of RCT | 30 mo | Nether-lands F=NR | CHX varnish (40% w/w CHX diacetate in sandrac resin) 2/yr | placebo | F topical 2/yr | 5-6 years and 11-12 years | DMFS/dmfs >0 | 36% | exp=NR; com=NR | stained fissures validated by removal of enamel | occlusals of all 1st or 2nd perm molars depending on subject age | visual, with removal of tissue in stained fissures | 1 | intra=NR | all with final exam | 68% ^2^ | exp=NR; com=NR 5% overall | 60; 55 | exp=NR; com=NR | exp=2.4 DFS-molar occ; com=2.2 DFS molar occ | −9%; p>0.05 | 55
12 S11 | Bratthall, Serinirach, Rapisuwon, et al., 1995^ 83 ^ | sub of split mouth | 24 mo | Thailand F = NR | 1% CHX varnish 3 times/8 mo | nil | NR | 12-13 years | plaque mS = "dense growth" | 11% among final exam group | exp=NR; com=NR | WHO, 1987^ 121 ^ | 1st or 2nd molars (paired) occ surface | visual | 2 | inter = NR; intra = NR | all with final exam | NR | exp=18%; com=18% | 9; 9 | exp=0; com=0 | exp=33%; com=44% | 25%; p=NR | 25
Combination Studies
13 S1 | Luoma, Murtomaa, Nuuja, et al., 1978^ 73 ^ | RCT | 24 mo | Finland F = NR | 1% CHX/NaF rinse 1/school day; toothpaste with same conc 2/day | nil | 0.02% NaF + OHI 1/yr | 11-15 years | "high DMF scores" | NR | exp=41; com=41 | Moller & Poulsen, 1973^ 117 ^ (no grade 1) | all permanent | visual/tactile, bitewing radio (proximal only) | 2 | inter = NR; intra = NR | all with final exam | 90% | exp=12%; com=2% | 36; 40 | exp=30.4 DMFS; com=28.0 DMFS | exp=2.9 DMFS; com=5.1 DMFS | 43%; p<0.001 NNT=0.9 | 60
14 S12 | Zickert, Emilson, & Krasse, 1982^ 89 ^ | sub of G-RCT, by class-room, n=4 | 36 mo | Sweden F = NR | 1% CHX gel; 1/day self-applied in custom tray for 14 days, repeated every 4 mo if mS>2.5*10^5^; occlusal sealant | nil | 0.2% NaF rinse 2/mo | 13-14 years | mS>10^6^ CFU/ml at baseline | 21% | exp=10; com=11 | Gustafsson, 1954 (inc. caries w/o defect on visible surfaces) | all permanent | visual/tactile, radio (proximal only) | 2 | inter = NR; intra = NR | full participants only | NR | exp=10%; com=27% | 9; 8 | exp=NR; com=NR | exp=3.9 DMFS; com=20.8 DMFS | 81%; p<0.001 NNT=0.2 | 45
15 S13 | Rask, Emilson, Krasse, et al., 1988^ 86 ^ | sub of RCT | 12 mo | Sweden F = NR | 1% CHX gel repeated as needed to achieve "satisfactory results" + NaF topical and home gel | nil | usual care, OHI diet info, NaF varnish or topical if dentist deems necessary | 50-60 years | combinations of salivary secretion <0.7ml/min; Lactobacilli> 10^5^ CFU/ml; mS>2.5*10^5^ CFU/ml | 23% | exp=16; com=12 | Gustafsson, 1954^ 118 ^, including demineralization | all permanent | visual/tactile, bitewing radio | 1 | Intra = NR | all with final exam | NR | exp=6%; com=17% | 15; 10 | exp=94 DMFS; com=92 DMFS | exp=0.19 DFS; com=1.67 DFS | 89%; p<0.05 NNT=0.7 | 45
16 S9 | Spets-Happonen, Luoma, Forss, et al., 1991^ 82 ^ | RCT | 33 mo | Finland F = NR | 0.05% CHX + 0.04% NaF + 500 ppm Sr rinse, 2/day for 5 days, every 3rd wk | nil | F varnish (Duraphat) 1/yr | 11 years | >1 DMFS in previous 2 yr | 13% | exp=NR; com=NR | Moller & Poulsen, 1973^ 117 ^ (no grade 1) | all permanent | visual/tactile, FOTI, bitewing radio (proximal only) | 2 | inter = 0.70k; intra = 0.79k | all with final exam | NR | exp=NR; com=NR | 54; 62 | exp=NR; com=NR | exp=3.5 DMFS; com=3.8 DMFS | 8%; p>0.05 NNT=9.2 | 70
16 S9 | Spets-Happonen, Luoma, Forss, et al., 1991^ 82 ^ | RCT | 33 mo | Finland F = NR | 0.05% CHX + 0.04% NaF rinse 2/day for 5 days, every 3rd wk | nil | F varnish (Duraphat) 1/yr | 11 years | >1 DMFS in previous 2 yr | 13% | exp=NR; com=NR | Moller & Poulsen, 1973^ 117 ^ (no grade 1) | all permanent | visual/tactile, FOTI, bitewing radio (proximal only) | 2 | inter = 0.70k; intra = 0.79k | all with final exam | NR | exp=NR; com=NR | 56; 62 | exp=NR; com=NR | exp=2.5 DFS; com=3.8 DMFS | 34%; p>0.05 NNT=2.1 | 70
17 S14+A5 | Petersson, Magnusson, Anderson, et al., 1998^ 88 ^ | G-RCT | 36 mo | Sweden F = NR | 1% CHX + 0.1% NaF varnish 2/yr | 0.1% NaF varnish, 2/yr | NR | 12 years (5th grade) | any proximal DMFS on bitewing radiograph | 79% | exp=115; com=104 | any detectable DFS on radiograph | permanent posterior proximals | bitewing radio (proximal only) | 1 | intra = 0.92 Pearson | all with final exam | NR | exp=0%; com=0% | 115; 104 | exp=2.0 DFS-prox; com=1.79 DFS-prox | exp=3.78 DFS-prox; com=3.01 DFS-prox | −26%; p = ns | 65
Studies of Other Agents
18 S15 | Kleber, Putt, Smith, et al., 1996^ 90 ^ | RCT | 12 mo | USA F=0.4 ppm | 0.885% alum rinse 1/day | placebo | NaF dentifrice | mean= 10.7 years (5th-6th grade) | any DMFS/dfs | 70% | exp=86; com=87 | Radike, 1968^ 122 ^ | all permanent | visual/tactile, radio (approx only) | 2 | inter = NR; intra = NR | all with final exam | NR | exp=11%; com=9% | 77; 86 | exp=4.74 DMFS; com=4.52 DMFS | exp=1.57 DMFS; com=2.03 DMFS | 23%; p = ns NNT=2.2 | 65
19 S16 | Beiswanger, Boneta, Mau, et al., 1998^ 92 ^ | sub of G-RCT, by class-room, n=123 | 36 mo | Puerto Rico F<0.1 ppm | sugar-free gum with sorbitol (40-60%), manitol (4-15%), aspartame (<0.6%) 3/day | nil | NR | mean=11.7 years (5th-7th grade) | DMFS > 0 | 87% | exp=NR; com=NR | Radike,1968^ 122 ^ (no white spots) | all permanent | visual/tactile, radio (proximal only) | 1 | intra = NR | partial ITT (5% of dropouts included) | NR | exp and com=47% | 607; 649 | exp = NR; com = NR | exp=8.3 DMFS; com=9.3 DMFS ^3^ | 11%; p<0.003 (one-tailed test) NNT=3.0 | 65
20 S17 | Loesche, Bradbury, & Woolfolk, 1977^ 93 ^ | RCT | mean = 31 mo | USA F = NR | 5% kanamycin gel 2/day for 1 wk, with tx repeated once after 5-7 wks | placebo | NR | 4-17 years | DFS/dfs > 10 | NR | exp=26; com=19 | cavitation | all primary & permanent | visual/tactile, full radio | 1 | intra = NR | full participants only | 100% | exp=38%; com=32% | 16; 13 | exp = NR; com = NR | exp=1.88 DMFS; com=3.46 DMFS | 46%; p = NR NNT=1.6 | 40
21 S18 | Sheykholeslam & Houpt, 1978^ 94 ^ | split mouth | 24 mo | USA F = "recently Fuoridted" | occlusal sealant (Delton), no repair | nil | NR | 6-10 years mean = 7.5 years | "evidence of previous dental caries" | 21% including need for caries-free 1st molar pair | exp=205; com=205 | NR | permanent 1st molar occlusals | visual/tactile | 2 | inter = NR; intra = NR | all with final exam | n/a | exp=15%; com=15% | 175; 175 | exp=0; com=0 | exp=0.06 1st mol. DMFS; com=0.51 1st mol. DMFS | 88%; p = NR NNT=4.4 | 65
22 S19 | Isokangas, 1987 ^ 91 ^ | sub of G-RCT, by school n=NR | 36 mo | Finland F<0.1 ppm | Xylitol gum 3.5 g/piece 3/day | nil | daily 1 mg, F tabs, 2 F rinses 2/mo, F topical 1-2/yr | 11-12 years (5th-6th grade) | 11 years DMFT > 5; 12 years DMFT > 7 | 19% | exp=34; com=36 | WHO, 1979^ 120 ^ no D_1;_ Grondahl, 1977^ 119 ^ | all permanent | visual/tactile, bitewing radio (final exam only) | 8 | inter=0.89, intra=0.18, % agreement | all with final exam | 7% used F tabs, 90% >2 pieces of gum/day | exp=13%; com=0% | 30; 36 | exp=6.8 DFS; com=6.5 DFS | exp=1.7 DFS; com=3.8 DFS | 55%; p<0.001 NNT=1.4 | 70
23 S20 | Seppä, Hausen, Pöllanen, et al., 1991^ 95 ^ | RCT | 24 mo | Finland F=1.0 ppm | mS test results and directive to treating dentists for heightened prevention attention | mS test results w/o directive | up to individual dentist | 13 years | DS >1 or mS>10^6^ CFU/ml | 37% | exp=130; com=135 | Moller & Poulsen, 1973^ 117 ^ (no grade 1) | all permanent except occlusals | visual/tactile, radio | 1 | intra = NR | all with final exam | >99% | exp=8%; com=7% | 120; 126 | exp=13.8 DMFS-no occ; com=14.7 DMFS-no occ | exp=2.22 DMFS-no occ; ocm=2.56 DMFS-no occ | 13%; p = ns | 60
Studies on Primary Teeth
24 S21 | Tenovuo, Hakkinen, Paunio, et al., 1992^ 87 ^ | RCT | 36 mo | Finland F = NR | 0.2 NaF and 1% CHX rinse administered to mothers of infants 3/day for 2 days twice/yr | nil | NR | 1 year | Mothers' mS >10^5^ CFU/ml on 2 consecutive samples | 74% | exp=59; com=53 | caries extending into dentin | all primary | visual/tactile | 1 | intra = NR | all with final exam | NR | exp=5%; com=6% | 56; 50 | exp=0 dft; com=0 dft | exp=0.59 dft; com=0.68 dft | 13%; p = ns NNT=33.5 | 40
25 S22 | Petersson, Twetman, & Pakhomov, 1998^ 78 ^ | sub of G-RCT by clinic, n=24 | 24 mo | Sweden 90% F <0.1 ppm; 10% F = 1.2 ppm | 0.1% F varnish 2/yr (Fuor Protector) | nil | NR | 4-5 years | >5 dfs at baseline | 7% among full participants | exp=NR; com=NR | WHO, 1987^ 121 ^ | primary ant & post proximals | visual/tactile | 24 | inter = NR; com = NR | full participants only | NR | exp=NR; com=NR | 145; 158 | exp = NR; com = NR | exp=1.73 dfs-prox; com=2.30 dfs-prox | 25%; p<0.05 NNT=3.5 | 50

1 Survival analysis on 1^st^ molars was ns.

2 Based on mean length of time between applications with 100% being 0.5 yr.

3 Adjusted for group assignment age, sex, baseline DMFS with random effects ANCOVA.

Explanations for Selected Column Headings

Type of Design: Study design of main study; subsets represent reported analyses of selected lesions in experimental and control groups that meet review criteria. Duration: Months from baseline to final examination. Country and F Status: Location of study; community water fluoridation status of participants. Other Professional Prevention: Other preventive dental procedures received by all subjects. Subject Age: Mean, range, and/or standard deviation of the participants at baseline if reported. Selection Criteria for CA Designation: Criteria used to identify caries-active or high caries-risk subjects in the study, either as the original subjects, or for subgroup analysis. CA as % of Population/Sample: For subsets of trials, the percent of all subjects in the trial who were designated as caries active; for trials, the actual or estimated sample population proportion determined to be caries active. Baseline CA Sample N: Number of caries-active subjects at baseline for experimental and comparison groups. Criteria for Caries: Criteria set used for caries examinations. Teeth: Tooth types (and specific surfaces, if any) examined. Type of Exam: Diagnostic method(s) used. Reliability: Reports the statistic and value for interexaminer and/or intraexaminer reliability. Type of Analysis: Approach to including subjects in the analysis, either analyses that include all subjects with baseline and final examinations, or analyses that also demand "full participation." Compliance Estimate: Information presented about subject compliance with study protocols. Attrition from Baseline: Percent of baseline subjects not included in final analysis, reported separately for experimental and control groups if available. Final N: Number of experimental and comparison group subjects included in the analysis. Baseline Caries Level: Mean caries index scores at baseline for analysis group. δ Caries: Caries increments for experimental and comparison groups from baseline to final exam. Percent Reduction: Percent difference in increment scores, calculated as (comp-exp)/comp. Quality Score: Evaluation of the quality of the study on a 0 to 100 scale (see Figure 3 for the scoring instrument).

Evidence Table 5. Prevention for caries-active individuals: Studies of various agents on orthodontically banded teeth

Author, Year | | Type of Design | Country and F Status | Duration | Prev. Agent | Comparison Agent | Teeth & Surfaces | Type of Exam | Compliance Estimate | Outcome
Author, Year | | Type of Design | Country and F Status | Duration | Prev. Agent | Comparison Agent | Teeth & Surfaces | Type of Exam | Compliance Estimate | Attrition from Baseline | Final N (exp; com) | % Sites w/ Demineralization | # Initial Lesions/ Subject | Lesion Depth | % Reduction | Quality Score
1 | Hirschfield, 1978^ 96 ^ | non-RCT | USA F = NR | 20-28 mo | APF rinse (Phosflur) 1/day | nil | #s 10, 19 all surfaces | visual | NR | exp=0%; com=0% | 60; 60 | exp=15%; com=32% | n/a | n/a | 53%; p 0<0.02 | 30
2 | Lundstrom, Hamp, & Nyman, 1980^ 98 ^ | RCT | Sweden F = NR | 24 mo | prophy + 0.2% CHX rinse 4 times, every 3rd wk | placebo rinse | #s 3, 4, 6, 27, 29, 30, smooth surfaces | visual | NR | exp=0%; com=0% | 15; 15 | n/a | exp=0.1; com=2.1 | n/a | 95%; p = NR | 50
2 | Lundstrom, Hamp, & Nyman, 1980^ 98 ^ | RCT | Sweden F = NR | 24 mo | prophy and placebo rinse every 3rd wk | placebo rinse | #s 3, 4, 6, 27, 29, 30, smooth surfaces | visual | NR | exp=0%; com=0% | 15; 15 | n/a | exp=0.7; com=2.1 | n/a | 67%; p = NR | 50
2 | Lundstrom, Hamp, & Nyman, 1980^ 98 ^ | RCT | Sweden F = NR | 24 mo | 0.2% CHX rinse 4 times, every 3rd wk | placebo rinse | #s 3, 4, 6, 27, 29, 30, smooth surfaces | visual | NR | exp=0%; com=0% | 15; 15 | n/a | exp=1.8; com=2.1 | n/a | 14%; p = NR | 50
3 | Holmen Mejare, Malmgren, et al., 1988^ 102 ^ | split mouth | Denmark F = nf | 5 wk | band removal & plaque removal w/ cotton pellet 1/wk | nil, no band removal | prem 1st premolars, smooth surfaces | visual | NR | exp=0%; com=0% | 7; 7 | exp=0%; com=100% | n/a | n/a | 100%; p = NR | 15
3 | Holmen Mejare, Malmgren, et al., 1988^ 102 ^ | split mouth | Denmark F = nf | 5 wk | band removal & non-F pumice cleaning 1/wk | nil, no band removal | prem 1st premolars, smooth surfaces | visual | NR | exp=0%; com=0% | 7; 7 | exp=0%; com=100% | n/a | n/a | 100%; p = NR | 15
4 | Boyd, 1993^ 97 ^ | non-RCT | USA F = NR | 26 mo | 0.05% NaF rinse 1/day + 1,100 ppm NaF tooth-paste | nil | all permanent facial surfaces | visual | 89% | exp=13%; com=9% | 26; 32 | n/a | exp=10.1; com=14.4 | n/a | 30%; p<0.05 | 45
4 | Boyd, 1993^ 97 ^ | non-RCT | USA F = NR | 26 mo | 0.4% SnF_2_ gel brushed on 2/day + 1,100 ppm NaF tooth-paste | nil | all permanent facial surfaces | visual | 88% | exp=20%; com=9% | 24; 32 | n/a | exp=4.1; com=14.4 | n/a | 72%; p<0.05 | 45
5 | Buyukyilmaz, Tangugsorn, Ogaard, et al., 1994^ 99 ^ | half mouth | Norway F = NR | 4 wk | 1% TiF topical | nil | prem premolars, facial surface | microradiography | NR | exp=0%; com=0% | NR | n/a | n/a | exp=26 µm; com=41 µm | 37%; p<0.05 | 10
6 | Ogaard, Duschner, Ruben, et al., 1996^ 100 ^ | split mouth | Norway F = NR | 4 wk | 5% F varnish (Duraphat) once | nil | premolars, facial surface, under band | microradiography | n/a | exp=0%; com=0% | 6; 6 | n/a | n/a | exp=80 µm; com=152 µm | 48%; p<0.02 | 15
7 | Ullsfoss, Ogaard, Arends, et al., 1994^ 101 ^ | RCT | Norway F = NR | 4 wk | 0.05 NaF rinse 1/day & 0.2% CHX rinse 2/day | 0.05 NaF rinse 1/day | selected premolars, facial surface, under band | microradiography | NR | exp=0%; com=0% | 15; 14 | n/a | n/a | exp=8 µm; com=26 µm | 69%; p<0.05 | 25

Evidence Table 6. Prevention for caries-active individuals: Studies of various agents on individuals with oral radiotherapy

Author, Year | | Type of Design | Duration and Start | Country and F status | Prev. Agent | Comparison Agent | Subj. Age | Selection Criteria for CA Designation | Teeth & Surfaces | Type of Exam | Type of Analysis | Compliance Estimate | Attrition from Baseline | Final N (exp; com) | Δ Caries | % Reduction | Quality Score
1 | Dreizen, Brown, Daly, et al., 1977^ 103 ^ | prospective cohort | individualized, mean = 20 mo | USA F = NR | disclosing dye, 1% NaF gel 1/day | placebo gel + disclosing dye 1/day | mean= 51.8 years (18-77) | >5,000 rads | all permanent | visual/ tactile, radio (approx only) | all with final exam | NR | exp=13%; com=8% | 13; 11 | exp=0.12 DMFS/mo; com=2.51 DMFS/mo | 95%; p<0.01 | 26
1 | Dreizen, Brown, Daly, et al., 1977^ 103 ^ | prospective cohort | individualized, mean = 20 mo | USA F = NR | disclosing dye, 1% NaF gel 1/day + sucrose restriction | placebo gel + disclosing dye 1/day | mean= 51.8 years (18-77) | >5,000 rads | all permanent | visual/ tactile, radio (approx only) | all with final exam | NR | exp=7%; com=8% | 14; 11 | exp=0.04 DMFS/mo; com=2.51 DMFS/mo | 98%; p<0.01 | 26
2 | Katz, 1982^ 108 ^ | prospective cohort | 6-10 mo | Spain F = NR | 1% CHX, 1% NaF topical 1/wk for 4 wk + 0.2% CHX, 0.05% NaF rinse 1/day | 1.23% APF topical 1/wk for 4 wks + 0.05 NaF rinse 1/day | mean= 50.3 years | NR | all permanent | visual/ tactile | all with final exam | NR | exp = NR; com = NR 51% overall | 16; 11 | exp=-0.27 DFS/mo; com=0.35 DMFS/mo | 177%; p<0.05 | 5
2 | Katz, 1982^ 108 ^ | prospective cohort | 6-10 mo | Spain F = NR | 0.2% CHX, 0.05% NaF rinse 1/day | 1.23% APF topical 1/wk for 4 wks + 0.05 NaF rinse 1/day | mean= 50.3 years | NR | all permanent | visual/ tactile | all with final exam | NR | exp=13; com=8 | 8; 11 | exp=0.02 DFS/mo; com=0.35 DMFS/mo | 94%; p = ns | 5
3 | Makkonen Edelman, & Forten, 1986^ 104 ^ | RCT | 12 mo | Finland F = NR | 0.2% NaF gel + prophy 1/wk + NaF-CaP rinse 2/day for 4 wks, then NaF-CaP rinse 1/day + NaF gel at 3 & 6 mo | 0.2% NaF gel + prophy 1/wk + 0.05% NaF rinse 2/day for 4 wks, then 0.05% NaF 1/day + 0.2% NaF gel at 3 & 6 mo | 49 years | >30 Gy | all permanent smooth surfaces | visual-buccal and lingual surfaces | all with final exam | NR | exp = NR; com = NR 38% overall | 17; 11 | exp=0.81 DFS/mo; com=1.12 DFS mo | 28%; p = NR | 21
4 | Al-Joburi, Clark, & Fisher, 1991^ 106 ^ | RCT stratified by radiation field | 12 mo: variable, before and after radiation therapy | Canada F = NR | 0.4% SnF_2_ gel brushed on 1/day | 1.1% NaF gel 1/day for 3 mo, then 1.1% NaF rinse 2/day | mean = 56.5 ± 13 years | sequential patients receiving radiation for head/neck cancer | all permanent | clinical with radiological confirmation | NR | only compliant subjects included in analyses | exp=42%; com=28% | 56; 69 | exp=0.06 DFS/mo; com=0.06 DFS/mo | 0%; p = ns | 37
4 | Al-Joburi, Clark, & Fisher, 1991^ 106 ^ | RCT stratified by radiation field | 12 mo: variable, before and after radiation therapy | Canada F = NR | 0.4% SnF_2_ gel brushed on 1/day | 1.1% NaF gel 1/day for 3 mo, then 1.1% NaF rinse 2/day | mean = 56.5 ± 13 years | sequential patients receiving radiation for head/neck cancer | all root | clinical with radiological confirmation | NR | only compliant subjects included in analyses | exp=42%; com=28% | 56; 69 | exp=0.13 RCI/mo; com=0.43 RCI/mo | 70%; p<0.05 | 37
5 | Spak, Johnson, & Ekstrand, 1994^ 105 ^ | RCT | 12 mo: from start of radiation therapy | Sweden F = NR | 1.23% APF gel 1/day for 4 wk, then 0.042 NaF gel sweetened w/ Xylitol 1/day | 0.042 NaF gel sweetened w/ Xylitol 1/day | mean= 58.7 years | all with >5 teeth receiving head/neck radiotherapy | all permanent, including root | visual/tactile, radio | NR | NR | exp=36%; com=30% | 18; 19 | exp=0.44 DMFS+RS/mo; com=0.36 DMFS+RS/mo | −22%; p = ns | 42
6 | Meyerowitz & Watson, 1998^ 107 ^ | RCT | 6 mo: >3 mo after radiation therapy | USA F = NR | intraoral slow release system, 24 mg NaF/day | 1.1% NaF gel 1/day | mean= 46.3 years | >40 Gy, at least 3 mo prior, & < 0.5 ml/min salivary flow | all permanent | visual/tactile, radio | all with final exam | NR | exp=38%; com=9% | 13; 10 | exp=0.01 DMFS/mo; com=0.03 DMFS/mo | 67%; p = ns | 26