# Bibliography

Aasenden R, DePaola PF, Brudevold F. Effects of daily rinsing and ingestion of fluoride solutions upon dental caries and enamel fluoride. Arch Oral Biol. 1972;17:1705-1714. [pmid: 4405216].
Aasenden R, Peebles TC. Effects of fluoride supplementation from birth on dental caries and fluorosis in teenaged children. Arch Oral Biol. 1978;23:111-115. [pmid: 274920].
Aasrum E, Ng'ang'a PM, Dahm S, Ogaard B. Tensile bond strength of orthodontic brackets bonded with a fluoride-releasing light-curing adhesive. An in vitro comparative study. Am J Orthod Dentofacial Orthop. 1993;104:48-50. [pmid: 8322723].
Abbott PV. Lower lip paraesthesia following restoration of a second premolar tooth. Case report. Aust Dent J. 1997;42:297-301.
Abdel-Al YK, Shabani IS, Lubani MM, et al. Autosomal recessive osteopetrosis in Arab children. Ann Trop Paediatr. 1994;14:59-64. [pmid: 7516136].
Abrahams LJ, Yonese M, Higuchi WI, Fox JL, Charbeneau GT. In vivo remineralization using a sustained topical fluoride delivery system. J Dent Res. 1980;59:583-587. [pmid: 6937490].
Abrams K, Sanso B. Approximate Bayesian inference for random effects meta-analysis. Stat Med. 1998;17:201-218. [pmid: 9483729].
Abrams RG, Chambers DW. Caries-inhibiting effect of a stannous fluoride silica gel dentifrice: a three-year clinical study. Clin Prev Dent. 1980;2:22-27. [pmid: 6253112].
Abreu Jr M, Tyndall DA, Ludlow JB. Detection of caries with conventional digital imaging and tuned aperture computed tomorgraphy using CRT monitor and laptop displays. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 1999;88:234-238. [pmid: 10468469].
Achong RA, Briskie DM, Hildebrandt GH, Feigal RJ, Loesche WJ. Effect of chlorhexidine varnish mouthguards on the levels of selected oral microorganisms in pediatric patients. Pediatr Dent. 1999;21:169-175. [pmid: 10355007].
Acs G, Lodolini G, Kaminsky S, Cisneros GJ. Effect of nursing caries on body weight in a pediatric population. Pediatr Dent. 1992;14:302-305. [pmid: 1303533].
Acs G, Shulman R, Ng MW, Chussid S. The effect of dental rehabilitation on the body weight of children with early childhood caries. Pediatr Dent. 1999;21:109-113. [pmid: 10197335].
Adams AB, Jones DA. The agar-replica technique for dental caries diagnosis. Has its time arrived?. Northwest Dent. 1996;75:23-25.
Adams PF, Marano MA. Current estimates from the National Health Interview Survey, 1994. Vital Health Stat. 1994;10.
Addy M. Evaluation of clinical trials of agents and procedures to prevent caries and periodontal disease: choosing products and recommending procedures. Int Dent J. 1995;45:185-196. [pmid: 7558357].
Addy M, Renton-Harper P, Myatt G. A plaque index for occlusal surfaces and fissures. Measurement of repeatability and plaque removal. J Clin Periodontol. 1998;25:164-168. [pmid: 9495616].
Adkins BL. Methodological developments for clinical trials. J Dent Res. 1977;56 Spec No:C130-135. [pmid: 273022].
Adler P, Szabo Z. Comparison of two mathematical descriptions of the cumulative caries prevalence. Acta Med Acad Sci Hung. 1979;36:211-222. [pmid: 545982].
Adriaens ML, Dermaut LR, Verbeeck RM. The use of 'Fluor Protector', a fluoride varnish, as a caries prevention method under orthodontic molar bands. Eur J Orthod. 1990;12:316-319. [pmid: 2401340].
Afflitto J, Schmid R, Esposito A, Toddywala R, Gaffar A. Fluoride availability in human saliva after dentifrice use: correlation with anticaries effects in rats. J Dent Res. Spec No. 1992;71:841-845. [pmid: 1592971].
Agerbaek N, Poulsen S, Melsen B, Glavind L. Effect of professional toothcleansing every third week on gingivitis and dental caries in children. Community Dent Oral Epidemiol. 1978;6:40-41. [pmid: 272263].
Ahlberg J, Murtomaa H, Meurman JH. Subsidized dental care associated with lower mutans streptococci count in male industrial workers. Acta Odontol Scand. 1999;57:83-86. [pmid: 10445360].
Ahlqwist M, Halling A, Hollender L. Rotational panoramic radiography in epidemiological studies of dental health. Comparison between panoramic radiographs and intraoral full mouth surveys. Swed Dent J. 1986;10:73-84. [pmid: 3518113].
Ainamo A, Soikkonen K, Wolf J, et al. Dental radiographic findings in the elderly in Helsinki, Finland. Acta Odontol Scand. 1994;52:243-249. [pmid: 7985510].
Ainamo J, Parvianinen K. Influence of increased toothbrushing frequency on dental health in low, optimal, and high fluoride areas in Finland. Community Dent Oral Epidemiol. 1989;17:296-299. [pmid: 2591180].
Aithal KS, Udupa DN, Tandon S. Clinical evaluation of sodium fluoride chewable tablets in dental caries. Indian J Dent Res. 1996;7:136-139. [pmid: 9495129].
Akehurst R, Sanderson D. Cost effectiveness in dental health: A review of strategies available for preventing caries. Br J Med Econ. 1994;7:43-54.
Akpata ES, al-Shammery AR, Saeed HI. Dental caries, sugar consumption and restorative dental care in 12-13-year-old children in Riyadh, Saudi Arabia. Community Dent Oral Epidemiol. 1992;20:343-346. [pmid: 1464229].
Akpata ES, Farid MR, al-Saif K, Roberts EA. Cavitation at radiolucent areas on proximal surfaces of posterior teeth. Caries Res. 1996;30:313-316. [pmid: 8877083].
Al-Joburi W, Clark C, Fisher R. A comparison of the effectiveness of two systems for the prevention of radiation caries. Clin Prev Dent. 1991;13:15-19. [pmid: 1809524].
Al-Joburi W, Koulourides T. Effect of fluoride on in vitro root surface lesions. Caries Res. 1984;18:33-40. [pmid: 6360374].
Al-Khateeb S, Forsberg CM, de Josselin de Jong E, Angmar-Mansson B. A longitudinal laser fluorescence study of white spot lesions in orthodontic patients. Am J Orthod Dentofacial Orthop. 1998;113:595-602. [pmid: 9637561].
al-Khateeb S, ten Cate JM, Angmar-Mansson B, et al. Quantification of formation and remineralization of artificial enamel lesions with a new portable fluorescence device. Adv Dent Res. 1997;11:502-506. [pmid: 9470510].
al-Khateeb TL, al-Marsafi AI, O'Mullane DM. Caries prevalence and treatment need amongst children in an Arabian community. Community Dent Oral Epidemiol. 1991;19:277-280. [pmid: 1742993].
al-Sehaibany F, White G, Rainey JT. The use of caries detector dye in diagnosis of occlusal carious lesions. J Clin Pediatr Dent. 1996;20:293-298. [pmid: 9151621].
al-Shalan TA, Erickson PR, Hardie NA. Primary incisor decay before age 4 as a risk factor for future dental caries. Pediatr Dent. 1997;19:37-41. [pmid: 9048412].
Alacam T. Evaluation of a tactile hardness test in indirect pulp capping. Int Endod J. 1985;18:274-276. [pmid: 3865903].
Alaluusua S Salivary counts of mutans streptococci and lactobacilli and past caries experience in caries prediction Caries Res 1993 27(suppl) 1:68 71 8500129
Alaluusua S Streptococcus mutans establishment and changes in salivary IgA in young children with reference to dental caries. Longitudinal studies and studies on associated methods Proc Finn Dent Soc 1983 79(suppl) 3:1 55
Alaluusua S, Kleemola-Kujala E, Gronroos L, Evalahti M. Salivary caries-related tests as predictors of future caries increment in teenagers. A three-year longitudinal study. Oral Microbiol Immunol. 1990;5:77-81. [pmid: 2087352].
Alaluusua S, Malmivirta R. Early plaque accumulation--a sign for caries risk in young children. Community Dent Oral Epidemiol. 1994;22:273-276. [pmid: 7813174].
Alanen P, Hurskainen K, Isokangas P, et al. Clinician's ability to identify caries risk subjects. Community Dent Oral Epidemiol. 1994;22:86-89. [pmid: 8205785].
Albandar JM, Buischi YA, Axelsson P. Caries lesions and dental restorations as predisposing factors in the progression of periodontal diseases in adolescents. A 3-year longitudinal study. J Periodontol. 1995;66:249-254. [pmid: 7782977].
Albandar JM, Buischi YA, Mayer MP, Axelsson P. Long-term effect of two preventive programs on the incidence of plaque and gingivitis in adolescents. J Periodontol. 1994;65:605-610. [pmid: 8083793].
Albert RJ, Cantin RY, Cross HG, Castaldi CR. Nursing caries in the Inuit children of the Keewatin. J Can Dent Assoc. 1988;54:751-758. [pmid: 3052718].
Albrecht M, Banoczy J, Baranyi E, et al. Studies of dental and oral changes of pregnant diabetic women. Acta Diabetol Lat. 1987;24:1-7. [pmid: 3497504].
Alexander WE, McDonald RE, Stookey GK. Effect of stannous fluoride on recurrent caries--results after 24 months. J Dent Res. 1973;52.
Allen CD, Ashley FP, Naylor MN. Caries experience in 11-year-old school girls between 1962 and 1981. A radiological study. Br Dent J. 1983;154:167-170. [pmid: 6573887].
Alley JW, Alderman EJ, Levy SM, Kuthy RA. Dietary fluoride supplements for children--the role of the physician. J Med Assoc Ga. 1989;78:629-632. [pmid: 2778408].
Allred H. Histochemical observations on the lipids of carious human dentine. Nature. 1966;210.
Allred H. The staining of the lipids in carious human dentine. Arch Oral Biol. 1969;14:271-276. [pmid: 4182945].
Alman JE. Statistical and ethical considerations in clinical trials. Community Dent Oral Epidemiol. 1980;8:267-272. [pmid: 6936129].
Almeida OP, Bozzo L. Morphology of the nerve fibers in both normal and inflamed human dental pulp. Acta Anat (Basel). 1973;84:597-607. [pmcid: 197609]. [pmid: 4574218].
Almqvist H, Wefel JS, Lagerlof F. Root hard-tissue demineralization rate measured by 125I absorptiometry: comparison with lesion-depth measurements. J Dent Res. 1990;69:1519-1521. [pmid: 2384629].
Altschuler GB, Belikov AV, Cernavin I. A comparison of three methods for the diagnosis of sound, stained, and carious dentine: Conventional, mechanico-acoustic, and laser-acoustic methods. J Clin Laser Med Surg. 1999;17:115-119. [pmid: 11199830].
Alvarez JO, Caceda J, Woolley TW, et al. A longitudinal study of dental caries in the primary teeth of children who suffered from infant malnutrition. J Dent Res. 1993;72:1573-1576. [pmid: 8254124].
Alvesalo L, Brummer R, Le Bell Y. On the use of fissure sealants in caries prevention. A clinical study. Acta Odontol Scand. 1977;35:155-159. [pmid: 331847].
Amaechi BT, Higham SM, Edgar WM. Factors influencing the development of dental erosion in vitro: enamel type, temperature and exposure time. J Oral Rehabil. 1999;26:624-630. [pmid: 10447814].
Amarante E, Raadal M, Espelid I. Impact of diagnostic criteria on the prevalence of dental caries in Norwegian children aged 5, 12 and 18 years. Community Dent Oral Epidemiol. 1998;26:87-94. [pmid: 9645401].
Dental practice parameters. Parameters for 12 oral health conditions. Adopted by the American Dental Association House of Delegates. October 1994 J Am Dent Assoc 1995(suppl):1 37
Anderson L, Shaw JM, McCargar L. Physiological effects of bulimia nervosa on the gastrointestinal tract. Can J Gastroenterol. 1997;11:451-459. [pmid: 9286483].
Anderson MH, Charbeneau GT. A comparison of digital and optical criteria for detecting carious dentin. J Prosthet Dent. 1985;53:643-646. [pmid: 2582117].
Anderson MH, Omnell KA. Modern management of dental caries: the cutting edge is not the dental bur. N M Dent J. 1995;46:10-14.
Anderson P, Davis GR, Ahluwalia MH. Monitoring de- and remineralisation of enamel in vitro using an infrared reflectance meter. Caries Res. 1996;30:394-399. [pmid: 8946106].
Anderson RJ. The changes in dental caries experience of 12-year-old school children in two Somerset schools. A review after an interval of 19 years. Br Dent J. 1984;157:20-22. [pmid: 6588979].
Andersson R, Grahnen H. Fluoride tablets in pre-school-age--effect on primary and permanent teeth. Sven Tandlak Tidskr. 1976;69:137-143. [pmid: 1068536].
Andersson-Wenckert IE, Folkesson UH, van Dijken JW. Durability of a polyacid-modified composite resin (compomer) in primary molars. A multicenter study. Acta Odontol Scand. 1997;55:255-260. [pmid: 9298168].
Andlaw RJ. Oral hygiene and dental caries--a review. Int Dent J. 1978;28:1-6. [pmid: 346493].
Andlaw RJ, Palmer JD, King J, Kneebone SB. Caries preventive effects of toothpastes containing monofluorophosphate and trimetaphosphate: a 3-year clinical trial. Community Dent Oral Epidemiol. 1983;11:143-147. [pmid: 6342928].
Angelillo IF, Torre I, Nobile CG, Villari P. Caries and fluorosis prevalence in communities with different concentrations of fluoride in the water. Caries Res. 1999;33:114-122. [pmid: 9892778].
Angmar-Mansson B, ten Bosch JJ. Advances in methods for diagnosing coronal caries--a review. Adv Dent Res. 1993;7:70-79. [pmid: 8260014].
Angulo M, Zinemanas E, Pivel L, Jorysz E, Casamayou R, Krasse B. Caries incidence, effect of preventive measures, and caries prediction in Uruguayan children. Acta Odontol Scand. 1995;53:1-6. [pmid: 7740923].
Ankkuriniemi O, Ainamo J. Dental health and dental treatment needs among recruits of the Finnish Defence Forces, 1919-91. Acta Odontol Scand. 1997;55:192-197. [pmid: 9226431].
Ann MT, Shoba T, Samaraj T. Effect of fluoride on root caries--an in vitro study. J Pierre Fauchard Acad. 1991;5:11-15. [pmid: 1810324].
Anneroth G. Microradiography in oral research. Sven Tandlak Tidskr. 1971;64:317-334. [pmid: 4950170].
Ansai T, Yamashita Y, Shibata Y, et al. Relationship between dental caries experience of a group of Japanese kindergarten children and the results of two caries activity tests conducted on their saliva and dental plaque. Int J Paediatr Dent. 1994;4:13-17. [pmid: 7748842].
Ansari G, Beeley JA, Reid JS, Foye RH. Caries detector dyes--an in vitro assessment of some new compounds. J Oral Rehabil. 1999;26:453-458. [pmid: 10397176].
Anson RA, Full CA, Wei SH. Retention of pit and fissure sealants placed in a dental school pedodontic clinic: a retrospective study. Pediatr Dent. 1982;4:22-26. [pmid: 6217453].
Anusavice KJ. Efficacy of nonsurgical management of the initial caries lesion. J Dent Educ. 1997;61:895-905. [pmid: 9420566].
Anusavice KJ. Treatment regimens in preventive and restorative dentistry. J Am Dent Assoc. 1995;126:727-743. [pmid: 7797729].
Aoba T, Moriwaki Y, Doi Y, Ozkazaki M, Takahashi J, Yagi T. The intact surface layer in natural enamel caries and acid-dissolved hydroxyapatite pellets. An X-ray diffraction study. J Oral Pathol. 1981;10:32-39. [pmid: 6782208].
Aoba T, Yagi T. Crystallographic and structural alterations in the mineral phase of human enamel with carious attacks. J Oral Pathol. 1982;11:201-209. [pmid: 6284895].
Aoki A, Ishikawa I, Yamada T, et al. Comparison between Er:YAG laser and conventional technique for root caries treatment in vitro. J Dent Res. 1998;77:1404-1414. [pmid: 9649169].
Appleton J, Williams MJ. Ultrastructural observations on the calcification of human dental pulp. Calcif Tissue Res. 1973;11:222-237. [pmid: 4350496].
Arakawa T, Langridge WH. Plants are not just passive creatures. Nature Medicine. 1998;4:550-551.
Aranda M, Garcia-Godoy F. Clinical evaluation of the retention and wear of a light-cured pit and fissure glass ionomer sealant. J Clin Pediatr Dent. 1995;19:273-277. [pmid: 7547485].
Arbabzadeh F, Gage JP, Young WG, Shahabi S, Swenson SM. Gap measurement and bond strength of five selected adhesive systems bonded to tooth structure. Aust Dent J. 1998;43:175-180. [pmid: 9707782].
Arends J, Ruben JL, Christoffersen J, Jongebloed WL, Zuidgeest TG. Remineralization of human dentine in vitro. Caries Res. 1990;24:432-435. [pmid: 2289224].
Arends J, Stokroos I, Jongebloed WG, Ruben J. The diameter of dentinal tubules in human coronal dentine after demineralization and air drying. A combined light microscopy and SEM study. Caries Res. 1995;29:118-121. [pmid: 7728825].
Ariji Y, Shimizu Y, Okano T, et al. Influence of x-ray beam angulation in the detection of proximal caries: Interobserver agreement in the CCD system. Oral Radiol. 1999;15:27-35.
Ariji Y, Takahashi JI, Matsui O, et al. In vitro comparison of subjective image quality of the Pana Digital intraoral x-ray imaging system and conventional intraoral radiography in caries detection. Oral Radiol. 1998;14:75-83.
Arnbjerg D, Poulsen S, Heidmann J. Evaluation of a photographic method for diagnosis of gingivitis and caries. Scand J Dent Res. 1992;100:207-210. [pmid: 1439524].
Arrow P. Control of occlusal caries in the first permanent molars by oral hygiene. Community Dent Oral Epidemiol. 1997;25:278-283. [pmid: 9332804].
Arrow P. Oral hygiene in the control of occlusal caries. Community Dent Oral Epidemiol. 1998;26:324-330. [pmid: 9792124].
Arrow P, Riordan PJ. Retention and caries preventive effects of a GIC and a resin-based fissure sealant. Community Dent Oral Epidemiol. 1995;23:282-285. [pmid: 8529341].
Artun J, Thylstrup A. A 3-year clinical and SEM study of surface changes of carious enamel lesions after inactivation. Am J Orthod Dentofacial Orthop. 1989;95:327-333. [pmid: 2705413].
Ashirov KA. Changes in the properties of permanent teeth enamel in children using fluorine-containing toothpastes. Stomatologiia (Mosk). 1994;73:51-54. [pmid: 7732536].
Ashley FP, Naylor MN, Emslie RD. Clinical testing of dicalcium phosphate supplemented sweets. (1). 3-year caries incidence in subjects aged 11 to 15 years. Br Dent J. 1974;136:361-366. [pmid: 4156180].
Ashley FP, Naylor MN, Emslie RD. Stannous fluoride and sodium monofluorophosphate dentifrices. Clinical testing in London school children--radiological findings. Br Dent J. 1969;127:125-128. [pmid: 4389702].
Ashley FP, Sainsbury RH. The effect of a school-based plaque control programme on caries and gingivitis. A 3-year study in 11 to 14-year-old girls. Br Dent J. 1981;150:41-45. [pmid: 6936036].
Ashley FP, Sainsbury RH. Post-study effects of a school-based plaque control programme. Br Dent J. 1982;153:337-338. [pmid: 6959646].
Ashley PF, Blinkhorn AS, Davies RM. Occlusal caries diagnosis: an in vitro histological validation of the Electronic Caries Monitor (ECM) and other methods. J Dent. 1998;26:83-88. [pmid: 9540303].
Astrom AN, Rise J. Analysis of adolescents' beliefs about the outcome of using dental floss and drinking non-sugared mineral water. Community Dent Oral Epidemiol. 1996;24:211-216. [pmid: 8871022].
Astroth J, Berg R, Berkey D, McDowell J, Hamman R, Mann J. Dental caries prevalence and treatment need in Chiriqui Province, Panama. Int Dent J. 1998;48:203-209. [pmid: 9779100].
Athanassouli I, Mamai-Homata E, Panagopoulos H, Koletsi-Kounari H, Apostolopoulos A. Dental caries changes between 1982 and 1991 in children aged 6-12 in Athens, Greece. Caries Res. 1994;28:378-382. [pmid: 8001062].
Atkinson JC, Fox PC. Salivary gland dysfunction. Clin Geriatr Med. 1992;8:499-511. [pmid: 1504941].
Attin T, Hellwig E. Salivary fluoride content after toothbrushing with a sodium fluoride and an amine fluoride dentifrice followed by different mouthrinsing procedures. J Clin Dent. 1996;7:6-8. [pmid: 9238877].
Attwood D, Blinkhorn AS. Reassessment of the effect of fluoridation on cost of dental treatment among Scottish schoolchildren. Community Dent Oral Epidemiol. 1989;17:79-82. [pmid: 2920544].
Attwood D, Blinkhorn AS, MacMillan AS. A comparison of the dental health of 5-year-old children from Glasgow, Scotland, in 1984 and 1987. J Int Assoc Dent Child. 1990;20:50-53. [pmid: 2130104].
Averill HM, Averill JE, Ritz AG. A 2-year comparison of three topical fluoride agents. J Am Dent Assoc. 1967;74:996-1001. [pmid: 5336276].
Averill HM, Averill JE, Ritz AG, Little MF. A two-year comparison of three topical fluoride agents. Am J Public Health Nations Health. 1967;57:1627-1634. [pmid: 4382975]. [pmcid: 1227695].
Awazawa Y. Re-examination of the morphology of caries susceptible grooves in the premolar and molar. J Nihon Univ Sch Dent. 1969;11:1-15. [pmid: 5255708].
Axelsson P. Ethical and legal consideration associated with clinical field trials: the views of a discussant. J Dent Res. 1980;59:1262-1266. [pmid: 6930399].
Axelsson P, Buischi YA, Barbosa MF, Karlsson R, Prado MC. The effect of a new oral hygiene training program on approximal caries in 12-15-year-old Brazilian children: results after three years. Adv Dent Res. 1994;8:278-284. [pmid: 7865087].
Axelsson P, Kristoffersson K, Karlsson R, Bratthall D. A 30-month longitudinal study of the effects of some oral hygiene measures on Streptococcus mutans and approximal dental caries. J Dent Res. 1987;66:761-765. [pmid: 3475309].
Axelsson P, Lindhe J. The effect of a preventive programme on dental plaque, gingivitis and caries in schoolchildren. Results after one and two years. J Clin Periodontol. 1974;1:126-138. [pmid: 4532119].
Axelsson P, Lindhe J. Effect of controlled oral hygiene procedures on caries and periodontal disease in adults. J Clin Periodontol. 1978;5:133-151. [pmid: 275282].
Axelsson P, Lindhe J. Effect of controlled oral hygiene procedures on caries and periodontal disease in adults. Results after 6 years. J Clin Periodontol. 1981;8:239-248. [pmid: 6947990].
Axelsson P, Lindhe J. Effect of fluoride on gingivitis and dental caries in a preventive program based on plaque control. Community Dent Oral Epidemiol. 1975;3:156-160. [pmid: 1056822].
Axelsson P, Lindhe J. Effect of oral hygiene instruction and professional toothcleaning on caries and gingivitis in schoolchildren. Community Dent Oral Epidemiol. 1981;9:251-255. [pmid: 6955123].
Axelsson P, Lindhe J, Nystrom B. On the prevention of caries and periodontal disease. Results of a 15-year longitudinal study in adults. J Clin Periodontol. 1991;18:182-189. [pmid: 2061418].
Axelsson P, Lindhe J, Waseby J. The effect of various plaque control measures on gingivitis and caries in schoolchildren. Community Dent Oral Epidemiol. 1976;4:232-239. [pmid: 1069613].
Axelsson P, Paulander J, Lindhe J. Relationship between smoking and dental status in 35-, 50-, 65-, and 75-year-old individuals. J Clin Periodontol. 1998;25:297-305. [pmid: 9565280].
Axelsson P, Paulander J, Nordkvist K, Karlsson R. Effect of fluoride containing dentifrice, mouthrinsing, and varnish on approximal dental caries in a 3-year clinical trial. Community Dent Oral Epidemiol. 1987;15:177-180. [pmid: 3476237].
Axelsson P, Paulander J, Svardstrom G, Tollskog G, Nordensten S Integrated caries prevention: effect of a needs-related preventive program on dental caries in children. County of Varmland, Sweden: results after 12 years Caries Res 1993 27(suppl) 1:83 94 8500132
Ayhan H, Suskan E, Yildirim S. The effect of nursing or rampant caries on height, body weight and head circumference. J Clin Pediatr Dent. 1996;20:209-212. [pmid: 8634207].
Babaahmady KG, Challacombe SJ, Marsh PD, Newman HN. Ecological study of Streptococcus mutans, Streptococcus sobrinus and Lactobacillus spp. at sub-sites from approximal dental plaque from children. Caries Res. 1998;32:51-58. [pmid: 9438572].
Bacic M, Ciglar I, Granic M, Plancak D, Sutalo J. Dental status in a group of adult diabetic patients. Community Dent Oral Epidemiol. 1989;17:313-316. [pmid: 2591185].
Backman B, Crossner CG, Holm AK. Reduction of caries in 8-year-old Swedish children between 1967 and 1979. Community Dent Oral Epidemiol. 1982;10:178-181. [pmid: 6956479].
Bader JD, Brown JP. Dilemmas in caries diagnosis. J Am Dent Assoc. 1993;124:48-50.
Bader JD, Graves RC, Disney JA, et al. Identifying children who will experience high caries increments. Community Dent Oral Epidemiol. 1986;14:198-201. [pmid: 3461904].
Bader JD, Kaplan AL. Treatment distributions in dental practice. J Dent Educ. 1983;47:142-148. [pmid: 6572205].
Bader JD, Levitch LC, Shugars DA, Heymann HO, McClure F. How dentists classified and treated non-carious cervical lesions. J Am Dent Assoc. 1993;124:46-54. [pmid: 8482781].
Bader JD, Shugars DA. Agreement among dentists' recommendations for restorative treatment. J Dent Res. 1993;72:891-896. [pmid: 8501287].
Bader JD, Shugars DA. Need for change in standards of caries diagnosis--epidemiology and health services research perspective. J Dent Educ. 1993;57:415-421. [pmid: 8315097].
Bader JD, Shugars DA. Understanding dentists' restorative treatment decisions. J Public Health Dent. 1992;52:102-110. [pmid: 1564688].
Bader JD, Shugars DA. Variation in dentists' clinical decisions. J Public Health Dent. 1995;55:181-188. [pmid: 7562733].
Bader JD, Shugars DA. What do we know about how dentists make caries-related treatment decisions?. Community Dent Oral Epidemiol. 1997;25:97-103. [pmid: 9088698].
Baehni PC, Guggenheim B. Potential of diagnostic microbiology for treatment and prognosis of dental caries and periodontal diseases. Crit Rev Oral Biol Med. 1996;7:259-277. [pmid: 8909881].
Baghdady VS, Ghose LJ. Comparison of the severity of caries attack in permanent first molars in Iraqi and Sudanese schoolchildren. Community Dent Oral Epidemiol. 1979;7:346-348. [pmid: 295718].
Bagramian RA. A 5-year school-based comprehensive preventive program in Michigan, U.S.A. Community Dent Oral Epidemiol. 1982;10:234-237. [pmid: 6958406].
Bagramian RA. Combination of school-based primary and secondary preventive dental programs in the United States and other countries. J Public Health Dent. 1979;39:275-278. [pmid: 292789].
Bagramian RA, Graves RC, Bhat M. A combined approach to preventing dental caries in schoolchildren: caries reductions after one year. J Am Dent Assoc. 1976;93:1014-1019. [pmid: 1067352].
Bagramian RA, Graves RC, Srivastava S. A combined approach to preventing dental caries in schoolchildren : caries reductions after 3 years. Community Dent Oral Epidemiol. 1978;6:166-171. [pmid: 278697].
Bagramian RA, Graves RC, Srivastava S. Sealant effectiveness for children receiving a combination of preventive methods in a fluoridated community: two-year results. J Dent Res. 1977;56:1511-1519. [pmid: 277472].
Bagramian RA, Srivastava S, Graves RC. Effectiveness of combined preventive methods on erupting teeth in children in a fluoridated community. Community Dent Oral Epidemiol. 1979;7:246-251. [pmid: 295703].
Bagramian RA, Srivastava S, Graves RC. Pattern of sealant retention in children receiving a combination of caries-preventive methods: three-year results. J Am Dent Assoc. 1979;98:46-50. [pmid: 365915].
Bahar A, Tagomori S. The effect of normal pulsed Nd-YAG laser irradiation on pits and fissures in human teeth. Caries Res. 1994;28:460-467. [pmid: 7850851].
Bandt CL, Boen JR. A prevalent misconception about sample size, statistical significance, and clinical importance. J Periodontol. 1972;43:181-183. [pmid: 4501976].
Banoczy J, Nemes J. Effect of amine fluoride (AmF)/stannous fluoride (SnF2) toothpaste and mouthwashes on dental plaque accumulation, gingivitis and root-surface caries. Proc Finn Dent Soc. 1991;87:555-559. [pmid: 1775483].
Banoczy J, Zimmermann P, Pinter A, Hadas E, Bruszt V. Effect of fluoridated milk on caries: 3-year results. Community Dent Oral Epidemiol. 1983;11:81-85. [pmid: 6573242].
Banting DW. Diagnosis and prediction of root caries. Adv Dent Res. 1993;7:80-86. [pmid: 8260015].
Baranska-Gachowska M, Zaleski W, Waszkiewicz-Golos B. Clinical diagnosis and the histological findings in dental pulp. Pol Med J. 1969;8:712-724. [pmid: 5807579].
Barenie J, Leske G, Ripa LW. The use of fiber optics transillumination for the detection of proximal caries. Oral Surg Oral Med Oral Pathol. 1973;36:891-897. [pmid: 4524840].
Barmes D, Barnaud J, Khambonanda S, Infirri JS. Field trials of preventive regimens in Thailand and French Polynesia. Int Dent J. 1985;35:66-72. [pmid: 3888852].
Barmes DE. Features of oral health care across cultures. Int Dent J. 1976;26:353-368. [pmid: 1067234].
Barr JK, Barr CE. The structure of the dental profession and the use of auxiliaries in Latin America. Soc Sci Med Med Psy Med Soc. 1980;14A:107-111.
Barrowman TR. Dental caries incidence as determined clinically and radiographically. J Dent Assoc S Afr. 1965;20:264-265. [pmid: 5213326].
Barwart O, Moschen I, Graber A, Pfaller K. In-vitro study to compare the efficacy of N-monochloro-D,L-2-aminobutyrate (NMAB, GK-101E) and water in caries removal. J Oral Rehabil. 1991;18:523-529. [pmid: 1762025].
Basdra EK, Huber H, Komposch G. Fluoride released from orthodontic bonding agents alters the enamel surface and inhibits enamel demineralization in vitro. Am J Orthod Dentofacial Orthop. 1996;109:466-472. [pmid: 8638590].
Bassi F, Mantecchini G, Carossa S, Preti G. Oral conditions and aptitude to receive implants in patients with removable partial dentures: a cross-sectional study. part I. oral conditions. J Oral Rehabil. 1996;23:50-54. [pmid: 8850161].
Bateman P. Deciduous caries and screening. Br Dent J. 1999;186.
Bauer JG, Cretin S, Schweitzer SO, Hunt RJ. The reliability of diagnosing root caries using oral examinations. J Dent Educ. 1988;52:622-629. [pmid: 3183171].
Bawden JW. After fluoride come sealants: a new epoch in control of dental caries. N C Med J. 1984;45:491-492. [pmid: 6590969].
Bawden JW. Fluoride varnish: a useful new tool for public health dentistry. J Public Health Dent. 1998;58:266-269. [pmid: 10390707].
Bawden JW, Granath L, Holst K, Koch G, Krasse P, Rootzen H. Effect of mouthrinsing with a sodium fluoride solution in children with different caries experience. Swed Dent J. 1980;4:111-117. [pmid: 6933705].
Bay I, Ainamo J. Caries experience among children in Copenhagen. Community Dent Oral Epidemiol. 1974;2:75-79. [pmid: 4153290].
Beal JF, James PM, Bradnock G, Anderson RJ. The relationship between dental cleanliness, dental caries incidence and gingival health. A longitudinal study. Br Dent J. 1979;146:111-114. [pmid: 282917].
Bean LR. High or low Kvp for caries determination?. J Am Soc Prev Dent. 1973;3:36-37. [pmid: 4535410].
Beck DJ. Clinical trials of topical fluorides. N Z Dent J. 1974;70:275-281. [pmid: 4156395].
Beck F. Periodontitis - A widespread disease. Fortschr Med. 1998;116:36-40. [pmid: 9844265].
Beck JD, Field HM. Pilot results of DMF treatment time index. Community Dent Oral Epidemiol. 1980;8:52-55. [pmid: 6929242].
Beck JD, Lawrence HP, Koch GG. Analytic approaches to longitudinal caries data in adults. Community Dent Oral Epidemiol. 1997;25:42-51. [pmid: 9088691].
Beck JD, Lawrence HP, Koch GG. A method for adjusting caries increments for reversals due to examiner misclassification. Community Dent Oral Epidemiol. 1995;23:321-330. [pmid: 8681513].
Beck JD, Weintraub JA, Disney JA, et al. University of North Carolina Caries Risk Assessment Study: comparisons of high risk prediction, any risk prediction, and any risk etiologic models. Community Dent Oral Epidemiol. 1992;20:313-321. [pmid: 1464224].
Begg C, Cho M, Eastwood S, et al. Improving the quality of reporting of randomized controlled trials. The CONSORT statement. JAMA. 1996;276:637-639. [pmid: 8773637].
Behrendt A, Knoblauch B, Schlechtriemen M, Wetzel WE. Problematic findings associated with nursing-bottle syndrome. Monatsschr Kinderheilkd. 1998;146:30-36.
Beighton D, Lynch E. Relationships between yeasts and primary root-caries lesions. Gerodontology. 1993;10:105-108. [pmid: 7713525].
Beighton D, Lynch E, Heath MR. A microbiological study of primary root-caries lesions with different treatment needs. J Dent Res. 1993;72:623-629. [pmid: 8450122].
Beiswanger BB, Billings RJ, Sturzenberger OP, Bollmer BW. Effect of an SnF2-Ca2P2O7 dentifrice and APF topical applications. ASDC J Dent Child. 1978;45:137-141. [pmid: 350920].
Beiswanger BB, Boneta AE, Mau MS, Katz BP, Proskin HM, Stookey GK. The effect of chewing sugar-free gum after meals on clinical caries incidence. J Am Dent Assoc. 1998;129:1623-1626. [pmid: 9818584].
Beiswanger BB, Gish CW, Mallatt ME. A three-year study of the effect of a sodium fluoride-silica abrasive dentifrice on dental caries. Pharmacol Ther Dent. 1981;6:9-16. [pmid: 6264507].
Beiswanger BB, Lehnhoff RW, Mallatt ME, Mau MS, Stookey GK. A clinical evaluation of the relative cariostatic effect of dentifrices containing sodium fluoride or sodium monofluorophosphate. ASDC J Dent Child. 1989;56:270-360. [pmid: 2668365].
Beiswanger BB, Mercer VH, Billings RJ, Stookey GK. A clinical caries evaluation of a stannous fluoride prophylactic paste and topical solution. J Dent Res. 1980;59:1386-1391. [pmid: 6995506].
Beiswanger BB, Stookey GK. The comparative clinical cariostatic efficacy of sodium fluoride and sodium monofluorophosphate dentifrices: a review of trials. ASDC J Dent Child. 1989;56:337-347. [pmid: 2549106].
Belcher MA, Stewart GP. Two-year clinical evaluation of an amalgam adhesive. J Am Dent Assoc. 1997;128:309-314. [pmid: 9066215].
Bell RM, Klein SP. Management and evaluation of the effects of misclassification in a controlled clinical trial. J Dent Res. Spec No. 1984;63:731-735. [pmid: 6586777].
Bellezza JJ, McCartha CD, Bradley ELJ, Denys FR, Retief DH. Four-year in vivo evaluation of the composite/bonding resin-tooth interface. Dent Mater. 1990;6:237-240. [pmid: 2086301].
Bellini HT, Arneberg P, von der Fehr FR. Oral hygiene and caries. A review. Acta Odontol Scand. 1981;39:257-265. [pmid: 7039213].
Beltran ED, Malvitz DM, Eklund SA. Validity of two methods for assessing oral health status of populations. J Public Health Dent. 1997;57:206-214. [pmid: 9558624].
Benedetto MD, Antonson DE. Use of CO2 laser for visible detection of enamel fissure caries. Quintessence Int. 1988;19:187-190. [pmid: 3152014].
Benelli EM, Serra MC, Rodrigues ALJ, Cury JA. In situ anticariogenic potential of glass ionomer cement. Caries Res. 1993;27:280-284. [pmid: 8402802].
Benn DK. Diagnosis of caries progression from serial bitewings: a comparison between teachers and practitioners. Br Dent J. 1993;175:26-32. [pmid: 8334049].
Benn DK. Radiographic caries diagnosis and monitoring. Dento Maxillo Facial Radiol. 1994;23:69-72.
Benn DK. Treatment protocols. J Am Dent Assoc. 1996;127.
Benn DK, Dankel DD, Kostewicz SH. Can low accuracy disease risk predictor models improve health care using decision support systems?. Proc AMIA Symp. 1998:577-581.
Benn DK, Dankel DD2, Clark D, Lesser RB, Bridgwater AB. Standardizing data collection and decision making with an expert system. J Dent Educ. 1997;61:885-894. [pmid: 9420565].
Benn DK, Meltzer MI. Will modern caries management reduce restorations in dental practice?. J Am Coll Dent. 1996;63:39-44.
Bennie AM, Tullis JI, Stephen KW, MacFadyen EE. Five years of community preventive dentistry and health education in the county of Sutherland, Scotland. Community Dent Oral Epidemiol. 1978;6:1-5. [pmid: 272258].
Benson PE, Pender N, Higham SM, Edgar WM. Morphometric assessment of enamel demineralisation from photographs. J Dent. 1998;26:669-677. [pmid: 9793289].
Bentley CD, Broderius CA, Crawford JJ. Evaluation of the Cariescreen SM method for enumeration of salivary mutans streptococci. Gen Dent. 1991;39:188-191. [pmid: 1869036].
Berga S, Trierweiler MW. Bacterial meningitis following epidural anesthesia for vaginal delivery: A case report. Obstet Gynecol. 1989;74:437-439. [pmid: 2761926].
Bergendal B, Hamp SE. Dietary pattern and dental caries in 19-year-old adolescents subjected to preventive measures focused on oral hygiene and/or fluorides. Swed Dent J. 1985;9:1-7. [pmid: 3859027].
Bergman B, Ericson A, Molin M. Long-term clinical results after treatment with conical crown-retained dentures. Int J Prosthodont. 1996;9:533-538. [pmid: 9171491].
Bergman B, Hugoson A, Olsson CO. Caries, periodontal and prosthetic findings in patients with removable partial dentures: a ten-year longitudinal study. J Prosthet Dent. 1982;48:506-514. [pmid: 6754910].
Bergman G, Anneroth G. Microradiography of oral tissues. Adv Oral Biol. 1970;4:313-368. [pmid: 4914037].
Bergman G, Anneroth G. A semiquantitative microradiographic study of the distribution of organic mass in human carious dentine. Arch Oral Biol. 1972;17:201-209. [pmid: 4505576].
Bergman G, Lind PO. A quantitative microradiographic study of incipient enamel caries. J Dent Res. 1966;45:1477-1484. [pmid: 5225322].
Bergman G, Linden LA. The action of the explorer on incipient caries. Sven Tandlak Tidskr. 1969;62:629-634. [pmid: 5267698].
Berkey CS, Douglass CW, Valachovic RW, Chauncey HH. Longitudinal radiographic analysis of carious lesion progression. Community Dent Oral Epidemiol. 1988;16:83-90. [pmid: 3162862].
Berkey CS, Douglass CW, Valachovic RW, Chauncey HH, McNeil BJ. Statistical methods for comparing dental diagnostic procedures. Community Dent Oral Epidemiol. 1990;18:169-176. [pmid: 2201479].
Berkowitz RJ, Moss M, Billings RJ, Weinstein P. Clinical outcomes for nursing caries treated using general anesthesia. ASDC J Dent Child. 1997;64:210-211, 228. [pmid: 9262804].
Berman DS, Slack GL. Caries progression and activity in approximal tooth surfaces. A longitudinal study. Br Dent J. 1973;134:51-57. [pmid: 4145948].
Berman DS, Slack GL. Dental caries in English school children: a longitudinal study. Br Dent J. 1972;133:529-538. [pmid: 4144217].
Bernick EB, Branch LG. Comparison of utilization of dental bitewing radiographs to current guidelines in an insured Massachusetts population. J Dent Educ. 1989;53:612-6128. [pmid: 2808875].
Berry CW. A better caries susceptibility test. Tex Dent J. 1979;97:19-20. [pmid: 298102].
Berset GP, Eriksen HM, Bjertness E, Hansen BF. Caries experience of 35-year-old Oslo residents and changes over a 20-year period. Community Dent Health. 1996;13:238-244. [pmid: 9018890].
Besimo C, Gachter M, Jahn M, Hassell T. Clinical performance of resin-bonded fixed partial dentures and extracoronal attachments for removable prostheses. J Prosthet Dent. 1997;78:465-471. [pmid: 9399188].
Beynon AD. Some observations on dental caries in a polar environment. Dent Pract Dent Rec. 1969;19:375-378. [pmid: 5255836].
Bian JY, Li RY, Wang WJ. Feasibility of milk fluoridation and trends in dental caries of children in China. Adv Dent Res. 1995;9:112-115. [pmid: 7546125].
Bibby BG. Organic enamel material and caries. Caries Res. 1971;5:305-322. [pmid: 4943288].
Biesbrock AR, Faller RV, Bartizek RD, Court LK, McClanahan SF. Reversal of incipient and radiographic caries through the use of sodium and stannous fluoride dentifrices in a clinical trial. J Clin Dent. 1998;9:5-10. [pmid: 9835826].
Bijella MF, Bijella VT, Lopes ES, Bastos JR. Comparison of dental prophylaxis and toothbrushing prior to topical APF applications. Community Dent Oral Epidemiol. 1985;13:208-211. [pmid: 3930138].
Bille J, Carstens K. Approximal caries progression in 13- to 15-year-old Danish children. Acta Odontol Scand. 1989;47:347-354. [pmid: 2692378].
Bille J, Thylstrup A. Radiographic diagnosis and clinical tissue changes in relation to treatment of approximal carious lesions. Caries Res. 1982;16:1-6. [pmid: 6948614].
Billings RJ, Banting DW. Future directions for root caries research. Gerodontology. 1993;10:114-119. [pmid: 7713527].
Bimstein E, Garcia-Godoy F. The significance of age, proximal caries, gingival inflammation, probing depths and the loss of lamina dura in the diagnosis of alveolar bone loss in the primary molars. ASDC J Dent Child. 1994;61:125-128. [pmid: 8046091].
Bimstein E, Treasure ET, Williams SM, Dever JG. Alveolar bone loss in 5-year-old New Zealand children: its prevalence and relationship to caries prevalence, socio-economic status and ethnic origin. J Clin Periodontol. 1994;21:447-450. [pmid: 7929855].
Birch S. The relative cost effectiveness of water fluoridation across communities: analysis of variations according to underlying caries levels. Community Dent Health. 1990;7:3-10. [pmid: 2113420].
Birch S, Gafni A, Markham B, Marriott M, Lewis D, Main P. Health years equivalents as a measurement of preferences for dental interventions. Community Dent Health. 1998;15:233-242. [pmid: 9973723].
Birkeland JM, Jorkjend L, Broch L. An approach to objective assessment of caries prophylactic measures in a dental health program. Community Dent Oral Epidemiol. 1975;3:126-131. [pmid: 1056817].
Birkeland JM, Torell P Caries-preventive fluoride mouthrinses Caries Res 1978 12(suppl) 1:38 51 277292
Bishay N, Petrikowski CG, Maxymiw WG, Lee L, Wood RE. Optimum dental radiography in bone marrow transplant patients. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 1999;87:375-379. [pmid: 10102604].
Bjarnason S. High caries levels: problems still to be tackled. Acta Odontol Scand. 1998;56:176-178. [pmid: 9688229].
Bjarnason S. On dental health in Icelandic children. Observations during a clinical dentifrice trial. Swed Dent J Suppl. 1989;57:1-40. [pmid: 2784233].
Bjarnason S, Finnbogason SY. Effect of different fluoride levels in dentifrice on the development of approximal caries. Caries Res. 1991;25:207-212. [pmid: 1878920].
Bjarnason S, Finnbogason SY, Holbrook P, Kohler B. Caries experience in Icelandic 12-year-old urban children between 1984 and 1991. Community Dent Oral Epidemiol. 1993;21:195-197. [pmid: 8370254].
Bjarnason S, Finnbogason SY, Kohler B, Holbrook WP. Trends in dental health among Icelandic urban children. Eur J Oral Sci. 1997;105:189-195. [pmid: 9249184].
Bjarnason S, Grondahl HG. Relationships between free smooth surface and proximal caries in the young permanent dentition. Community Dent Oral Epidemiol. 1996;24:7-10. [pmid: 8833506].
Bjorndal L, Darvann T. A light microscopic study of odontoblastic and non-odontoblastic cells involved in tertiary dentinogenesis in well-defined cavitated carious lesions. Caries Res. 1999;33:50-60. [pmid: 9831780].
Bjorndal L, Darvann T, Thylstrup A. A quantitative light microscopic study of the odontoblast and subodontoblastic reactions to active and arrested enamel caries without cavitation. Caries Res. 1998;32:59-69. [pmid: 9438573].
Bjorndal L, Larsen T, Thylstrup A. A clinical and microbiological study of deep carious lesions during stepwise excavation using long treatment intervals. Caries Res. 1997;31:411-417. [pmid: 9353579].
Bjorndal L, Thylstrup A. A practice-based study on stepwise excavation of deep carious lesions in permanent teeth: a 1-year follow-up study. Community Dent Oral Epidemiol. 1998;26:122-128. [pmid: 9645406].
Blagaic B, Pecina-Hrncevic A. Evaluation of fissure sealant of children's permanent molars. Paediatr Croatica. 1994;38:247-251.
Blaustein DI. Lateral sensory inhibition: a possible mechanism for paradoxes in the localization of dental pain. J Oral Surg. 1973;31:837-840. [pmid: 4517827].
Blinkhorn AS. The effect of changes in caries prevalence on oral health promotion--the United Kingdom experience. Int Dent J. 1994;44:439-443. [pmid: 7814112].
Blinkhorn AS, Brown MD, Attwood D, Downer MC. The effect of fluoridation on the dental health of urban Scottish Schoolchildren. J Epidemiol Community Health. 1981;35:98-101. [pmid: 7299343].
Blinkhorn AS, Clarkson JE. The International Scientific Assembly on the Comparative Anticaries Efficacy of Sodium Fluoride and Sodium Monofluorophosphate Dentifrices. Am J Dent. 1993;6 Spec No.
Blinkhorn AS, Davies RM. Caries prevention. A continued need worldwide. Int Dent J. 1996;46:119-125. [pmid: 8886863].
Blinkhorn AS, Downer MC, Mackie IC, Bleasdale RS. Evaluation of a practice based preventive programme for adolescents. Community Dent Oral Epidemiol. 1981;9:275-279. [pmid: 6955127].
Blinkhorn AS, Hassall DC, Holloway PJ, Mellor AC, Worthington HV An assessment of capitation in the new General Dental Service contract Community Dent Health 1996 13(suppl) 1:3 20
Blinkhorn AS, Holloway PJ, Davies TG. Combined effects of a fluoride dentifrice and mouthrinse on the incidence of dental caries. Community Dent Oral Epidemiol. 1983;11:7-11. [pmid: 6572128].
Blinkhorn AS, Kay EJ. A clinical study in children: comparing the anticaries effect of three fluoride dentifrices. Clin Prev Dent. 1988;10:14-6.
Blinkhorn AS, Wight C, Yardley A. Report of two dental health programmes for adolescents in the Lothian region of Scotland. J Dent. 1987;15:213-217. [pmid: 3479465].
Boggs AM, Maurer SM, Mourino AP, Farrington FH, Shetty NS. Recall intervals: effect on treatment needs: a retrospective study. J Clin Pediatr Dent. 1996;20:119-122. [pmid: 8619970].
Bohannan HM, Disney JA, Graves RC, Anderson PE, Klein SP. Operation of the National Preventive Dentistry Demonstration Program. J Public Health Dent. 1985;45:75-82. [pmid: 2409276].
Bohannan HM, Graves RC, Disney JA, Stamm JW, Abernathy JB, Bader JD. Effect of secular decline in caries on the evaluation of preventive dentistry demonstrations. J Public Health Dent. 1985;45:83-89. [pmid: 2409277].
Boksman L, Carson B. Two-year retention and caries rates of UltraSeal XT and FluoroShield light-cured pit and fissure sealants. Gen Dent. 1998;46:184-187. [pmid: 9663075].
Boksman L, Gratton DR, McCutcheon E, Plotzke OB. Clinical evaluation of a glass ionomer cement as a fissure sealant. Quintessence Int. 1987;18:707-709. [pmid: 2959981].
Boksman L, McConnell RJ, Carson B, McCutcheon-Jones EF. A 2-year clinical evaluation of two pit and fissure sealants placed with and without the use of a bonding agent. Quintessence Int. 1993;24:131-133. [pmid: 8511264].
Bolin AK, Bolin A, Alfredsson L. Children's dental health in Europe. Caries treatment need in 5- and 12-year-old children from eight EU countries. Acta Odontol Scand. 1996;54:355-361. [pmid: 8997433].
Bolin AK, Bolin A, Koch G, Alfredsson L. Children's dental health in Europe. Clinical calibration of dental examiners in eight EU countries. Swed Dent J. 1995;19:183-193. [pmid: 8614899].
Bondestam O, Gahnberg L, Sund ML, Linder L. Effect of chlorhexidine gel treatment on the prevalence of mutans streptococci and lactobacilli in patients with impaired salivary secretion rate. Spec Care Dentist. 1996;16:123-127. [pmid: 9084325].
Boston DW, Cotmore JM, Sperrazza L. Caries diagnosis with dye-staining at amalgam restoration margins. Am J Dent. 1995;8:280-282. [pmid: 8695001].
Botha CT, de Wet FA. Polymerisation shrinkage around composite resin restorations--an in vitro study. J Dent Assoc S Afr. 1994;49:201-207. [pmid: 9508937].
Bowen WH. Caries activity tests. Int Dent J. 1969;19:267-272. [pmid: 4892618].
Bowen WH. Use of supporting laboratory or clinical data in caries clinical trials. J Dent Res. Spec No. 1984;63:757-61. [pmid: 6586780].
Bowen WH, Pearson SK. The effects of sucralose, xylitol, and sorbitol on remineralization of caries lesions in rats. J Dent Res. 1992;71:1166-1168. [pmid: 1607434].
Bowman WD, Evans MD, Wietfeldt JR, et al. In situ fluoride uptake from 0.05% neutral NaF mouthrinses: effects of a novel enhanced delivery system. Am J Dent. 1988;1:113-117. [pmid: 3214558].
Boyd RL. Comparison of three self-applied topical fluoride preparations for control of decalcification. Angle Orthod. 1993;63:25-30. [pmid: 8507027].
Boyd RL. Effects on gingivitis of daily rinsing with 1.5% H2O_2_. J Clin Periodontol. 1989;16:557-562. [pmid: 2794090].
Boyd RL. Long-term evaluation of a SnF2 gel for control of gingivitis and decalcification in adolescent orthodontic patients. Int Dent J. 1994;44:119-130. [pmid: 8021037].
Boyd RL. Two-year longitudinal study of a peroxide-fluoride rinse on decalcification in adolescent orthodontic patients. J Clin Dent. 1992;3:83-87. [pmid: 1449617].
Boyd RL, Chun YS. Eighteen-month evaluation of the effects of a 0.4% stannous fluoride gel on gingivitis in orthodontic patients. Am J Orthod Dentofacial Orthop. 1994;105:35-41. [pmid: 8291491].
Boyd RL, Leggott P, Quinn R, Buchanan S, Eakle W, Chambers D. Effect of self-administered daily irrigation with 0.02% SnF2 on periodontal disease activity. J Clin Periodontol. 1985;12:420-431. [pmid: 3860511].
Boyd RL, Rose CM. Effect of rotary electric toothbrush versus manual toothbrush on decalcification during orthodontic treatment. Am J Orthod Dentofacial Orthop. 1994;105:450-456. [pmid: 8166094].
Boyle EL, Higham SM, Edgar WM. The production of subsurface artificial caries lesions on third molar teeth. Caries Res. 1998;32:154-158. [pmid: 9544864].
Brackett WW, Robinson PB. Composite resin and glass-ionomer cement: current status for use in cervical restorations. Quintessence Int. 1990;21:445-447. [pmid: 2243948].
Brambilla E, Felloni A, Gagliani M, Malerba A, Garcia-Godoy F, Strohmenger L. Caries prevention during pregnancy: results of a 30-month study. J Am Dent Assoc. 1998;129:871-877. [pmid: 9685762].
Brambilla E, Gagliani M, Felloni A, Garcia-Godoy F, Strohmenger L. Caries-preventive effect of topical amine fluoride in children with high and low salivary levels of mutans streptococci. Caries Res. 1999;33:423-427. [pmid: 10529526].
Brambilla E, Toselli A, Felloni A, Gagliani M, Malerba A, Strohmenger L. The effect of biannual applications of amine fluoride solution on caries incidence in permanent first molars: a 5-year study. Int J Paediatr Dent. 1997;7:9-14. [pmid: 9524466].
Bratthall D, Hansel-Petersson G, Sundberg H. Reasons for the caries decline: what do the experts believe?. Eur J Oral Sci. 1996;104:416-422. discussion 423-425, 430-432. [pmid: 8930592].
Bratthall D, Serinirach R, Hamberg K, Widerstrom L. Immunoglobulin A reaction to oral streptococci in saliva of subjects with different combinations of caries and levels of mutans streptococci. Oral Microbiol Immunol. 1997;12:212-218. [pmid: 9467389].
Bratthall D, Serinirach R, Rapisuwon S, et al. A study into the prevention of fissure caries using an antimicrobial varnish. Int Dent J. 1995;45:245-254. [pmid: 7558363].
Bravo M, Baca P, Llodra JC, Osorio E. A 24-month study comparing sealant and fluoride varnish in caries reduction on different permanent first molar surfaces. J Public Health Dent. 1997;57:184-186. [pmid: 9383759].
Bravo M, Garcia-Anllo I, Baca P, Llodra JC. A 48-month survival analysis comparing sealant (Delton) with fluoride varnish (Duraphat) in 6- to 8-year-old children. Community Dent Oral Epidemiol. 1997;25:247-250. [pmid: 9192156].
Bravo M, Llodra JC, Baca P, Osorio E. Effectiveness of visible light fissure sealant (Delton) versus fluoride varnish (Duraphat): 24-month clinical trial. Community Dent Oral Epidemiol. 1996;24:42-46. [pmid: 8833514].
Bres EF, Barry JC, Hutchison JL. A structural basis for the carious dissolution of the apatite crystals of human tooth enamel. Ultramicroscopy. 1983-1984;12:367-371.
Breslin H. Practical prevention of dental disease in schoolchildren. Public Health. 1979;93:230-234. [pmid: 461675].
Bretz WA, Djahjah CA, Almeida RS, et al. Effect of a chlorhexidine varnish on caries lesions. Oral Health. 1995;85:29-30.
Brewster JE. Educational and practice standards for dental auxiliaries. Int Dent J. 1995;45:255-260. [pmid: 7558364].
Brickley M, Kay E, Shepherd J. Public health aspects of third molar surgery. The effect of surgeons' treatment thresholds on efficiency and effectiveness. Community Dent Health. 1995;12:70-76. [pmid: 7648414].
Briley JB, Dove SB, Mertz-Fairhurst EJ, Hermesch CB. Computer-assisted densitometric image analysis (CADIA) of previously sealed carious teeth: a pilot study. Oper Dent. 1997;22:105-114. [pmid: 9484148].
Briner WW. How is it decided when to conduct a large-scale caries clinical trial?. J Dent Res. Spec No. 1984;63:715-718. [pmid: 6427312].
Brink SG, Nader PR. Comprehensive health screening in elementary schools: an outcome evaluation. J Sch Health. 1984;54:75-78. [pmid: 6563316].
Bristow PD. Notes on a fluoride mouth-rinsing scheme in Portsmouth. Br Dent J. 1975;139:329-330. [pmid: 1058012].
Brocklehurst PR, Joshi RI, Northeast SE. The effect of air-polishing occlusal surfaces on the penetration of fissures by a sealant. Int J Paediatr Dent. 1992;2:157-162. [pmid: 1304806].
Broder HL, Catalanotto FA, Reisine S, Variagiannis E. Compliance is poor among HIV-infected children with unmet dental needs. Pediatr Dent. 1996;18:137-138. [pmid: 8710716].
Brodeur JM, Simard PL, Demers M, et al. Comparative effects of FMR programs in fluoridated and unfluoridated communities. J Can Dent Assoc. 1988;54:761-765. [pmid: 3052719].
Brooks JD, Azhdari S, Ashrafi MH. A comparative study of three tinted, unfilled pit and fissure sealants. Eleven-month results in Milwaukee, Wisconsin. Clin Prev Dent. 1985;7:4-10.
Brooks JD, Mertz-Fairhurst EJ, Della-Giustina VE, Williams JE, Fairhurst CW. A comparative study of two pit and fissure sealants: three-year results in Augusta, Ga. J Am Dent Assoc. 1979;99:42-46. [pmid: 379101].
Brooks JD, Mertz-Fairhurst EJ, Della-Giustina VE, Williams JE, Fairhurst CW. A comparative study of two pit and fissure sealants: two-year results in Augusta, Ga. J Am Dent Assoc. 1979;98:722-725. [pmid: 374449].
Broughton J. Te mahi niho hauora ki Ratana Pa: the dental health project at Ratana Pa. N Z Dent J. 1995;91:94-96. [pmid: 7566756].
Brouwer ID, Backer Dirks O, De Bruin A, Hautvast J. Unsuitability of World Health Organisation guidelines for fluoride concentrations in drinking water in Senegal. Lancet. 1988;1:223-225. [pmid: 2893047].
Brown LJ, Wall TP, Lazar V. Trends in total caries experience: permanent and primary teeth. J Am Dent Assoc. 2000;131:223-231. [pmid: 10680391].
Brown LP, Mulqueen TF, Storey E. The effect of fluoride consumption and social class on dental caries in 8-year-old children. Aust Dent J. 1990;35:61-68. [pmid: 2322173].
Brown LR, Dreizen S, Daly TE, et al. Interrelations of oral microorganisms, immunoglobulins, and dental caries following radiotherapy. J Dent Res. 1978;57:882-893. [pmid: 281362].
Browning WD, Johnson WW, Gregory PN. Reduction of postoperative pain: a double-blind, randomized clinical trial. J Am Dent Assoc. 1997;128:1661-1667. [pmid: 9415763].
Brudevold F, Aasenden R, Srinivasian BN, Bakhos Y. Lead in enamel and saliva, dental caries and the use of enamel biopsies for measuring past exposure to lead. J Dent Res. 1977;56:1165-1171. [pmid: 272374].
Brudevold F, Tehrani A, Attarzadeh F, Goulet D, van Houte J. Effect of some salts of calcium, sodium, potassium, and strontium on intra-oral enamel demineralization. J Dent Res. 1985;64:24-27. [pmid: 3855415].
Bruerd B, Jones C. Preventing baby bottle tooth decay: eight-year results. Public Health Rep. 1996;111:63-65. [pmid: 8610193]. [pmcid: 1381744].
Bruerd B, Kinney MB, Bothwell E. Preventing baby bottle tooth decay in American Indian and Alaska native communities: a model for planning. Public Health Rep. 1989;104:631-640. [pmid: 2511598]. [pmcid: 1580151].
Brugnera AJ, Rosso N, Duarte D, Pinto ACG, Genovese W. The use of carbon dioxide laser in pit and fissure caries prevention: Clinical evaluation. J Clin Laser Med Surg. 1997;15:79-82. [pmid: 9612182].
Brunelle JA. Use and misuse of computers in the design and analysis of dental clinical trials. J Dent Res. 1984;63 Spec No:820-824. [pmid: 6586787].
Bruszt P. Greatly impeded mouth opening in Bechterew's disease. Report of a case. Oral Surg Oral Med Oral Pathol. 1967;23:443-445. [pmid: 5227394].
Bruszt P, Banoczy J, Esztary I, et al. Caries prevalence of preschoolchildren in Baja, Hungary in 1955 and 1975. Community Dent Oral Epidemiol. 1977;5:136-139. [pmid: 266435].
Bruun C, Bille J, Hansen KT, Kann J, Qvist V, Thylstrup A. Three-year caries increments after fluoride rinses or topical applications with a fluoride varnish. Community Dent Oral Epidemiol. 1985;13:299-303. [pmid: 3910338].
Bruun C, Lambrou D, Larsen MJ, Fejerskov O, Thylstrup A. Fluoride in mixed human saliva after different topical fluoride treatments and possible relation to caries inhibition. Community Dent Oral Epidemiol. 1982;10:124-129. [pmid: 6955116].
Bryan ET, Williams JE. The cariostatic effectiveness of a phosphate-fluoride gel administered annually to school children; final results. J Public Health Dent. 1970;30:13-16. [pmid: 4149070].
Budtz-Jorgensen E. Prognosis of overdenture abutments in elderly patients with controlled oral hygiene. A 5 year study. J Oral Rehabil. 1995;22:3-8. [pmid: 7897556].
Buhler H. Extraoral apical elongation of deeply damaged roots with titanium posts. A comparison of 2 methods. J Clin Periodontol. 1996;23:1117-1126. [pmid: 8997657].
Buischi YA, Axelsson P, Barbosa MdF, Mayer MP, do Prado MC, de Oliveira LB. Salivary Streptococcus mutans and caries prevalence in Brazilian schoolchildren. Community Dent Oral Epidemiol. 1989;17:28-30. [pmid: 2783899].
Bukovics E, Uberhuber CW, Husinsky I, et al. Distribution of caries among tooth types in fluoride and non-fluoride areas. Acta Med Acad Sci Hung. 1976;33:81-87. [pmid: 1023738].
Buonocore MG. Caries prevention in pits and fissures sealed with an adhesive resin polymerized by ultraviolet light: a two-year study of a single adhesive application. J Am Dent Assoc. 1971;82:1090-1093. [pmid: 4928100].
Buonocore MG. Pit and fissure sealing. Dent Clin North Am. 1975;19:367-383. [pmid: 1090469].
Burgess JO. Dental materials for the restoration of root surface caries. Am J Dent. 1995;8:342-351. [pmid: 8695014].
Burleson JA, Kegeles SS, Lund AK. Effects of decisional control and work orientation on persistence in preventive health behavior. Health Psychol. 1990;9:1-17. [pmid: 2323324].
Burns PE. Log-linear analysis of dental caries occurrence in four skeletal series. Am J Phys Anthropol. 1979;51:637-647. [pmid: 391060].
Burt BA. How useful are cross-sectional data from surveys of dental caries?. Community Dent Oral Epidemiol. 1997;25:36-41. [pmid: 9088690].
Burt BA. Prevention policies in the light of the changed distribution of dental caries. Acta Odontol Scand. 1998;56:179-186. [pmid: 9688230].
Burt BA, Berman DS, Silverstone LM. Sealant retention and effects on occlusal caries after 2 years in a public program. Community Dent Oral Epidemiol. 1977;5:15-21. [pmid: 318957].
Burt BA, Eklund SA, Loesche WJ. Dental benefits of limited exposure to fluoridated water in childhood. J Dent Res. 1986;65:1322-1325. [pmid: 3478391].
Buyer DM. Fluoride: the difference between prevention and restoration. J Indiana Dent Assoc. 1993;72:6-7. [pmid: 8271099].
Buyukyilmaz T, Ogaard B, Duschner H, Ruben J, Arends J. The caries-preventive effect of titanium tetrafluoride on root surfaces in situ as evaluated by microradiography and confocal laser scanning microscopy. Adv Dent Res. 1997;11:448-452. [pmid: 9470503].
Buyukyilmaz T, Tangugsorn V, Ogaard B, Arends J, Ruben J, Rolla G. The effect of titanium tetrafluoride (TiF4) application around orthodontic brackets. Am J Orthod Dentofacial Orthop. 1994;105:293-296. [pmid: 8135216].
Cahen PM, Frank RM, Turlot JC, Jung MT. Comparative unsupervised clinical trial on caries inhibition effect of monofluorophosphate and amine fluoride dentifrices after 3 years in Strasbourg, France. Community Dent Oral Epidemiol. 1982;10:238-241. [pmid: 6754242].
Cahen PM, Obry-Musset AM, Grange D, Frank RM. Caries prevalence in 6- to 15-year-old French children based on the 1987 and 1991 national surveys. J Dent Res. 1993;72:1581-1587. [pmid: 8254126].
Cain BE, Corpron RE, Fee CL, Strachan DS, Kowalski CJ. Dose related remineralization using intraoral fluoride-releasing devices in situ. Caries Res. 1994;28:284-290. [pmid: 8069886].
Calderone JJ, Davis JM. The New Mexico sealant program: a progress report. J Public Health Dent. 1987;47:145-149. [pmid: 3302245].
Caliskan MK. Pulpotomy of carious vital teeth with periapical involvement. Int Endod J. 1995;28:172-176. [pmid: 8626202].
Canto MT. Changes in public health policy related to fluoride concentrations in public water supplies. J Public Health Dent. 1998;58.
Caplan DJ, Slade GD, Biesbrock AR, Bartizek RD, McClanahan SF, Beck JD. A comparison of increment and incidence density analyses in evaluating the anticaries effects of two dentifrices. Caries Res. 1999;33:16-22. [pmid: 9831776].
A review of preventive strategies and management J Am Dent Assoc 1995 126(suppl):1S 24S 7790681
Carlos JP. The influence of research on clinical dental practice. J Dent Educ. 1984;48:242-24. [pmid: 6371086].
Carlos JP, Senning RS. Error and bias in dental clinical trials. J Dent Res. 1968;47:142-148. [pmid: 4867757].
Carlsson A, Petersson M, Twetman S. 2-year clinical performance of a fluoride-containing fissure sealant in young schoolchildren at caries risk. Am J Dent. 1997;10:115-119. [pmid: 9545884].
Carlsson J, Grahnen H, Jonsson G. Lactobacilli and streptococci in the mouth of children. Caries Res. 1975;9:333-339. [pmid: 1055636].
Carlsson P, Angmar-Mansson B, Redmo-Emanuelsson IM, Anderssen K. Effects on demineralization of enamel by fluoridated sucrose: a pilot study in an in situ caries model. Adv Dent Res. 1995;9:9-13.
Caron GA, Murchison DF, Cohen RB, Broome JC. Resistance to fracture of teeth with various preparations for amalgam. J Dent. 1996;24:407-410. [pmid: 8990685].
Carr JD. X-ray evidence of the rate of dental caries. Dent Clin North Am. 1968;:581-587.
Carr LM. Fluoridation in Canberra. III. Dental caries after ten years. Aust Dent J. 1976;21:440-444. [pmid: 1070976].
Carr LM. Fluoridation: the Brisbane fallacy. Aust Dent J. 1990;35:191-192. [pmid: 2346409].
Carroll RA, Stookey GK, Muhler JC. The clinical effectiveness of phosphate-enriched breakfast cereals on the incidence of dental caries in adults: results after one year. J Am Dent Assoc. 1968;76:564-567. [pmid: 4384007].
Carvalho JC, Ekstrand KR, Thylstrup A. Dental plaque and caries on occlusal surfaces of first permanent molars in relation to stage of eruption. J Dent Res. 1989;68:773-779. [pmid: 2715469].
Carvalho JC, Ekstrand KR, Thylstrup A. Results after 1 year of non-operative occlusal caries treatment of erupting permanent first molars. Community Dent Oral Epidemiol. 1991;19:23-28. [pmid: 2019085].
Cassin AM, Pearson GJ, Picton DCA. Fissure sealants as a means of prolonging longevity of amalgam restorations - An in-vitro feasibility study. Clin Mater. 1991;7:203-207. [pmid: 10149135].
Cautley AJ. Root caries: some clinical aspects. N Z Dent J. 1993;89:132-136. [pmid: 8278119].
Cavaillon JP, Conge M, Mirisch D, Nemeth T, Sitbon JM. Longitudinal study on oral health of dental students at Paris VII University. Community Dent Oral Epidemiol. 1982;10:137-143. [pmid: 6955119].
Cayley AS, Holt RD. The influence of audit on the diagnosis of occlusal caries. Caries Res. 1997;31:97-102. [pmid: 9118191].
Cederberg RA, Frederiksen NL, Benson BW, Shulman JD. Effect of different background lighting conditions on diagnostic performance of digital and film images. Dento Maxillo Facial Radiol. 1998;27:293-297.
Cellier KM, Fanning EA, Gotjamanos T, Vowles NJ. Some statistical aspects of a clinical study on dental caries in children. Arch Oral Biol. 1968;13:483-508. [pmid: 4386355].
AT A GLANCE 1999. Improving oral health: Preventing unnescssary disease among all Americans. accessed October 18, 1999. Web Page.
Chadwick BL, Dummer PM, van der Stelt PF. The effect of alterations in horizontal X-ray beam angulation and bucco-lingual cavity width on the radiographic depth of approximal cavities. J Oral Rehabil. 1999;26:292-301. [pmid: 10232857].
Chan DC, Swift EJJ, Bishara SE. In vitro evaluation of a fluoride-releasing orthodontic resin. J Dent Res. 1990;69:1576-1579. [pmid: 2398185].
Chan MF, Jones JC. A comparison of four in vitro marginal leakage tests applied to root surface restorations. J Dent. 1992;20:287-293. [pmid: 1280658].
Chan MF, Jones JC. Marginal sealing ability of four restorative materials placed in root surfaces. Eur J Prosthodont Restor Dent. 1993;2:23-27. [pmid: 8180614].
Chandler JA, Brudvik JS. Clinical evaluation of patients eight to nine years after placement of removable partial dentures. J Prosthet Dent. 1984;51:736-743. [pmid: 6588196].
Charbeneau GT, Dennison JB. Clinical success and potential failure after single application of a pit and fissure sealant: a four-year report. J Am Dent Assoc. 1979;98:559-564. [pmid: 372286].
Charbeneau GT, Dennison JB, Ryge G. A filled pit and fissure sealant: 18-month results. J Am Dent Assoc. 1977;95:299-306. [pmid: 330602].
Charbeneau GT, Lund MR, Phillips RW, et al. Report of the Committee on Scientific Investigation of the American Academy of Restorative Dentistry. J Prosthet Dent. 1976;36:441-467. [pmid: 787509].
Cherry DV. Asymmetry of dental caries in relation to handedness and gender. J Mo Dent Assoc. 1981;61:12-14. [pmid: 6938728].
Cherry-Peppers G, Ship JA. Oral health in patients with type II diabetes and impaired glucose tolerance. Diabetes Care. 1993;16:638-641. [pmid: 8462394].
Chestnutt IG, MacFarlane TW, Aitchison TC, Stephen KW. Evaluation of the in vitro cariogenic potential of Streptococcus mutans strains isolated from 12-year-old children with differing caries experience. Caries Res. 1995;29:455-460. [pmid: 8556748].
Chestnutt IG, Schafer F, Jacobson AP, Stephen KW. Incremental susceptibility of individual tooth surfaces to dental caries in Scottish adolescents. Community Dent Oral Epidemiol. 1996;24:11-16. [pmid: 8833507].
Chestnutt IG, Schafer F, Jacobson AP, Stephen KW. The influence of toothbrushing frequency and post-brushing rinsing on caries experience in a caries clinical trial. Community Dent Oral Epidemiol. 1998;26:406-411. [pmid: 9870540].
Chestnutt IG, Schafer F, Jacobson AP, Stephen KW. The prevalence and effectiveness of fissure sealants in Scottish adolescents. Br Dent J. 1994;177:125-129. [pmid: 8074951].
Cheung VW, Holt RD. The influence of two different lights on reliability in the diagnosis of caries and gingivitis in children. Community Dent Health. 1986;3:129-134. [pmid: 3460669].
Chewing gum and the dental health balance. FDI World. 1993;2:13-16. [pmid: 9552809].
Chidyllo SA. Intraoral examination in pyogenic facial lesions. Am Fam Physician. 1992;46:461-464. [pmid: 1636562].
Chikte UM, Lewis HA, Rudolph MJ. The effectiveness of a school-based fluoride mouth rinse programme. J Dent Assoc S Afr. 1996;51:697-700. [pmid: 9461935].
Chintakanon K, Boonpinon P. Ectopic eruption of the first permanent molars: prevalence and etiologic factors. Angle Orthod. 1998;68:153-160. [pmid: 9564425].
Choksi SK, Brady JM, Dang DH, Rao MS. Detecting approximal dental caries with transillumination: a clinical evaluation. J Am Dent Assoc. 1994;125:1098-1102. [pmid: 8064051].
Chow LC, Takagi S. Remineralization of root lesions with concentrated calcium and phosphate solutions. Dent Mater J. 1995;14:31-36. [pmid: 8940543].
Christensen GJ. A new challenge--root caries in mature people. J Am Dent Assoc. 1996;127:379-380. [pmid: 8819785].
Chung CK, Millett DT, Creanor SL, Gilmour WH, Foye RH. Fluoride release and cariostatic ability of a compomer and a resin-modified glass ionomer cement used for orthodontic bonding. J Dent. 1998;26:533-538. [pmid: 9699448].
Cimasoni G, Held AJ. The distribution of organic material in the initial carious lesion: an histochemical study after decalcification with the brain technique. Helvetica Odontologica Acta. 1970;14:1-5. [pmid: 4245271].
Cipriano TM, Santos JF. Clinical behavior of repaired amalgam restorations: a two-year study. J Prosthet Dent. 1995;73:8-11. [pmid: 7699605].
Clark DC, Hanley JA, Stamm JW, Weinstein PL. An empirically based system to estimate the effectiveness of caries-preventive agents. A comparison of the effectiveness estimates of APF gels and solutions, and fluoride varnishes. Caries Res. 1985;19:83-95. [pmid: 3919948].
Clark DC, Hann HJ, Williamson MF, Berkowitz J. Effects of lifelong consumption of fluoridated water or use of fluoride supplements on dental caries prevalence. Community Dent Oral Epidemiol. 1995;23:20-24. [pmid: 7774172].
Clark DC, Mechanic M, Banting DW. A further look at the role of radiographs in trials of caries-prophylactic agents. J Public Health Dent. 1982;42:237-250. [pmid: 6957608].
Clark DC, Morgan J, MacEntee MI. Effects of a 1% chlorhexidine gel on the cariogenic bacteria in high-risk elders: a pilot study. Spec Care Dentist. 1991;11:101-103. [pmid: 1887358].
Clark DC, Robert G, Tessier C, et al. The results after 20 months of a study testing the efficacy of a weekly fluoride mouthrinsing program. J Public Health Dent. 1985;45:252-256. [pmid: 3866866].
Clark DC, Stamm JW, Quee TC, Robert G. Results of the Sherbrooke-Lac Megantic fluoride varnish study after 20 months. Community Dent Oral Epidemiol. 1985;13:61-64. [pmid: 3857148].
Clark DC, Stamm JW, Robert G, Tessier C. Results of a 32-month fluoride varnish study in Sherbrooke and Lac-Megantic, Canada. J Am Dent Assoc. 1985;111:949-953. [pmid: 3905917].
Clark DC, Stamm JW, Tessier C, Robert G. The final results of the Sherbrooke-Lac Megantic fluoride varnish study. J Can Dent Assoc. 1987;53:919-922. [pmid: 3319099].
Clark JW, Corpron RE, More FG, Easton JW, Merrill DF, Kowalski CJ. Comparison of the effects of two topical fluoride regimens on demineralized enamel in vivo. J Dent Res. 1988;67:954-958. [pmid: 3170909].
Clark MM, Album MM, Lloyd RW. Preventive dentistry and the family physician. Am Fam Physician. 1996;53:619-626. [pmid: 8629542].
Clarke NG, Graf H, Fanning EA. Fluoride ion release from dentifrices and caries inhibition in a clinical trial. Aust Dent J. 1971;16:249-251. [pmid: 4940673].
Clarkson BH, Wefel JS, Feagin FF. Fluoride distribution in enamel after in vitro caries-like lesion formation. J Dent Res. 1986;65:963-966. [pmid: 3458757].
Clarkson BH, Wefel JS, Miller I. The effect of polyvalent metal ion mordanting on caries-like lesion progression in enamel. J Dent Res. 1984;63:13-18. [pmid: 6582074].
Clarkson BH, Wefel JS, Miller I. A model for producing caries-like lesions in enamel and dentin using oral bacteria in vitro. J Dent Res. 1984;63:1186-1189. [pmid: 6592198].
Clarkson BH, Wefel JS, Miller I, Edie J. Microprobe and SEM analysis of surface coatings on caries-like lesions in enamel after metal ion mordanting and APF application. J Dent Res. 1984;63:106-110. [pmid: 6582089].
Clarkson JE, Ellwood RP, Chandler RE. A comprehensive summary of fluoride dentifrice caries clinical trials. Am J Dent. 1993;6 Spec No:S59-106. [pmid: 7488358].
Clerehugh V, Blinkhorn AS, Downer MC, et al. Changes in the caries prevalence of 11-12-year-old schoolchildren in the North-West of England from 1968 to 1981. Community Dent Oral Epidemiol. 1983;11:367-370. [pmid: 6581002].
Clifton TL, Tyndall DA, Ludlow JB. Extraoral radiographic imaging of primary caries. Dento Maxillo Facial Radiol. 1998;27:193-198.
Cline JT, Messer LB. Long term retention of sealants applied by inexperienced operators in Minneapolis. Community Dent Oral Epidemiol. 1979;7:206-212. [pmid: 391475].
Clinical caries trials. Proceedings of a conference at the American Dental Association, Chicago, Illinois, May 17-19, 1983. J Dent Res. 1984;63 Spec No:694-827. [pmid: 6586774].
Clinical effectiveness of some fluoride-containing toothpastes. Bull World Health Organ. 1982;60:633-638. [pmid: 6291796].
Cobb BH, Rozier GR, Bawden JW. A clinical study of the caries preventive effects of an APF solution and APF thixotropic gel. Pediatr Dent. 1980;2:263-266. [pmid: 6941001].
Cohen LD. Pit and fissure sealants. An Underutilized preventive technology. Int J Technol Assess Health Care. 1990;6:378-391. [pmid: 2228454].
Cohen S, Massler M. Pulpal response to dental caries in human primary teeth. J Dent Child. 1967;34:130-139. [pmid: 5336469].
Coli P, Derhami K, Brannstrom M. In vitro marginal leakage around Class II resin composite restorations with glass-ceramic inserts. Quintessence Int. 1997;28:755-760. [pmid: 9573868].
Collier FI, Heath MR, Lynch E, Beighton D. Assessment of the clinical status of primary root carious lesions using an enzymic assay. Caries Res. 1993;27:60-64. [pmid: 8448776].
Collins WJ, McCall DR, Strang R, et al. Experience with a mobile fissure sealing unit in the Greater Glasgow area: results after three years. Community Dent Health. 1985;2:195-202. [pmid: 3904939].
Colquhoun J. Dental caries among children in New Zealand. Community Dent Oral Epidemiol. 1995;23.
Colquhoun J. Fluoridation. Nature. 1986;324.
Colquhoun J. Influence of social class and fluoridation on child dental health. Community Dent Oral Epidemiol. 1985;13:37-41. [pmid: 3855733].
Colquhoun J, Mann R. Fluoridation trials. N Z Med J. 1989;102.
Principal requirements for controlled clinical trials of caries preventive agents and procedures. Technical report no. 1, third edition, Commission on Oral Health, Research and Epidemiology. Int Dent J. 1982;32:292-310. [pmid: 6958658].
Condon M. Variability in the diagnosis of dental caries. Afr Dent J. 1988;2:22-25. [pmid: 3272732].
Congleton JB3, Crenshaw MA, Bawden JW. The diffusion of fluoride ion from acidulated phosphate fluoride topical products. ASDC J Dent Child. 1978;45:133-136. [pmid: 350919].
Conti AJ. The anticaries benefit of a higher fluoride content dentifrice in a Florida community. Compend Suppl. 1988:S379-383.
Conti AJ, Lotzkar S, Daley R, Cancro L, Marks RG, McNeal DR. A 3-year clinical trial to compare efficacy of dentifrices containing 1.14% and 0.76% sodium monofluorophosphate. Community Dent Oral Epidemiol. 1988;16:135-138. [pmid: 3288434].
Cook LJ. The implications of protocol-based care on dental services in the military. Mil Med. 1999;164:556-561. [pmid: 10459264].
Cook SR. A longitudinal radiographic study of caries progression in dental students. Aust Dent J. 1984;29:315-320. [pmid: 6598034].
Cooney PV, Hardwick F. A fissure sealant pilot project in a third party insurance program in Manitoba [published erratum appears in J Can Dent Assoc 1994 Apr;60(4):264]. J Can Dent Assoc. 1994;60:140-141, 144-145. [pmid: 8111658].
Copeland JS. A long-term look at sealants. Northwest Dent. 1996;75:29-30. [pmid: 9487890].
Coppock DA. Fluoride concentrations of surface enamel before and after tropical application of stannous fluoride in naval recruits. J R Nav Med Serv. 1975;61:48-52. [pmid: 1100817].
Corbin SB. Oral disease prevention technologies for community use. Int J Technol Assess Health Care. 1991;7:327-344. [pmid: 1938193].
Coulter ID, Marcus M, Freed JR. Consistency across panels of ratings of appropriateness of dental care treatment procedures. Community Dent Health. 1998;15:97-104. [pmid: 9793226].
Coulter WA, Murray SD, Kinirons MJ. The use of a concentrated oral rinse culture technique to sample oral candida and lactobacilli in children, and the relationship between candida and lactobacilli levels and dental caries experience: a pilot study. Int J Paediatr Dent. 1993;3:17-21. [pmid: 8329332].
Report of workshop aimed at defining guidelines for caries clinical trials: superiority and equivalency claims for anticaries dentifrices. J Am Dent Assoc. 1988;117:663-665. [pmid: 3225378].
Crabb HS. 'Arrested caries'. Br Dent J. 1966;121:167-174 concl. [pmid: 5263153].
Crabb HS. Enamel caries. Observations on the histology and pattern of progress of the approximal lesion. Br Dent J. 1966;121:115-129 contd. [pmid: 5222146].
Crabb HS. A new approach to the interpretation of the microradiographic image. Arch Oral Biol. 1967;12:1195-1198. [pmid: 5234298].
Crabb HS, Mortimer KV. Dental caries and enamel structure. Nature. 1966;209:611-612. [pmid: 5921189].
Craig GG. The use of a calcium sucrose phosphates-calcium orthophosphate complex as a cariostatic agent. Br Dent J. 1975;138:25-28. [pmid: 1089411].
Craig GG, Powell KR. Dental caries in susceptible fissures after prolonged fluoride application. Community Dent Oral Epidemiol. 1979;7:158-160. [pmid: 287587].
Craig GG, Powell KR, Cooper MH. Caries progression in primary molars: 24-month results from a minimal treatment programme. Community Dent Oral Epidemiol. 1981;9:260-265. [pmid: 6955124].
Crall JJ, Silverstone LM, Clarkson BH, Wefel JS, Wei SH. Fluoride uptake and in vitro caries-like lesion formation in enamel after two-step topical fluoride applications. Caries Res. 1982;16:162-169. [pmid: 6951639].
Creanor SL, Awawdeh LA, Saunders WP, Foye RH, Gilmour WH. The effect of a resin-modified glass ionomer restorative material on artificially demineralised dentine caries in vitro. J Dent. 1998;26:527-531. [pmid: 9699447].
Creanor SL, Macfarlane TW, Mackenzie D, Weetman DA, Strang R, Stephen KW. Microbiology and acid/anion profiles of enamel surface plaque from an in situ caries appliance. Caries Res. 1986;20:392-397. [pmid: 3463418].
Creanor SL, Strang R, Gilmour WH, et al. The effect of chewing gum use on in situ enamel lesion remineralization. J Dent Res. 1992;71:1895-1900. [pmid: 1452890].
Creanor SL, Strang R, Telfer S, MacDonald I, Smith MJ, Stephen KW. In situ appliance for the investigation of enamel de- and remineralization. A pilot study. Caries Res. 1986;20:385-391. [pmid: 3463417].
Crossner CG. Salivary lactobacillus counts in the prediction of caries activity. Community Dent Oral Epidemiol. 1981;9:182-190. [pmid: 6949671].
Crossner CG, Unell L. A longitudinal study of dental health and treatment need in Swedish teenagers. Community Dent Oral Epidemiol. 1986;14:10-14. [pmid: 3456868].
Cueto EI, Buonocore MG. Sealing of pits and fissures with an adhesive resin: its use in caries prevention. J Am Dent Assoc. 1967;75:121-128. [pmid: 5338243].
Curtis SN, Dooley CL. Cariostatic activity of (1,6-bis-[2-ethylhexylbiguanido]-hexane) in conventional rats. J Dent Res. 1979;58:1405-1412. [pmid: 285110].
Dabrowska E, Zdanowicz-Wiloch J, Pawinska-Magnuszewska M, Stokowska W. Intravital treatment of the pulp with simultaneous laser biostimulation. Rocz Akad Med Bialymst. 1997;42:168-176. [pmid: 9581476].
Daculsi G, Kerebel B, Le Cabellec MT, Kerebel LM. Qualitative and quantitative data on arrested caries in dentine. Caries Res. 1979;13:190-202. [pmid: 287559].
Dagenais ME, Clark BG. Receiver operating characteristics of RadioVisioGraphy. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 1995;79:238-245. [pmid: 7614189].
Dahllof G, Modeer T, Bolme P, Ringden O, Heimdahl A. Oral health in children treated with bone marrow transplantation: a one-year follow-up. ASDC J Dent Child. 1988;55:196-200. [pmid: 3290297].
Dahlquist LM, Gil KM. Using parents to maintain improved dental flossing skills in children. J Appl Behav Anal. 1986;19:255-260. [pmid: 3771418]. [pmcid: 1308069].
Daly TE, Drane JB, MacComb WS. Management of problems of the teeth and jaw in patients undergoing irradiation. Am J Surg. 2972;124:539-542.
Damato FA, Stephen KW. Demonstration of a fluoride dose response with an in situ single-section dental caries model. Caries Res. 1994;28:277-283. [pmid: 8069885].
Damen JJ, Exterkate RA, ten Cate JM. Reproducibility of TMR for the determination of longitudinal mineral changes in dental hard tissues. Adv Dent Res. 1997;11:415-419. [pmid: 9470498].
Daniels TE, Fox PC. Salivary and oral components of Sjogren's syndrome. Rheum Dis Clin North Am. 1992;18:571-589. [pmid: 1496162].
Dargent-Pare C, Wolikow M, Brafman J, Letrait S, Boissonnat V, Espie JP. Caries prevalence in children following a prevention program in Seine- Saint-Denis (France). Rev Epidemiol Sante Publique. 1999;47:19-28. [pmid: 10214673].
Dasanayake AP, Roseman JM, Caufield PW, Butts JT. Distribution and determinants of mutans streptococci among African-American children and association with selected variables. Pediatr Dent. 1995;17:192-198. [pmid: 7617494].
Davenport ES, Day S, Hardie JM, Smith JM. A comparison between commercial kits and conventional methods for enumeration of salivary mutans streptococci and lactobacilli. Community Dent Health. 1992;9:261-271. [pmid: 1450999].
Davies EE, Meister FJ, Lommel TJ. Panoramic versus periapical surveys. A comparison of findings on freshman dental students. Dent Radiogr Photogr. 1977;50:41-47. [pmid: 270444].
Davies GN. Early childhood caries--a synopsis. Community Dent Oral Epidemiol. 1998;26:106-116. [pmid: 9671208].
Davies GN, Horowitz HS, Wada W. The assessment of dental caries for public health purposes. Community Dent Oral Epidemiol. 1973;1:68-73. [pmid: 4153613].
Davies MH, Eccles JD. Attitudes of dental patients to conservation treatment in different chair positions. J Dent. 1978;6:294-298. [pmid: 282298].
Davies MJ, Spencer AJ, Westwater A, Simmons B. Dental caries among Australian Aboriginal, non-aboriginal Australian- born, and overseas-born children. Bull World Health Organ. 1997;75:197-203. [pmid: 9277006].
Davila JM, Buonocore MG, Greeley CB, Provenza DV. Adhesive penetration in human artificial and natural white spots. J Dent Res. 1975;54:999-1008. [pmid: 1058886].
de Araujo FB, de Araujo DR, dos Santos CK, de Souza MA. Diagnosis of approximal caries in primary teeth: radiographic versus clinical examination using tooth separation. Am J Dent. 1996;9:54-56. [pmid: 9522685].
De Araujo FB, Rosito DB, Toigo E, dos Santos CK. Diagnosis of approximal caries: radiographic versus clinical examination using tooth separation. Am J Dent. 1992;5:245-248. [pmid: 1299248].
De Bruyn H, Van Rijn LJ, Purdell-Lewis DJ, Arends J. Influence of various fluoride varnishes on mineral loss under plaque. Caries Res. 1988;22:76-83. [pmid: 3162404].
De Craene GP, Martens C, Dermaut R. The invasive pit-and-fissure sealing technique in pediatric dentistry: an SEM study of a preventive restoration. ASDC J Dent Child. 1988;55:34-42. [pmid: 3276746].
de Josselin de Jong E, Sundstrom F, Westerling H, Tranaeus S, ten Bosch JJ, Angmar-Mansson B. A new method for in vivo quantification of changes in initial enamel caries with laser fluorescence. Caries Res. 1995;29:2-7. [pmid: 7867045].
de Liefde B. Dental caries: diagnosis and treatment planning. N Z Dent J. 1980;76:12-15. [pmid: 6929431].
de Liefde B. Identification and preventive care of high caries-risk children: a longitudinal study. N Z Dent J. 1989;85:112-116. [pmid: 2797545].
de Liefde B. A study of the chemical treatment of early caries of occlusal pits and fissures. N Z Dent J. 1987;83:10-12. [pmid: 3103032].
De Los Santos R, Lin YT, Corpron RE, Beltran ED, Strachan DS, Landry PA. In situ remineralization of root surface lesions using a fluoride chewing gum or fluoride-releasing device. Caries Res. 1994;28:441-446. [pmid: 7850848].
de Soet JJ, Holbrook WP, van Amerongen WE, Schipper E, Homburg CH, de Graaff J. Prevalence of Streptococcus sobrinus in relation to dental caries in children from Iceland and The Netherlands. ASDC J Dent Child. 1990;57:337-342. [pmid: 2212191].
de Soet JJ, Weerheijm KL, van Amerongen WE, de Graaff J. A comparison of the microbial flora in carious dentine of clinically detectable and undetectable occlusal lesions. Caries Res. 1995;29:46-49. [pmid: 7867050].
de Souza-Gugelmin MC, Ito IY, Campos GM. Study of the correlation between the gingival immunologic defense index and parameters associated with dental caries. Braz Dent J. 1996;7:91-95. [pmid: 9206360].
de Vries HC, Ruiken HM, Konig KG, van 't Hof MA. Radiographic versus clinical diagnosis of approximal carious lesions. Caries Res. 1990;24:364-370. [pmid: 2261609].
Dean JA, Barton DH, Vahedi I, Hatcher EA. Progression of interproximal caries in the primary dentition. J Clin Pediatr Dent. 1997;22:59-62. [pmid: 9643207].
Deery C, Fyffe HE, Nugent Z, Nuttall NM, Pitts NB. The effect of placing a clear pit and fissure sealant on the validity and reproducibility of occlusal caries diagnosis. Caries Res. 1995;29:377-381. [pmid: 8521440].
Deery C, Fyffe HE, Nugent Z, Nuttall NM, Pitts NB. Integrity, maintenance and caries susceptibility of sealed surfaces in adolescents receiving regular care from general dental practitioners in Scotland. Int J Paediatr Dent. 1997;7:75-80. [pmid: 9524457].
Deery C, Fyffe HE, Nuttall NM, Nugent ZJ, Pitts NB. The dental caries status of Scottish adolescents reported to be regular attenders. Initial results from a primary dental care based research network. Br Dent J. 1999;187:95-100. [pmid: 10464989].
Deery C, Pitts NB. The differentiation of sealant restorations from preventive fissure sealants, in subjects with clear sealants. Community Dent Health. 1992;9:385-390. [pmid: 1486526].
Demers M, Brodeur JM, Simard PL, Mouton C, Veilleux G, Frechette S. Caries predictors suitable for mass-screenings in children: a literature review. Community Dent Health. 1990;7:11-21. [pmid: 2192779].
DenBesten P, Ko HS. Fluoride levels in whole saliva of preschool children after brushing with 0.25 g (pea-sized) as compared to 1.0 g (full-brush) of a fluoride dentifrice. Pediatr Dent. 1996;18:277-280. [pmid: 8857654].
Denes J, Gabris K. Results of a 3-year oral hygiene programme, including amine fluoride products, in patients treated with fixed orthodontic appliances. Eur J Orthod. 1991;13:129-133. [pmid: 2055251].
Dennison JB, Straffon LH, Corpron RE, Charbeneau GT. A clinical comparison of sealant and amalgam in the treatment of pits and fissures. 1. Clinical performance after 18 months. Pediatr Dent. 1980;2:167-175. [pmid: 6938930].
Dennison JB, Straffon LH, Corpron RE, Charbeneau GT. A clinical comparison of sealant and amalgam in the treatment of pits and fissures. 2. Clinical application and maintenance during an 18-month period. Pediatr Dent. 1980;2:176-183. [pmid: 6938931].
Dennison JB, Straffon LH, More FG. Evaluating tooth eruption on sealant efficacy. J Am Dent Assoc. 1990;121:610-614. [pmid: 2229741].
Dens F, Boute P, Vinckier F, Declerck D. Quantitative determination of immunologic components of salivary gland secretion in long-term, event-free pediatric oncology patients. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 1995;79:701-704. [pmid: 7621026].
Dens FL, Boute P, Vinckier F, Declerck D. Salivary caries risk factors in long-term event-free survivors of pediatric malignant diseases. J Clin Pediatr Dent. 1996;20:241-245. [pmid: 8634214].
Dental health services in Magadan/Chukotka, USSR. Alaska Med. 1991;33:29-33. [pmid: 2053685].
DePaola PF Clinical studies of monofluorophosphate dentifrices Caries Res 1983 17(suppl) 1:119 135 6357453
DePaola PF. Clinical studies on MFP/calcium containing abrasive. Int Dent J. 1993;43:89-96. [pmid: 8478134].
DePaola PF. Combined use of a sodium fluoride prophylaxis paste and a spray containing acidulated sodium fluoride solution. J Am Dent Assoc. 1967;75:1407-1411. [pmid: 4383326].
DePaola PF. Discussion of a hypothetical protocol for a clinical field trial. J Dent Res. 1980;59:1254-1257. [pmid: 6993514].
DePaola PF. The effect of various partial recording methods upon the findings of an incremental caries study. J Oral Ther Pharmacol. 1968;4:247-252. [pmid: 4384483].
DePaola PF. Examiner inconsistency in clinical caries research. J Oral Ther Pharmacol. 1967;4:200-204. [pmid: 6080135].
DePaola PF. The interpretation of findings in clinical caries trials. ASDC J Dent Child. 1974;41:11-18. [pmid: 4148797].
DePaola PF. A review of clinical trials utilizing acidulated phosphate-fluoride topical agents. J Am Coll Dent. 1968;35:22-33. [pmid: 4383845].
DePaola PF, Aasenden R, Brudevold F. The use of topically applied acidulated phosphate-fluoride preceded by mild etching of the enamel: a one-year clinical trial. Arch Oral Biol. 1971;16:1155-1163. [pmid: 4944060].
DePaola PF, Jordan HV, Soparkar PM. Inhibition of dental caries in school children by topically applied vancomycin. Arch Oral Biol. 1977;22:187-191. [pmid: 326237].
DePaola PF, Lax M. The caries-inhibiting effect of acidulated phosphate-fluoride chewable tablets: a two-year double-blind study. J Am Dent Assoc. 1968;76:554-557. [pmid: 4865754].
DePaola PF, Soparkar M, Van Leeuwen M, DeVelis R. The anticaries effect of single and combined topical fluoride systems in school children. Arch Oral Biol. 1980;25:649-653. [pmid: 7016089].
DePaola PF, Soparkar P, Foley S, Bookstein F, Bakhos Y. Effect of high-concentration ammonium and sodium fluoride rinses on dental caries in schoolchildren. Community Dent Oral Epidemiol. 1977;5:7-14. [pmid: 318958].
DePaola PF, Soparkar PM, Triol C, et al. The relative anticaries effectiveness of sodium monofluorophosphate and sodium fluoride as contained in currently available dentifrice formulations. Am J Dent. 1993;6 Spec No:S7-12. [pmid: 7488359].
Derand T, Petersson LG. Inhibiting effect on demineralization of permanent root surfaces after different topical application of fluorides and a solution containing Fe- and Al-ions. Swed Dent J. 1982;6:117-120. [pmid: 6955988].
Derkson GD, Ponti P. Nursing bottle syndrome; prevalence and etiology in a non-fluoridated city. J Can Dent Assoc. 1982;48:389-393. [pmid: 7049333].
Derkson GD, Richardson AS, Jinks GM. Clinical evaluation of a restoration containing fluoride: two-year results. Pediatr Dent. 1989;11:286-290. [pmid: 2639322].
Deutchman M, Petrou ID, Mellberg JR. Effect of fluoride and glycyrrhizin mouthrinses on artificial caries lesions in vivo. Caries Res. 1989;23:206-208. [pmid: 2736584].
Diesendorf M. Misleading publicity for a fluoridation trial. N Z Med J. 1988;101:832-833. [pmid: 3205496].
Diesendorf M. The mystery of declining caries. Community Dent Oral Epidemiol. 1989;17:106-107. [pmid: 2784085].
Dijkman GE, de Vries J, Arends J. Effect of glutardialdehyde on secondary caries in situ. Caries Res. 1992;26:293-298. [pmid: 1423446].
Dimitriadis AG, Sassouni V, Draus FJ. The effects of topical fluoride applications underneath loose orthodontic bands. Angle Orthod. 1974;44:94-99. [pmid: 4589512].
Dini EL, Foschini AL, de Mendonca FC, de Nardo G, Abbad G, Frais RL. Changes in dental caries prevalence of school children in Araraquara, SP, Brazil. Int Dent J. 1996;46:82-85. [pmid: 8930678].
Dini EL, Holt RD, Bedi R. Prevalence and severity of caries in 3-12-year-old children from three districts with different fluoridation histories in Araraquara, SP, Brazil. Community Dent Health. 1998;15:44-48. [pmid: 9791615].
Dionysopoulos P, Kotsanos N, Koliniotou-Koubia, Papagodiannis Y. Secondary caries formation in vitro around fluoride-releasing restorations. Oper Dent. 1994;19:183-188. [pmid: 8700758].
Dionysopoulos P, Kotsanos N, Papadogianis Y. Secondary caries formation in vitro around glass ionomer-lined amalgam and composite restorations. J Oral Rehabil. 1996;23:511-519. [pmid: 8866262].
Dionysopoulos P, Kotsanos N, Papadogiannis Y, Konstantinidis A. Artificial caries formation around fluoride-releasing restorations in roots. J Oral Rehabil. 1998;25:814-820. [pmid: 9846901].
Dionysopoulos P, Kotsanos N, Papadogiannis Y, Konstantinidis A. Artificial secondary caries around two new F-containing restoratives. Oper Dent. 1998;23:81-86. [pmid: 9573793].
Dirks OB The benefits of water fluoridation Caries Res 1974 8suppl:2 15 4152072
Disney JA, Abernathy JR, Graves RC, Mauriello SM, Bohannan HM, Zack DD. Comparative effectiveness of visual/tactile and simplified screening examinations in caries risk assessment. Community Dent Oral Epidemiol. 1992;20:326-332. [pmid: 1464226].
Disney JA, Bohannan HM. The role of occlusal sealants in preventive dentistry. Dent Clin North Am. 1984;28:21-35. [pmid: 6368277].
Disney JA, Graves RC, Stamm JW, Bohannan HM, Abernathy JR. Comparative effects of a 4-year fluoride mouthrinse program on high and low caries forming grade 1 children. Community Dent Oral Epidemiol. 1989;17:139-143. [pmid: 2736895].
Disney JA, Graves RC, Stamm JW, Bohannan HM, Abernathy JR. The University of North Carolina Caries Risk Assessment Study. II. Baseline caries prevalence. J Public Health Dent. 1990;50:178-185. [pmid: 2342031].
do Rego MA, de Araujo MA. A 2-year clinical evaluation of fluoride-containing pit and fissure sealants placed with an invasive technique. Quintessence Int. 1996;27:99-103. [pmid: 9063219].
Dodds MW. Dilemmas in caries diagnosis--applications to current practice and need for research. J Dent Educ. 1993;57:433-438. [pmid: 8315100].
Dodds MW, Edgar WM. Interactions between fluoride and plaque in the remineralization of enamel caries-like lesions. Am J Dent. 1991;4:111-114. [pmid: 1863429].
Dodds MWJ. Dental caries diagnosis - Toward the 21st century. Nat Med. 1996;2.
Doherty JM, Krippene B. Fluoridation in Cudahy. Five-year evaluation. Wis Med J. 1972;71:10-11.
Doherty NJ. Economic costs of attrition in clinical trials. J Dent Res. 1982;61:649-653. [pmid: 6806340].
Dolles OK, Gjermo P. Caries increment and gingival status during 2 years' use of chlorhexidine- and fluoride-containing dentifrices. Scand J Dent Res. 1980;88:22-27. [pmid: 6929082].
Dominkovic T. Early diagnosis of fissure caries using the dental operating lamp. Sven Tandlak Tidskr. 1975;68:19-24. [pmid: 1055472].
Domoto P, Weinstein P, Leroux B, Koday M, Ogura S, Iatridi-Roberson I. White spots caries in Mexican-American toddlers and parental preference for various strategies. ASDC J Dent Child. 1994;61:342-6. [pmid: 7897003].
Donly KJ. Posterior composite resin: use for anterior restorations. ASDC J Dent Child. 1990;57:260-262. [pmid: 2373783].
Donly KJ, Ingram C. An in vitro caries inhibition of photopolymerized glass ionomer liners. ASDC J Dent Child. 1997;64:128-130. [pmid: 9189003].
Donly KJ, Segura A, Wefel JS, Hogan MM. Evaluating the effects of fluoride-releasing dental materials on adjacent interproximal caries. J Am Dent Assoc. 1999;130:817-825. [pmid: 10377639].
Donly KJ, Stufflebeam M, Garcia-Godoy F. Effect of topical fluoride application before and after amalgam restoration placement on recurrent caries inhibition. Am J Dent. 1998;11:151-153. [pmid: 10388367].
Donovan TE, Cho GC. Materials for conservative posterior restorations. J Calif Dent Assoc. 1996;24:32-38. [pmid: 9120610].
Dooland M. The fate of first permanent molars recorded as 'doubtfully carious' at a school dental clinic. Aust Dent J. 1982;27:117-118. [pmid: 6956278].
Dooland M, Smales R. The diagnosis of fissure-caries in permanent molar teeth. ASDC J Dent Child. 1982;49:181-185. [pmid: 6953078].
Douglass CW, Gammon MD. The epidemiology of dental caries and its impact on the operative dentistry curriculum. J Dent Educ. 1984;48:547-555. [pmid: 6593346].
Douglass CW, McNeil BJ. Clinical decision analysis methods applied to diagnostic tests in dentistry. J Dent Educ. 1983;47:708-714. [pmid: 6581205].
Douglass CW, Valachovic RW, Wijesinha A, Chauncey HH, Kapur KK, McNeil BJ. Clinical efficacy of dental radiography in the detection of dental caries and periodontal diseases. Oral Surg Oral Med Oral Pathol. 1986;62:330-339. [pmid: 3462638].
Douglass JM, O'Sullivan DM, Tinanoff N. Temporal changes in dental caries levels and patterns in a Native American preschool population. J Public Health Dent. 1996;56:171-175. [pmid: 8906699].
Dove SB, McDavid WD. A comparison of conventional intra-oral radiography and computer imaging techniques for the detection of proximal surface dental caries. Dento Maxillo Facial Radiol. 1992;21:127-134.
Downer MC. Concurrent validity of an epidemiological diagnostic system for caries with the histological appearance of extracted teeth as validating criterion. Caries Res. 1975a;9:231-246. [pmid: 1090371].
Downer MC. The quality of caries data from the national and BASCD surveys. Community Dent Health. 1992;9:107-108. [pmid: 1504876].
Downer MC. Time trends in caries experience of children in England and Wales. Caries Res. 1992;26:466-472. [pmid: 1294308].
Downer MC. Validation of methods used in dental caries diagnosis. Int Dent J. 1989;39:241-246. [pmid: 2691404].
Downer MC, Blinkhorn AS, Holt RD, Wight C, Attwood D. Dental caries experience and defects of dental enamel among 12-year-old children in north London, Edinburgh, Glasgow and Dublin. Community Dent Oral Epidemiol. 1994;22:283-285. [pmid: 7813176].
Downer MC, Holloway PJ, Davies TG. Clinical testing of a topical fluoride caries preventive programme. Br Dent J. 1976;141:242-247. [pmid: 788724].
Downer MC, Kay EJ. Restorative treatment decisions from bitewing radiographs--performance of dental epidemiologists and general dental practitioners. Community Dent Oral Epidemiol. 1996;24:101-105. [pmid: 8654028].
Downer MC, Mitropoulos CM. Improvement in selection of study participants. J Dent Res. 1984;63 Spec No:752-756. [pmid: 6586779].
Downer MC, Moles DR. Health gain from restorative dental treatment evaluated by computer simulation. Community Dent Health. 1998;15:32-39. [pmid: 9791613].
Downer MC, Nordling H, Samaletdin A, et al A comparison of dental care for children in Edinburgh and Helsinki Community Dent Health 1986 3(suppl) 1:3 45
Downer MC, O'Brien GJ. Evaluating health gains from restorative dental treatment. Community Dent Oral Epidemiol. 1994;22:209-213. [pmid: 7924233].
Downer MC, O'Mullane DM. A comparison of the concurrent validity of two epidemiologic diagnostic systems for caries evaluation. Community Dent Oral Epidemiol. 1975b;3:20-24. [pmid: 1053969].
Downer MC, Spencer SJ. Evaluating a dental caries preventive programme. R Soc Health J. 1973;93:129-132. [pmid: 4148578].
Downer MC, Whittle JG, Teagle FA. Factors influencing the local planning of dental services. Community Dent Oral Epidemiol. 1979;7:264-269. [pmid: 295706].
Downer MC, Worthington HV. The status of bite-wing radiographs in enhancing discriminatory ability in caries prophylactic clinical trials. Caries Res. 1992;26:195-200. [pmid: 1628294].
Doyle WA, Brose JA. A five-year study of the longevity of fissure sealants. ASDC J Dent Child. 1978;45:127-129. [pmid: 350917].
Dragoo MR. Resin-ionomer and hybrid-ionomer cements: Part I. Comparison of three materials for the treatment of subgingival root lesions. Int J Periodontics Restorative Dent. 1996;16:594-601. [pmid: 9242097].
Dragoo MR. Resin-ionomer and hybrid-ionomer cements: part II, human clinical and histologic wound healing responses in specific periodontal lesions. Int J Periodontics Restorative Dent. 1997;17:75-87. [pmid: 10332255].
Dreizen S, Brown LR, Daly TE, Drane JB. Prevention of xerostomia-related dental caries in irradiated cancer patients. J Dent Res. 1977;56:99-104. [pmid: 264889].
Driscoll WS. A review of clinical research on the use of prenatal fluoride administration for prevention of dental caries. ASDC J Dent Child. 1981;48:109-117. [pmid: 7012207].
Driscoll WS, Heifetz SB, Brunnelle JA. Treatment and posttreatment effects of chewable fluoride tablets on dental caries: findings after 7 1/2 years. J Am Dent Assoc. 1979;99:817-821. [pmid: 290677].
Driscoll WS, Heifetz SB, Korts DC. Effect of acidulated phosphate-fluoride chewable tablets on dental caries in schoolchildren: results after 30 months. J Am Dent Assoc. 1974;89:115-120. [pmid: 4151915].
Driscoll WS, Heifetz SB, Korts DC. Effect of chewable fluoride tablets on dental caries in schoolchildren: results after six years of use. J Am Dent Assoc. 1978;97:820-824. [pmid: 102674].
Driscoll WS, Heifetz SB, Korts DC, Meyers RJ, Horowitz HS. Effect of acidulated phosphate-fluoride chewable tablets in schoolchildren: results after 55 months. J Am Dent Assoc. 1977;94:537-543. [pmid: 264923].
Driscoll WS, Nowjack-Raymer R, Heifetz SB, Li SH, Selwitz RH. Evaluation of the comparative effectiveness of fluoride mouthrinsing, fluoride tablets, and both procedures in combination: interim findings after five years. J Public Health Dent. 1990;50:13-17. [pmid: 2295997].
Driscoll WS, Nowjack-Raymer R, Selwitz RH, Li SH, Heifetz SB. A comparison of the caries-preventive effects of fluoride mouthrinsing, fluoride tablets, and both procedures combined: final results after eight years. J Public Health Dent. 1992;52:111-116. [pmid: 1564689].
Driscoll WS, Swango PA, Horowitz AM, Kingman A. Caries-preventive effects of daily and weekly fluoride mouthrinsing in a fluoridated community: final results after 30 months. J Am Dent Assoc. 1982;105:1010-1013. [pmid: 6961143].
Driscoll WS, Swango PA, Horowitz AM, Kingman A. Caries-preventive effects of daily and weekly fluoride mouthrinsing in an optimally fluoridated community: findings after eighteen months. Pediatr Dent. 1981;3:316-320. [pmid: 6952165].
Drummond BK, Bimstein E. Prevalence of marginal alveolar bone loss in children referred for treatment to the Paediatric Clinic at the School of Dentistry, University of Otago. N Z Dent J. 1995;91:138-140. [pmid: 8602288].
du Plessis JB, van der Walt R, de Leeuw J, Dames J. A comparison of the effects of different concentrations of fluoride in the drinking water in different parts of Port Elizabeth and Despatch: a first report. J Dent Assoc S Afr. 1996;51:651-655. [pmid: 9461983].
du Plessis JB, van Rooyen JJ, Naude DA, van der Merwe CA. Water fluoridation in South Africa: will it be effective?. J Dent Assoc S Afr. 1995;50:545-549. [pmid: 8613580].
Duckworth JE, Webber RL, Youmans H, Fewell TR. The effects of spectral distribution on x-ray image quality. Oral Surg Oral Med Oral Pathol. 1981;52:314-320. [pmid: 6945542].
Duckworth R. Fluoride dentifrices. A review of clinical trials in the United Kingdom. Br Dent J. 1968;124:505-509. [pmid: 4385071].
Duckworth RM, Knoop DT, Stephen KW. Effect of mouthrinsing after toothbrushing with a fluoride dentifrice on human salivary fluoride levels. Caries Res. 1991;25:287-291. [pmid: 1913767].
Duckworth RM, Morgan SN, Gilbert RJ. Oral fluoride measurements for estimation of the anti-caries efficacy of fluoride treatments. J Dent Res. 1992;71 Spec No:836-840. [pmid: 1592970].
Duffy MB, Bernet JK, Chovanec GK, Majerus GJ, Frazier PJ, Newell KJ. Dental hygienists' knowledge, opinions, and use of pit and fissure sealants: a comparison of two states. J Public Health Dent. 1987;47:121-133. [pmid: 3475467].
Duggal MS, Tahmassebi JF, Toumba KJ, Mavromati C. The effect of different etching times on the retention of fissure sealants in second primary and first permanent molars. Int J Paediatr Dent. 1997;7:81-86. [pmid: 9524458].
Duggan G, Midda M. Clinical trial of a new fissure sealant. J Int Assoc Dent Child. 1987;18:17-20. [pmid: 3078701].
Duke ES, Robbins JW, Snyder DS. Clinical evaluation of a dentinal adhesive system: three-year results. Quintessence Int. 1991;22:889-895. [pmid: 1839860].
Duke SA, Forward GC. The relationship between anticaries activity of monofluorophosphate dentifrices and their performances in laboratory tests. Caries Res. 1985;19:284-288. [pmid: 3888395].
Duke SA, Rees DA, Forward GC. Increased plaque calcium and phosphorus concentrations after using a calcium carbonate toothpaste containing calcium glycerophosphate and sodium monofluorophosphate. Pilot study. Caries Res. 1979;13:57-59. [pmid: 283888].
Duncan RC, Heaven T, Weems RA, Firestone AR, Greer DF, Patel JR. Using computers to diagnose and plan treatment of approximal caries. Detected in radiographs. J Am Dent Assoc. 1995;126:873-882. [pmid: 7629363].
Dunipace AJ, Hall AF, Kelly SA, et al. An in situ interproximal model for studying the effect of fluoride on enamel. Caries Res. 1997;31:60-70. [pmid: 8955997].
Dunipace AJ, Zhang W, Beiswanger AJ, Stookey GK. An in vitro model for studying the efficacy of fluoride dentifrices in preventing root caries. Caries Res. 1994;28:315-321. [pmid: 8001052].
Dunne SM, Goolnik JS, Millar BJ, Seddon RP. Caries inhibition by a resin-modified and a conventional glass ionomer cement, in vitro. J Dent. 1996;24:91-94. [pmid: 8636500].
Dwyer DM, Berman DS, Silverstone LM. A study of approximal carious lesions in primary molars. J Int Assoc Dent Child. 1973;4:41-46. [pmid: 4535298].
Dyer JR, Shannon IL. MFP versus stannous fluoride mouthrinses for prevention of decalcification in orthodontic patients. ASDC J Dent Child. 1982;49:19-21. [pmid: 6948831].
Eckerbom M. Prevalence and technical standard of endodontic treatment in a Swedish population. A longitudinal study. Swed Dent J Suppl. 1993;93:1-45. [pmid: 8503096].
Edblad E, Gustafsson A, Svenson B, Jansson L. Number and frequency of bitewing radiographs and assessment of approximal caries in 14-to-19-year-old Swedish adolescents. Swed Dent J. 1998;22:157-164. [pmid: 9850558].
Edelstein BL, Douglass CW, Brown LJ, Kingman A, Brunelle JA, Selwitz RH. Dispelling the myth that 50 percent of U.S. schoolchildren have never had a cavity. Public Health Rep. 1995;110:521-533. [pmid: 19313278].
Edgar WM. Sugar substitutes, chewing gum and dental caries--a review. Br Dent J. 1998;184:29-32. [pmid: 9479811].
Edgar WM, Geddes DA, Jenkins GN, Rugg-Gunn AJ, Howell R. Effects of calcium glycerophosphate and sodium fluoride on the induction in vivo of caries-like changes in human dental enamel. Arch Oral Biol. 1978;23:655-661. [pmid: 31854].
Edgar WM, Rugg-Gunn AJ, Jenkins GN, Geddes DA. Photographic and direct visual recording of experimental caries-like changes in human dental enamel. Arch Oral Biol. 1978;23:667-673. [pmid: 281900].
Edlund K, Koch G. Effect on caries of daily supervised toothbrushing with sodium monofluorophosphate and sodium fluoride dentifrices after 3 years. Scand J Dent Res. 1977;85:41-45. [pmid: 190671].
Edmunds DH, Whittaker DK, Green RM. Suitability of human, bovine, equine, and ovine tooth enamel for studies of artificial bacterial carious lesions. Caries Res. 1988;22:327-336. [pmid: 3214846].
Educational qualifications of public health dentists. Am J Public Health Nations Health. 1967;57:682-691. [pmid: 5630293]. [pmcid: 1227280].
Edward S. Changes in caries diagnostic criteria over time related to the insertion of fillings. A comparative study. Acta Odontol Scand. 1997;55:23-222. [pmid: 9083571].
Edward S. Dental caries on adjacent approximal tooth surfaces in relation to order of eruption. Acta Odontol Scand. 1997;55:27-30. [pmid: 9083572].
Edward S, Fjellstrom A, Henrikson CO, Nord CE. A comparative study of clinical and roentgenological recording of proximal caries in primary molars of preschool children. Odontol Revy. 1973;24:317-324. [pmid: 4520470].
Eggertsson H, Analoui M, van der Veen M, Gonzalez-Cabezas C, Eckert G, Stookey G. Detection of early interproximal caries in vitro using laser fluorescence, dye-enhanced laser fluorescence and direct visual examination. Caries Res. 1999;33:227-233. [pmid: 10207199].
Ehrenreich DW. A comparison of the effects of zinc-oxide eugenol and calcium hydroxide on carious dentin in human primary molars. ASDC J Dent Child. 1968;35:451-456. [pmid: 4879574].
Ehrlich J, Weisgold A, Updegrave W. A comparative study of panorex and periapical radiographs for evaluating caries and periodontal disease. Isr J Dent Med. 1977;26:27-29.
Ehudin DZ, Thompson VP. Tensile bond strength of dental adhesives bonded to simulated caries-exposed dentin. J Prosthet Dent. 1994;71:165-173. [pmid: 8126672].
Eickholz P, Kolb I, Lenhard M, Hassfeld S, Staehle H. Digital radiography of interproximal caries: effect of different filters. Caries Res. 1999;33:234-241. [pmid: 10207200].
Eidelman E. Composite resin support of undermined enamel in amalgam restorations. Pediatr Dent. 1999;21:118-120. [pmid: 10197337].
Eidelman E, Finn SB, Koulourides T. Remineralization of carious dentin treated with calcium hydroxide. J Dent Child. 1965;32:218-225. [pmid: 5318013].
Einwag J, Hellwig E, Hotz P, Stadtler P. The relative caries-inhibiting efficacy of amine fluoride and sodium fluoride in compatible dentifrices--results of a consensus conference. Quintessence Int. 1995;26:707-713. [pmid: 8935113].
Ekanayake LS, Sheiham A. Reducing rates of progression of dental caries in British schoolchildren. A study using bitewing radiographs. Br Dent J. 1987;163:265-269. [pmid: 3479139].
Eklund SA, Pittman JL, Heller KE. Professionally applied topical fluoride and restorative care in insured children. J Public Health Dent. 2000;60:33-38. [pmid: 10734614].
Eklund SA, Pittman JL, Smith RC. Trends in per-patient gross income to dental practices from insured patients, 1980-1995. J Am Dent Assoc. 1998;129:1559-1565. [pmid: 9818573].
Ekstrand J, Fomon SJ, Ziegler EE, Nelson SE. Fluoride pharmacokinetics in infancy. Pediatr Res. 1994;35:157-163. [pmid: 8165049].
Ekstrand K, Qvist V, Thylstrup A. Light microscope study of the effect of probing in occlusal surfaces. Caries Res. 1987;21:368-374. [pmid: 3475183].
Ekstrand KR, Bruun G, Bruun M. Plaque and gingival status as indicators for caries progression on approximal surfaces. Caries Res. 1998;32:41-45. [pmid: 9438570].
Ekstrand KR, Carvalho JC, Thylstrup A. Restorative caries treatment patterns in Danish 20-year-old males in 1986 and 1991. Community Dent Oral Epidemiol. 1994;22:75-79. [pmid: 8205783].
Ekstrand KR, Kuzmina I, Bjorndal L, Thylstrup A. Relationship between external and histologic features of progressive stages of caries in the occlusal fossa. Caries Res. 1995;29:243-250. [pmid: 7656292].
Ekstrand KR, Ricketts DN, Kidd EA. Do occlusal carious lesions spread laterally at the enamel-dentin junction? A histolopathological study. Clin Oral Invest. 1998;2:15-20.
Ekstrand KR, Ricketts DN, Kidd EA. Reproducibility and accuracy of three methods for assessment of demineralization depth of the occlusal surface: an in vitro examination. Caries Res. 1997;31:224-231. [pmid: 9165195].
Ekstrand KR, Ricketts DN, Kidd EA, Qvist V, Schou S. Detection, diagnosing, monitoring and logical treatment of occlusal caries in relation to lesion activity and severity: an in vivo examination with histological validation. Caries Res. 1998;32:247-254. [pmid: 9643366].
El Khizzi N, Kasab SA, Osoba AO. HACEK group endocarditis at the Riyadh Armed Forces Hospital. J Infect. 1997;34:69-74. [pmid: 9120328].
Elderton RJ. Clinical studies concerning re-restoration of teeth. Adv Dent Res. 1990;4:4-9. [pmid: 2206212].
Elderton RJ. The General Dental Service in Scotland: an evaluation of findings reported by the Dundee Dental Health Services Research Unit. Community Dent Health. 1985;2:225-236. [pmid: 3904940].
Eli I, Bar-Tal Y, Fuss Z, Silberg A. Effect of intended treatment on anxiety and on reaction to electric pulp stimulation in dental patients. J Endod. 1997;23:694-697. [pmid: 9587311].
Eli I, Weiss EI, Tzohar A, Littner MM, Gelernter I, Kaffe I. Interpretation of bitewing radiographs. Part 1. Evaluation of the presence of approximal lesions. J Dent. 1996;24:379-383. [pmid: 8990680].
Ellingsen JE, Rolla G. Treatment of dentin with stannous fluoride--SEM and electron microprobe study. Scand J Dent Res. 1987;95:281-286. [pmid: 3476983].
Ellingsen RH, Artun J. Pulpal response to orthognathic surgery: a long-term radiographic study. Am J Orthod Dentofacial Orthop. 1993;103:338-343. [pmid: 8480699].
Emami Z, al-Khateeb S, de Josselin de Jong E, Sundstrom F, Trollsas K, Angmar-Mansson B. Mineral loss in incipient caries lesions quantified with laser fluorescence and longitudinal microradiography. A methodologic study. Acta Odontol Scand. 1996;54:8-13. [pmid: 8669246].
Emery ACJ. Hospital dental service: a clinical evaluation to determine its justification. J Am Dent Assoc. 1975;90:1018-1021. [pmid: 1092746].
Emilson CG. Outlook for Hibitane in dental caries. J Clin Periodontol. 1977;4:136-143. [pmid: 350907].
Emilson CG, Fornell J. Effect of toothbrushing with chlorhexidine gel on salivary microflora, oral hygiene, and caries. Scand J Dent Res. 1976;84:308-319. [pmid: 790537].
Emilson CG, Ravald N, Birkhed D. Effects of a 12-month prophylactic programme on selected oral bacterial populations on root surfaces with active and inactive carious lesions. Caries Res. 1993;27:195-200. [pmid: 8519057].
Emslie RD. Fluoridised milk. Lancet. 1977;1.
Englander HR, DePaola PF. Enhanced anticaries action from drinking water containing 5 ppm fluoride. J Am Dent Assoc. 1979;98:35-39. [pmid: 282343].
Englander HR, Keyes PH, Gestwicki M, Sultz HA. Clinical anticaries effect of repeated topical sodium fluoride applications by mouthpieces. J Am Dent Assoc. 1967;75:638-644. [pmid: 4382492].
Ennever J, Peterson JK, Hester WR, Segreto VA, Radike AW. Influence of alkaline pH on the effectiveness of sodium fluoride dentifrices. J Dent Res. 1980;59:658-661. [pmid: 6928417].
Enno A, Craig GG. Economic aspects of the prolonged fluoride application method. Aust Dent J. 1982;27:91-93. [pmid: 6810860].
Erickson RL. Root surface treatment with glass ionomers and resin composites. Am J Dent. 1994;7:279-285. [pmid: 7986453].
Erickson RL, Glasspoole EA. Model investigations of caries inhibition by fluoride-releasing dental materials. Adv Dent Res. 1995;9:315-323. discussion 324-331. [pmid: 8615951].
Ericson D, Zimmerman M, Raber H, Gotrick B, Bornstein R, Thorell J. Clinical evaluation of efficacy and safety of a new method for chemo-mechanical removal of caries. A multi-centre study. Caries Res. 1999;33:171-177. [pmid: 10207191].
Ericsson SY Cariostatic mechanisms of fluorides: clinical observations Caries Res 1977 11(suppl) 1:2 41 11044
Eriksen HM. Has caries merely been postponed?. Acta Odontol Scand. 1998;56:173-175. [pmid: 9688228].
Eriksen HM, Grytten J, Holst D. Is there a long-term caries-preventive effect of sugar restrictions during World War II?. Acta Odontol Scand. 1991;49:163-167. [pmid: 1882651].
Eriksen HM, Pears G. In vitro caries related to marginal leakage around composite resin restorations. J Oral Rehabil. 1978;5:15-20. [pmid: 272439].
Espeland MA, Handelman SL. Using latent class models to characterize and assess relative error in discrete measurements. Biometrics. 1989;45:587-599. [pmid: 2765639].
Espelid I. Radiographic diagnoses and treatment decisions on approximal caries. Community Dent Oral Epidemiol. 1986;14:265-270. [pmid: 3466745].
Espelid I, Tveit AB. Clinical and radiographic assessment of approximal carious lesions. Acta Odontol Scand. 1986;44:31-37. [pmid: 3456691].
Espelid I, Tveit AB. Diagnostic quality and observer variation in radiographic diagnoses of approximal caries. Acta Odontol Scand. 1986;44:39-46. [pmid: 3456692].
Espelid I, Tveit AB, Erickson RL, Keck SC, Glasspoole EA. Radiopacity of restorations and detection of secondary caries. Dent Mater. 1991;7:114-117. [pmid: 1936639].
Espelid I, Tveit AB, Fjelltveit A. Variations among dentists in radiographic detection of occlusal caries. Caries Res. 1994;28:169-175. [pmid: 8033190].
Espelid I, Tveit AB, Riordan PJ. Radiographic caries diagnosis by clinicians in Norway and Western Australia. Community Dent Oral Epidemiol. 1994;22:214-219. [pmid: 7924234].
Ethical and legal considerations associated with clinical field trials. Discussion. J Dent Res. 1980;59:1267-1270. [pmid: 6930400].
Ettinger RL, Bergman W, Wefel J. Effect of fluoride on overdenture abutments. Am J Dent. 1994;7:17-21. [pmid: 9115673].
Ettinger RL, Manderson D, Wefel JS, Jensen ME. An in vitro evaluation of the prevention of caries on overdenture abutments. J Dent Res. 1988;67:1338-1341. [pmid: 3049716].
Ettinger RL, Olson RJ, Wefel JS, Asmussen C. In vitro evaluation of topical fluorides for overdenture abutments. J Prosthet Dent. 1997;78:309-314. [pmid: 9297649].
Ettinger RL, Taylor TD, Scandrett FR. Treatment needs of overdenture patients in a longitudinal study: five-year results. J Prosthet Dent. 1984;52:532-537. [pmid: 6389835].
Evans DJ, Rugg-Gunn AJ, Tabari ED. The effect of 25 years of water fluoridation in Newcastle assessed in four surveys of 5-year-old children over an 18-year period. Br Dent J. 1995;178:60-64. [pmid: 7848758].
Evans DJ, Rugg-Gunn AJ, Tabari ED, Butler T. The effect of fluoridation and social class on caries experience in 5-year-old Newcastle children in 1994 compared with results over the previous 18 years. Community Dent Health. 1996;13:5-10.
Evans DJ, Southwick CA, Davies HT. Clinical trials in primary dental care. Br Dent J. 1998;185:110-111.
Fabien V, Obry-Musset AM, Hedelin G, Cahen PM. Caries prevalence and salt fluoridation among 9-year-old schoolchildren in Strasbourg, France. Community Dent Oral Epidemiol. 1996;24:408-411. [pmid: 9007359].
Faine MP, Allender D, Baab D, Persson R, Lamont RJ. Dietary and salivary factors associated with root caries. Spec Care Dentist. 1992;12:177-182. [pmid: 1440139].
Faine MP, Oberg D. Survey of dental nutrition knowledge of WIC nutritionists and public health dental hygienists. J Am Diet Assoc. 1995;95:190-194. [pmid: 7852685].
Faller RV. The application of in situ models for evaluation of new fluoride-containing systems. Adv Dent Res. 1995;9:290-299. discussion 300-303. [pmid: 8615949].
Faller RV, Best JM, Featherstone JD, Barrett-Vespone NA. Anticaries efficacy of an improved stannous fluoride toothpaste. J Clin Dent. Spec No. 1995;6:89-96. [pmid: 8593199].
Fanning EA, Cellier KM, Gotjamanos T, Vowles NJ. The effect of fluoride dentifrices on the caries incidence of individual tooth surfaces. Aust Dent J. 1971;16:287-290. [pmid: 5286886].
Fanning EA, Cellier KM, Somerville CM. South Australian kindergarten children: effects of fluoride tablets and fluoridated water on dental caries in primary teeth. Aust Dent J. 1980;25:259-263. [pmid: 6936002].
Fanning EA, Gotjamanos T, Vowles NJ. The use of fluoride dentifrices in the control of dental caries: methodology and results of a clinical trial. Aust Dent J. 1968;13:201-206. [pmid: 4385839].
Fanning EA, Gotjamanos T, Vowles NJ, Cellier KM, Simmons DW. The use of fluoride dentifrices in the control of dental caries: a preliminary report of a clinical trial. Med J Aust. 1967;1:383-385. [pmid: 5336377].
Farges JC, Joffre A, Lesot H, Bleicher F, Magloire H. Immunocytochemical localization of fibronectin and a 165-kDa membrane protein in the odontoblast layer under initial carious lesions in man. Arch Oral Biol. 1995;40:1023-1028. [pmid: 8670020].
A reader's and writer's guide to the publication of clinical trials. Reports of agents and procedures to prevent caries and periodontal diseases. Federation Dentaire Internationale. Int Dent J. 1995;45:177-184. [pmid: 7558356].
Fearne JM, Bryan EM, Elliman AM, Brook AH, Williams DM. Enamel defects in the primary dentition of children born weighing less than 2000 g. Br Dent J. 1990;168:433-437. [pmid: 2361083].
Featherstone JD. Fluoride, remineralization and root caries. Am J Dent. 1994;7:271-274. [pmid: 7986451].
Featherstone JD, Rosenberg H. Lipid effect on the progress of artificial carious lesions in dental enamel. Caries Res. 1984;18:52-55. [pmid: 6580954].
Featherstone JD, ten Cate JM, Shariati M, Arends J. Comparison of artificial caries-like lesions by quantitative microradiography and microhardness profiles. Caries Res. 1983;17:385-391. [pmid: 6577953].
Featherstone JDB, Glena R, Shariati M, Shields CP. Dependence of in vitro demineralization of apatite and remineralization of dental enamel on fluoride concentration. J Dent Res. 1990;69:620-625. [pmid: 2312892].
Fedele DJ, Sheets CG. Issues in the treatment of root caries in older adults. J Esthet Dent. 1998;10:243-252. [pmid: 10321194].
Fehr FRvd. A study of carious lesions produced in vivo in unabraded, abraded, exposed, and F-treated human enamel surfaces, with emphasis on the x-ray dense outer layer. Arch Oral Biol. 1967;12:797-814. [pmid: 5232355].
Feigal RJ. Sealants and preventive restorations: review of effectiveness and clinical changes for improvement. Pediatr Dent. 1998;20:85-92. [pmid: 9566011].
Fejerskov O. Recent advancements in the treatment of root surface caries. Int Dent J. 1994;44:139-144. [pmid: 8063435].
Fejerskov O. Strategies in the design of preventive programs. Adv Dent Res. 1995;9:82-88. [pmid: 7546141].
Fejerskov O, Baelum V, Luan WM, Manji F. Caries prevalence in Africa and the People's Republic of China. Int Dent J. 1994;44:425-433. [pmid: 7814110].
Fejerskov O, Luan WM, Nyvad B, Budtz-Jorgensen E, Holm-Pedersen P. Active and inactive root surface caries lesions in a selected group of 60- to 80-year-old Danes. Caries Res. 1991;25:385-391. [pmid: 1747890].
Feller RP, Kiger RD, Triol CW, et al. Comparison of the clinical anticaries efficacy of an 1100 NaF silica-based dentifrice containing triclosan and a copolymer to an 1100 NaF silica-based dentifrice without those additional agents: a study on adults in California. J Clin Dent. 1996;7:85-89. [pmid: 9238883].
Feller RP, Ricks CL, Matthews TG, Santucci EA. Three-year clinical evaluation of composite formulations for posterior teeth. J Prosthet Dent. 1987;57:544-550. [pmid: 3474401].
Fennis-Ie YL, Verdonschot EH, van't Hof MA. Performance of some diagnostic systems in the prediction of occlusal caries in permanent molars in 6- and 11-year-old children. J Dent. 1998;26:403-408. [pmid: 9699429].
Fennis-le YL, Verdonschot EH, Burgersdijk RC, Konig KG, van't Hof MA. Effect of 6-monthly applications of chlorhexidine varnish on incidence of occlusal caries in permanent molars: a 3-year study. J Dent. 1998;26:233-238. [pmid: 9594475].
Fernandez NA, Burgos JC, Asenjo CF, Rosa IR. Nutrition survey of five rural Puerto Rican communities. Bol Assoc Med P R. 1969;61:42-52.
Ferreira Zandona AG, Analoui M, Beiswanger BB, et al. An in vitro comparison between laser fluorescence and visual examination for detection of demineralization in occlusal pits and fissures. Caries Res. 1998;32:210-218. [pmid: 9577987].
Ferrer Tuset I, Catala Pizarro M, Elorza Arizmendi JFJ. The importance of a child's first permanent molars. Rev Esp Pediatr. 1993;49:103-107.
Fertig JW. Hypothesis testing vs. statistical estimation procedures in caries clinical trials. J Dent Res. Spec No. 1984;63:808-813. [pmid: 6586785].
Fidler PE. A comparison of treatment patterns and costs for a fluoride and non-fluoride community. Community Health. 1977;9:103-113. [pmid: 603989].
Finn SB. The role of a dicalcium phosphate chewing gum in the control of human dental caries. Int Dent J. 1967;17:339-352. [pmid: 4383232].
Finn SB, Jamison HC. The effect of a dicalcium phosphate chewing gum on caries incidence in children: 30-month results. J Am Dent Assoc. 1967;74:987-995. [pmid: 4381314].
Firestone AR. Human interdental plaque-pH data and rat caries tests: results with the same substances. J Dent Res. 1982;61:1130-1136. [pmid: 6749923].
Firestone AR, Lussi A, Weems RA, Heaven TJ. The effect of experience and training on the diagnosis of approximal coronal caries from bitewing radiographs. A Swiss-American comparison. Schweiz Monatsschr Zahnmed. 1994;104:719-723. [pmid: 8042021].
Firestone AR, Sema D, Heaven TJ, Weems RA. The effect of a knowledge-based, image analysis and clinical decision support system on observer performance in the diagnosis of approximal caries from radiographic images. Caries Res. 1998;32:127-134. [pmid: 9544861].
Fischman S, Picozzi A, Juliano D, Slakter M, English J. Examiner standardization for caries studies. J Dent Res. 1976;55:926-929. [pmid: 1069772].
Fischman SL. Clinical research--caries and periodontal disease. Symp Pharmacol Ther Toxicol Group. 1975:21-31.
Fitch DR, Boyd WJ, McCoy RB, Pelleu GB. Amalgam repair of cast gold crown margins: a microleakage assessment. Gen Dent. 1982;30:328-330. [pmid: 6757049].
Fitzgerald RJ, Adams BO, Davis ME. A microbiological study of recurrent dentinal caries. Caries Res. 1994;28:409-415. [pmid: 7850843].
Flack VF, Atchison KA, Hewlett ER, White SC. Relationships between clinician variability and radiographic guidelines. J Dent Res. 1996;75:775-782. [pmid: 8655774].
Flaitz CM, Hicks MJ. Effects of sodium fluoride and stannous fluoride solutions on caries-like lesion formation around adhesive orthodontic brackets: an in vitro study. Quintessence Int. 1988;19:117-123. [pmid: 3269570].
Flaitz CM, Hicks MJ. Remineralization of caries-like lesions of enamel with acidulated calcifying fluids: a polarized light microscopic study. Pediatr Dent. 1996;18:205-209. [pmid: 8784910].
Flaitz CM, Hicks MJ, Silverstone LM. Radiographic, histologic, and electronic comparison of occlusal caries: an in vitro study. Pediatr Dent. 1986;8:24-28.
Fleiss JL. Assessing treatment effects in caries trials using ordered categorical data. J Dent Res. 1984;63 Spec No:778-83:778-783. [pmid: 6373867].
Fleiss JL, Kingman A. Statistical management of data in clinical research. Crit Rev Oral Biol Med. 1990;1:55-66. [pmid: 2101261].
Fleiss JL, Slakter MJ, Fischman SL, Park MH, Chilton NW. Inter-examiner reliability in caries trials. J Dent Res. 1979;58:604-609. [pmid: 283091].
Fleming WJ, Burgess RC, Lewis DW. Effect on caries of self-application of a zirconium silicate paste containing 9% stannous fluoride. Community Dent Oral Epidemiol. 1976;4:142-148. [pmid: 1066200].
Flint DJ, Paunovich E, Moore WS, Wofford DT, Hermesch CB. A diagnostic comparison of panoramic and intraoral radiographs. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 1998;85:731-735. [pmid: 9638709].
Fluoridated salt used in dental research project in Colombia. Controlled study conducted in remote Andes mountain site. J Am Dent Assoc. 1967;75:582-584. [pmid: 4382491].
Fluoridation. Aust Dent J. 1990;35:187-191. [pmid: 2346408].
Fluoride toxicity. Editorial. Lancet. 1973;2:889-890. [pmid: 4126923].
Flynn M. Scanning electron microscope investigation of in vivo performance of eight composite resins. J Prosthet Dent. 1978;39:529-532. [pmid: 349142].
Fogels HR, Alman JE, Meade JJ, O'Donnell JP. The relative caries-inhibiting effects of a stannous fluoride dentifrice in a silica gel base. J Am Dent Assoc. 1979;99:456-459. [pmid: 224083].
Fogels HR, Cancro LP, Bianco J, Fischman SL. The anticaries effect of supervised toothbrushing with a nonfluoride dentifrice. ASDC J Dent Child. 1982;49:424-427. [pmid: 6960029].
Fogels HR, Meade JJ, Griffith J, Miragliuolo R, Cancro LP. A clinical investigation of a high-level fluoride dentifrice. ASDC J Dent Child. 1988;55:210-215. [pmid: 3290299].
Fontana M, Dunipace AJ, Gregory RL, et al. An in vitro microbial model for studying secondary caries formation. Caries Res. 1996;30:112-118. [pmid: 8833134].
Fontana M, Li Y, Dunipace AJ, et al. Measurement of enamel demineralization using microradiography and confocal microscopy. A correlation study. Caries Res. 1996;30:317-325. [pmid: 8877084].
Formann AK. Measurement errors in caries diagnosis: some further latent class models. Biometrics. 1994;50:865-871. [pmid: 7981408].
Forsling JO, Halling A, Lundin SA, et al. Proximal caries prevalence in 19-year-olds living in Sweden. A radiographic study in four counties. Swed Dent J. 1999;23:59-70. [pmid: 10431341].
Forsman B. The caries preventing effect of mouthrinsing with 0.025 percent sodium fluoride solution in Swedish children. Community Dent Oral Epidemiol. 1974;2:58-65. [pmid: 4153500].
Forsman B. Studies on the effect of dentifrices with low fluoride content. Community Dent Oral Epidemiol. 1974;2:166-175. [pmid: 4154819].
Forsman B, Ericsson Y. Breastfeeding, formula feeding and dental health in low-fluoride districts in Sweden. Community Dent Oral Epidemiol. 1974;2:1-6. [pmid: 4528452].
Forss H, Halme E. Retention of a glass ionomer cement and a resin-based fissure sealant and effect on carious outcome after 7 years. Community Dent Oral Epidemiol. 1998;26:21-25. [pmid: 9511837].
Forss H, Saarni UM, Seppa L. Comparison of glass-ionomer and resin-based fissure sealants: a 2-year clinical trial. Community Dent Oral Epidemiol. 1994;22:21-24. [pmid: 8143437].
Forss H, Seppa L. Prevention of enamel demineralization adjacent to glass ionomer filling materials. Scand J Dent Res. 1990;98:173-178. [pmid: 2111576].
Forsten L. Clinical experience with glass ionomer for proximal fillings. Acta Odontol Scand. 1993;51:195-200. [pmid: 8237303].
Foster LV. Three year in vivo investigation to determine the progression of approximal primary carious lesions extending into dentine. Br Dent J. 1998;185:353-357. [pmid: 9807919].
Foster LV. Validity of clinical judgements for the presence of secondary caries associated with defective amalgam restorations. Br Dent J. 1994;177:89-93. [pmid: 8060719].
Frame PS, Sawai R, Bowen WH, Meyerowitz C. Preventive dentistry: practitioners' recommendations for low-risk patients compared with scientific evidence and practice guidelines. Am J Prev Med. 2000;18:159-162. [pmid: 10698247].
Frankl SN, Alman JE. Report of a three-year clinical trial comparing a toothpaste containing sodium monofluorophosphate with two marketed products. J Oral Ther Pharmacol. 1968;4:443-450. [pmid: 4385708].
Frankl SN, Fleisch S, Diodati RR. The topical anticariogenic effect of daily rinsing with an acidulated phosphate fluoride solution. J Am Dent Assoc. 1972;85:882-886. [pmid: 4403645].
Frencken JE, Makoni F, Sithole WD. Atraumatic restorative treatment and glass-ionomer sealants in a school oral health programme in Zimbabwe: evaluation after 1 year. Caries Res. 1996;30:428-433. [pmid: 8946101].
Frencken JE, Rugarabamu P, Amuli JA, Mulder J, Lihepa A. Oral health status of employees in sugar and sisal estates in Tanzania. Afr Dent J. 1989;3:9-16. [pmid: 2640133].
Frencken JE, Songpaisan Y, Phantumvanit P, Pilot T. An atraumatic restorative treatment (ART) technique: evaluation after one year. Int Dent J. 1994;44:460-464. [pmid: 7814116].
Frencken JE, Truin GJ, van't Hof MA, et al. Prevalence of dental caries in 7-13-yr-old children in Morogoro District, Tanzania, in 1984, 1986, and 1988. Community Dent Oral Epidemiol. 1990;18:2-8. [pmid: 2297976].
Friedl KH, Hiller KA, Schmalz G. Placement and replacement of amalgam restorations in Germany. Oper Dent. 1994;19:228-232. [pmid: 9028243].
Friedl KH, Hiller KA, Schmalz G. Placement and replacement of composite restorations in Germany. Oper Dent. 1995;20:34-38. [pmid: 8700766].
Friedl KH, Schmalz G, Hiller KA, Saller A. In-vivo evaluation of a feldspathic ceramic system: 2-year results. J Dent. 1996;24:25-31. [pmid: 8636488].
Friis-Hasche E, Bergmann J, Wenzel A, Thylstrup A, Pedersen KM, Petersen PE. Dental health status and attitudes to dental care in families participating in a Danish fluoride tablet program. Community Dent Oral Epidemiol. 1984;12:303-307. [pmid: 6593149].
Frostell G. Lycasin as a sugar substitute. Dtsch Zahnarztl Z. 1977;32:S71-75. [pmid: 16739].
Frostell G, Birkhed D, Edwardsson S, et al. Effect of partial substitution of invert sugar for sucrose in combination with Duraphat treatment on caries development in preschool children: the Malmo Study. Caries Res. 1991;25:304-310. [pmid: 1913770].
Frostell G, Blomlof L, Blomqvist T, et al. Substitution of sucrose by lycasin in candy 'the roslagen study'. Acta Odontol Scand. 1974;32:235-254. [pmid: 4156451].
Fry AE, Neely AR, Ruhlman DC, Phatak NM. Topical use of corticosteroids for the relief of pain sensitivity of dentin and pulp. Clinical observations. J Oral Ther Pharmacol. 1965;2:88-93. [pmid: 5318019].
Fuks AB, Bimstein E, Guelmann M, Klein H. Assessment of a 2 percent buffered glutaraldehyde solution in pulpotomized primary teeth of schoolchildren. ASDC J Dent Child. 1990;57:371-375. [pmid: 2120303].
Fuks AB, Edelman E, Biton N, Shapira J. A comparison of the retentive properties of two filled resins used as fissure sealants. ASDC J Dent Child. 1982;49:127-130. [pmid: 6460795].
Full CA. The infected primary molar - a retrospective study. Quintessence Int. 1981;12:183-186. [pmid: 6944728].
Furhoff AK, Tomson Y, Ilie M, et al. A multidisciplinary clinical study of patients suffering from illness associated with release of mercury from dental restorations: Medical and odontological aspects. Scand J Prim Health Care. 1998;16:247-252. [pmid: 9932320].
Furseth R. Further observations on the fine structure of orally exposed and carious human dental cementum. Arch Oral Biol. 1971;16:71-85. [pmid: 5279422].
Furseth R, Johansen E. A microradiographic comparison of sound and carious human dental cementum. Arch Oral Biol. 1968;13:1197-1206. [pmid: 4885781].
Furseth R, Johansen E. The mineral phase of sound and carious human dental cementum studied by electron microscopy. Acta Odontol Scand. 1970;28:305-322. [pmid: 5269861].
Fusayama T, Kurosaki N. Structure and removal of carious dentin. Int Dent J. 1972;22:401-411. [pmid: 4507649].
Fusayama T, Terachima S. Differentiation of two layers of carious dentin by staining. J Dent Res. 1972;51.
Fusayama T, Terashima S. Differentiation of two layers of carious dentin by staining. Bull Tokyo Med Dent Univ. 1972;19:83-92. [pmid: 4113753].
The future of prevention: in private practices or schools?. J Am Dent Assoc. 1975;90:444-446. [pmid: 1053786].
Gabris K, Nagy G, Madlena M, et al. Associations between microbiological and salivary caries activity tests and caries experience in Hungarian adolescents. Caries Res. 1999;33:191-195. [pmid: 10207194].
Gaffar A, Afflitto J, Nabi N. Chemical agents for the control of plaque and plaque microflora: an overview. Eur J Oral Sci. 1997;105:502-507. [pmid: 9395116].
Gaffar A, Afflitto J, Nabi N, Herles S, Kruger I, Olsen S. Recent advances in plaque, gingivitis, tartar and caries prevention technology. Int Dent J. 1994;44:63-70. [pmid: 8021038].
Gaffar A, Blake-Haskins JC, Sullivan R, Simone A, Schmidt R, Saunders F. Cariostatic effects of a xylitol/NaF dentifrice in vivo. Int Dent J. 1998;48:32-39. [pmid: 9779081].
Galal A, Manson-Hing L, Jamison H. A comparison of combinations of clinical and radiographic examinations in evaluation of a dental clinic population. Oral Surg Oral Med Oral Pathol. 1985;60:553-561. [pmid: 3864117].
Galan D, Lynch E. Epidemiology of root caries. Gerodontology. 1993;10:59-71. [pmid: 7713528].
Gale TJ, Hanes CM, Myers DR, Russell CM. Performance of sealants applied to first permanent molars in a dental school setting. Pediatr Dent. 1998;20:341-344. [pmid: 9803435].
Gallagher IH, Pearce EI. The sugar alcohols. Non-cariogenic sweeteners. N Z Dent J. 1977;73:200-206. [pmid: 351471].
Gallien GSJ, Schuman NJ. Local versus general anesthesia: a study of pulpal response in the treatment of cariously exposed teeth. J Am Dent Assoc. 1985;111:599-601. [pmid: 3863861].
Gao XJ, Elliott JC, Anderson P. Scanning and contact microradiographic study of the effect of degree of saturation on the rate of enamel demineralization. J Dent Res. 1991;70:1332-1337. [pmid: 1939826].
Garcia-Godoy F. Clinical significance of the conclusions from the International Scientific Assembly on the Comparative Anticaries Efficacy of Sodium Fluoride and Sodium Monofluorophosphate Dentifrices. Am J Dent. Spec No. 1993;6.
Garcia-Godoy F, de Araujo FB. Enhancement of fissure sealant penetration and adaptation: the enameloplasty technique. J Clin Pediatr Dent. 1994;19:13-18. [pmid: 7865416].
Garcia-Godoy F, Flaitz CM, Hicks MJ. Secondary caries adjacent to amalgam restorations lined with a fluoridated dentin desensitizer. Am J Dent. 1998;11:254-258. [pmid: 10477975].
Garcia-Godoy F, Jesen ME. Artificial recurrent caries in glass ionomer-lined amalgam restorations. Am J Dent. 1990;3:89-93. [pmid: 2076235].
Garcia-Godoy F, Summitt JB, Donly KJ. Caries progression of white spot lesions sealed with an unfilled resin [published erratum appears in J Clin Pediatr Dent 1997 Summer;21(4):356]. J Clin Pediatr Dent. 1997;21:141-143. [pmid: 9484106].
Garlichs UA, Brandau H, Bossmann K. Histotopochemical determination of metabolic activity of carbohydrate metabolism in plaque from sound and carious enamel. Caries Res. 1974;8:234-248. [pmid: 4152006].
Geiger AM, Gorelick L, Gwinnett AJ, Griswold PG. The effect of a fluoride program on white spot formation during orthodontic treatment. Am J Orthod Dentofacial Orthop. 1988;93:29-37. [pmid: 3276146].
Gelhard TB, Arends J. Microradiography of in vivo remineralized lesions in human enamel. II. J Biol Buccale. 1984;12:59-65. [pmid: 6584426].
Gera I Prevention of periodontal disease LEGE ARTIS MED Vol 8(6)(Pp 428 435) 1998
Gerbino G, Tarello F, Fasolis M, De Gioanni PP. Rigid fixation with teeth in the line of mandibular fractures. Int J Oral Maxillofac Surg. 1997;26:182-186. [pmid: 9180227].
Gerdin PO. Studies in dentifrices. 6. The inhibitory effect of some grinding and non-grinding fluoride dentifrices on dental caries. Including tests of a new, non-grinding manganese-fluoride dentifrice. Sven Tandlak Tidskr. 1972;65:521-532. [pmid: 4517210].
Gerdin PO. Studies in dentifrices, 8: clinical testing of an acidulated, nongrinding dentifrice with reduced fluorine contents. Sven Tandlak Tidskr. 1974;67:283-297. [pmid: 4153809].
Geurtsen W, Spahl W, Leyhausen G. Variability of cytotoxicity and leaching of substances from four light- curing pit and fissure sealants. J Biomed Mater Res. 1998;44:73-77.
Ghani SH, Creanor SL, Luffingham JK, Foye RH. The influence of fluoride-releasing bonding composites in the development of artificial white spot lesions. An ex vivo study. Br J Orthod. 1994;21:375-378. [pmid: 7857897].
Gibson GB, Richardson AS. Sticky fissure management. 30-month report. J Can Dent Assoc. 1980;46:255-258. [pmid: 6444840].
Gift HC, Corbin SB, Nowjack-Raymer RE. Public knowledge of prevention of dental disease. Public Health Rep. 1994;109:397-404. [pmid: 8190863]. [pmcid: 1403504].
Gift HC, Frew R, Hefferren JJ. Attitudes toward and use of pit and fissure sealants. ASDC J Dent Child. 1975;42:460-466. [pmid: 1107371].
Gift HC, Reisine ST, Larach DC. The social impact of dental problems and visits [published erratum appears in Am J Public Health 1993 Jun;83(6):816]. Am J Public Health. 1992;82:1663-1668. [pmid: 1456343]. [pmcid: 1694558].
Gilmour AS, Edmunds DH. The polarized light microscopic appearance of caries-like lesions adjacent to restored cavities in the crowns and roots of extracted human teeth. J Oral Rehabil. 1998;25:929-939. [pmid: 9888228].
Gilmour AS, Edmunds DH, Newcombe RG. Prevalence and depth of artificial caries-like lesions adjacent to cavities prepared in roots and restored with a glass ionomer or a dentin-bonded composite material. J Dent Res. 1997;76:1854-1861. [pmid: 9390479].
Giordano PC, Harteveld CL, Bok LA, et al. A complex haemoglobinopathy diagnosis in a family with both beta [degree] - and alpha([degree] /+)-thalassaemia homozygosity. European Journal of Human Genetics. 1999;7:163-168. [pmid: 10196699].
Gish CW, Mercer VH, Stookey GK, Dahl LO. Self-application of fluoride as a community preventive measure: rationale, procedures, and three-year results. J Am Dent Assoc. 1975;90:388-397. [pmid: 234137].
Gisselsson H, Birkhed D, Bjorn AL. Effect of a 3-year professional flossing program with chlorhexidine gel on approximal caries and cost of treatment in preschool children. Caries Res. 1994;28:394-399. [pmid: 8001065].
Gisselsson H, Birkhed D, Bjorn AL. Effect of professional flossing with chlorhexidine gel on approximal caries in 12- to 15-year-old schoolchildren. Caries Res. 1988;22:187-192. [pmid: 3163527].
Gisselsson H, Birkhed D, Emilson CG. Effect of professional flossing with NaF or SnF2 gel on approximal caries in 13-16-year-old schoolchildren. Acta Odontol Scand. 1999;57:121-125. [pmid: 10445367].
Gisselsson H, Bjorn AL, Birkhed D. Immediate and prolonged effect of individual preventive measures in caries and gingivitis susceptible children. Swed Dent J. 1983;7:13-21. [pmid: 6574610].
Giunta JL, Kaplan MA. Unusual external resorption of a maxillary lateral. J Clin Pediatr Dent. 1994;18:135-137. [pmid: 8054293].
Gladys S, Van Meerbeek B, Inokoshi S, et al. Clinical and semiquantitative marginal analysis of four tooth-coloured inlay systems at 3 years. J Dent. 1995;23:329-338. [pmid: 8530722].
Glass RL. Radiographic evidence of tin uptake by human tooth structure. Arch Oral Biol. 1967;12:401-406. [pmid: 5228812].
Glass RL. A two-year clinical trial of sorbitol chewing gum. Caries Res. 1983;17:365-368. [pmid: 6347385].
Glass RL, Fleisch S. Diet and dental caries: dental caries incidence and the consumption of ready-to-eat cereals. J Am Dent Assoc. 1974;88:807-813. [pmid: 4149952].
Glass RL, Naylor MN. A clinical trial of two fluoride dentifrices in an area of low caries prevalence. Community Dent Health. 1997;14:74-78. [pmid: 9225534].
Glass RL, Peterson JK, Bixler D. The effects of changing caries prevalence and diagnostic criteria on clinical caries trials. Caries Res. 1983;17:145-151. [pmid: 6337712].
Glenn FB. Immunity conveyed by a fluoride supplement during pregnancy. ASDC J Dent Child. 1977;44:391-395. [pmid: 332731].
Glenn FB. Immunity conveyed by sodium-fluoride supplement during pregnancy: part II. ASDC J Dent Child. 1979;46:17-24. [pmid: 283075].
Glenn FB, Glenn WD3, Duncan RC. Fluoride tablet supplementation during pregnancy for caries immunity: a study of the offspring produced. Am J Obstet Gynecol. 1982;143:560-564. [pmid: 7091227].
Glenn FB, Glenn WD3, Duncan RC. Unpublished NIDR-Eastman Dental Center prenatal fluoride (PNF) study. J Dent Res. 1992;71.
Godson JH, Williams SA. Oral health and health related behaviours among three-year-old children born to first and second generation Pakistani mothers in Bradford, UK. Community Dent Health. 1996;13:27-33.
Goho C. Pilot study: a digital toothbrushing technique for field use. Mil Med. 1986;151:227-229. [pmid: 3085014].
Goldberg HJ, Weintraub JA, Roghmann KJ, Cornwell WS. Measuring periodontal disease in ancient populations: root and wear indices in study of American Indian skulls. J Periodontol. 1976;47:348-351. [pmid: 778374].
Goldberg J, Tanzer J, Munster E, Amara J, Thal F, Birkhed D. Cross-sectional clinical evaluation of recurrent enamel caries, restoration of marginal integrity, and oral hygiene status. J Am Dent Assoc. 1981;102:635-641. [pmid: 6972399].
Goldman M, Kronman JH. A preliminary report on a chemomechanical means of removing caries. J Am Dent Assoc. 1976;93:1149-1153. [pmid: 794090].
Gonzalez-Cabezas C, Fontana M, Dunipace AJ, et al. Measurement of enamel remineralization using microradiography and confocal microscopy. A correlational study. Caries Res. 1998;32:385-392. [pmid: 9701664].
Goorhuis J, Purdell-Lewis DJ. .25% and 0.4% amine fluoride gel for weekly topical application. An in vivo study on human dental enamel. Caries Res. 1986;20:458-464. [pmid: 3463429].
Gordon M, Newbrun E. Comparison of trends in the prevalence of caries and restorations in young adult populations of several countries. Community Dent Oral Epidemiol. 1986;14:104-109. [pmid: 3457673].
Gordon SR. Measurement of oral status and treatment need among subjects with dental prostheses: are the measures less reliable than the prostheses? Part III: Fixed prosthodontics and restorative dentistry. J Prosthet Dent. 1991;66:55-59. [pmid: 1941676].
Gorelick L, Geiger AM, Gwinnett AJ. Incidence of white spot formation after bonding and banding. Am J Orthod. 1982;81:93-98. [pmid: 6758594].
Gorrel C. Equine dentistry: evolution and structure. Equine Vet J. 1997;29:169-170. [pmid: 9234006].
Goshima T, Goshima Y. Radiographic detection of recurrent carious lesions associated with composite restorations. Oral Surg Oral Med Oral Pathol. 1990;70:236-239. [pmid: 2290656].
Gotfredsen E, Wenzel A, Grondahl HG. Observers' use of image enhancement in assessing caries in radiographs taken by four intra-oral digital systems. Dento Maxillo Facial Radiol. 1996;25:34-38.
Gotjamanos T. Paediatric dentistry discussion paper and case report. Management of small carious lesions in primary teeth: caries removal versus fluoride application and periodic 'observation' until exfoliation. Aust Dent J. 1997;42:372-374. [pmid: 9470278].
Gotjamanos T. Pulp response in primary teeth with deep residual caries treated with silver fluoride and glass ionomer cement ('atraumatic' technique). Aust Dent J. 1996;41:328-334. [pmid: 8961607].
Gourley JM. A two-year study of fissure sealant in two Nova Scotia communities. J Public Health Dent. 1975;35:132-137. [pmid: 1055237].
Grainger RM, Lehnhoff RW, Bollmer BW, Zacherl WA. Analysis of covariance in dental caries clinical trials. J Dent Res. 1984;63 Spec No:766-72:766-772. [pmid: 6586781].
Grajower R, Novickas D. The amalgam margin angle, marginal breakdown and adjacent caries in occlusal enamel, a pilot study on extracted teeth. J Oral Rehabil. 1988;15:257-268. [pmid: 3164365].
Granath L, Schroder U, Sundin B. Clinical evaluation of preventive and class-I composite resin restorations. Acta Odontol Scand. 1992;50:359-364. [pmid: 1476053].
Gratt BM, White SC, Bauer JG. A clinical comparison between xeroradiography and film radiography for the detection of recurrent caries. Oral Surg Oral Med Oral Pathol. 1988;65:483-489. [pmid: 3163139].
Graves RC, Beck JD, Disney JA, Drake CW. Root caries prevalence in black and white North Carolina adults over age 65. J Public Health Dent. 1992;52:94-101. [pmid: 1564697].
Graves RC, Bohannan HM, Disney JA, Stamm JW, Bader JD, Abernathy JR. Recent dental caries and treatment patterns in US children. J Public Health Dent. 1986;46:23-29. [pmid: 3457186].
Graves RC, Disney JA, Beck JD, Abernathy JR, Stamm JW, Bohannan HM. The University of North Carolina caries risk assessment study: caries increments of misclassified children. Community Dent Oral Epidemiol. 1992;20:169-74. [pmid: 1526098].
Gray A, Ferguson MM. The use of low-tack chewing gum for individuals wearing orthodontic appliances. Aust Dent J. 1996;41:373-376. [pmid: 9008993].
Gray AS, Gunther DM, Munns PM. Fluoride paste and rinse in a school dental program. J Can Dent Assoc. 1980;46:651-654. [pmid: 7002266].
Gray GB. An evaluation of sealant restorations after 2 years. Br Dent J. 1999;186:569-575. [pmid: 10405472].
Gray GB, Paterson RC. Fissure caries diagnosis and resulting treatment decisions by clinical community dental officers and general dental practitioners. Eur J Prosthodont Restor Dent. 1997;5:23-29. [pmid: 9594734].
Gray GB, Paterson RC. Management of fissure caries in the community dental services using sealant restorations: a field trial. Eur J Prosthodont Restor Dent. 1998;6:33-40. [pmid: 9680884].
Gray GB, Paterson RC. Prediction of the extent of caries in pit and fissure lesions in a field trial in the west of Scotland. Caries Res. 1997;31:329-335. [pmid: 9286515].
Green E. A clinical evaluation of two methods of caries prevention in newly-erupted first permanent molars. Aust Dent J. 1989;34:407-409. [pmid: 2818298].
Green GE, Wilson RM, Freeman NC. Human blood types and dental caries experience. J Dent Res. 1966;45.
Greenspan D. Xerostomia: Diagnosis and management. Oncology. 1996;10:7-11. [pmid: 8723427].
Gregory RL, Michalek SM, Filler SJ, Mestecky J, McGhee JR. Prevention of Streptococcus mutans colonization by salivary IgA antibodies. J Clin Immunol. 1985;5:55-62. [pmid: 3980676].
Grembowski D, Fiset L, Milgrom P, Forrester K, Spadafora A. Factors influencing the appropriateness of restorative dental treatment: an epidemiologic perspective. J Public Health Dent. 1997;57:19-30. [pmid: 9150060].
Grenby TH, Phillips A, Mistry M. Studies of the dental properties of lactitol compared with five other bulk sweeteners in vitro. Caries Res. 1989;23:315-319. [pmid: 2766316].
Griffen AL, Goepferd SJ. Preventive oral health care for the infant, child, and adolescent. Pediatr Clin North Am. 1991;38:1209-1226. [pmid: 1886743].
Grobler SR, Joubert JJ. The relative distribution of fluoride in erupted and unerupted enamel of human third molars from a low fluoride area. Arch Oral Biol. 1988;33:627-630. [pmid: 3245785].
Grodzka K, Augustyniak L, Budny J, et al. Caries increment in primary teeth after application of Duraphat fluoride varnish. Community Dent Oral Epidemiol. 1982;10:55-59. [pmid: 6952970].
Groeneveld A. Longitudinal study of prevalence of enamel lesions in a fluoridated and non-fluoridated area. Community Dent Oral Epidemiol. 1985;13:159-163. [pmid: 3860338].
Groeneveld A, Arends J. The effect of SnF2 and cetylaminohydrofluoride solutions on the acid demineralisation of enamel. Caries Res. 1974;8:275-282. [pmid: 4600503].
Groeneveld A, Van Eck AA, Backer Dirks O. Fluoride in caries prevention: is the effect pre- or post-eruptive?. J Dent Res. 1990;69 Spec No:751-755. discussion 820-823. [pmid: 2179337].
Gron P, Brudevold F. The effectiveness of NaF dentifrices. J Dent Child. 1967;34:123-127. [pmid: 5336467].
Grondahl HG. Decision strategies in radiographic caries diagnosis. Swed Dent J. 1979;3:173-180. [pmid: 298381].
Grondahl HG. Radiographic caries diagnosis. A study of caries progression and observer performance. Swed Dent J Suppl. 1979:1-32.
Grondahl HG. Some factors influencing observer performance in radiographic caries diagnosis. Swed Dent J. 1979;3:157-172. [pmid: 298380].
Grondahl HG, Hollender L. Dental caries and restoration. IV. A six-year longitudinal study of the caries increment of proximal surfaces. Swed Dent J. 1979;3:47-55. [pmid: 288180].
Grondahl HG, Hollender L, Malmcrona E, Sundquist B. Dental caries and restorations in teenargers. II. A longitudinal radiographic study of the caries increment of proximal surfaces among urban teenagers in Sweden. Swed Dent J. 1977;1:51-57. [pmid: 268692].
Grondahl HG, Molin L. Roentgenographic comparison of state of teeth in dental students in 1948 and 1968. Sven Tandlak Tidskr. 1970;63:919-927. [pmid: 4395468].
Grosfeld O, Czarnecka B, Drecka-Kuzan K, Szymanska-Jagiello W, Zyszko A. Clinical investigations of the temporomandibular joint in children and adolescents with rheumatoid arthritis. Scand J Rheumatol. 1973;2:145-149. [pmid: 4769068].
Grossman ES, Matejka JM. Amalgam marginal quality assessment: a comparison of seven methods. J Oral Rehabil. 1997;24:496-505. [pmid: 9250836].
Grossman ES, Matejka JM. Amalgam restoration and in vitro caries formation. J Prosthet Dent. 1995;73:199-209. [pmid: 7722937].
Grossman ES, Matejka JM. Effect of restorative materials and in vitro carious challenge on amalgam margin quality. J Prosthet Dent. 1996;76:239-245. [pmid: 8887794].
Grossman ES, Matejka JM. Reliability of outer lesion secondary caries as a predictor of wall lesions. Am J Dent. 1999;12:31-36. [pmid: 10477996].
Gruythuysen RJ, van der Linden LW, Woltgens JH, Geraets WG. Differences between primary and permanent teeth in posteruptive age dependency of radiological changes in enamel during the development of approximal caries. J Biol Buccale. 1992;20:59-62. [pmid: 1522086].
Gu ZQ, Chen QM, Wei S. The clinical application of a chemomechanical caries removal system (Caridex): a comparative study. Compendium. 1987;8:638-640. [pmid: 3479255].
Gugushe TS, du Plessis JB. Regional urban-rural distribution of dental caries experience in Swaziland. SADJ. 1998;53:409-412. [pmid: 9927939].
Guha-Chowdhury N, Drummond BK, Smillie AC. Total fluoride intake in children aged 3 to 4 years--a longitudinal study. J Dent Res. 1996;75:1451-1457. [pmid: 8876596].
Gulzow HJ. Comparative biochemical investigations on the degradation of sugars and sugar alcohols by microorganisms of the oral cavity. Int Z Vitam Ernahrungsforsch Beih. 1976;15:348-357. [pmid: 1066332].
Gunay H, Dmoch-Bockhorn K, Gunay Y, Geurtsen W. Effect on caries experience of a long-term preventive program for mothers and children starting during pregnancy. Clin Oral Invest. 1998;2:137-142.
Gurdal P, Akdeniz BG. Comparison of two methods for radiometric evaluation of resin-based restorative materials. Dento Maxillo Facial Radiol. 1998;27:236-239.
Gurgan S, Onen A, Koprulu H. In vitro effects of alcohol-containing and alcohol-free mouthrinses on microhardness of some restorative materials. J Oral Rehabil. 1997;24:244-246. [pmid: 9131482].
Gustafson G, Stelling E, Mornstad H, Brunius E. The effect of the calcium saccharose phosphate preparation Anticay on dental caries in the golden hamster. Odontol Revy. 1973;24:325-334. [pmid: 4520471].
Gustafsson RE, Quensel CE, Lanke LS, Lundqvist C, Grahnen H, Bonow BE, Krasse B. The Vipeholm Dental Caries Study. Acta Odont Scand. 1953;11:232-64.
Guthua SW, Mwaniki DL, Maina DM. Replacement therapy utilising autotransplanted wisdom teeth. East Afr Med J. 1994;71:35-38. [pmid: 8055762].
Gwinnett AJ. Caries prevention through sealing of pits and fissures. J Can Dent Assoc. 1971;37:458-461. [pmid: 4940694].
Gwinnett AJ. A comparison of proximal carious lesions as seen by clinical radiography, contact microradiography, and light microscopy. J Am Dent Assoc. 1971;83:1078-1080. [pmid: 5286138].
Gyurkovics C, Zimmermann P, Hadas E, Banoczy J. Effect of fluoridated milk on caries: 10-year results. J Clin Dent. 1992;3:121-124. [pmid: 1306678].
Haberman S, Bouschor C, Matthews L, Saunders E. Fine structure of soft carious dentine. Oral Surg Oral Med Oral Pathol. 1967;24:216-223. [pmid: 5339704].
Hafstrom-Bjorkman U, Sundstrom F, de Josselin de Jong E, Oliveby A, Angmar-Mansson B. Comparison of laser fluorescence and longitudinal microradiography for quantitative assessment of in vitro enamel caries. Caries Res. 1992;26:241-247. [pmid: 1423438].
Hakansson J, Eriksen TE. Treatment of caries and periodontitis in Sweden in 1974-77. Community Dent Oral Epidemiol. 1982;10:301-307. [pmid: 6961978].
Hakeberg M, Berggren U, Grondahl HG. A radiographic study of dental health in adult patients with dental anxiety. Community Dent Oral Epidemiol. 1993;21:27-30. [pmid: 8432101].
Halbach S, Kremers L, Willruth H, et al. Compartmental transfer of mercury released from amalgam. Hum Exp Toxicol. 1997;16:667-672. [pmid: 9426369].
Hall AF, Creanor SL, Strang R, Foye R. Determination of plaque pH changes within the trough of an in situ appliance used to study mineral changes in early carious lesions. Caries Res. 1997;31:50-54. [pmid: 8955995].
Hall AF, Creanor SL, Strang R, et al. The effect of sucrose-containing chewing-gum use on in situ enamel lesion remineralization. Caries Res. 1995;29:477-482. [pmid: 8556752].
Hall AF, DeSchepper E, Ando M, Stookey GK. In vitro studies of laser fluorescence for detection and quantification of mineral loss from dental caries. Adv Dent Res. 1997;11:507-514. [pmid: 9470511].
Hall AF, Sadler JP, Strang R, de Josselin de Jong E, Foye RH, Creanor SL. Application of transverse microradiography for measurement of mineral loss by acid erosion. Adv Dent Res. 1997;11:420-425. [pmid: 9470499].
Hallgren A, Oliveby A, Twetman S. Fluoride concentration in plaque adjacent to orthodontic appliances retained with glass ionomer cement. Caries Res. 1993;27:51-54. [pmid: 8448774].
Hals E. Histology of natural secondary caries associated with silicate cement restorations in human teeth. Arch Oral Biol. 1975;20:291-296. [pmid: 1056772].
Hals E. The structure of experimental in vitro lesions around silicate fillings in human teeth. Arch Oral Biol. 1975;20:283-289. [pmid: 1056771].
Hals E, Andreassen BH, Bie T. Histopathology of natural caries around silver amalgam fillings. Caries Res. 1974;8:343-358. [pmid: 4525801].
Hals E, Halse A. Electron probe microanalysis of secondary carious lesions associated with silver amalgam fillings. Acta Odontol Scand. 1975;33:149-160. [pmid: 1067717].
Hals E, Norderval IT. Histopathology of experimental in vivo caries around silicate fillings. Acta Odontol Scand. 1973;31:357-367. [pmid: 4520985].
Hals E, Simonsen LT. Histopathology of experimental in vivo caries around silver amalgam fillings. Caries Res. 1972;6:16-33. [pmid: 4500616].
Halse A, Espelid I, Tveit AB, White SC. Detection of mineral loss in approximal enamel by subtraction radiography. Oral Surg Oral Med Oral Pathol. 1994;77:177-182. [pmid: 8139837].
Halse A, White SC, Espelid I, Bjorg A. Visualization of stannous fluoride treatment of carious lesions by subtraction radiography. Oral Surg Oral Med Oral Pathol. 1990;69:378-381. [pmid: 2179803].
Hamilton ME, Coulby WM. Oral health knowledge and habits of senior elementary school students. J Public Health Dent. 1991;51:212-219. [pmid: 1941772].
Hamp SE, Johansson LA. Dental prophylaxis for youths in their late teens. I. Clinical effect of different preventive regimes on oral hygiene, gingivitis and dental caries. J Clin Periodontol. 1982;9:22-34. [pmid: 6949924].
Hamp SE, Johansson LA, Karlsson R. Clinical effects of preventive regimens for young people in their early and middle teens in relation to previous experience with dental prevention. Acta Odontol Scand. 1984;42:99-108. [pmid: 6588726].
Hamza O, Matee MI, Sultan HH. Reasons for taking radiographs in general dental practice in Dar-es-Salaam, Tanzania. Int Dent J. 1998;48:374-377. [pmid: 9779121].
Hanachowicz L. Caries prevention using a 1.2% sodium monofluorophosphate dentifrice in an aluminium oxide trihydrate base. Community Dent Oral Epidemiol. 1984;12:10-16. [pmid: 6365424].
Hancock PA, Blinkhorn AS. A comparison of the perceived and normative needs for dental care in 12-year-old children in the northwest of England. Community Dent Health. 1996;13:81-85. [pmid: 8763137].
Hand JS, Hunt RJ, Kohout FJ. Five-year incidence of tooth loss in Iowans aged 65 and older. Community Dent Oral Epidemiol. 1991;19:48-51. [pmid: 2019091].
Handelman SL, Leverett DH, Espeland M, Curzon J. Retention of sealants over carious and sound tooth surfaces. Community Dent Oral Epidemiol. 1987;15:1-5. [pmid: 3542360].
Handelman SL, Leverett DH, Espeland MA, Curzon JA. Clinical radiographic evaluation of sealed carious and sound tooth surfaces. J Am Dent Assoc. 1986;113:751-754. [pmid: 2946739].
Handelman SL, Leverett DH, Iker HP. Longitudinal radiographic evaluation of the progress of caries under sealants. J Pedod. 1985;9:119-126. [pmid: 3855997].
Handelman SL, Leverett DH, Solomon ES, Brenner CM. Use of adhesive sealants over occlusal carious lesions: radiographic evaluation. Community Dent Oral Epidemiol. 1981;9:256-259. [pmid: 7049556].
Handleman SL, Buonocore MG, Schoute PC. Progress report on the effect of a fissure sealant on bacteria in dental caries. J Am Dent Assoc. 1973;87:1189-1191. [pmid: 4521577].
Hanes CM, Myers DR, Dushku JC. The influence of practice type, region, and age on treatment recommendations for primary teeth. Pediatr Dent. 1992;14:240-245. [pmid: 1303523].
Hanes CM, Myers DR, Dushku JC, Davis HC. Gender differences in the characteristics of dental services provided for children. ASDC J Dent Child. 1992;59:437-443. [pmid: 1491082].
Hannerz H, Westerberg I. Economic assessment of a six-year project with extensive use of dental hygienists in the dental care of children: a pilot study. Community Dent Health. 1996;13:40-43. [pmid: 8634896].
Hansen BF. Clinical and roentgenologic caries detection. A comparison. Dento Maxillo Facial Radiol. 1980;9:34-36.
Hansen EK. Three-year study of cervical erosions restored with resin and dentin-bonding agent. Acta Odontol Scand. 1989;47:301-306. [pmid: 2531531].
Hard MM, Esselbaugh NC, Jacobson FL. Bone density and dental caries. J Am Diet Assoc. 1965;47:274-281. [pmid: 4378667].
Hardie JM, Thomson PL, South RJ, et al A longitudinal epidemiological study on dental plaque and the development of dental caries--interim results after two years J Dent Res 1977 56Spec No:C90-8.
Hardwick JL, Teasdale J, Bloodworth G. Caries increments over 4 years in children aged 12 at the start of water fluoridation. Br Dent J. 1982;153:217-222. [pmid: 6958287].
Hargreaves JA, Chester CG. Clinical trial among Scottish children of an anti-caries dentifrice containing 2 percent sodium monofluorophosphate. Community Dent Oral Epidemiol. 1973;1:47-57. [pmid: 4608298].
Hargreaves JA, Cleaton-Jones PE. Dental caries changes in the Scottish Isle of Lewis. Caries Res. 1990;24:137-141. [pmid: 2340544].
Harris NO, Moolenaar L, Hornberger N, Knight GH, Frew RA. Adhesive sealant clinical trial: effectiveness in a school population of the U. S. Virgin Islands. J Prev Dent. 1976;3:27-37.
Harris R. Interpretation of clinical observations. Aust Dent J. 1976;21:535-537. [pmid: 799500].
Harrison RL, Davis DW. Caries experience of Native children of British Columbia, Canada, 1980-1988. Community Dent Oral Epidemiol. 1993;21:102-107. [pmid: 8485968].
Hasegawa T, Retief DH. Quantitative microleakage of some dentinal bonding restorative systems. Dent Mater. 1993;9:114-117. [pmid: 8595839].
Haskell EW, Stanley HR, Chellemi J, Stringfellow H. Direct pulp capping treatment: a long-term follow-up. J Am Dent Assoc. 1978;97:607-612. [pmid: 281402].
Hassall DC, Holloway PJ. Levels of restorative care under capitation. Br Dent J. 1998;184:348-350. [pmid: 9599889].
Hassan FM, Farid AM. The antibacterial effect of calcium hydroxide and zinc oxide eugenol cements on carious dentine. Egypt Dent J. 1988;34:17-28. [pmid: 3165330].
Hassed SJ, Kincannon JM, Arnold GL. Clouston syndrome: An ectodermal dysplasia without significant dental findings. Am J Med Genet. 1996;61:274-276. [pmid: 8741874].
Hasselrot L. Tunnel restorations. A 3 1/2-year follow up study of Class I and II tunnel restorations in permanent and primary teeth. Swed Dent J. 1993;17:173-182. [pmid: 8291027].
Hatibovic-Kofman S, Suljak JP, Koch G. Remineralization of natural carious lesions with a glass ionomer cement. Swed Dent J. 1997;21:11-17. [pmid: 9178445].
Hatibovic-Kofman S, Wright GZ, Braverman I. Microleakage of sealants after conventional, bur, and air-abrasion preparation of pits and fissures. Pediatr Dent. 1998;20:173-176. [pmid: 9635312].
Haugejorden O. Adoption of fluoride-based caries preventive innovations in a public dental service. Community Dent Oral Epidemiol. 1988;16:5-10. [pmid: 3422620].
Haugejorden O. The construction and use of diagnostic standards for primary radiographic caries. Acta Odontol Scand. 1976;34:69-77. [pmid: 1066953].
Haugejorden O. The construction and use of diagnostic standards for radiographic caries incidence scores. Acta Odontol Scand. 1977;35:95-102. [pmid: 266830].
Haugejorden O. Proposals for standardization of terms in clinical trials of caries preventive agents and procedures. Community Dent Oral Epidemiol. 1978;6:231-232. [pmid: 363336].
Haugejorden O. A study of the methods of radiographic diagnosis of dental caries in epidemiological investigations. Acta Odontol Scand Suppl. 1974;32:1-269. [pmid: 4620124].
Haugejorden O, Lervik T, Birkeland JM, Jorkjend L. An 11-year follow-up study of dental caries after discontinuation of school-based fluoride programs. Acta Odontol Scand. 1990;48:257-263. [pmid: 2220333].
Haugejorden O, Lervik T, Riordan PJ. Comparison of caries prevalence 7 years after discontinuation of school-based fluoride rinsing or toothbrushing in Norway. Community Dent Oral Epidemiol. 1985;13:2-6. [pmid: 3855728].
Haugejorden O, Nielsen WA. Experimental study of two methods of data collection by questionnaire. Community Dent Oral Epidemiol. 1987;15:205-208. [pmid: 3476244].
Haugejorden O, Nord A. Caries incidence after topical application of varnishes containing different concentrations of sodium fluoride: 3-year results. Scand J Dent Res. 1991;99:295-300. [pmid: 1771375].
Haugejorden O, Nord A, Klock KS. Direct evidence concerning the 'major role' of fluoride dentifrices in the caries decline: A 6-year analytical cohort study. Acta Odontol Scand. 1997;55:173-180. [pmid: 9226428].
Haugejorden O, Slack GL. Progression of approximal caries in relation to radiographic scoring codes. A pilot study. Acta Odontol Scand. 1975;33:211-217. [pmid: 1067721].
Haugejorden O, Slack GL. A study of intra-examiner error associated with recording of radiographic caries at different diagnostic levels. Acta Odontol Scand. 1975;33:169-181. [pmid: 1067718].
Hausen H, Heinonen OP, Paunio I. Fluoride exposure combinations and caries in permanent dentition among Finnish children. Community Dent Oral Epidemiol. 1981;9:108-111. [pmid: 6946892].
Hawley GM, Hamilton FA, Worthington HV, et al. A 30-month study investigating the effect of adding triclosan/copolymer to a fluoride dentifrice. Caries Res. 1995;29:163-167. [pmid: 7621489].
Hayden WJ. Dental health services research utilizing comprehensive clinical databases and information technology. J Dent Educ. 1997;61:47-55. [pmid: 9024342].
Hazen SP, Chilton NW, Mumma RDJ. The problem of root caries. I. Literature review and clinical description. J Am Dent Assoc. 1973;86:137-144. [pmid: 4565266].
Heaven TJ, Firestone AR, Feagin FF. Computer-based image analysis of natural approximal caries on radiographic films. J Dent Res. Spec No. 1992;71:846-849. [pmid: 1592972].
Heaven TJ, Firestone AR, Feagin FF. Quantitative radiographic measurement of dentinal lesions. J Dent Res. 1990;69:51-54. [pmid: 2406306].
Heaven TJ, Firestone AR, Weems RA. The effect of multiple examinations on the diagnosis of approximal caries and the restoration of approximal surfaces. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 1999;87:386-391. [pmid: 10102606].
Heaven TJ, Weems RA, Firestone AR. The use of a computer-based image analysis program for the diagnosis of approximal caries from bitewing radiographs. Caries Res. 1994;28:55-58. [pmid: 8124698].
Hebel KS, Graser GN, Featherstone JD. Abrasion of enamel and composite resin by removable partial denture clasps. J Prosthet Dent. 1984;52:389-397. [pmid: 6384478].
Hedegard B. Longitudinal follow-up studies in prosthetic dentistry. Int Dent J. 1973;23:489-494. [pmid: 4587843].
Hefferren JJ. A review of approaches to the detection of dental caries. Council on Dental Materials and Devices. J Am Dent Assoc. 1973;86:1358-1364. [pmid: 4573560].
Hefferren JJ, Cooley RO, Hall JB, Olsen NH, Lyon HW. Use of ultraviolet illumination in oral diagnosis. J Am Dent Assoc. 1971;82:1353-1360. [pmid: 5280049].
Heidmann J. Inconsistencies in a nationwide caries recording system. Community Dent Oral Epidemiol. 1985;13:216-218. [pmid: 3930139].
Heidmann J, Poulsen S. Comparative three-year caries protection from an aluminum-containing and a fluoride-containing toothpaste. Caries Res. 1997;31:85-90. [pmid: 9118189].
Heidmann J, Poulsen S, Arnbjerg D, Kirkegaard E, Laurberg L. Caries development after termination of a fluoride rinsing program. Community Dent Oral Epidemiol. 1992;20:118-121. [pmid: 1623700].
Heifetz SB. Ethical considerations and study design. J Dent Res. Spec No. 1984;63:719-724. [pmid: 6586775].
Heifetz SB, Brunelle JA, Horowitz HS, Leske GS. Examiner consistency and group balance at baseline of a caries clinical trial. Community Dent Oral Epidemiol. 1985;13:82-85. [pmid: 3886274].
Heifetz SB, Driscoll WS, Creighton WE. The effect on dental caries of weekly rinsing with a neutral sodium fluoride or an acidulated phosphate-fluoride mouthwash. J Am Dent Assoc. 1973;87:364-368. [pmid: 4146249].
Heifetz SB, Horowitz HS, Driscoll WS. Effect of school water fluoridation on dental caries: results in Seagrove, NC, after eight years. J Am Dent Assoc. 1978;97:193-196. [pmid: 277589].
Heifetz SB, Horowitz HS, Driscoll WS. Two-year evaluation of a self-administered procedure for the topical application of acidulated phosphate-fluoride; final report. J Public Health Dent. 1970;30:7-12. [pmid: 4149071].
Heifetz SB, Kingman A. The impact of ethical considerations on future dental caries: clinical field trials. J Dent Res. 1980;59:1337-1340. [pmid: 6930412].
Heifetz SB, Meyers R, Kingman A. A comparison of the anticaries effectiveness of daily and weekly rinsing with sodium fluoride solutions: findings after two years. Pediatr Dent. 1981;3:17-20. [pmid: 6951146].
Heifetz SB, Proskin HM. Serendipitous results of a pilot study: precaution indicated. J Clin Dent. 1995;6:117-119. [pmid: 8694985].
Heitetz SB, Horowitz HS, Meyers RJ, Li SH. Evaluation of the comparative effectiveness of fluoride mouthrinsing, fluoride tablets, and both procedures in combination: interim findings after two years. Pediatr Dent. 1987;9:121-125. [pmid: 3475680].
Heithersay GS, Dahlstrom SW, Marin PD. Incidence of invasive cervical resorption in bleached root-filled teeth. Aust Dent J. 1994;39:82-87. [pmid: 8018064].
Helfernstein U, Steiner M. Prediction of costs in a selective caries prevention programme. Community Dent Health. 1992;9:49-55. [pmid: 1617486].
Hellden LB, Elliot A, Steffensen B, Steffensen JE. The prognosis of tunnel preparations in treatment of class III furcations. A follow-up study. J Periodontol. 1989;60:182-187. [pmid: 2724031].
Helle A. Two fissure sealants tested for retention and caries reduction in Finnish children. Proc Finn Dent Soc. 1975;71:91-95. [pmid: 1161776].
Heller KE, Reed SG, Bruner FW, Eklund SA, Burt BA. Longitudinal evaluation of sealing molars with and without incipient dental caries in a public health program. J Public Health Dent. 1995;55:148-153. [pmid: 7562727].
Hellsing G, Giblin AG, Gray CJ, Bowen WH. Absorption of a dextranase--concanavalin a conjugate on to hydroxyapatite. Arch Oral Biol. 1977;22:163-166. [pmid: 326236].
Helm S, Helm T. Caries among Danish schoolchildren in birth-cohorts 1950-78. Community Dent Oral Epidemiol. 1990;18:66-69. [pmid: 2335064].
Helminen SK, Meurman JH, Laaksonen SS. Caries reduction by a single application of a fissure sealant predicted from 5-year survey data. Proc Finn Dent Soc. 1980;76:53-55. [pmid: 7443687].
Heloe LA. Oral health status and treatment needs in a disadvantaged, rural population in Norway. Community Dent Oral Epidemiol. 1973;1:94-103. [pmid: 4153425].
Hennon DK, Stookey GK, Muhler JC. The clinical anticariogenic effectiveness of supplementary fluoride-vitamin preparations--results at the end of four years. J Dent Child. 1967;34:439-443. [pmid: 4383721].
Hennon DK, Stookey GK, Muhler JC. Prevalence and distribution of dental caries in preschool children. J Am Dent Assoc. 1969;79:1405-1414. [pmid: 5259860].
Hennon DK, Stookey GK, Muhler JC. Prophylaxis of dental caries: relative effectiveness of chewable fluoride preparations with and without added vitamins. J Pediatr. 1972;80:1018-1021. [pmid: 5026023].
Henrikson CO Iodine 125 as a radiation source for odontological roentgenology Acta Radiol Diagn (Stockh) 1967(suppl)2103569 5 89 6082981
Henrikson CO, Edward S. A roentgenologic method for registering dental caries of primary molars in preschool children. Odontol Revy. 1973;24:235-244. [pmid: 4518197].
Hess JW, Margolis FJ. The physician's role in caries prevention. Am Fam Physician. 1981;24:171-173. [pmid: 6792892].
Hewlett ER, Atchison KA, White SC, Flack V. Radiographic secondary caries prevalence in teeth with clinically defective restorations. J Dent Res. 1993;72:1604-1608. [pmid: 8254130].
Hicks MJ, Barr ES, Flaitz CM. Formocresol pulpotomies in primary molars: a radiographic study in a pediatric dentistry practice. J Pedod. 1986;10:331-339. [pmid: 2980416].
Hicks MJ, Flaitz CM. Caries formation in vitro around a fluoride-releasing pit and fissure sealant in primary teeth. ASDC J Dent Child. 1998;65:161-168. [pmid: 9668943].
Hicks MJ, Flaitz CM, Westerman GH, Blankenau RJ, Powell GL, Berg JH. Caries-like lesion initiation and progression around laser-cured sealants. Am J Dent. 1993;6:176-180. [pmid: 7803003].
Hicks MJ, Silverstone LM. Fissure sealants and dental enamel. A histological study of microleakage in vitro. Caries Res. 1982;16:353-360. [pmid: 6754080].
Hicks MJ, Silverstone LM. Internal morphology of surface zones from acid-etched caries-like lesions: a scanning electron microscopic study. J Dent Res. 1985;64:1296-1301. [pmid: 3912417].
Hicks MJ, Westerman GH, Flaitz CM, Blankenau RJ, Powell GL, Berg JH. Effects of argon laser irradiation and acidulated phosphate fluoride on root caries. Am J Dent. 1995;8:10-14. [pmid: 7546465].
Hicks TW, Davis-Burchat L, Fendley S, Jeffrey B. Infant feeding caries: Part I. A review and trial preventive project. Ont Dent. 1995;72:17-19, 22-23. [pmid: 9468954].
Hill B, Geddes DA. A photographic approach to recording pre-carious changes on teeth in situ. Med Biol Illus. 1975;25:79-88. [pmid: 1160415].
Hinding JH, Buonocore MG. The effects of varying the application protocol on the retention of pit and fissure sealant: a two-year clinical study. J Am Dent Assoc. 1974;89:127-131. [pmid: 4599143].
Hintze H. Caries behaviour in Danish teenagers: a longitudinal radiographic study. Int J Paediatr Dent. 1997;7:227-234. [pmid: 9482028].
Hintze H. Screening with conventional and digital bite-wing radiography compared to clinical examination alone for caries detection in low-risk children. Caries Res. 1993;27:499-504. [pmid: 8281566].
Hintze H, Christoffersen L, Wenzel A. In vitro comparison of Kodak Ultra-speed, Ektaspeed, and Ektaspeed Plus, and Agfa M2 Comfort dental x-ray films for the detection of caries. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 1996;81:240-244. [pmid: 8665322].
Hintze H, Wenze A. Clinical and laboratory radiographic caries diagnosis. A study of the same teeth. Dento Maxillo Facial Radiol. 1996;25:115-118.
Hintze H, Wenzel A. Clinically undetected dental caries assessed by bitewing screening in children with little caries experience. Dento Maxillo Facial Radiol. 1994;23:19-23.
Hintze H, Wenzel A, Danielsen B, Nyvad B. Reliability of visual examination, fibre-optic transillumination, and bite-wing radiography, and reproducibility of direct visual examination following tooth separation for the identification of cavitated carious lesions in contacting approximal surfaces. Caries Res. 1998;32:204-209. [pmid: 9577986].
Hintze H, Wenzel A, Jones C. In vitro comparison of D- and E-speed film radiography, RVG, and visualix digital radiography for the detection of enamel approximal and dentinal occlusal caries lesions. Caries Res. 1994;28:363-367. [pmid: 8001059].
Hintze H, Wenzel A, Larsen MJ. Stereomicroscopy, film radiography, microradiography and naked-eye inspection of tooth sections as validation for occlusal caries diagnosis. Caries Res. 1995;29:359-363. [pmid: 8521437].
Hirschfield RE. Control of decalcification by use of fluoride mouthrinse. ASDC J Dent. 1978;45:458-460.
Hirschfield RE, Johnston LE. Decalcification under orthodontic bands. Angle Orthod. 1974;44:218-221. [pmid: 4527732].
Hochberg Z, Weisman Y. Calcitriol-resistant rickets due to vitamin D receptor defects. Trends Endocrinol Metab. 1995;6:216-220. [pmid: 18406705].
Hodge H, Buchanan M, Jones J, O'Donnell P. The evaluation of the infant dental health education programme developed in Sefton. Community Dent Health. 1985;2:175-185. [pmid: 3864517].
Hodge HC, Holloway PJ, Davies TG, Worthington HV. Caries prevention by dentifrices containing a combination of sodium monofluorophosphate and sodium fluoride. Report of a 3-year clinical trial. Br Dent J. 1980;149:201-204. [pmid: 7004469].
Hodges DJ, Mangum FI, Ward MT. Relationship between gap width and recurrent dental caries beneath occlusal margins of amalgam restorations. Community Dent Oral Epidemiol. 1995;23:200-204. [pmid: 7587139].
Hogan JI. Fluoride tablet distribution from maternal and child health centres: a feasibility study. Health Visit. 1982;55:60-63. [pmid: 6916739].
Holan G, Chosack A, Eidelman E. Clinical evaluation of Class II combined amalgam-composite restorations in primary molars after 6 to 30 months. ASDC J Dent Child. 1996;63:341-345. [pmid: 8958346].
Holbrook WP, de Soet JJ, de Graaff J. Prediction of dental caries in pre-school children. Caries Res. 1993;27:424-430. [pmid: 8242681].
Holland TJ, Whelton H, O'Mullane DM, Creedon P. Evaluation of a fortnightly school-based sodium fluoride mouthrinse 4 years following its cessation. Caries Res. 1995;29:431-434. [pmid: 8556744].
Hollender L. Decision making in radiographic imaging. J Dent Educ. 1992;56:834-843. [pmid: 1487586].
Hollender L, Koch G. Effect of local application of fluoride on initial demineralization of buccal surface of maxillary incisors. Clinical assessment from colour slides. Sven Tandlak Tidskr. 1976;69:1-5. [pmid: 769226].
Hollender L, Koch G. Influence of topical application of fluoride on rate of progress of carious lesions in children. A long-term roentgenographic follow-up. Odontol Revy. 1969;20:37-41. [pmid: 5256524].
Hollender L, Koch G. Roentgenographic partial recording of caries in assessment of effect of prophylactic measures. Odontol Revy. 1969;20:267-282. [pmid: 5262281].
Hollister MC, Weintraub JA. The association of oral status with systemic health, quality of life, and economic productivity. J Dent Educ. 1993;57:901-912. [pmid: 8263237].
Holloway PJ, Blinkhorn AS, Hassall DC, Mellor AC, Worthington HV. An assessment of capitation in the General Dental Service Contract. 1. The level of caries and its treatment in regularly attending children and adolescents. Br Dent J. 1997;182:418-423. [pmid: 9217338].
Holloway PJ, Worthington HV. The responsibility of the institutional review board in the development of field studies. J Dent Res. 1980;59:1258-1261. [pmid: 6930398].
Holloway PJ, Worthington HV. Sodium fluoride or sodium monofluorophosphate? A critical view of a meta-analysis on their relative effectiveness in dentifrices. Am J Dent. Spec No. 1993;6:S55-58. [pmid: 7488357].
Holm AK. Dental health in a group of Swedish 8-year-olds followed since the age of 3. Community Dent Oral Epidemiol. 1978;6:71-77. [pmid: 275020].
Holm AK. Effect of a fluoride varnish (Duraphat*) in preschool children. Community Dent Oral Epidemiol. 1979;7:241-245. [pmid: 295702].
Holm GB, Holst K, Mejare I. The caries-preventive effect of a fluoride varnish in the fissures of the first permanent molar. Acta Odontol Scand. 1984;42:193-197. [pmid: 6594021].
Holmen L, Mejare I, Malmgren B, Thylstrup A. The effect of regular professional plaque removal on dental caries in vivo. A polarized light and scanning electron microscope study. Caries Res. 1988;22:250-256. [pmid: 3165719].
Holmen L, Thylstrup A, Featherstone JD, Fredebo L, Shariati M. A scanning electron microscopic study of surface changes during development of artificial caries. Caries Res. 1985;19:11-21. [pmid: 3856482].
Holst A. A 3-year clinical evaluation of Ketac-Silver restorations in primary molars. Swed Dent J. 1996;20:209-214. [pmid: 9065982].
Holst A, Brannstrom M. Restoration of small proximal dentin lesions with the tunnel technique. A 3-year clinical study performed in Public Dental Service clinics. Swed Dent J. 1998;22:143-148. [pmid: 9850556].
Holst A, Braune K. Dental assistants' ability to select caries risk-children and to prevent caries. Swed Dent J. 1994;18:243-249. [pmid: 7725238].
Holst A, Martensson I, Laurin M. Identification of caries risk children and prevention of caries in pre-school children. Swed Dent J. 1997;21:185-191. [pmid: 9472147].
Holst D. A comparative radiographic investigation of caries prevalence in Danish schoolchildren. Community Dent Oral Epidemiol. 1976;4:254-258. [pmid: 1069615].
Holt RA, Nordquist RE. Effect of resin/fluoride and holmium:YAG laser irradiation on the resistance to the formation of caries-like lesions. J Prosthodont. 1997;6:11-19. [pmid: 9497764].
Holt RD. 'A comparison of bitewing radiography and interdental transillumination as adjuncts to the clinical identification of approximal caries in posterior teeth'. Br Dent J. 1988;164.
Holt RD. The pattern of caries in a group of 5-year-old children and in the same cohort at 9 years of age. Community Dent Health. 1995;12:93-99. [pmid: 7648418].
Holt RD, Abdulkarim NT, Rule DC. An evaluation of bitewing radiographs in 5-year-old children. Community Dent Health. 1990;7:389-394. [pmid: 2292069].
Holt RD, Azevedo MR. Fibre optic transillumination and radiographs in diagnosis of approximal caries in primary teeth. Community Dent Health. 1989;6:239-247. [pmid: 2679987].
Holt RD, Morris CE, Winter GB, Downer MC. Enamel opacities and dental caries in children who used a low fluoride toothpaste between 2 and 5 years of age. Int Dent J. 1994;44:331-341. [pmid: 7822059].
Holt RD, Winter GB, Fox B, Askew R. Effects of dental health education for mothers with young children in London. Community Dent Oral Epidemiol. 1985;13:148-151. [pmid: 3860335].
Holtta P, Alaluusua S. Effect of supervised use of a fluoride toothpaste on caries incidence in pre-school children. Int J Paediatr Dent. 1992;2:145-149. [pmid: 1304804].
Holund U. Effect of a nutrition education program, 'learning by teaching', on adolescents' knowledge and beliefs. Community Dent Oral Epidemiol. 1990;18:61-65. [pmid: 2335063].
Honkala E, Kolmakow S, Nyyssonen V, Kuzmina E, Vasina S. Background factors affecting dental caries in permanent teeth of Finnish and Soviet children. ASDC J Dent Child. 1992;59:28-33. [pmid: 1531661].
Honkala E, Kolmakow S, Sainio P, Olshevsky VA, Hurskainen K. Caries experience and treatment need among adults responding to an invitation for dental examination and treatment in two Karelian communities in Russia. Acta Odontol Scand. 1996;54:171-175. [pmid: 8811139].
Hood CA, Hunter ML, Kingdon A. Demographic characteristics, oral health knowledge and practices of mothers of children aged 5 years and under referred for extraction of teeth under general anaesthesia. Int J Paediatr Dent. 1998;8:131-136. [pmid: 9728098].
Hoppenbrouwers PM, Driessens FC, Borggreven JM. The vulnerability of unexposed human dental roots to demineralization. J Dent Res. 1986;65:955-958. [pmid: 3011869].
Horiot JC, Schraub S, Bone MC, et al. Dental preservation in patients irradiated for head and neck tumours: A 10-year experience with topical fluoride and a randomized trial between two fluoridation methods. Radiother Oncol. 1983;1:77-82. [pmid: 6680214].
Horowitz AM, Suomi JD, Peterson JK, Lyman BA. Effects of supervised daily dental plaque removal by children: II. 24 months' results. J Public Health Dent. 1977;37:180-188. [pmid: 268433].
Horowitz AM, Suomi JD, Peterson JK, Voglesong RH, Mathews BL. Effects of supervised daily dental plaque removal by children: first-year results. J Public Health Dent. 1976;36:193-200. [pmid: 1065757].
Horowitz HS. Clinical trials of preventives for dental caries. J Public Health Dent. 1972;32:229-233. [pmid: 4564805].
Horowitz HS. Critique of Kingman's methods of projecting long-term relative efficacy of products exhibiting small short-term efficacy. Am J Dent. Spec No. 1993;6:S51-54. [pmid: 7488356].
Horowitz HS. The effect on dental caries of topically applied acidulated phosphate-fluoride: results after one year. J Oral Ther Pharmacol. 1968;4:286-291. [pmid: 4384484].
Horowitz HS. Effect on dental caries of topically applied acidulated phosphate-fluoride: results after two years. J Am Dent Assoc. 1969;78:568-572. [pmid: 4387801].
Horowitz HS. Ethical considerations of study participants in dental caries clinical trials. Community Dent Oral Epidemiol. 1976;4:43-50. [pmid: 767047].
Horowitz HS. Evaluation of the effect of interexaminer reliability in clinical trials of dental caries prevention. Community Dent Oral Epidemiol. 1983;11:384-385. [pmid: 6360522].
Horowitz HS. The halcyon days of clinical field studies of dental caries prevention, 1960-1980. J Dent Res. 1998;77:1380-1383. [pmid: 9649165].
Horowitz HS. Measurement and expression of treatment effects in caries clinical trials. J Dent Res. Spec No. 1984;63:709-714. [pmid: 6427311].
Horowitz HS, Baume LJ, Dirks OB, Davies GN, Slack GL. Principal requirements for controlled clinical trials of caries preventive agents and procedures. Int Dent J. 1973;23:506-529. [pmid: 4594237].
Horowitz HS, Creighton WE, McClendon BJ. The effect on human dental caries of weekly oral rinsing with a sodium fluoride mouthwash: a final report. Arch Oral Biol. 1971;16:609-616. [pmid: 4397601].
Horowitz HS, Heifetz SB. Clinical tests of dentifrices. Pharmacol Ther Dent. 1975;2:235-244.
Horowitz HS, Heifetz SB. Evaluation of topical applications of stannous fluoride to teeth of children born and reared in a fluoridated community: interim report. J Dent Child. 1967;34:290-295. [pmid: 4382434].
Horowitz HS, Heifetz SB, Law FE. Effect of school water fluoridation on dental caries: final results in Elk Lake, Pa, after 12 years. J Am Dent Assoc. 1972;84:832-838. [pmid: 4400471].
Horowitz HS, Heifetz SB, Law FE, Driscoll WS. School fluoridation studies in Elk Lake, Pennsylvania, and Pike County, Kentucky--results after eight years. Am J Public Health Nations Health. 1968;58:2240-2250. [pmid: 4387263]. [pmcid: 1229128].
Horowitz HS, Heifetz SB, McCune RJ. The effectiveness of an adhesive sealant in preventing occlusal caries: findings after two years in Kalispell, Montana. J Am Dent Assoc. 1974;89:885-890. [pmid: 4153720].
Horowitz HS, Heifetz SB, Meyers RJ, Driscoll WS, Korts DC. Evaluation of a combination of self-administered fluoride procedures for the control of dental caries in a nonfluoride area: findings after four years. J Am Dent Assoc. 1979;98:219-223. [pmid: 311366].
Horowitz HS, Heifetz SB, Meyers RJ, Driscoll WS, Korts DC. Evaluation of a combination of self-administered fluoride procedures for control of dental caries in a non-fluoride area: findings after 2 years. Caries Res. 1977;11:178-185. [pmid: 265758].
Horowitz HS, Heifetz SB, Meyers RJ, Driscoll WS, Li SH. A program self-administered fluorides in a rural school system. Community Dent Oral Epidemiol. 1980;8:177-183. [pmid: 6936117].
Horowitz HS, Heifetz SB, Poulsen S. Retention and effectiveness of a single application of an adhesive sealant in preventing occlusal caries: final report after five years of a study in Kalispell, Montana. J Am Dent Assoc. 1977;95:1133-1139. [pmid: 271677].
Horowitz HS, Lucye HS. A clinical study of stannous fluoride in a prophylaxis paste and as a solution. J Oral Ther Pharmacol. 1966;3:17-25. [pmid: 5334852].
Horowitz HS, Meyers RJ, Heifetz SB, Driscoll WS, Li SH. Combined fluoride, school-based program in a fluoride-deficient area: results of an 11-year study. J Am Dent Assoc. 1986;112:621-625. [pmid: 3486893].
Horowitz HS, Peterson JK. Evaluation of examiner variability and the use of radiographs in determining the efficacy of community fluoridation. Arch Oral Biol. 1966;11:867-875. [pmid: 4381080].
Horowitz HS, Thompson MB. Evaluation of a stannous fluoride dentifrice for use in dental public health programs. 3. Supplementary findings. J Am Dent Assoc. 1967;74:979-986. [pmid: 4381425].
Horsted P, Sandergaard B, Thylstrup A, El Attar K, Fejerskov O. A retrospective study of direct pulp capping with calcium hydroxide compounds. Endod Dent Traumatol. 1985;1:29-34. [pmid: 3858095].
Horton PS, Sippy FH, Kerber PE, Paule CL. Analysis of interpretations of full-mouth and panoramic surveys. Oral Surg Oral Med Oral Pathol. 1977;44:468-475. [pmid: 269343].
Horup N, Melsen B, Terp S. Relationship between malocclusion and maintenance of teeth. Community Dent Oral Epidemiol. 1987;15:74-78. [pmid: 3471380].
Hoszek A, Pierreville F, Schittek M, Ericson D. Fissure penetration and antibacterial effect in vitro of a glass ionomer cement containing chlorhexidine gluconate. Swed Dent J. 1998;22:133-141. [pmid: 9850555].
Hotz PR. Experimental secondary caries around amalgam, composite and glass ionomer cement fillings in human teeth. SSO Schweiz Monatsschr Zahnheilkd. 1979;89:965-986. [pmid: 293928].
Houpt M, Eidelman E, Shey Z, Fuks A, Chosack A, Shapira J. Occlusal composite restorations: 4-year results. J Am Dent Assoc. 1985;110:351-353. [pmid: 3158684].
Houpt M, Fuks A, Eidelman E, Shey Z. Composite/sealant restoration: 6 1/2-year results. Pediatr Dent. 1988;10:304-306. [pmid: 3272956].
Houpt M, Fuks A, Shapira J, Chosack A, Eidelman E. Autopolymerized versus light-polymerized fissure sealant. J Am Dent Assoc. 1987;115:55-56. [pmid: 3301981].
Houpt M, Sheykholeslam Z. The clinical effectiveness of Delton fissure sealant after one year. ASDC J Dent Child. 1978;45:130-132. [pmid: 350918].
Houwink B, Dirks OB, Kwant GW. A nine-year study of topical application with stannous fluoride in identical twins and the caries experience five years after ending the applications. Caries Res. 1974;8:27-38. [pmid: 4525329].
Howat AP. A comparison of the sensitivity of caries diagnostic criteria. Caries Res. 1981;15:331-337. [pmid: 6940668].
Howat AP, Brandt RS. Discriminatory ability of caries diagnosis from bitewing radiographs in caries prophylactic trials. Community Dent Oral Epidemiol. 1980;8:184-188. [pmid: 7006897].
Howat AP, Hollaway PJ, Davies TG. Caries prevention by daily supervised use of a MFP gel dentifrice. Report of a 3-year clinical trial. Br Dent J. 1978;145:233-235. [pmid: 359013].
Howat AP, Holloway PJ. The effect of diagnostic criteria on the efficiency of experimental clinical trials. J Dent Res. Spec No. 1977;56:C116-122. [pmid: 344367].
Howat AP, Holloway PJ, Brandt RS. The effect of diagnostic criteria on the sensitivity of dental epidemiological data. Caries Res. 1981;15:117-123. [pmid: 6937259].
Howe MJ, Shapiro S, Aldridge WC. Reduction in DMFT amongst Tulsa, Oklahoma children: 1955-1979. Part 1. A profile of dental health of children in the city of Tulsa. J Okla Dent Assoc. 1981;72:15-20. [pmid: 6943311].
Hse KM, Wei SH. Clinical evaluation of compomer in primary teeth: 1-year results. J Am Dent Assoc. 1997;128:1088-1096. [pmid: 9260418].
Huang JS. Vertical root fracture. Oral Surg Oral Med Oral Pathol. 1993;76:129-130. [pmid: 8351110].
Hubbard MJ. Correlated light and scanning electron microscopy of artificial carious lesions. J Dent Res. 1982;61:14-19. [pmid: 6948009].
Hughes DO, Hembree JHJ, Weber FN. Preparations to prevent enamel decalcification during orthodontic treatment compared. An in vitro study. Am J Orthod. 1979;75:416-420. [pmid: 285617].
Hugoson A, Koch G, Bergendal T, et al. Oral health of individuals aged 3-80 years in Jonkoping, Sweden, in 1973 and 1983. II. A review of clinical and radiographic findings. Swed Dent J. 1986;10:175-194. [pmid: 3492058].
Hugoson A, Koch G, Bergendal T, Laurell L, Lundgren D. Caries prevalence and distribution in individuals aged 20-80 years in Jonkoping, Sweden, 1973 and 1983. Swed Dent J. 1988;12:133-140. [pmid: 3264625].
Hugoson A, Koch G, Hallonsten AL. Caries prevalence and distribution in individuals aged 3-20 years in Jonkoping, Sweden, 1973, 1978 and 1983. Swed Dent J. 1988;12:125-132. [pmid: 3264624].
Huizinga ED, Ruben J, Arends J. Effect of an antimicrobial-containing varnish on root demineralisation in situ. Caries Res. 1990;24:130-132. [pmid: 2187615].
Hujoel PP. Design and analysis issues in split mouth clinical trials. Community Dent Oral Epidemiol. 1998;26:85-86. [pmid: 9645400].
Hujoel PP, Isokangas PJ, Tiekso J, et al. A re-analysis of caries rates in a preventive trial using Poisson regression models. J Dent Res. 1994;73:573-579. [pmid: 8120223].
Hujoel PP, Makinen KK, Bennett CA, et al. The optimum time to initiate habitual xylitol gum-chewing for obtaining long-term caries prevention. J Dent Res. 1999;78:797-803. [pmid: 10096456].
Hujoel PP, Powell LV, Kiyak HA. The effects of simple interventions on tooth mortality: findings in one trial and implications for future studies. J Dent Res. 1997;76:867-874. [pmid: 9126183].
Hull PS, Worthington HV, Clerehugh V, Tsirba R, Davies RM, Clarkson JE. The reasons for tooth extractions in adults and their validation. J Dent. 1997;25:233-237. [pmid: 9175351].
Hung TW, Richardson AS. Clinical evaluation of glass ionomer-silver cermet restorations in primary molars: one year results. J Can Dent Assoc. 1990;56:239-240. [pmid: 2110027].
Hunt DR, Makinson OF. Transmission illumination of teeth. A system for operative dentistry procedures. Aust Dent J. 1988;33:280-287. [pmid: 3252779].
Hunt RJ, Fann SJ, Kantor ML, Morris AL. Assessing dental practice quality by evaluating radiology items. J Public Health Dent. 1992;52:264-268. [pmid: 1404071].
Huntington E. Increasing the sensitivity of caries clinical trials by applying logistic modelling to specific teeth. Community Dent Oral Epidemiol. 1985;13:264-267. [pmid: 3902345].
Hurlburt CE, Wuehrmann AH. Comparison of interproximal carious lesion detection in panoramic and standard intraoral radiography. J Am Dent Assoc. 1976;93:1154-1158. [pmid: 1069793].
Hutton J, Koulourides T, Borden L. Evaluation of cariostatic disciplines for postradiation caries. Caries Res. 1982;16:390-397. [pmid: 6958372].
Huysmans MC, Hintze H, Wenzel A. Effect of exposure time on in vitro caries diagnosis using the Digora system. Eur J Oral Sci. 1997;105:15-20. [pmid: 9085024].
Huysmans MC, Longbottom C, Hintze H, Verdonschot EH. Surface-specific electrical occlusal caries diagnosis: reproducibility, correlation with histological lesion depth, and tooth type dependence. Caries Res. 1998;32:330-336. [pmid: 9701657].
Huysmans MC, Longbottom C, Pitts N. Electrical methods in occlusal caries diagnosis: An in vitro comparison with visual inspection and bite-wing radiography. Caries Res. 1998;32:324-329. [pmid: 9701656].
Huysmans MC, Longbottom C, Pitts NB, Los P, Bruce PG. Impedance spectroscopy of teeth with and without approximal caries lesions--an in vitro study. J Dent Res. 1996;75:1871-1878. [pmid: 9003234].
Huysmans MC, Verdonschot EH, Rondel P. Electrical conductance and electrode area on sound smooth enamel in extracted teeth. Caries Res. 1995;29:88-93. [pmid: 7728834].
Hyde EJ. Caries-inhibiting action of three different topically-applied agents on incipient lesions in newly erupted teeth: results after 24 months. J Can Dent Assoc. 1973;39:189-193. [pmid: 4569193].
Hyman J, Bakker V. Xeroradiographic detection of tooth and bone pathology. Oral Surg Oral Med Oral Pathol. 1979;47:482-484. [pmid: 286267].
Hypothetical protocol: clinical field trial title: a comparative study of sealants, amalgam restorations and fluoride rinsing of teeth on the progression and prevention of carious lesions. J Dent Res. 1980;59:1240-1242. [pmid: 6993512].
Ibsen RL. Use of a filled diacrylate as fissure sealant: one-year clinical study. J Am Soc Prev Dent. 1973;3:60-65. [pmid: 4620678].
Ie YL, Verdonschot EH. Performance of diagnostic systems in occlusal caries detection compared. Community Dent Oral Epidemiol. 1994;22:187-191. [pmid: 8070247].
Ie YL, Verdonschot EH, Schaeken MJ, van't Hof MA. Electrical conductance of fissure enamel in recently erupted molar teeth as related to caries status. Caries Res. 1995;29:94-99. [pmid: 7728835].
Ignelzi MAJ, Felds HW, White RP, Bergenholtz G, Booth FA. Intracoronal radiolucencies within unerupted teeth: Case report and review of literature. Oral Surg Oral Med Oral Pathol. 1990;70:214-220. [pmid: 2290652].
Iijima Y, Takagi O, Duschner H, Ruben J, Arends J. Influence of nail varnish on the remineralization of enamel single sections assessed by microradiography and confocal laser scanning microscopy. Caries Res. 1998;32:393-400. [pmid: 9701665].
Iijima Y, Takagi O, Ruben J, Arends J. In vitro remineralization of in vivo and in vitro formed enamel lesions. Caries Res. 1999;33:206-213. [pmid: 10207196].
Imfeld T, Schmid R, Lutz F, Guggenheim B. Cariogenicity of Milchschnitte (Ferrero GmbH) and apple in program-fed rats. Caries Res. 1991;25:352-358. [pmid: 1747885].
Imfeld TN. Clinical caries studies with polyalcohols. A literature review. Schweiz Monatsschr Zahnmed. 1994;104:941-945. [pmid: 8091172].
Imfeld TN, Steiner M, Menghini GD, Marthaler TM. Prediction of future high caries increments for children in a school dental service and in private practice. J Dent Educ. 1995;59:941-944. [pmid: 7490375].
Inaba D, Takagi O, Arends J. A computer-assisted videodensitometric method to visualize mineral distributions in in vitro and in vivo formed root caries lesions. Eur J Oral Sci. 1997;105:74-80. [pmid: 9085032].
Infante PF, Gillespie GM. Dental caries experience in the deciduous dentition of rural Guatemalan children ages 6 months to 7 years. J Dent Res. 1976;55:951-957. [pmid: 1069776].
Ingers G, Cromvik U, Gleerup A, Ronnerman A. The effect on space conditions of unilateral grinding of carious proximal surfaces of primary molars--a longitudinal study. ASDC J Dent Child. 1982;49:30-34. [pmid: 6948833].
Irigoyen M, Szpunar S. Dental caries status of 12-year-old students in the state of Mexico. Community Dent Oral Epidemiol. 1994;22:311-314. [pmid: 7813183].
Is chewing gum good for teeth?. Drug Ther Bull. 1992;30:23-24. [pmid: 1591992].
Isler SL, Doline SL, Ruff J. Interproximal caries inhibition in a pedodontic practice: a seven-year retrospective study. J N J Dent Assoc. 1982;53:49-58. [pmid: 6955458].
Ismail A, Brodeur JM, Gagnon P, et al. Restorative treatments received by children covered by a universal, publicly financed, dental insurance plan. J Public Health Dent. 1997;57:11-18. [pmid: 9150059].
Ismail AI. Clinical diagnosis of precavitated carious lesions. Community Dent Oral Epidemiol. 1997;25:13-23. [pmid: 9088688].
Ismail AI, Gagnon P. A longitudinal evaluation of fissure sealants applied in dental practices. J Dent Res. 1995;74:1583-1590. [pmid: 7560420].
Ismail AI, King W, Clark DC. An evaluation of the Saskatchewan pit and fissure sealant program: a longitudinal followup. J Public Health Dent. 1989;49:206-211. [pmid: 2810215].
Isogangas P, Makinen KK, Tiekso J, Alanen P. Long-term effect of xylitol chewing gum in the prevention of dental caries: a follow-up 5 years after termination of a prevention program. Caries Res. 1993;27:495-498. [pmid: 8281565].
Isokangas P. Xylitol chewing gum in caries prevention. A longitudinal study on Finnish school children. Proc Finn Dent Soc. 1987;83 (suppl) 1:1-117. [pmid: 3685009].
Isokangas P, Alanen P, Tiekso J. The clinician's ability to identify caries risk subjects without saliva tests--a pilot study. Community Dent Oral Epidemiol. 1993;21:8-10. [pmid: 8432109].
Isokangas P, Alanen P, Tiekso J, Makinen KK. Xylitol chewing gum in caries prevention: a field study in children. J Am Dent Assoc. 1988;117:315-320. [pmid: 3166474].
Isokangas P, Tenovuo J, Soderling E, Mannisto H, Makinen KK. Dental caries and mutans streptococci in the proximal areas of molars affected by the habitual use of xylitol chewing gum. Caries Res. 1991;25:444-448. [pmid: 1810656].
Isokangas P, Tiekso J, Alanen P, Makinen KK. Long-term effect of xylitol chewing gum on dental caries. Community Dent Oral Epidemiol. 1989;17:200-203. [pmid: 2758793].
Isotupa KP, Gunn S, Chen CY, Lopatin D, Makinen KK. Effect of polyol gums on dental plaque in orthodontic patients. Am J Orthod Dentofacial Orthop. 1995;107:497-504. [pmid: 7733059].
Ito K, Murai S. Root resorption associated with hydroxyapatite particles: a case report. Quintessence Int. 1995;26:377-383. [pmid: 8602416].
Itthagarun A, Wei SH. Analysis of fluoride ion concentrations and in vitro fluoride uptake from different commercial dentifrices. Int Dent J. 1996;46:357-361. [pmid: 9147125].
Iwaku M, Inokoshi S, Hosoda H, Fusayama T. Conservative dentistry with a caries detector and a chemically adhesive composite. A longitudinal study of a new system. Br Dent J. 1983;155:19-22. [pmid: 6577880].
Jackson D. Controlled clinical trials and caries prevention. Br Dent J. 1974;137:425-429. [pmid: 4155312].
Jackson D, Burch PR. Dental caries as a degenerative disease. Gerontologia. 1969;15:203-216. [pmid: 5772173].
Jackson D, Goward PE, Morrell GV. Fluoridation in Leeds. A clinical survey of 5-year-old children. Br Dent J. 1980;149:231-234. [pmid: 6932900].
Jackson D, Gravely JF, Pinkham IO. Fluoridation in Cumbria. A clinical study. Br Dent J. 1975;139:319-322. [pmid: 1058010].
Jackson D, James PM, Thomas FD. Fluoridation in Anglesey 1983: a clinical study of dental caries. Br Dent J. 1985;158:45-49. [pmid: 3855636].
Jackson RD, Kelly SA, Katz BP, Hull JR, Stookey GK. Dental fluorosis and caries prevalence in children residing in communities with different levels of fluoride in the water. J Public Health Dent. 1995;55:79-84. [pmid: 7643331].
Jacob LS, Flaitz CM, Nichols CM, Hicks MJ. Role of dentinal carious lesions in the pathogenesis of oral candidiasis in HIV infection. J Am Dent Assoc. 1998;129:187-194. [pmid: 9495050].
James PM, Anderson RJ, Beal JF, Bradnock G. A 3-year clinical trial of the effect on dental caries of a dentifrice containing 2% sodium monoflurophosphate. Community Dent Oral Epidemiol. 1977;5:67-72. [pmid: 321181].
Janhom A, van der Stelt PF, van Ginkel FC, Geraets WG. Effect of noise on the compressibility and diagnostic accuracy for caries detection of digital bitewing radiographs. Dento Maxillo Facial Radiol. 1999;28:6-12.
Jansma J, Vissink A, Spijkervet FKL, et al. Protocol for the prevention and treatment of oral sequelae resulting from head and neck radiation therapy. Cancer. 1992;70:2171-2180. [pmid: 1394048].
Jara L, Ondarza A, Blanco R, Rivera L. Composition of the parotid saliva in Chilean children with Down's syndrome. Arch Biol Med Exp (Santiago). 1991;24:57-60. [pmid: 1845018].
Jean-Baptiste M. Caries prevention during pregnancy: results of 30-month study. J Nurse Midwifery. 1999;44:164-165. [pmid: 10328695].
Jenkins GN, Edgar WM. The effect of daily gum-chewing on salivary flow rates in man. J Dent Res. 1989;68:786-790. [pmid: 2715471].
Jenkins S, Addy M, Newcombe R. Evaluation of a mouthrinse containing chlorhexidine and fluoride as an adjunct to oral hygiene. J Clin Periodontol. 1993;20:20-25. [pmid: 8421111].
Jensen ME, Kohout F. The effect of a fluoridated dentifrice on root and coronal caries in an older adult population. J Am Dent Assoc. 1988;117:829-832. [pmid: 3204243].
Jensen ME, Wefel JS, Triolo PT, Hammesfahr PD. Effects of a fluoride-releasing fissure sealant on artificial enamel caries. Am J Dent. 1990;3:75-78. [pmid: 2076228].
Jerrell RG, Bennett CG. Utilization of sealants by practicing pedodontists. J Pedod. 1984;8:378-386. [pmid: 6239024].
Jessee SA, Makins SR, Bretz WA. Accuracy of proximal caries depth determination using two intraoral film speeds. Gen Dent. 1999;47:88-93. [pmid: 10321157].
Johansen E, Olsen TO. Topical fluorides in the prevention and arrest of dental caries. In: Continuing Evalu1214ation of the Use of Fluorides. Boulder, Colo.: Westview Press. 1979; 11) W3 A101S. 1977;v.11:pp. ;:61-110.
Johansen JR, Gjermo P, Eriksen HM. Effect of 2-years' use of chlorhexidine-containing dentifrices on plaque, gingivitis, and caries. Scand J Dent Res. 1975;83:288-292. [pmid: 1101363].
Johnsen DC. Response to Horowitz: research issues in early childhood caries. Community Dent Oral Epidemiol. 1998;26:82-83. [pmid: 9671203].
Johnsen DC. The role of the pediatrician in identifying and treating dental caries. Pediatr Clin North Am. 1991;38:1173-1181. [pmid: 1886741].
Johnsen DC, Schubot D, Bhat M, Jones PK. Caries pattern identification in primary dentition: a comparison of clinician assignment and clinical analysis groupings. Pediatr Dent. 1993;15:113-115. [pmid: 8327361].
Johnson AR. The early carious lesion of enamel. J Oral Pathol. 1975;4:128-157. [pmid: 810551].
Johnson MF. Comparative efficacy of NaF and SMFP dentifrices in caries prevention: a meta-analytic overview. Caries Res. 1993;27:328-336. [pmid: 8402811].
Johnson NW. The problem of dental caries. Practitioner. 1969;202:49-58. [pmid: 5801940].
Johnson NW, Poole DF, Tyler JE. Factors affecting the differential dissolution of human enamel in acid and EDTA. A scanning electron microscope study. Arch Oral Biol. 1971;16:385-396. [pmid: 4996466].
Johnston DW, Grainger RM, Ryan RK. The decline of dental caries in Ontario school children. J Can Dent Assoc. 1986;52:411-417. [pmid: 3516345].
Johnston DW, Lewis DW. Three-year randomized trial of professionally applied topical fluoride gel comparing annual and biannual applications with/without prior prophylaxis. Caries Res. 1995;29:331-336. [pmid: 8521432].
Jokstad A, Mjor IA. Ten years' clinical evaluation of three luting cements. J Dent. 1996;24:309-315. [pmid: 8916643].
Jones C, Taylor G, Woods K, Whittle G, Evans D, Young P. Jarman underprivileged area scores, tooth decay and the effect of water fluoridation. Community Dent Health. 1997;14:156-160. [pmid: 9332040].
Jones JA. Root caries: prevention and chemotherapy. Am J Dent. 1995;8:352-357. [pmid: 8695015].
Jones RB. Continuity of care in a county dental public health center. J Public Health Dent. 1983;43:145-151. [pmid: 6576171].
Jones RR, Cleaton-Jones P. Depth and area of dental erosions, and dental caries, in bulimic women. J Dent Res. 1989;68:1275-1278. [pmid: 2632616].
Jones S. Fluoride: spanning the health divide. Nurs Stand. 1992;7:36-39. [pmid: 1476885].
Jones SJ. Morphology of calculus formation on the human tooth surface. Proc R Soc Med. 1972;65:903-905. [pmid: 5085102]. [pmcid: 1644655].
Jones SJ, Boyde A. Scanning microscopic observations on dental caries. Scanning Microsc. 1987;1:1991-2002. [pmid: 3433076].
Jordan HV. A systematic approach to antibiotic control of dental caries. J Can Dent Assoc. 1973;39:703-708. [pmid: 4583360].
Jordan HV, Hammond BF. Filamentous bacteria isolated from human root surface caries. Arch Oral Biol. 1972;17:1333-1342. [pmid: 4627234].
Jordan RE, Suzuki M, Skinner DH. Indirect pulp-capping of carious teeth with periapical lesions. J Am Dent Assoc. 1978;97:37-43. [pmid: 277573].
Joshi A, Douglass CW, Feldman H, Mitchell P, Jette A. Consequences of success: do more teeth translate into more disease and utilization?. J Public Health Dent. 1996;56:190-197. [pmid: 8906702].
Joshi A, Douglass CW, Jette A, Feldman H. The distribution of root caries in community-dwelling elders in New England. J Public Health Dent. 1994;54:15-23. [pmid: 8164187].
Joshipura KJ, Kent RL, DePaola PF. Gingival recession: intra-oral distribution and associated factors. J Periodontol. 1994;65:864-871. [pmid: 7990024].
Joyston-Bechal S, Hayes K, Davenport ES, Hardie JM. Caries incidence, mutans stsreptococci and loctobacilli in irradiated patients during a 12-month preventive programme using chlorhexidine and fluoride. Caries Res. 1992;26:384-390. [pmid: 1468104].
Kaffe I, Gordon M, Laufer B, Littner MM. Detection of proximal carious lesions: two-film versus four-film bitewing radiography. Oral Surg Oral Med Oral Pathol. 1984;57:567-571. [pmid: 6587305].
Kahnberg KE. Intra-alveolar transplantation. I. A 10-year follow-up of a method for surgical extrusion of root fractured teeth. Swed Dent J. 1996;20:165-172. [pmid: 9000325].
Kailis DG, Silva DG. Carnarvon studies. IV. Prevalence of ntal caries in 472 Caucasian schoolchildren examined in Carnarvon, Western Australia (August 1963). Aust Dent J. 1970;15:396-407 contd. [pmid: 4395240].
Kaimenyi JT, Hassan SR, Mutema AM. Managing dental caries at the dental unit of Kenyatta National Hospital Nairobi, Kenya. East Afr Med J. 1987;64:860-863. [pmid: 3505209].
Kallestal C, Holm AK. Allocation of dental caries prevention in Swedish teenagers. Community Dent Oral Epidemiol. 1994;22:100-105. [pmid: 8205773].
Kallestal C, Matsson L. Marginal bone loss in 16-year-old Swedish adolescents in 1975 and 1988. J Clin Periodontol. 1991;18:740-743. [pmid: 1752998].
Kallestal C, Oscarson N, Holm AK. Costs for prevention of dental caries in a group of Swedish teenagers. Swed Dent J. 1997;21:193-197. [pmid: 9472148].
Kallestal C, Wang NJ, Petersen PE, Arnadottir IB. Caries-preventive methods used for children and adolescents in Denmark, Iceland, Norway and Sweden. Community Dent Oral Epidemiol. 1999;27:144-151. [pmid: 10226725].
Kambhu PP, Ettinger RL, Wefel JS. An in vitro evaluation of artificial caries-like lesions on restored overdenture abutments. J Dent Res. 1988;67:582-584. [pmid: 3049717].
Kamen A, Schmee J. Diagnostic errors and multiple examiners in anticariogenic studies. J Dent Res. 1974;53.
Kamen A, Schreer SB. Consistency vs validity--or are both possible in clinical studies of anticariogenic agents?. J Dent Res. 1975;54.
Kandelman D, Bar A, Hefti A. Collaborative WHO xylitol field study in French Polynesia. I. Baseline prevalence and 32-month caries increment. Caries Res. 1988;22:55-62. [pmid: 3422062].
Kandelman D, Gagnon G. A 24-month clinical study of the incidence and progression of dental caries in relation to consumption of chewing gum containing xylitol in school preventive programs. J Dent Res. 1990;69:1771-1775. [pmid: 2229617].
Kandemir S. The radiographic investigation of the visibility of secondary caries adjacent to the gingiva in Class II amalgam restorations. Quintessence Int. 1997;28:387-392. [pmid: 9477902].
Kaneko T, Matsukubo T, Yatake T, Muramatsu Y, Takaesu Y. Evaluation of acidogenicity of commercial isomaltooligosaccharides mixture and its hydrogenated derivative by measurement of pH response under human dental plaque. Biosci Biotechnol Biochem. 1995;59:372-377. [pmid: 7766171].
Kang BC, Farman AG, Scarfe WC, Goldsmith LJ. Mechanical defects in dental enamel vs. natural dental caries: observer differentiation using Ektaspeed Plus film. Caries Res. 1996;30:156-162. [pmid: 8833141].
Kang BC, Farman AG, Scarfe WC, Goldsmith LJ. Observer differentiation of proximal enamel mechanical defects versus natural proximal dental caries with computed dental radiography. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 1996;82:459-465. [pmid: 8899789].
Kang BC, Goldsmith LJ, Farman AG. Observer differentiation of mechanical defects versus natural dental caries cavitations on monitor-displayed images with imaging plate readout. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 1998;86:595-600. [pmid: 9830655].
Kanjilal D, Verma RS, Merkrebs A. Clinical manifestation of children with a deletion of the short arm of chromosome 18 (18p-). Dysmorphol Clin Gent. 1988;2:109-114.
Kankaala TM, Virtanen JI, Larmas MA. Timing of first fillings in the primary dentition and permanent first molars of asthmatic children. Acta Odontol Scand. 1998;56:20-24. [pmid: 9537730].
Kantor ML, Reiskin AB, Lurie AG. A clinical comparison of X-ray films for detection of proximal surface caries [published erratum appears in J Am Den Assoc 1986 Mar;112(3):310]. J Am Dent Assoc. 1985;111:967-969. [pmid: 3864852].
Kapsimalis P, Rosenthal SL, Updegrave W, Evans R, Hurley B, Cobe HM. The relationship between caries activity, flow rate, total nitrogen and the mucin content of saliva. J Oral Med. 1966;21:107-110. [pmid: 4380491].
Kapur KK, Deupree R, Dent RJ, Hasse AL. A randomized clinical trial of two basic removable partial denture designs. Part I: Comparisons of five-year success rates and periodontal health. J Prosthet Dent. 1994;72:268-282. [pmid: 7965900].
Karjalainen S, Eriksson AL, Ruokola M, Toivonen A. Caries development after substitution of supervised fluoride rinses and toothbrushings by unsupervised use of fluoride toothpaste. Community Dent Oral Epidemiol. 1994;22:421-424. [pmid: 7882656].
Karjalainen S, Hannula P. Variation of reproducibility and agreement in radiographic caries diagnosis among dental teachers. Proc Finn Dent Soc. 1988;84:71-78. [pmid: 3393522].
Karlstedt E, Kaitila I, Pirinen S. Phenotypic features of dentition in diastrophic dysplasia. J Craniofac Genet Dev Biol. 1996;16:164-173. [pmid: 8872707].
Karlzen-Reuterving G, van Dijken JW. A three-year follow-up of glass ionomer cement and resin fissure sealants. ASDC J Dent Child. 1995;62:108-110. [pmid: 7608367].
Kashket S, Ahern JM. Correlation between physical changes in tooth enamel and changes in iodide penetrability following in vitro or intraoral demineralization. Caries Res. 1989;23:232-237. [pmid: 2790855].
Kassebaum DK, McDavid WD, Dove SB, Waggener RG. Spatial resolution requirements for digitizing dental radiographs. Oral Surg Oral Med Oral Pathol. 1989;67:760-769. [pmid: 2740097].
Kaste LM, Selwitz RH, Oldakowski RJ, Brunelle JA, Winn DM, Brown LJ. Coronal caries in the primary and permanent dentition of children and adolescents 1-17 years of age: United States, 1988-1991. J Dent Res. Spec No. 1996;75:631-641. [pmid: 8594087].
Katz RV. An epidemiologic study of the relationship between various states of occlusion and the pathological conditions of dental caries and periodontal disease. J Dent Res. 1978;57:433-439. [pmid: 277545].
Katz RV. The RCI revisited after 15 years: used, reinvented, modified, debated, and natural logged. J Public Health Dent. 1996;56:28-34. [pmid: 8667314].
Katz RV, Hazen SP, Chilton NW, Mumma RDJ. Prevalence and intraoral distribution of root caries in an adult population. Caries Res. 1982;16:265-271. [pmid: 6980052].
Katz S. The use of fluoride and chlorhexidine for the prevention of radiation caries. J Am Dent Assoc. 1982;104:164-170. [pmid: 6948892].
Kaurich M, Kawakami K, Perez P, Munn T, Hasse AL, Garrett NR. A clinical comparison of a glass ionomer cement and a microfilled composite resin in restoring root caries: two-year results. Gen Dent. 1991;39:346-349. [pmid: 1839833].
Kawabata K, Kawamura M, Sasahara H, Morishita M, Bachchu MA, Iwamoto Y. Development of an oral health indicator in infants. Community Dent Health. 1997;14:79-83. [pmid: 9225535].
Kay EJ, Brickley M, Knill-Jones R. Restoration of approximal carious lesions--application of decision analysis. Community Dent Oral Epidemiol. 1995;23:271-275. [pmid: 8529339].
Kay EJ, Knill-Jones R. Variation in restorative treatment decisions: application of Receiver Operating Characteristic curve (ROC) analysis. Community Dent Oral Epidemiol. 1992;20:113-117. [pmid: 1623699].
Kay EJ, Locker D. Is dental health education effective? A systematic review of current evidence. Community Dent Oral Epidemiol. 1996;24:231-235. [pmid: 8871028].
Kay EJ, Locker D. Variations in restorative treatment decisions: an international comparison. Community Dent Oral Epidemiol. 1996;24:376-379. [pmid: 9007352].
Kay EJ, Nuttall NM. Relationship between dentists' treatment attitudes and restorative decisions made on the basis of simulated bitewing radiographs. Community Dent Oral Epidemiol. 1994;22:71-74. [pmid: 8205782].
Kay EJ, Nuttall NM, Knill-Jones R. Restorative treatment thresholds and agreement in treatment decision-making. Community Dent Oral Epidemiol. 1992;20:265-268. [pmid: 1424545].
Kay EJ, Watts A, Paterson RC, Blinkhorn AS. Preliminary investigation into the validity of dentists' decisions to restore occlusal surfaces of permanent teeth. Community Dent Oral Epidemiol. 1988;16:91-94. [pmid: 3162863].
Keem S, Elbaum M. Wavelet representations for monitoring changes in teeth imaged with digital imaging fiber-optic transillumination. IEEE Trans Med Imaging. 1997;16:653-663. [pmid: 9368121].
Keene HJ. Dental caries prevalence in early Polynesians from the Hawaiian Islands. J Dent Res. 1986;65:935-938. [pmid: 3519714].
Keene HJ, Fleming TJ, Toth BB. Cariogenic microflora in patients with Hodgkin's disease before and after mantle field radiotherapy. Oral Surg Oral Med Oral Pathol. 1994;78:577-582. [pmid: 7838462].
Keller U, Hibst R, Geurtsen W, et al. Erbium:YAG laser application in caries therapy. Evaluation of patient perception and acceptance. J Dent. 1998;26:649-656. [pmid: 9793286].
Kelly K, Gelbier S, Gibbons D. A comparison between the findings of a routine school dental inspection and epidemiological data from the same five year old children. Community Dent Health. 1989;6:233-238. [pmid: 2804761].
Keltjens HM, Creugers TJ, Schaeken MJ, Van der Hoeven JS. Effects of chlorhexidine-containing gel and varnish on abutment teeth in patients with overdentures. J Dent Res. 1992;71:1582-1586. [pmid: 1522289].
Keltjens HM, Schaeken MJ, van der Hoeven JS, Hendriks JC. Caries control in overdenture patients: 18-month evaluation on fluoride and chlorhexidine therapies. Caries Res. 1990;24:371-375. [pmid: 2261610].
Kerckaert GA. Electron microscopy of human carious dental enamel. Arch Oral Biol. 1973;18:751-758. [pmid: 4516543].
Kerkhove BCJ, Herman SC, Klein AI, McDonald RE. A clinical and television densitometric evaluation of the indirect pulp capping technique. J Dent Child. 1967;34:192-201. [pmid: 5338514].
Keszthelyi G, Szabo I, Strahan JD. Loss of attachment adjacent to class II carious lesions. J Clin Periodontol. 1985;12:405-410. [pmid: 3859499].
Ketley CE, Holt RD. Visual and radiographic diagnosis of occlusal caries in first permanent molars and in second primary molars. Br Dent J. 1993;174:364-370. [pmid: 8494666].
Keys HM, McCasland JP. Techniques and results of a comprehensive dental care program in head and neck cancer patients. Int J Radiation Oncology Biol Phys. 1976;1:859-865.
Khalaf MA. Evaluation of new scoring systems for dye penetration for in vitro comparative microleakage studies. Egypt Dent J. 1995;41:1049-1056. [pmid: 9497640].
Khanna SL, Harrop TS. A five-film oral radiographic survey for children. ASDC J Dent Child. 1973;40:42-48. [pmid: 4567388].
Khocht A, Simon G, Person P, Denepitiya JL. Gingival recession in relation to history of hard toothbrush use. J Periodontol. 1993;64:900-905. [pmid: 8229627].
Kidd EA. Assessment of caries risk. Dent Update. 1998;25:385-390. [pmid: 10478031].
Kidd EA. The histopathology of enamel caries in young and old permanent teeth. Br Dent J. 1983;155:196-198. [pmid: 6578821].
Kidd EA, Beighton D. Prediction of secondary caries around tooth-colored restorations: a clinical and microbiological study. J Dent Res. 1996;75:1942-1946. [pmid: 9033448].
Kidd EA, Beighton D. Relevance of the use of rubber dam in microbiological sampling of carious dentine. Caries Res. 1997;31:41-43. [pmid: 8955993].
Kidd EA, Joyston-Bechal S. Susceptibility of natural carious lesions in enamel to an artificial caries-like attack in vitro. Br Dent J. 1986;160:345-348. [pmid: 3459483].
Kidd EA, Joyston-Bechal S, Beighton D. Diagnosis of secondary caries: a laboratory study. Br Dent J. 1994;176:135-138, 139. [pmid: 8123316].
Kidd EA, Joyston-Bechal S, Beighton D. Microbiological validation of assessments of caries activity during cavity preparation. Caries Res. 1993;27:402-408. [pmid: 8242678].
Kidd EA, Joyston-Bechal S, Beighton D. The use of a caries detector dye during cavity preparation: a microbiological assessment. Br Dent J. 1993;174:245-248. [pmid: 8461203].
Kidd EA, Joyston-Bechal S, Smith MM, Allan R, Howe L, Smith SR. The use of a caries detector dye in cavity preparation. Br Dent J. 1989;167:132-134. [pmid: 2789871].
Kidd EA, McLean JW. The cavity sealing ability of cemented cast gold restorations assessed in vitro by an acidified gel artificial caries technique. Br Dent J. 1979;147:39-41. [pmid: 378246].
Kidd EA, Naylor MN, Wilson RF. Prevalence of clinically undetected and untreated molar occlusal dentine caries in adolescents on the Isle of Wight. Caries Res. 1992;26:397-401. [pmid: 1468106].
Kidd EA, Pitts NB. A reappraisal of the value of the bitewing radiograph in the diagnosis of posterior approximal caries. Br Dent J. 1990;169:195-200. [pmid: 2223291].
Kidd EA, Richards A, Thylstrup A, Fejerskov O. The susceptibility of 'young' and 'old' human enamel to artificial caries in vitro. Caries Res. 1984;18:226-230. [pmid: 6584213].
Kidd EA, Ricketts DN, Beighton D. Criteria for caries removal at the enamel-dentine junction: a clinical and microbiological study. Br Dent J. 1996;180:287-291. [pmid: 8639369].
Kidd EA, Thylstrup A, Fejerskov O. The histopathology of enamel caries in fluorosed deciduous teeth. Caries Res. 1981;15:346-352. [pmid: 6942917].
Kidd EA, Thylstrup A, Fejerskov O, Silverstone LM. Histopathology of caries-like lesions created in vitro in fluorosed and sound enamel. Caries Res. 1978;12:268-274. [pmid: 279407].
Kihn PW, Barnes DM. The clinical longevity of porcelain veneers: a 48-month clinical evaluation. J Am Dent Assoc. 1998;129:747-752. [pmid: 9631616].
Kilpatrick NM, Murray JJ, McCabe JF. A clinical comparison of a light cured glass ionomer sealant restoration with a composite sealant restoration. J Dent. 1996;24:399-405. [pmid: 8990684].
Kim SY, Ohk SH, Bai DH, Yu JH. Purification and properties of bacteriolytic enzymes from Bacillus licheniformis YS-1005 against Streptococcus mutans. Biosci Biotechnol Biochem. 1999;63:73-77. [pmid: 10052124].
Kimura Y, Arrastio-Jitosho AMA, Wilder-Smith P, et al. Thermal, microstructural and physicochemical effects of nanosecond pulsed Nd:YAG laser irradiation on dentin. Lasers Life Sci. 1998;8:37-50.
King NM, Shaw L. Value of bitewing radiographs in detection of occlusal caries. Community Dent Oral Epidemiol. 1979;7:218-221. [pmid: 293240].
King NM, Yung LK, Holmgren CJ. Clinical performance of preventive resin restorations placed in a hospital environment. Quintessence Int. 1996;27:627-632. [pmid: 9180420].
Kingman A. Adequte cohort sizes for caries clinical trials. Community Dent Oral Epidemiol. 1978;6:30-35. [pmid: 342183].
Kingman A. A method of utilizing the subjects' initial caries experience to increase efficiency in caries clinical trials. Community Dent Oral Epidemiol. 1979;7:87-90. [pmid: 371908].
Kingman A. Methods of projecting long-term relative efficacy of products exhibiting small short-term efficacy. Caries Res. 1993;27:322-327. [pmid: 8402810].
Kingman A. Stratification methods in caries clinical trials. J Dent Res. Spec No. 1984;63:773-777. [pmid: 6586782].
Kingman A, Selwitz RH. Proposed methods for improving the efficiency of the DMFS index in assessing initiation and progression of dental caries. Community Dent Oral Epidemiol. 1997;25:60-68. [pmid: 9088693].
Kircos LT, Vandre RH, Lorton L. Exposure reduction of 96% in intraoral radiography. J Am Dent Assoc. 1986;113:746-750. [pmid: 3465788].
Kirkegaard E, Petersen G, Poulsen S, Holm SA, Heidmann J. Caries-preventive effect of Duraphat varnish applications versus fluoride mouthrinses: 5-year data. Caries Res. 1986;20:548-555. [pmid: 3465448].
Kirkham J, Robinson C, Strafford SM, et al. The chemical composition of tooth enamel in recessive dystrophic epidermolysis bullosa: significance with respect to dental caries. J Dent Res. 1996;75:1672-1678. [pmid: 8952620].
Kjaerheim V, von der Fehr FR, Poulsen S. Two-year study on the effect of professional toothcleaning on schoolchildren in Oppegard, Norway. Community Dent Oral Epidemiol. 1980;8:401-406. [pmid: 6942956].
Klausner LH, Charbeneau GT. Amalgam restorations: a cross-sectional survey of placement and replacement. J Mich Dent Assoc. 1985;67:249-252. [pmid: 3875729].
Kleber CJ, Putt MS, Smith CE, Gish CW. Effect of supervised use of an alum mouthrinse on dental caries incidence in caries-susceptible children: a pilot study. ASDC J Dent Child. 1996;63:393-402. [pmid: 9017171].
Kleier DJ, Hicks MJ, Flaitz CM. A comparison of Ultraspeed and Ektaspeed dental x-ray film: in vitro study of the radiographic and histologic appearance of interproximal lesions. Quintessence Int. 1987;18:623-631. [pmid: 3478747].
Kleier DJ, Hicks MJ, Flaitz CM. A comparison of Ultraspeed and Ektaspeed dental x-ray film: in vitro study of the radiographic appearance of interproximal lesions. Oral Surg Oral Med Oral Pathol. 1987;63:381-385. [pmid: 3473366].
Klein AI. Clinical television research instrumentation. J Am Dent Assoc. 1967;74:1210-1219. [pmid: 5336843].
Klein U, Kanellis MJ, Drake D. Effects of four anticaries agents on lesion depth progression in an in vitro caries model. Pediatr Dent. 1999;21:176-180. [pmid: 10355008].
Klingberg G, Berggren U. Dental problem behaviors in children of parents with severe dental fear. Swed Dent J. 1992;16:27-32. [pmid: 1579885].
Klock B, Krasse B. A comparison between different methods for prediction of caries activity. Scand J Dent Res. 1979;87:129-139. [pmid: 292160].
Klock B, Serling J, Kinder S, Manwell MA, Tinanoff N. Comparison of effect of SnF2 and NaF mouthrinses on caries incidence, salivary S. mutans and gingivitis in high caries prevalent adults. Scand J Dent Res. 1985;93:213-217. [pmid: 3860905].
Klooz DN. A collaborative fissure sealant program in Niagara region. Ont Dent. 1996;73:24, 26, 28-29 passim. [pmid: 9470618].
Knodle JM. Controlled fluoridation benefits after 14 years of implementation. Clin Prev Dent. 1989;11:21-26. [pmid: 2638956].
Kobayashi S, Kishi H, Yoshihara A, et al. Treatment and posttreatment effects of fluoride mouthrinsing after 17 years. J Public Health Dent. 1995;55:229-233. [pmid: 8551462].
Koch G. Caries increment in schoolchildren during and two years after end of supervised rinsing of the mouth with sodium fluoride solution. Odontol Revy. 1969;20:323-330. [pmid: 5262285].
Koch G. Comparison and estimation of effect on caries of daily supervised toothbrushing with a dentifrice containing sodium fluoride and a dentifrice containing potassium fluoride and manganese chloride. A three-year clinical test. Odontol Revy. 1972;23:341-354. [pmid: 4563096].
Koch G. Importance of early determination of caries risk. Int Dent J. 1988;38:203-210. [pmid: 3063663].
Koch G, Bergmann-Arnadottir I, Bjarnason S, Finnbogason S, Hoskuldsson O, Karlsson R. Caries-preventive effect of fluoride dentifrices with and without anticalculus agents: a 3-year controlled clinical trial. Caries Res. 1990;24:72-79. [pmid: 2403486].
Koch G, Edlund K, Hoogendoorn H. Lactoperoxidase in the prevention of plaque accumulation, gingivitis and dental caries. II. Effect of mouthrinses with amyloglucosidase and glucoseoxidase on plaque accumulation on teeth in individuals on a sucrose diet. Odontol Revy. 1973;24:367-372. [pmid: 4588714].
Koch G, Petersson LG, Kling E, Kling L. Effect of 250 and 1000 ppm fluoride dentifrice on caries. A three-year clinical study. Swed Dent J. 1982;6:233-238. [pmid: 6963006].
Koch G, Petersson LG, Ryden H. Effect of flouride varnish (Duraphat) treatment every six months compared with weekly mouthrinses with 0.2 per cent NaF solution on dental caries. Swed Dent J. 1979;3:39-44. [pmid: 288179].
Koch G, Strand G. Effect of an enzyme dentifrice on caries. A two-year clinical pilot study. Swed Dent J. 1979;3:9-13. [pmid: 373155].
Koday M, Rosenstein DI, Nana Lopez GM Dental decay rates among children of migrant workers in Yakima, WA Public Health Rep 1990 105 530 5332120733 2120733 1580110
Kogon SL, Stephens RG, Reid JA. The selection of the most efficient radiographic survey for young adult patients. Dent J. 1978;44:317-319. [pmid: 279458].
Kogon SL, Stephens RG, Reid JA, Donner A. Ektaspeed and a screen/film system compared with Ultra-Speed in the interpretation of early proximal caries. J Can Dent Assoc. 1984;50:397-401. [pmid: 6375836].
Kohler B, Andreen I. Influence of caries-preventive measures in mothers on cariogenic bacteria and caries experience in their children. Arch Oral Biol. 1994;39:907-911. [pmid: 7741661].
Kohler B, Bratthall D. Practical method to facilitate estimation of Streptococcus mutans levels in saliva. J Clin Microbiol. 1979;9:584-588. [pmcid: 275352]. [pmid: 383745].
Kohler B, Hager B. Influence of salivary levels of mutans streptococci on colonization of crown margins: a longitudinal study. J Prosthet Dent. 1993;69:524-528. [pmid: 8483132].
Kolmakow S, Honkala E, Borovsky EV, Kuzmina EM, Vasina SA. Effect of the mineralizing agent on the permanent teeth. J Clin Pediatr Dent. 1991;15:179-187. [pmid: 1878329].
Kolmakow S, Honkala E, Borovsky EV, Nyyssonen V, Smirnova TA, Paunio I. Relationship between lesions of enamel focal demineralization and caries in groups of Finnish and Russian children. J Pedod. 1987;11:358-374. [pmid: 3481824].
Kolmakow S, Honkala E, Kuzmina EM, et al. Surface-specific effect of a mineralizing agent on the permanent teeth and on periodontal status. J Clin Pediatr Dent. 1991;15:113-119. [pmid: 1931746].
Kolmakow S, Honkala E, Puranen M, Sainio P. Dento-facial morphology and caries experience: an epidemiological study. J Clin Pediatr Dent. 1991;16:31-37. [pmid: 1815741].
Kolmakow S, Kuzmina EM, Smirnova TA, Honkala E, Borovsky EV. Mineralizing agents in caries prevention: a review of the effects of Remodent. J Pedod. 1990;14:231-234. [pmid: 2098076].
Kolmakow S, Nyyssonen V, Honkala E, Paunio I. Determining the caries at-risk child: Part II--Assessment of initial caries in the permanent dentition of children. J Pedod. 1984;9:67-76. [pmid: 6596419].
Komatsu H, Shimokobe H, Kawakami S, Yoshimura M. Caries-preventive effect of glass ionomer sealant reapplication: study presents three-year results. J Am Dent Assoc. 1994;125:543-549. [pmid: 8195496].
Konig KG, Navia JM, Kingman S, et al. Nutritional role of sugars in oral health. Am J Clin Nutr. 1995;62:275S-283S. [pmid: 7598084].
Kopczyk RA, Abrams H, Brown AT, Matheny JL, Kaplan AL. Clinical and microbiological effects of a sanguinaria-containing mouthrinse and dentifrice with and without fluoride during 6 months of use. J Periodontol. 1991;62:617-622. [pmid: 1770421].
Kratochvil FJ, Davidson PN, Guijt J. Five-year survey of treatment with removable partial dentures. Part I. J Prosthet Dent. 1982;48:237-244.
Krauss NA, Machlin S, Kass BL. Use of Health Care Services, 1996. MEPS Finding No. 7. Rockville, MD: Agency for Health Care Policy and Research; 1999.
Kretzschmar JL, Kretzschmar DP. Common oral conditions. Am Fam Physician. 1996;54:225-230+233-234. [pmid: 8677838].
Kreulen CM, de Soet JJ, Weerheijm KL, van Amerongen WE. In vivo cariostatic effect of resin modified glass ionomer cement and amalgam on dentine. Caries Res. 1997;31:384-389. [pmid: 9286523].
Kreulen CM, van Amerongen WE, Akerboom HB, Borgmeijer PJ. Two-year results with box-only resin composite restorations. ASDC J Dent Child. 1995;62:395-400. [pmid: 8636474].
Krishnan VK, Bindhu DB, Manjusha K. Studies on microleakage associated with visible light cured dental composites. J Biomater Appl. 1996;10:348-359. [pmid: 8859406].
Kristoffersson K, Grondahl HG, Bratthall D. The more Streptococcus mutans, the more caries on approximal surfaces. J Dent Res. 1985;64:58-61. [pmid: 3855421].
Kroll RG, Budnick J, Kobren A. Incidence of dental caries and periodontal disease in Down's syndrome. N Y State Dent J. 1970;36:151-156. [pmid: 4391771].
Kronmiller JE, Nirschl RF, Close JM. Evaluation of bitewing intervals in children. ASDC J Dent Child. 1986;53:110-114. [pmid: 3457030].
Kronmiller JE, Nirschl RF, Zullo TG. Patient's age at the initial detection of interproximal caries. ASDC J Dent Child. 1988;55:105-109. [pmid: 3162470].
Kubota K, Okada S, Ono Y, et al. Dental survey in Nigeria. Part I. Prevalence of dental caries in Nigeria. Bull Tokyo Med Dent Univ. 1984;31:61-72. [pmid: 6589095].
Kubota K, Yonemitsu M, Hollist NO, et al. Five-year follow-up caries study among Nigerian children. Community Dent Oral Epidemiol. 1990;18:197-199. [pmid: 2387135].
Kullman L. Accuracy and precision in some dental radiographic methods. A methodological study with special considerations in age estimation in juveniles. Swed Dent J Suppl. 1995;104:1-38. [pmid: 7660316].
Kullman L, Martinsson T. Computerized registration of epidemiological data from intraoral radiographs. Swed Dent J. 1985;9:89-96. [pmid: 3860996].
Kumar JV, Swango PA, Lininger LL, Leske GS, Green EL, Haley VB. Changes in dental fluorosis and dental caries in Newburgh and Kingston, New York. Am J Public Health. 1998;88:1866-1870. [pmid: 9842391]. [pmcid: 1509052].
Kumasaki M. An electric characteristic of the tooth and its equivalent circuit and clinical application. Part 2. Med J Osaka Univ. 1975;9:19-30.
Kunzel W. The cost and economic consequences of water fluoridation. Caries Res. 1974;8:28-35. [pmid: 4600857].
Kunzel W, Fischer T. Rise and fall of caries prevalence in German towns with different F concentrations in drinking water. Caries Res. 1997;31:166-173. [pmid: 9165185].
Kurien M, Mathew J, Job A, Zachariah N. Ludwig's angina. Clin Otolaryngol Allied Sci. 1997;22:263-265. [pmid: 9222634].
Kuriyama M, Dobbyn RC, Takagi S, Chow LC. Microradiography with an x-ray image magnifier: Application to dental hard tissue. Med Phys. 1987;14:968-974. [pmid: 3696083].
Kurosaki N, Sato Y, Iwaku M, Fusayama T. Effect of a carious dentin softener on the dentin and pulp. J Prosthet Dent. 1977;38:169-173. [pmid: 268428].
Kutsch VK. Dental caries illumination with the argon laser. J Clin Laser Med Surg. 1993;11:323-327.
Kuwabara RK, Massler M. Pulpal reactions to active and arrested carious lesions. J Dent Child. 1966;33:190-204. [pmid: 5326837].
Kuzmina IN, Kuzmina E, Ekstrand KR. Dental caries among children from Solntsevsky--a district in Moscow, 1993. Community Dent Oral Epidemiol. 1995;23:266-270. [pmid: 8529338].
Kwan SY, Prendergast MJ, Williams SA. The diagnostic reliability of clinical dental auxiliaries in caries prevalence surveys--a pilot study. Community Dent Health. 1996;13:145-149. [pmid: 8897737].
Kwant GW. Topical application of sodium hexafluorostannate solution on 5 to 9 year old Tiel children. Ned Tijdschr Tandheelkd. 1976;83:6-16. [pmid: 802244].
Lachapelle D, Couture C, Brodeur JM, Sevigny J. The effects of nutritional quality and frequency of consumption of sugary foods on dental caries increment. Can J Public Health. 1990;81:370-375. [pmid: 2253154].
Lagerweij M, van der Veen M, Ando M, Lukantsova L, Stookey G. The validity and repeatability of three light-induced fluorescence systems: An in vitro study. Caries Res. 1999;33:220-226. [pmid: 10207198].
Lagerweij MD, Damen JJ, ten Cate JM. The effect of a fluoridated toothpaste on dentinal lesions in plaque-filled grooves: an intra-oral crossover study. J Dent Res. 1996;75:1687-1691. [pmid: 8952622].
Laher MH. A comparison between dental caries, gingival health and dental service usage in Bangladeshi and white Caucasian children aged 7, 9, 11, 13 and 15 years residing in an inner city area of London, UK. Community Dent Health. 1990;7:157-163. [pmid: 2379090].
Lai PY, Seow WK, Tudehope DI, Rogers Y. Enamel hypoplasia and dental caries in very-low birthweight children: a case-controlled, longitudinal study. Pediatr Dent. 1997;19:42-49. [pmid: 9048413].
Lalloo R, Solanki GS. An evaluation of a school-based comprehensive public oral health care programme. Community Dent Health. 1994;11:152-155. [pmid: 7953934].
Lamb WJ, Corpron RE, More FG, Beltran ED, Strachan DS, Kowalski CJ. In situ remineralization of subsurface enamel lesion after the use of a fluoride chewing gum. Caries Res. 1993;27:111-116. [pmid: 8319253].
Lammers PC, Borggreven J, Driessens FCM, Van 't Hof MA. Acid-susceptibility of lesions in bovine enamel after remineralization in the presence of fluoride and/or carbonate. Caries Res. 1992;26:1-7. [pmid: 1568231].
Lang NP, Hotz P, Graf H, et al. Effects of supervised chlorhexidine mouthrinses in children. A longitudinal clinical trial. J Periodontal Res. 1982;17:101-111. [pmid: 6211534].
Langeland K, Langeland LK. Indirect capping and the treatment of deep carious lesions. Int Dent J. 1968;18:326-380. [pmid: 4969599].
Langeland K, Langeland LK, Anderson DM. Corticosteroids in dentistry. Int Dent J. 1977;27:217-251. [pmid: 411759].
Langlais RP, Skoczylas LJ, Prihoda TJ, Langland OE, Schiff T. Interpretation of bitewing radiographs: application of the kappa statistic to determine rater agreements. Oral Surg Oral Med Oral Pathol. 1987;64:751-756. [pmid: 3480493].
Langmore SE, Terpenning MS, Schork A, et al. Predictors of aspiration pneumonia: How important is dysphagia?. Dysphagia. 1998;13:69-81. [pmid: 9513300].
Langsjoen OM. Dental effects of diet and coca-leaf chewing on two prehistoric cultures of northern Chile. Am J Phys Anthropol. 1996;101:475-489. [pmid: 9016362].
Lappalainen R, Koskenranta-Wuorinen P, Markkanen H. Periodontal and cariological status in relation to different combinations of removable dentures in elderly men. Gerodontics. 1987;3:122-124. [pmid: 3476328].
Larje O, Larson RH. Reduction of dental caries in rats by intermittent feeding with sucrose substitutes. Arch Oral Biol. 1970;15:805-816. [pmid: 5273403].
Larmas M. A new dip-slide method for the counting of salivary lactobacilli. Proc Finn Dent Soc. 1975;71:31-35. [pmid: 1096144].
Larmas M. Saliva and dental caries: diagnostic tests for normal dental practice. Int Dent J. 1992;42:199-208. [pmid: 1399036].
Larmas MA, Virtanen JI, Bloigu RS. Timing of first restorations in permanent teeth: a new system for oral health determination [published erratum appears in J Dent 1996 Jan-Mar;24(1-2):152]. J Dent. 1995;23:347-352. [pmid: 8530725].
Larsson B, Johansson I, Hallmans G, Ericson T. Relationship between dental caries and risk factors for atherosclerosis in Swedish adolescents?. Community Dent Oral Epidemiol. 1995;23:205-210. [pmid: 7587140].
Larsson B, Johansson I, Weinehall L, Hallmans G, Ericson T. Cardiovascular disease risk factors and dental caries in adolescents: effect of a preventive program in Northern Sweden (the Norsjo project). Acta Paediatr. 1997;86:63-71. [pmid: 9116429].
Latcham NL, Powell RN, Jago JD, Seymour GJ, Aitken JF. Changes in proximal caries status of Brisbane 15-year-old children over a ten year period. Aust Dent J. 1982;27:357-359. [pmid: 6963149].
Lavonius E, Kerosuo E, Kallio P, Pietila I, Mjor IA. Occlusal restorative decisions based on visual inspection--calibration and comparison of different methods. Community Dent Oral Epidemiol. 1997;25:156-159. [pmid: 9181290].
Lawrence HP, Benn DK, Sheiham A. Digital radiographic measurement of approximal caries progression in fluoridated and non-fluoridated areas of Rio de Janeiro, Brazil. Community Dent Oral Epidemiol. 1997;25:412-418. [pmid: 9429813].
Lawrence HP, Hunt RJ, Beck JD. Three-year root caries incidence and risk modeling in older adults in North Carolina. J Public Health Dent. 1995;55:69-78. [pmid: 7643330].
Lawrence HP, Hunt RJ, Beck JD, Davies GM. Five-year incidence rates and intraoral distribution of root caries among community-dwelling older adults. Caries Res. 1996;30:169-179. [pmid: 8860026].
Lawrence HP, Sheiham A. Caries progression in 12- to 16-year-old schoolchildren in fluoridated and fluoride-deficient areas in Brazil. Community Dent Oral Epidemiol. 1997;25:402-411. [pmid: 9429812].
Lazarchik DA, Firestone AR, Heaven TJ, Filler SJ, Lussi A. Radiographic evaluation of occlusal caries: effect of training and experience. Caries Res. 1995;29:355-358. [pmid: 8521436].
Le Bell Y, Forsten L. Sealing of preventively enlarged fissures. Acta Odontol Scand. 1980;38:101-104. [pmid: 6929642].
Leake JL, Martinello BP. A four year evaluation of a a fissure sealant in a public health setting. J Can Dent Assoc. 1976;42:409-415. [pmid: 1068139].
Leake JL, Williams JI, Armstrong LW. Assessing the effectiveness of a management information system in improving preschoolers' use of fluoride supplements. Can J Public Health. 1987;78:25-30. [pmid: 3828935].
Leake JL, Woodward GL. The use of dental radiographs to estimate the probability of cavitation of carious interproximal lesions. Part II: Two patient scenarios. J Can Dent Assoc. 1996;62:737-740. [pmid: 8908877].
Leal FR, Cohen ME, Forgas-Brockmann L, Meyer DM, Simecek J. A prospective study of sealant application in Navy recruits. Mil Med. 1998;163:107-109. [pmid: 9503904].
Leal FR, Forgas-Brockmann L, Simecek J, Cohen ME, Meyer DM. A prospective study of sealant application in navy recruits. Mil Med. 1998;163:107-109. [pmid: 9503904].
Lee CQ, Shey Z, Cobb CM. Microscopic appearance of enamel white-spot lesions after acid etching. Quintessence Int. 1995;26:279-284. [pmid: 7568748].
Lees S. Ultra-sonics in hard tissues. Int Dent J. 1971;21:403-417. [pmid: 5292201].
Lees S, Barber FE. Looking into the tooth and its surfaces with ultrasonics. Ultrasonics. 1971;9:95-100. [pmid: 5555104].
Lees S, Barber FE, Lobene RR. Dental enamel: detection of surface changes by ultrasound. Science. 1970;169:1314-1316. [pmid: 5454140].
LeGeros RZ, Silverstone LM, Daculsi G, Kerebel LM. In vitro caries-like lesion formation in F-containing tooth enamel. J Dent Res. 1983;62:138-144. [pmid: 6571867].
Lehmann AR, Thompson AF, Harcourt SA, Stefanini M, Norris PG. Cockayne's syndrome: Correlation of clinical features with cellular sensitivity of RNA synthesis to UV irradiation. J Med Genet. 1993;30:679-682. [pmid: 7692050].
Lehner T. Immunization against dental caries. Vaccine. 1985;3:65-68. [pmid: 3159164].
Lehner T, Challacombe SJ, Caldwell J. Immunologic basis for vaccination against dental caries in rhesus monkeys. J Dent Res. 1976;55 Spec No:C166-80:166-180. [pmid: 1060654].
Lehner T, Ma JK, Kelly CG. A mechanism of passive immunization with monoclonal antibodies to a 185,000 M(r) streptococcal antigen. Adv Exp Med Biol. 1992;327:151-163. [pmid: 1295336].
Lehtonen OP, Grahn EM, Stahlberg TH, Laitinen LA. Amount and avidity of salivary and serum antibodies against Streptococcus mutans in two groups of human subjects with different dental caries susceptibility. Infect Immun. 1984;43:308-313. [pmcid: 263427]. [pmid: 6690406].
Leijon G, Marken KE. Roentgenological diagnosis of proximal caries. Deviations between observers and comparison between the recordings from periapical and bite-wing roentgenograms. Acta Odontol Scand. 1968;26:35-61. [pmid: 5248105].
Leksell E, Ridell K, Cvek M, Mejare I. Pulp exposure after stepwise versus direct complete excavation of deep carious lesions in young posterior permanent teeth. Endod Dent Traumatol. 1996;12:192-196. [pmid: 9028183].
Lemasney J, O'Mullane D, Coleman M. Effect of fluoridation on dental health in 5- and 11-year-old Irish schoolchildren. Community Dent Oral Epidemiol. 1984;12:218-222. [pmid: 6590172].
Lenhard M, Mayer T, Pioch T, Eickholz P. A method to monitor dental demineralisation in vitro. Caries Res. 1996;30:326-333. [pmid: 8877085].
Lennon MA, O'Mullane DM, Taylor GO. A pragmatic clinical trial of fissure sealants in a community dental service programme for 6-10-year-old children. Community Dent Health. 1984;1:101-109. [pmid: 6443343].
Lennon MA, Worthington HV, Coventry P, Mellor AC, Holloway PJ. The Capitation Study. 2. Does capitation encourage more prevention?. Br Dent J. 1990;168:213-215. [pmid: 2180458].
Leon AR. The effect of approximal carious lesions on the periodontium. Br Dent J. 1977;143:18-21. [pmid: 268189].
Leontyev VK, Ivanova GG, Zhorova TN. Electrometric diagnosis of dental hard tissue lesions. Stomatologiia (Mosk). 1990;69:19-24.
Lervik T, Haugejorden O, Aas C. Progression of posterior approximal carious lesions in Norwegian teenagers from 1982 to 1986. Acta Odontol Scand. 1990;48:223-227. [pmid: 2220328].
Lesan WR. Diagnostic significance of radiographs on proximal surface caries in epidemiological surveys. East Afr Med J. 1989;66:289-292. [pmid: 2787239].
Leske GS, Pollard ST, Shipman WL. Comparison of dental surveys in Elmira and Corning, New York. N Y State Dent J. 1972;38:540-543. [pmid: 4146336].
Leske GS, Ripa LW. Ethical and legal considerations associated with clinical field trials. J Dent Res. 1980;59:1243-1253. [pmid: 6993513].
Leske GS, Ripa LW. Three-year root caries increments: implications for clinical trials. J Public Health Dent. 1989;49:142-146. [pmid: 2671353].
Leske GS, Ripa LW, Sposato A. Posttreatment benefits in a school-based fluoride mouthrinsing program. Increased benefits associated with increasing participation. Clin Prev Dent. 1985;7:4-7.
Lester KS, Boyde A. Some preliminary observations on caries ('remineralization') crystals in enamel and dentine by surface electron microscopy. Virchows Arch A Pathol Pathol Anat. 1967;344:196-212.
Leverett DH. Effectiveness of mouthrinsing with fluoride solutions in preventing coronal and root caries. J Public Health Dent. 1989;49:310-316. [pmid: 2681733].
Leverett DH. Fluorides and the changing prevalence of dental caries. Science. 1982;217:26-30. [pmid: 7089534].
Leverett DH, Adair SM, Vaughan BW, Proskin HM, Moss ME. Randomized clinical trial of the effect of prenatal fluoride supplements in preventing dental caries. Caries Res. 1997;31:174-179. [pmid: 9165186].
Leverett DH, Handelman SL, Brenner CM, Iker HP. Use of sealants in the prevention and early treatment of carious lesions: cost analysis. J Am Dent Assoc. 1983;106:39-42. [pmid: 6222101].
Levine RS. The differential inorganic composition of dentine within active and arrested carious lesions. Caries Res. 1973;7:245-260. [pmid: 4518170].
Levine RS. An initial clinical assessment of a mineralising mouthrinse. Br Dent J. 1975;138:249-253. [pmid: 1091279].
Levine RS. The microradiographic features of dentine caries. Observations on 200 lesions. Br Dent J. 1974;137:301-306. [pmid: 4531340].
Levy SM, Jenson ME, Doering JV, Sheth JJ. Evaluation of a glass ionomer cement and a microfilled composite resin in the treatment of root surface caries. Gen Dent. 1989;37:468-472. [pmid: 2534806].
Lewis DW. Another update for Canadian dentists regarding chlorhexidine varnish therapy for the prevention of dental caries. J Can Dent Assoc. 1994;60:717-720. discussion 721-722, 725. [pmid: 8087680].
Lewis DW, Hargreaves JA. Epidemiology of dental caries in the premolar and second molar teeth of Scottish children in relation to pits and fissures. Community Dent Oral Epidemiol. 1977;5:46-54. [pmid: 264418].
Lewis DW, Ismail AI, Goldbloom R, et al. Periodic health examination, 1995 update: 2. Prevention of dental caries. CMAJ. 1995;152:836-846. [pmid: 7697577]. [pmcid: 1337757].
Lewis DW, Kay EJ, Main PA, Pharoah MG, Csima A. Dentists' variability in restorative decisions, microscopic and radiographic caries depth. Community Dent Oral Epidemiol. 1996;24:106-111. [pmid: 8654029].
Lewis DW, Limeback H. Comparison of recommended and actual mean intakes of fluoride by Canadians. J Can Dent Assoc. 1996;62:708-709, 712-715. [pmid: 8908873].
Lewis JM. Improving dental health status indicators for evaluation. Community Dent Oral Epidemiol. 1996;24:32-36. [pmid: 8833512].
Li SH, Kingman A, Forthofer R, Swango P. Comparison of tooth surface-specific dental caries attack patterns in US schoolchildren from two national surveys. J Dent Res. 1993;72:1398-1405. [pmid: 8408882].
Li Y, Navia JM, Bian JY. Caries experience in deciduous dentition of rural Chinese children 3-5 years old in relation to the presence or absence of enamel hypoplasia. Caries Res. 1996;30:8-15. [pmid: 8850577].
Libby G, Arcuri MR, LaVelle WE, Hebl L. Longevity of fixed partial dentures. J Prosthet Dent. 1997;78:127-131. [pmid: 9260128].
Lieberman JE, Webber RL. Clinical evaluation of a prototype intraoral source x-ray system. Oral Surg Oral Med Oral Pathol. 1978;46:318-327. [pmid: 362311].
Lijmer JG, Mol BW, Heisterkamp S, et al. Empirical evidence of design-related bias in studies of diagnostic tests. JAMA. 1999;282:1061-1066. [pmid: 10493205].
Lin AN. Management of patients with Epidermolysis bullosa. Dermatol Clin. 1996;14:381-387. [pmid: 8725592].
Lincir I, Rosin-Grget K. Caries-preventive effect of two different topical fluoride concentrations with two different frequencies of application in preschool children. Caries Res. 1993;27:484-487. [pmid: 8281563].
Lind OP, Moller IJ, Fehr FRvd, Larsen MJ. Caries-preventive effect of dentifrice containing 2percent sodium monofluorophosphate in a natural fluoride area in Denmark. Community Dent Oral Epidemiol. 1974;2:104-113. [pmid: 4153291].
Lind OP, von der Fehr FR, Larsen MJ, Moller IJ. Anti-caries effect of a 2% Na2PO3F-dentifrice in a Danish fluoride area. Community Dent Oral Epidemiol. 1976;4:7-14. [pmid: 1061652].
Lindhe J, Axelsson P. The effect of controlled oral hygiene and topical fluoride application on caries and gingivitis in Swedish schoolchildren. Community Dent Oral Epidemiol. 1973;1:9-16. [pmid: 4528772].
Lindhe J, Axelsson P, Tollskog G. Effect of proper oral hygiene on gingivitis and dental caries in Swedish schoolchildren. Community Dent Oral Epidemiol. 1975;3:150-155. [pmid: 1097171].
Lindquist B, Edward S, Torell P, Krasse B. Effect of different caries preventive measures in children highly infected with mutans streptococci. Scand J Dent Res. 1989;97:330-337. [pmid: 2799271].
Linke HA. Sugar alcohols and dental health. World Rev Nutr Diet. 1986;47:134-162. [pmid: 3088853].
Linton JL. Quantitative measurements of remineralization of incipient caries. Am J Orthod Dentofacial Orthop. 1996;110:590-597. [pmid: 8972804].
Lith A, Grondahl HG. Intervals between bitewing examinations in young patients when applying a radiologic algorithm. Community Dent Oral Epidemiol. 1992;20:181-186. [pmid: 1526100].
Lith A, Grondahl HG. Predicting development of approximal dentin lesions by means of past caries experience. Community Dent Oral Epidemiol. 1992;20:25-29. [pmid: 1547608].
Liu RS, Chu LS, Yen SH, et al. Detection of anaerobic odontogenic infections by fluorine-18 fluoromisonidazole. Eur J Nucl Med. 1996;23:1384-1387. [pmid: 8781145].
Lizi EC. A case for a dental surgeon at regional radiotherapy centres. Br Dent J. 1992;173:24-26. [pmid: 1535779].
Lloyd A, Gutmann J, Dummer P, Newcombe R. Microleakage of Diaket and amalgam in root-end cavities prepared using MicroMega sonic retro-prep tips. Int Endod J. 1997;30:196-204. [pmid: 9477805].
Lloyd CH, Scrimgeour SN, Chudek JA, Hunter G, MacKay RL. Magnetic resonance microimaging of carious teeth. Quintessence Int. 1997;28:349-355. [pmid: 9452700].
Lo EC, Schwarz E, Wong MC. Arresting dentine caries in Chinese preschool children. Int J Paediatr Dent. 1998;8:253-260. [pmid: 9927926].
Lobene RR, Zulgar-Nain BJ, Hein JW. Masking of enamel caries by topically applied stannous fluoride: a source of error in clinical diagnosis. J Oral Ther Pharmacol. 1966;3:35-43. [pmid: 5958249].
Lobene RR, Zulqar-Nain BJ. Radiographic study of the area-volume relationship in interproximal cavities. J Dent Res. 1966;45:939-944. [pmid: 5222497].
Locker D. Incidence of root caries in an older Canadian population. Community Dent Oral Epidemiol. 1996;24:403-407. [pmid: 9007358].
Loesche WJ, Bradbury DR, Woolfolk MP. Reduction of dental decay in rampant caries individuals following short-term kanamycin treatment. J Dent Res. 1977;56:254-265. [pmid: 323316].
Loesche WJ, Straffon LH. Longitudinal investigation of the role of Streptococcus mutans in human fissure decay. Infect Immun. 1979;26:498-507. [pmcid: 414644]. [pmid: 397929].
Lohr KN, Carey TS. Assessing 'best evidence': issues in grading the quality of studies for systematic reviews. Jt Comm J Qual Improv. 1999;25:470-479. [pmid: 10481816].
Lokshin MF. Preventive oral health care: A review for family physicians. Am Fam Physician. 1994;50:1677-1684. [pmid: 7976998].
Longbottom C, Huysmans M-C, Pitts NB, Los P, Bruce PG. Detection of dental decay and its extent using a. c. impedance spectroscopy. Nat Med. 1996;2:235-237. [pmid: 8574971].
Longbottom C, Pitts NB. CO2 laser and the diagnosis of occlusal caries: in vitro study. J Dent. 1993;21:234-239. [pmid: 8354749].
Longbottom C, Pitts NB. Initial comparison between endoscopic and conventional methods of caries diagnosis. Quintessence Int. 1990;21:531-540. [pmid: 2094851].
Loo CY, Willcox MD, Knox KW. Surface-associated properties of Actinomyces strains and their potential relation to pathogenesis. Oral Microbiol Immunol. 1994;9:12-18. [pmid: 7478749].
Lopes ES, Nagem Filho H, Chiodi J, Tavano O. Interexaminer variability when using Viegas' simplified caries index. J Public Health Dent. 1973;33:7-12. [pmid: 4143984].
Lopez L, Berkowitz R, Zlotnik H, Moss M, Weinstein P. Topical antimicrobial therapy in the prevention of early childhood caries. Pediatr Dent. 1999;21:9-11. [pmid: 10029961].
Lopez Marcos JF, Moreno Pascual C, Diez Gudino E Alban test and caries in a group of sportsmen ARCH MED DEPORTE Vol 15(67)(Pp 373 377) 1998
Louw AJ, Carstens IL, Hartshorne JE, Blignaut RJ. Effectiveness of two school-based caries preventive programmes. J Dent Assoc S Afr. 1995;50:43-49. [pmid: 8613581].
Lu KH. A critical evaluation of diagnostic errors, true increment and examiner's accuracy in caries experience assessment by a probabilistic model. Arch Oral Biol. 1968;13:1133-1147. [pmid: 5250452].
Lu KH. A Markov model of diagnostic errors in assessment of caries experience. Arch Oral Biol. 1970;15:869-877. [pmid: 5273408].
Lu KH, Hanna JD, Peterson JK. Effect on dental caries of a stannous fluoride-calcium pyrophosphate dentrifice in an adult population: one-year results. Pharmacol Ther Dent. 1980;5:11-16. [pmid: 6251487].
Lu KH, Ruhlman CD, Chung KL, Sturzenberger OP, Lehnhoff RW. A three-year clinical comparison of a sodium monofluorophosphate dentifrice with sodium fluoride dentifrices on dental caries in children. ASDC J Dent Child. 1987;54:241-244. [pmid: 3476523].
Lu KH, Van Winkle L. A critical evaluation of some problems associated with clinical caries trials by computer simulation. J Dent Res. 1984;63 Spec No:796-807:796-807. [pmid: 6586784].
Lu KH, Yen DJ, Zacherl WA, Ruhlman CD, Sturzenberger OP, Lehnhoff RW. The effect of a fluoride dentifrice containing an anticalculus agent on dental caries in children. ASDC J Dent Child. 1985;52:449-451. [pmid: 2999206].
Luan WM, Baelum V, Chen X, Fejerskov O. Dental caries in adult and elderly Chinese. J Dent Res. 1989;68:1771-1776. [pmid: 2600259].
Ludlow JB, Abreu MJ. Performance of film, desktop monitor and laptop displays in caries detection. Dento Maxillo Facial Radiol. 1999;28:26-30.
Ludlow JB, Platin E, Delano EO, Clifton L. The efficacy of caries detection using three intraoral films under different processing conditions. J Am Dent Assoc. 1997;128:1401-1408. [pmid: 9332141].
Lundberg M. The bisector projection or bite-wing technique in the radiologic diagnosis of proximal primary caries. A comparison between methods and a study of discrepancies between observers. Odontol Tidskr. 1965;73:567-578. [pmid: 5217196].
Lundberg T, Isaksson S. A clinical follow-up study of 278 autotransplanted teeth. Br J Oral Maxillofac Surg. 1996;34:181-185. [pmid: 8861295].
Lundeen RC, McDavid WD, Barnwell GM. Proximal surface caries detection with direct-exposure and rare earth screen/film imaging. Oral Surg Oral Med Oral Pathol. 1988;66:734-745. [pmid: 3205558].
Lunder N, von der Fehr FR. Approximal cavitation related to bite-wing image and caries activity in adolescents. Caries Res. 1996;30:143-147. [pmid: 8833139].
Lundgren M, Birkhed D, Steen G, Emilson CG, Osterberg T, Steen B. Oral glucose clearance in nonagenarians in relation to functional capacity, medication and oral variables. Gerodontology. 1997;14:17-27. [pmid: 9610299].
Lundman UA, Bolin AK, Rangne Y, Bolin A. Dental survey at school with the purpose to select children with no actual need of dental treatment. Swed Dent J. 1998;22:203-210. [pmid: 9974204].
Lundstrom F, Hamp SE, Nyman S. Systematic plaque control in children undergoing long-term orthodontic treatment. Eur J Orthod. 1980;2:27-39. [pmid: 6935056].
Lundstrom F, Krasse B. Caries incidence in orthodontic patients with high levels of Streptococcus mutans. Eur J Orthod. 1987;9:117-121. [pmid: 3472889].
Lundstrom F, Krasse B. Streptococcus mutans and lactobacilli frequency in orthodontic patients; the effect of chlorhexidine treatments. Eur J Orthod. 1987;9:109-116. [pmid: 3472888].
Luoma AR, Ronnberg K. Caries experience and distribution in relation to treatment needs among teenagers in Espoo, Finland. Community Dent Oral Epidemiol. 1991;19:101-103. [pmid: 2049914].
Luoma AR, Ronnberg K. Twelve-year follow-up of caries prevalence and incidence in children and young adults in Espoo, Finland. Community Dent Oral Epidemiol. 1987;15:29-32. [pmid: 3467891].
Luoma H. Chlorhexidine solutions, gels and varnishes in caries prevention. Proc Finn Dent Soc. 1992;88:147-153. [pmid: 1298965].
Luoma H, Meurman J, Helminen S, Heikkila H. Retention of a fissure sealant with caries reduction in Finnish children after six months. Scand J Dent Res. 1973;81:510-512. [pmid: 4520613].
Luoma H, Murtomaa H, Nuuja T, et al. A simultaneous reduction of caries and gingivitis in a group of schoolchildren receiving chlorhexidine-fluoride applications. Results after 2 years. Caries Res. 1978;12:290-298. [pmid: 279410].
Luoma H, Nyman A, Toivonen A, et al. Effect of caries in mentally handicapped children of addition of fluoride and bicarbonate-phosphate to dietary sugar products. Scand J Dent Res. 1979;87:197-207. [pmid: 392699].
Lura HE. The caries-pathogenetic theories of to-day. J Nihon Univ Sch Dent. 1971;13:119-125. [pmid: 4946460].
Lussi A. Comparison of different methods for the diagnosis of fissure caries without cavitation. Caries Res. 1993;27:409-416. [pmid: 8242679].
Lussi A. Impact of including or excluding cavitated lesions when evaluating methods for the diagnosis of occlusal caries. Caries Res. 1996;30:389-393. [pmid: 8946094].
Lussi A. Validity of diagnostic and treatment decisions of fissure caries. Caries Res. 1991;25:296-303. [pmid: 1913769].
Lussi A, Firestone A, Schoenberg V, Hotz P, Stich H. In vivo diagnosis of fissure caries using a new electrical resistance monitor. Caries Res. 1995;29:81-87. [pmid: 7728833].
Lussi A, Gygax M, Hotz P, Luthi D. A new method for finishing minicavities. Scanning Microsc. 1988;2:1553-1557. [pmid: 3201199].
Lussi A, Imwinkelried S, Pitts N, Longbotton C, Reich E. Performance and reproducibility of a laser fluorescence system for detection of occlusal caries in vitro. Caries Res. 1999;33:261-266. [pmid: 10343088].
Lynch E, Beighton D. A comparison of primary root caries lesions classified according to colour. Caries Res. 1994;28:233-239. [pmid: 8069878].
Lynch E, Beighton D. Relationships between mutans streptococci and perceived treatment need of primary root-caries lesions. Gerodontology. 1993;10:98-104. [pmid: 7713533].
Lyttle HA, Sidhu N, Smyth B. A study of the classification and treatment of noncarious cervical lesions by general practitioners. J Prosthet Dent. 1998;79:342-346. [pmid: 9553890].
Ma DS, Paik DI, Park DY, Moon HS, Chang YI, Kim JB. Relationship between microhardness and fluorine contents on tooth enamel determined by PIGE analysis. J Radioanal Nucl Chem. 1997;217:225-227.
Machiulskiene V, Nyvad B, Baelum V. Prevalence and severity of dental caries in 12-year-old children in Kaunas, Lithuania 1995. Caries Res. 1998;32:175-180. [pmid: 9577982].
Mack RB, Dean JA. Electrosurgical pulpotomy: a retrospective human study. ASDC J Dent Child. 1993;60:107-114. [pmid: 8486853].
MacKay BJ, Goodman H, Cox D, Grossbard BL, Iacono VJ, Pollock JJ. Development of an enzyme-linked immunosorbent assay for determination of lysozyme in human parotid and submandibular-sublingual salivas. J Clin Microbiol. 1984;19:844-848. [pmcid: 271196]. [pmid: 6470098].
Madigan A, Murray PA, Houpt M, Catalanotto F, Feuerman M. Caries experience and cariogenic markers in HIV-positive children and their siblings. Pediatr Dent. 1996;18:129-136. [pmid: 8710715].
Mafeni JO, Messer LB. Parental knowledge and attitudes towards pit and fissure sealants. Aust Dent J. 1994;39:172-180. [pmid: 8067935].
Magnusson BO. Therapeutic pulpotomies in primary molars with the formocresol technique. A clinical and histological follow-up. Acta Odontol Scand. 1978;36:157-165. [pmid: 277052].
Maijer R, Smith DC. A comparison between zinc phosphate and glass ionomer cement in orthodontics. Am J Orthod Dentofacial Orthop. 1988;93:273-279. [pmid: 3281438].
Main PA, Lewis DW, Hawkins RJ. A survey of general dentists in Ontario, Part I: Sealant use and knowledge. J Can Dent Assoc. 1997;63:542, 545-553. [pmid: 9264215].
Mainwaring PJ, Naylor MN. A four-year clinical study to determine the caries-inhibiting effect of calcium glycerophosphate and sodium fluoride in calcium carbonate base dentifrices containing sodium monofluorophosphate. Caries Res. 1983;17:267-276. [pmid: 6342787].
Mainwaring PJ, Naylor MN. A three-year clinical study to determine the separate and combined caries-inhibiting effects of sodium monofluorophosphate toothpaste and an acidulated phosphate-fluoride gel. Caries Res. 1978;12:202-212. [pmid: 356989].
Makinen KK. A dietary procedure for preventing dental caries in young adults. J Am Coll Health. 1993;41:172-180. [pmid: 8436732].
Makinen KK. Xylitol and oral health. Adv Food Res. 1979;25:137-158. [pmid: 391000].
Makinen KK. Xylitol-based caries prevention: is there enough evidence for the existence of a specific xylitol effect?. Oral Dis. 1998;4:226-230. [pmid: 10200700].
Makinen KK, Bennett CA, Hujoel PP, et al. Xylitol chewing gums and caries rates: a 40-month cohort study. J Dent Res. 1995;74:1904-1913. [pmid: 8600188].
Makinen KK, Chiego DJJ, Allen P, et al. Physical, chemical, and histologic changes in dentin caries lesions of primary teeth induced by regular use of polyol chewing gums. Acta Odontol Scand. 1998;56:148-156. [pmid: 9688223].
Makinen KK, Hujoel PP, Bennett CA, et al. A descriptive report of the effects of a 16-month xylitol chewing-gum programme subsequent to a 40-month sucrose gum programme. Caries Res. 1998;32:107-112. [pmid: 9544858].
Makinen KK, Hujoel PP, Bennett CA, Isotupa KP, Makinen PL, Allen P. Polyol chewing gums and caries rates in primary dentition: a 24-month cohort study. Caries Res. 1996;30:408-417. [pmid: 8946097].
Makinen KK, Makinen PL, Pape HRJ, et al. Stabilisation of rampant caries: polyol gums and arrest of dentine caries in two long-term cohort studies in young subjects. Int Dent J. 1995;45:93-107. [pmid: 7607749].
Makinen KK, Makinen PL, Pape HRJ, et al. Conclusion and review of the Michigan Xylitol Programme (1986-1995) for the prevention of dental caries. Int Dent J. 1996;46:22-34. [pmid: 8744914].
Makinen KK, Pemberton D, Cole J, Makinen PL, Chen CY, Lambert P. Saliva stimulants and the oral health of geriatric patients. Adv Dent Res. 1995;9:125-126. [pmid: 7546130].
Makinen KK, Pemberton D, Makinen PL, et al. Polyol-combinant saliva stimulants and oral health in Veterans Affairs patients--an exploratory study. Spec Care Dentist. 1996;16:104-115. [pmid: 9084323].
Makinen KK, Scheinin A. Turku sugar studies. VI. The administration of the trial and the control of the dietary regimen. Acta Odontol Scand. 1976;34:217-239. [pmid: 795261].
Makinen KK, Scheinin A. Xylitol and dental caries. Annu Rev Nutr. 1982;2:133-150. [pmid: 6764729].
Makinen KK, Soderling E, Isokangas P, Tenovuo J, Tiekso J. Oral biochemical status and depression of Streptococcus mutans in children during 24- to 36-month use of xylitol chewing gum. Caries Res. 1989;23:261-267. [pmid: 2790861].
Makkonen T. Studies on oral complications of head and neck cancer radiotherapy. Proc Finn Dent Soc. 1988;84 (suppl) 4-5:1-111. [pmid: 3405992].
Makkonen TA, Edelman L, Forsten L. Salivary flow and caries prevention in patients receiving radiotherapy. Proc Finn Dent Soc. 1986;82:93-100. [pmid: 3737609].
Mallon DE, Mellberg JR. Analysis of dental hard tissue by computerized microdensitometry. J Dent Res. 1985;64:112-116. [pmid: 3855881].
Mallow PK, Durward CS, Klaipo M. Restoration of permanent teeth in young rural children in Cambodia using the atraumatic restorative treatment (ART) technique and Fuji II glass ionomer cement. Int J Paediatr Dent. 1998;8:35-40. [pmid: 9558544].
Malone WF, Bell C, Massler M. Physicochemical characteristics of active and arrested carious lesions of dentin. J Dent Res. 1966;45:16-26. [pmid: 5216787].
Mandall NA, McCord JF, Blinkhorn AS, Worthington HV, O'Brien KD. Does the ethnicity of teenage children influence oral self perception and prevalence of dental disease?. Br Dent J. 1998;185:358-362. [pmid: 9807920].
Manji F, Fejerskov O, Baelum V. Pattern of dental caries in an adult rural population. Caries Res. 1989;23:55-62. [pmid: 2784073].
Manji F, Fejerskov O, Nagelkerke NJ, Baelum V. A random effects model for some epidemiological features of dental caries. Community Dent Oral Epidemiol. 1991;19:324-328. [pmid: 1764899].
Manji F, Gelbier S, Simmons S. The personnel required to treat first-year children at schools in three London boroughs. Community Medicine. 1983;5:97-103. [pmid: 6872502].
Mann J, Horesh E, Ran F, Gedalia I. The effect of fluoride drop administration on dental caries increment--a longitudinal study. Isr J Dent Sci. 1989;2:148-152. [pmid: 2490929].
Mann J, Karniel C, Triol CW, et al. Comparison of the clinical anticaries efficacy of a 1500 NaF silica-based dentifrice containing triclosan and a copolymer to a 1500 NaF silica-based dentifrice without those additional agents: a study on adults in Israel. J Clin Dent. 1996;7:90-95. [pmid: 9238884].
Mann J, Pettigrew JC, Revach A, Arwas JR, Kochavi D. Assessment of the DMF-S index with the use of bitewing radiographs. Oral Surg Oral Med Oral Pathol. 1989;68:661-665. [pmid: 2812720].
Mann J, Revach A, Call R, Arwas J, Sgan-Cohen H. Prevalence and distribution of caries in a Jerusalem adolescent population by age, sex, and family income. J Public Health Dent. 1989;49:158-162. [pmid: 2788736].
Mann J, Sgan-Cohen HD, Asher RS, Amir E, Cohen S, Sarnat H. A treatment need index: a pilot study. Int J Paediatr Dent. 1993;3:129-134. [pmid: 8260460].
Manning RH, Edgar WM, Agalamanyi EA. Effects of chewing gums sweetened with sorbitol or a sorbitol/xylitol mixture on the remineralisation of human enamel lesions in situ. Caries Res. 1992;26:104-109. [pmid: 1521303].
Mansbridge JN, Brown MD. Changes in dental caries prevalence in Edinburgh children over three decades. Community Dent Health. 1985;2:3-13. [pmid: 3861212].
Maragakis GM, Polychronopoulou A, Papagiannoulis L. Association of cemento-enamel junction--alveolar bone crest distance and proximal caries in primary molars. J Clin Pediatr Dent. 1998;23:45-50. [pmid: 10023233].
Marcenes WS, Sheiham A. Composite indicators of dental health: functioning teeth and the number of sound-equivalent teeth (T-Health). Community Dent Oral Epidemiol. 1993;21:374-378. [pmid: 8306616].
Marchetti C, Piacentini C, Menghini P. Morphometric computerized analysis on the dentinal tubules and the collagen fibers in the dentine of human permanent teeth. Bull Group Int Rech Sci Stomatol Odontol. 1992;35:125-129. [pmid: 1297471].
Marcushamer M, Garcia-Godoy F, Chan DC. Caries protection after orthodontic band cementation with glass ionomer. ASDC J Dent Child. 1993;60:300-303. [pmid: 8258573].
Marcusson A, Norevall LI, Persson M. White spot reduction when using glass ionomer cement for bonding in orthodontics: a longitudinal and comparative study. Eur J Orthod. 1997;19:233-242. [pmid: 9239953].
Margolis FJ. Value of fluoride supplements in prevention of dental caries. Editorial. JAMA. 1975;234:312-313. [pmid: 1174246].
Margolis FJ, Macauley J, Freshman E. The effects of measured doses of fluoride. A five-year preliminary report. Am J Dis Child. 1967;113:670-672. [pmid: 4381737].
Margolis FJ, Reames HR, Freshman E, MaCauley CD, Mehaffey H. Flouride. Ten-year prospective study of deciduous and permanent dentition. Am J Dis Child. 1975;129:794-800. [pmid: 1096595].
Margolis HC, Moreno EC. Composition and cariogenic potential of dental plaque fluid. Crit Rev Oral Biol Med. 1994;5:1-25. [pmid: 7999948].
Margolis HC, Moreno EC. Physicochemical perspectives on the cariostatic mechanisms of systemic and topical fluorides. J Dent Res. 1990;69:606-613. [pmid: 2179321].
Margolis HC, Zhang YP, Lee CY, Kent RLJ, Moreno EC. Kinetics of enamel demineralization in vitro. J Dent Res. 1999;78:1326-1335. [pmid: 10403460].
Marinelli CB, Donly KJ, Wefel JS, Jakobsen JR, Denehy GE. An in vitro comparison of three fluoride regimens on enamel remineralization. Caries Res. 1997;31:418-422. [pmid: 9353580].
Marino RJ, Onetto JE. Caries experience in urban and rural Chilean 3-year-olds. Community Dent Oral Epidemiol. 1995;23:60-61. [pmid: 7774179].
Marken KE, Lofberg PG, Hedegard B. Clinical review of patients with fixed bridges (2). A study of deviations between observers. J Oral Rehabil. 1974;1:391-419. [pmid: 4530834].
Markitziu A, Heling I. Endodontic treatment of patients who have undergone irradiation of the head and neck. A longitudinal follow-up of eleven endodontically treated teeth. Oral Surg Oral Med Oral Pathol. 1981;52:294-298. [pmid: 6945540].
Marks RG, Conti AJ, Moorhead JE, Cancro L, D'Agostino RB. Results from a three-year caries clinical trial comparing NaF and SMFP fluoride formulations. Int Dent J. 1994;44:275-285. [pmid: 7960166].
Marks RG, D'Agostino R, Moorhead JE, Conti AJ, Cancro L. A fluoride dose-response evaluation in an anticaries clinical trial. J Dent Res. 1992;71:1286-1291. [pmid: 1613177].
Marsh PD, Featherstone A, McKee AS, et al. A microbiological study of early caries of approximal surfaces in schoolchildren. J Dent Res. 1989;68:1151-1154. [pmid: 2632599].
Marshall GWJ, Staninec M, Torii Y, Marshall SJ. Comparison of backscattered scanning electron microscopy and microradiography of secondary caries. Scanning Microsc. 1989;3:1043-1049. discussion 1049-1050. [pmid: 2633330].
Marthaler T. Practical aspects of salt fluoridation. SSO Schweiz Monatsschr Zahnheilkd. 1983;93:1197-1214. [pmid: 6582599].
Marthaler TM. Caries-inhibition after seven years of unsupervised use of an amine fluoride dentifrice. Br Dent J. 1968;124:510-515. [pmid: 4385072].
Marthaler TM Caries-inhibition by an amine fluoride dentifrice results after 6 years in children with low caries activity Helvetica Odontologica Acta 1974 18(suppl) 8:35 44 4150790
Marthaler TM Cariostatic efficacy of the combined use of fluorides J Dent Res 1990 69Spec No:797-800;discussion 820 823
Marthaler TM. Confidence limits of results of clinical caries tests with fluoride administration. Caries Res. 1971;5:343-372. [pmid: 4399770].
Marthaler TM. Dental caries 12 years after introduction of a preventive program-preliminary report from seven communities. SSO Schweiz Monatsschr Zahnheilkd. 1977;87:825-828. [pmid: 272055].
Marthaler TM. Estimation of sample size for longitudinal clinical caries trials. Helvetica Odontologica Acta. 1967;11:168-174. [pmid: 4383324].
Marthaler TM. Improvement of diagnostic methods in clinical caries trials. J Dent Res. Spec No. 1984;63:746-751. [pmid: 6373866].
Marthaler TM. Interim report on DMF-reduction 16 years after the introduction of a preventive program. Community Dent Oral Epidemiol. 1981;9:210-214. [pmid: 6952981].
Marthaler TM, Bandi A, Steiner M. Computers in preventive dentistry. Int Dent J. 1980;30:201-213. [pmid: 6934162].
Marthaler TM, Germann M. Radiographic and visual appearance of small smooth surface caries lesions studied on extracted teeth. Caries Res. 1970;4:224-242. [pmid: 5270191].
Marthaler TM, Konig KG, Muhlemann HR. The effect of a fluoride gel used for supervised toothbrushing 15 or 30 times per year. Helvetica Odontologica Acta. 1970;14:67-77. [pmid: 4395021].
Marthaler TM, Moos B. Observations on gingival health in communities with and without school-based preventive programs. J Clin Periodontol. 1983;10:602-608. [pmid: 6581175].
Marthaler TM, Muhlemann HR. Clinical anticaries effect of supervised toothbrushing with fluoride tablets for topical application. Helvetica Odontologica Acta. 1970;14:77-79. [pmid: 4395022].
Marthaler TM, Wiesner V. Rapidity of penetration of radiolucent areas through mesial enamel of first permanent molars. Helvetica Odontologica Acta. 1973;17:19-26. [pmid: 4699375].
Masalin K. Caries-risk-reducing effects of xylitol-containing chewing gum and tablets in confectionery workers in Finland. Community Dent Health. 1992;9:3-10. [pmid: 1617485].
Mass E, Zilberman U. Clinical and radiographic evaluation of partial pulpotomy in carious exposure of permanent molars. Pediatr Dent. 1993;15:257-259. [pmid: 8247900].
Massler M. Changing concepts in the treatment of carious lesions. Br Dent J. 1967;123:547-548. [pmid: 5234627].
Massler M. Pulpal reactions to dental caries. Int Dent J. 1967;17:441-460. [pmid: 5233875].
Massler M, Pawlak J. The affected and infected pulp. Oral Surg Oral Med Oral Pathol. 1977;43:929-947. [pmid: 266685].
Matee MI, Mikx FH, Maselle SY, Van Palenstein Helderman WH. Rampant caries and linear hypoplasia (short communication). Caries Res. 1992;26:205-208. [pmid: 1628296].
Matejka J, Sinwell R, Cleaton-Jones P, et al. Dental caries at five and twelve years in a South African Indian community: a longitudinal study. Int J Epidemiol. 1989;18:423-426. [pmid: 2767857].
Mathiesen AT, Ogaard B, Rolla G. Oral hygiene as a variable in dental caries experience in 14-year-olds exposed to fluoride. Caries Res. 1996;30:29-33. [pmid: 8850580].
Matsson L, Hjersing K, Sjodin B. Periodontal conditions in Vietnamese immigrant children in Sweden. Swed Dent J. 1995;19:73-81. [pmid: 7676388].
Matsson L, Sjodin B, Blomquist HK. Periodontal health in adopted children of Asian origin living in Sweden. Swed Dent J. 1997;21:177-184. [pmid: 9472146].
Matsuda Y, Okano T, Igeta A, Seki K. Effects of exposure reduction on the accuracy of an intraoral photostimulable-phosphor imaging system in detecting incipient proximal caries. Oral Radiol. 1995;11:11-16.
Matsumoto K, Ueda S, Horie T. Pulmonary tuberculosis complicated with tuberculosis of oral mucosa, mandible and cervical lymph nodes. Kekkaku. 1995;70:301-305. [pmid: 7760539].
Matsuo T, Nakanishi T, Shimizu H, Ebisu S. A clinical study of direct pulp capping applied to carious-exposed pulps. J Endod. 1996;22:551-556. [pmid: 9198445].
Matteson SR, Phillips C, Kantor ML, Leinedecker T. The effect of lesion size, restorative material, and film speed on the detection of recurrent caries. Oral Surg Oral Med Oral Pathol. 1989;68:232-237. [pmid: 2674831].
Mattila ML, Paunio P, Rautava P, Ojanlatva A, Sillanpaa M. Changes in dental health and dental health habits from 3 to 5 years of age. J Public Health Dent. 1998;58:270-274. [pmid: 10390708].
Mattos-Graner RdO, Rontani RM, Gaviao MB, Bocatto HA. Caries prevalence in 6-36-month-old Brazilian children. Community Dent Health. 1996;13:96-98. [pmid: 8763140].
Maupome G, Hernandez-Guerrero JC, Garcia-Luna M, Trejo-Alvarado A, Hernandez-Perez M, Diez-de-Bonilla J. In vivo diagnostic assessment of dentinal caries utilizing acid red and povidone-iodine dyes. Oper Dent. 1995;20:119-122. [pmid: 7479189].
Maurer SM, Boggs AM, Mourino AP, Farrington FH. Recall intervals: effect on treatment needs of the handicapped patient: a retrospective study. J Clin Pediatr Dent. 1996;20:123-126. [pmid: 8619971].
Mauriello SM, Bader JD, Disney JA, Graves RC. Examiner agreement between hygienists and dentists for caries prevalence examinations. J Public Health Dent. 1990;50:32-37. [pmid: 2296001].
Mauriello SM, Overman VP, Mann GB. Clinical evaluation of a samarium compound filter and E-speed film. Quintessence Int. 1996;27:769-773. [pmid: 9161270].
McClendon BJ, Driscoll WS, Abrams AM, Barbano JP. A procedure for estimating sample size in clinical trials of dental caries preventives. J Dent Res. 1972;51:1589-1593. [pmid: 4404820].
McClendon BJ, Horowitz HS. Comparability of study groups in clinical trials of caries preventive agents. J Dent Res. 1971;50.
McConchie JM, Richardson AS, Hole LW, McCombie F, Kolthammer. Caries-preventive effect of two concentrations of stannous fluoride mouthrinse. Community Dent Oral Epidemiol. 1977;5:278-283. [pmid: 342181].
McCormick J, Manson-Hing L, Wolff AE, Koulourides T. Remineralizing mouthwash rationale and a pilot clinical study. Ala J Med Sci. 1970;7:92-97. [pmid: 4913754].
McCune RJ. Report on a symposium on chemomechanical caries removal: a multicenter study. Compend Contin Educ Dent. 1986;7:151-152, 154, 156 passim. [pmid: 3514117].
McDonald H, Bassett S, Hargreaves JA, Williamson MF. Dental caries and mutans streptococci levels in preschool children: a community research pilot project. Probe. 1996;30:132-135. [pmid: 9611432].
McDonald SP, Cowell CR, Sheiham A. Methods of preventing dental caries used by dentists for their own children. Br Dent J. 1981;151:118-121. [pmid: 6942867].
McDonald SP, Sheiham A. A clinical comparison of non-traumatic methods of treating dental caries. Int Dent J. 1994;44:465-470. [pmid: 7814117].
McDonald SP, Sheiham A. The distribution of caries on different tooth surfaces at varying levels of caries--a compilation of data from 18 previous studies. Community Dent Health. 1992;9:39-48. [pmid: 1535537].
McGhee Jr, Michalek SM, Webb J, Navia JM, Rahman AF, Legler DW. Effective immunity to dental caries: protection of gnotobiotic rats by local immunization with Streptococcus mutans. J Immunol. 1975;114:300-305. [pmid: 804000].
McInnes-Ledoux P, Ledoux WR, Weinberg R. Bond strength of dentinal bonding agents to chemomechanically prepared dentin. Dent Mater. 1987;3:331-336. [pmid: 3326778].
McKnight-Hanes C, Myers DR, Dushku JC, Barenie JT. A comparison of general dentists' and pediatric dentists' treatment recommendations for primary teeth. Pediatr Dent. 1991;13:344-348. [pmid: 1843990].
Medcalf GW. Ten years of fluoridation in Perth, Western Australia. Aust Dent J. 1978;23:474-476. [pmid: 285668].
Mejare I, Grondahl HG, Carlstedt K, Grever AC, Ottosson E. Accuracy at radiography and probing for the diagnosis of proximal caries. Scand J Dent Res. 1985;93:178-184. [pmid: 3858967].
Mejare I, Kallest lC, Stenlund H. Incidence and progression of approximal caries from 11 to 22 years of age in Sweden: A prospective radiographic study. Caries Res. 1999;33:93-100. [pmid: 9892776].
Mejare I, Kallestal C, Stenlund H, Johansson H. Caries development from 11 to 22 years of age: a prospective radiographic study. Prevalence and distribution. Caries Res. 1998;32:10-16. [pmid: 9438566].
Mejare I, Malmgren B. Clinical and radiographic appearance of proximal carious lesions at the time of operative treatment in young permanent teeth. Scand J Dent Res. 1986;94:19-26. [pmid: 3458277].
Mejare I, Mjor IA. Glass ionomer and resin-based fissure sealants: a clinical study. Scand J Dent Res. 1990;98:345-350. [pmid: 2144660].
Mellberg JR, Blake-Haskins J, Petrou ID, Grote NE. Remineralization and demineralization in situ from a triclosan/co-polymer/fluoride dentifrice. J Dent Res. 1991;70:1441-1443. [pmid: 1960255].
Mellberg JR, Castrovince LA, Rotsides ID. In vivo remineralization by a monofluorophosphate dentifrice as determined with a thin-section sandwich method. J Dent Res. 1986;65:1078-1083. [pmid: 3461023].
Mellberg JR, Franchi GJ, Englander HR, Mosley GW, Nicholson CR. Short intensive topical APF applications and dental caries in a fluoridated area. Community Dent Oral Epidemiol. 1978;6:117-120. [pmid: 357073].
Mellberg JR, Mallon DE. Soluble calcium-enhanced remineralization of artificial caries lesions with monofluorophosphate. Caries Res. 1984;18:416-420. [pmid: 6592042].
Mellberg JR, Nicholson CR. Weekly mouth-rinsing with 3000 ppm of fluoride; the effect of concentration of fluoride in the enamel. J Public Health Dent. 1974;34:2-7. [pmid: 4149311].
Mellberg JR, Nicholson CR, Trubman A. The acquisition of fluoride by tooth enamel in vivo from self-applied APF gel and prophylaxis paste. Caries Res. 1973;7:173-178. [pmid: 4583437].
Mellberg JR, Peterson JK, Nicholson CR. Fluoride uptake and caries inhibition from self-application of an acidulated-phosphate-fluoride prophylaxis paste. Caries Res. 1974;8:52-60. [pmid: 4151959].
Mellberg JR, Petrou ID, Deutchman M, Grote N. The effects of 1% pyrophosphate and 0.02% sodium fluoride on artificial caries lesions in vivo. J Dent Res. 1988;67:1461-1465. [pmid: 2848876].
Mellberg JR, Petrou ID, Fletcher R, Grote N. Evaluation of the effects of a pyrophosphate-fluoride anticalculus dentifrice on remineralization and fluoride uptake in situ. Caries Res. 1991;25:65-69. [pmid: 1649005].
Mellberg JR, Petrou ID, Grote NE. A study of the ability of an in situ remineralization model to differentiate between the effects of two fluoride dentifrices that produced significantly different clinical caries results. J Dent Res. 1992;71:1169-1172. [pmid: 1607435].
Melsen B, Rolla G. Reduced clinical effect of monofluorophosphate in the presence of sodium lauryl sulphate. Caries Res. 1983;17:549-553. [pmid: 6580081].
Mendoza DB, Eakle WS, Kahl EA, Ho R. Root reinforcement with a resin-bonded preformed post. J Prosthet Dent. 1997;78:10-14. [pmid: 9237140].
Mercer VH, Muhler JC. Comparison of single topical applications of sodium fluoride and stannous fluoride. J Dent Res. 1972;51:1325-1330. [pmid: 4403466].
Merrett MC, Elderton RJ. An in vitro study of restorative dental treatment decisions and dental caries. Br Dent J. 1984;157:128-133. [pmid: 6591943].
Mertz-Fairhurst EJ. Current status of sealant retention and caries prevention. J Dent Educ. 1984;48:18-26. [pmid: 6230379].
Mertz-Fairhurst EJ, Call-Smith KM, Shuster GS, et al. Clinical performance of sealed composite restorations placed over caries compared with sealed and unsealed amalgam restorations. J Am Dent Assoc. 1987;115:689-694. [pmid: 3479490].
Mertz-Fairhurst EJ, Curtis JWJ, Ergle JW, Rueggeberg FA, Adair SM. Ultraconservative and cariostatic sealed restorations: results at year 10. J Am Dent Assoc. 1998;129:55-66. [pmid: 9448347].
Mertz-Fairhurst EJ, Della-Giustina VE, Brooks JE, Williams JE, Fairhurst CW. A comparative study of two pit and fissure sealants: results after 4 1/2 years in Augusta, Ga. J Am Dent Assoc. 1981;103:235-238. [pmid: 6455463].
Mertz-Fairhurst EJ, Fairhurst CW, Williams JE, Della-Giustina VE, Brooks JD. A comparative clinical study of two pit and fissure sealants: 7-year results in Augusta, GA. J Am Dent Assoc. 1984;109:252-255. [pmid: 6236247].
Mertz-Fairhurst EJ, Fairhurst CW, Williams JE, Della-Giustina VE, Brooks JD. A comparative clinical study of two pit and fissure sealants: six-year results in Augusta, Ga. J Am Dent Assoc. 1982;105:237-239. [pmid: 6214573].
Mertz-Fairhurst EJ, Richards EE, Williams JE, et al. Sealed restorations: 5-year results. Am J Dent. 1992;5:5-10. [pmid: 1524744].
Mertz-Fairhurst EJ, Schuster GS, Fairhurst CW. Arresting caries by sealants: results of a clinical study. J Am Dent Assoc. 1986;112:194-197. [pmid: 3456377].
Mertz-Fairhurst EJ, Schuster GS, Williams JE, Fairhurst CW. Clinical progress of sealed and unsealed caries. Part I: Depth changes and bacterial counts. J Prosthet Dent. 1979;42:521-526. [pmid: 385850].
Mertz-Fairhurst EJ, Schuster GS, Williams JE, Fairhurst CW. Clinical progress of sealed and unsealed caries. Part II: Standardized radiographs and clinical observations. J Prosthet Dent. 1979;42:633-637. [pmid: 292775].
Mertz-Fairhurst EJ, Smith CD, Williams JE, et al. Cariostatic and ultraconservative sealed restorations: six-year results. Quintessence Int. 1992;23:827-838. [pmid: 1305301].
Mertz-Fairhurst EJ, Williams JE, Pierce KL, et al. Sealed restorations: 4-year results [published erratum appears in Am J Dent 1991 Jun;4(3):122]. Am J Dent. 1991;4:43-49. [pmid: 2003895].
Mertz-Fairhurst EJ, Williams JE, Schuster GS, et al. Ultraconservative sealed restorations: three-year results. J Public Health Dent. 1991;51:239-250. [pmid: 1941777].
Messer JG. An overview of dental care delivery and dental health in Northern Newfoundland and Labrador. Canadian Journal of Community Dentistry. 1988;3:45-53. [pmid: 2485428].
Messer LB, Calache H, Morgan MV. The retention of pit and fissure sealants placed in primary school children by Dental Health Services, Victoria. Aust Dent J. 1997;42:233-239. [pmid: 9316310].
Messer LB, Cline JT. Relative caries experience of sealed versus unsealed permanent posterior teeth: a three-year study. ASDC J Dent Child. 1980;47:175-182. [pmid: 6991560].
Messimer S, Hickner J. Oral fluoride supplementation: improving practitioner compliance by using a protocol. J Fam Pract. 1983;17:821-825. [pmid: 6631346].
Metz JE, Brackett WW. Performance of a glass ionomer luting cement over 8 years in a general practice. J Prosthet Dent. 1994;71:13-15. [pmid: 8120838].
Meurman JH, Helminen SK, Luoma H. Caries reduction over 5 years from a single application of a fissure sealant. Scand J Dent Res. 1978;86:153-156. [pmid: 276913].
Meurman JH, Luoma H, Heikkila H, Rautio P. Caries reduction 1.5 years after application of a fissure sealant as related to dietary habits. Scand J Dent Res. 1975;83:1-6. [pmid: 1056077].
Meyerowitz C, Featherstone JD, Billings RJ, et al. Use of an intra-oral model to evaluate 0.05% sodium fluoride mouthrinse in radiation-induced hyposalivation. J Dent Res. 1991;70:894-898. [pmid: 2022771].
Meyerowitz C, Watson GE. The efficacy of an intraoral fluoride-releasing system in irradiated head and neck cancer patients: a preliminary study. J Am Dent Assoc. 1998;129:1252-1259. [pmid: 9766106].
Mileman P, Purdell-Lewis D, van der Weele L. Effect of variation in caries diagnosis and degree of caries on treatment decisions by dental teachers using bitewing radiographs. Community Dent Oral Epidemiol. 1983;11:356-362. [pmid: 6581000].
Mileman P, Purdell-Lewis DJ, Dummer P, van der Weele L. Diagnosis and treatment decisions when using bitewing radiographs--a comparison between two dental schools. J Dent. 1985;13:140-151. [pmid: 3861634].
Mileman PA, Espelid I. Decisions on restorative treatment and recall intervals based on bitewing radiographs. A comparison between national surveys of Dutch and Norwegian practitioners. Community Dent Health. 1988;5:273-284. [pmid: 3196957].
Mileman PA, Mulder E, van der Weele L. Factors influencing the likelihood of successful decisions to treat dentin caries from bitewing radiographs. Community Dent Oral Epidemiol. 1992;20:175-180. [pmid: 1526099].
Mileman PA, van der Weele LT. Accuracy in radiographic diagnosis: Dutch practitioners and dental caries. J Dent. 1990;18:130-136. [pmid: 2205637].
Mileman PA, van der Weele LT. The role of caries recognition: treatment decisions from bitewing radiographs. Dento Maxillo Facial Radiol. 1996;25:228-233.
Millar BJ, Abiden F, Nicholson JW. In vitro caries inhibition by polyacid-modified composite resins ('compomers'). J Dent. 1998;26:133-136. [pmid: 9540310].
Miller J. Waste of dental pain. Int Dent J. 1978;28:66-71. [pmid: 273571].
Miller J, Vaughan-Williams E, Furlong R, Harrison L. Dental caries and children's weights. J Epidemiol Community Health. 1982;36:49-52. [pmid: 7069355].
Miller JT, Shannon IL. A clinical report. Water-free stannous-fluoride gel and post-irradiation caries. J Public Health Dent. 1972;32.
Miller MB. Restoring Class V lesions Part I: Carious lesions. Pract Periodontics Aesthet Dent. 1997;9:441-442. [pmid: 9550070].
Miller S, Gaffar A, Sullivan R, Heu R, Truong T, Stranick M. Evaluation of a new dentifrice for the treatment of sensitive teeth. J Clin Dent. Spec No. 1994;5:71-79. [pmid: 8534377].
Miller WA. Spread of carious lesions in dentin. J Am Dent Assoc. 1969;78:1327-1330. [pmid: 5253496].
Miller WA, Everett MM. Histochemical studies on calcified tissues. 3. Amino acid histochemistry of carious dentine and dentinal reactions to caries. Caries Res. 1974;8:331-342. [pmid: 4600852].
Millett DT, Nunn JH, Welbury RR, Gordon PH. Decalcification in relation to brackets bonded with glass ionomer cement or a resin adhesive. Angle Orthod. 1999;69:65-70. [pmid: 10022187].
Mills DC, Hollis S. Training for dental screening using clinical photographs. Community Dent Health. 1997;14:245-247. [pmid: 9458583].
Mitchell L, Murray JJ. Fissure sealants: a critique of their cost-effectiveness. Community Dent Oral Epidemiol. 1989;17:19-23. [pmid: 2492915].
Mitropoulos C. DMFS(e) index for selection of clinical trial subjects. Community Dent Oral Epidemiol. 1985;13:30-32. [pmid: 3855731].
Mitropoulos CM. A comparison of fibre-optic transillumination with bitewing radiographs. Br Dent J. 1985;159:21-23. [pmid: 3861187].
Mitropoulos CM. The use of fibre-optic transillumination in the diagnosis of posterior approximal caries in clinical trials. Caries Res. 1985;19:379-384. [pmid: 3861261].
Mitropoulos CM, Holloway PJ, Davies TG, Worthington HV. Relative efficacy of dentifrices containing 250 or 1000 ppm F- in preventing dental caries--report of a 32-month clinical trial. Community Dent Health. 1984;1:193-200. [pmid: 6399218].
Mitropoulos CM, Worthington HV. The effect of different light sources on measuring the prevalence of dental caries. Community Dent Health. 1984;1:111-114. [pmid: 6599383].
Mjor IA. Histologic studies of human coronal dentine following cavity preparations and exposure of ground facets in vivo. Arch Oral Biol. 1967;12:247-263. [pmid: 4164353].
Mjor IA. The location of clinically diagnosed secondary caries. Quintessence Int. 1998;29:313-317. [pmid: 9693650].
Mjor IA. The reasons for replacement and the age of failed restorations in general dental practice. Acta Odontol Scand. 1997;55:58-63. [pmid: 9083578].
Mjor IA. Selection of restorative materials in general dental practice in Sweden. Acta Odontol Scand. 1997;55:53-57. [pmid: 9083577].
Mjor IA, Karlsen K. The interface between dentine and irregular secondary dentine. Acta Odontol Scand. 1970;28:363-376. [pmid: 4987882].
Mjor IA, Qvist V. Marginal failures of amalgam and composite restorations. J Dent. 1997;25:25-30. [pmid: 9080736].
Mobley MJ. Fluoride uptake from in situ brushing with a SnF2 and a NaF dentifrice. J Dent Res. 1981;60:1943-1948. [pmid: 6946109].
Modeer T, Twetman S, Bergstrand F. Three-year study of the effect of fluoride varnish (Duraphat) on proximal caries progression in teenagers. Scand J Dent Res. 1984;92:400-407. [pmid: 6593805].
Mojon P, Favre P, Chung JP, Budtz-Jorgensen E. Examiner agreement on caries detection and plaque accumulation during dental surveys of elders. Gerodontology. 1995;12:49-55. [pmid: 8626181].
Mojon P, MacEntee MI. Estimates of time and propensity for dental treatment among institutionalised elders. Gerodontology. 1994;11:99-107. [pmid: 7750972].
Mojon P, Rentsch A, Budtz-Jorgensen E, Baehni PC. Effects of an oral health program on selected clinical parameters and salivary bacteria in a long-term care facility. Eur J Oral Sci. 1998;106:827-834. [pmid: 9708685].
Molander B. Panoramic radiography in dental diagnostics. Swed Dent J Suppl. 1996;119:1-26. [pmid: 8971997].
Molander B, Ahlqwist M, Grondahl HG. Panoramic and restrictive intraoral radiography in comprehensive oral radiographic diagnosis. Eur J Oral Sci. 1995;103:191-198. [pmid: 7552948].
Molander B, Ahlqwist M, Grondahl HG, Hollender L. Comparison of panoramic and intraoral radiography for the diagnosis of caries and periapical pathology. Dento Maxillo Facial Radiol. 1993;22:28-32.
Molin M, Bergman B, Ericson A. A clinical evaluation of conical crown retained dentures. J Prosthet Dent. 1993;70:251-256. [pmid: 8410733].
Moller IJ. The implementation of field trials. J Dent Res. Spec No:. 1977;56:C136-141. [pmid: 273023].
Moller IJ, Holst JJ, Sorensen E. Caries reducing effect of a sodium monofluorophosphate dentifrice. Br Dent J. 1968;124:209-213. [pmid: 4384257].
Moller IJ, Poulsen S. The effect of sorbitol-containing chewing gum on the incidence of dental caries; plaque and gingivits in Danish schoolchildren. Community Dent Oral Epidemiol. 1973;1:58-67. [pmid: 4153719].
Moller IJ, Poulsen S. A standardized system for diagnosing, recording and analyzing dental caries data. Scand J Dent Res. 1973;81:1-11. [pmid: 4143940].
Moon HS, Jung JY, Horowitz AM, Ma DS, Paik DI. Korean dental hygienists' knowledge and opinions about etiology and prevention of dental caries. Community Dent Oral Epidemiol. 1998;26:296-302. [pmid: 9792120].
Moore DS, Gilpatrick RO, Cloyd JS. Two-year clinical evaluation of preventive resin restorations. Journal of the Tennessee Dental Association. 1994;74:27-30. [pmid: 9520767].
Moore MA, Gregory RL, Switalski LM, Hakki ZW, Gfell LE, Kowolik MJ. Differential activation of human neutrophils by Streptococcus mutans isolates from root surface lesions and caries-free and caries-active subjects. Oral Microbiol Immunol. 1998;13:41-46. [pmid: 9573821].
Moorhead JE, Conti AJ, Marks RG, Cancro LP. The effect of supervised brushing on caries inhibition in school age children. J Clin Dent. 1991;2:97-102. [pmid: 1812906].
Mor BM, Rodda JC. In vitro remineralisation of artificial caries-like lesions with milk. N Z Dent J. 1983;79:10-15. [pmid: 6573578].
Morgan H, Wilson R, Elliott JC, Dowker SE, Anderson P. Cells for the study of acidic dissolution in packed apatite powders as model systems for dental caries. Caries Res. 1998;32:428-434. [pmid: 9745116].
Morgan MV, Campain AC, Adams GG, Crowley SJ, Wright FA. The efficacy and effectiveness of a primary preventive dental programme in non-fluoridated areas of Victoria, Australia. Community Dent Health. 1998;15:263-271. [pmid: 9973728].
Morgan MV, Crowley SJ, Wright C. Economic evaluation of a pit and fissure dental sealant and fluoride mouthrinsing program in two nonfluoridated regions of Victoria, Australia. J Public Health Dent. 1998;58:19-27. [pmid: 9608442].
Morris AJ. Differences in epidemiological findings when changing from the Anglepoise desk lamp to the Daray Versatile Medical Light. Community Dent Health. 1995;12:167-170. [pmid: 7584585].
Mortimer KV. The relationship of deciduous enamel structure to dental disease. Caries Res. 1970;4:206-223. [pmid: 5270190].
Mortimer KV, Tranter TC. A scanning electron microscope study of carious enamel. Caries Res. 1971;5:240-263. [pmid: 5284351].
Mosha HJ, Manji F, Frencken JE, Thaker LS. Changes in dental caries experience of 12-year olds in low fluoride urban and rural areas of Tanzania. East Afr Med J. 1991;68:963-968. [pmid: 1800095].
Mount GJ, Hume WR. A new cavity classification. Aust Dent J. 1998;43:153-159. [pmid: 9707777].
Moystad A, Svanaes DB, Larheim TA, Grondahl HG. Effect of image magnification of digitized bitewing radiographs on approximal caries detection: an in vitro study. Dento Maxillo Facial Radiol. 1995;24:255-259.
Moystad A, Svanaes DB, Risnes S, Larheim TA, Grondahl HG. Detection of approximal caries with a storage phosphor system. A comparison of enhanced digital images with dental X-ray film. Dento Maxillo Facial Radiol. 1996;25:202-206.
Muhammed AH, Manson-Hing LR, Ala B. A comparison of panoramic and intraoral radiographic surveys in evaluating a dental clinic population. Oral Surg Oral Med Oral Pathol. 1982;54:108-117. [pmid: 6956817].
Muhler JC. A clinical comparison of fluoride and antienzyme dentifrices. ASDC J Dent Child. 1970;37.
Muhler JC. A clinical evaluation of the dental caries experience in children receiving a self-applied stannous fluoride-alkali aluminum silicate prophylactic paste during a twelve-month study period. ASDC J Dent Child. 1976;43:345-346. [pmid: 184131].
Muhler JC. Mass treatment of children with a stannous fluoride-zirconium silicate self-administered prophylactic paste for partial control of dental caries. J Am Coll Dent. 1968;35:45-57. [pmid: 4383846].
Muhler JC, Kelley GE, Stookey GK, Lindo FI, Harris NO. The clinical evaluation of a patient-administered SnF2-ZrSiO4 prophylactic paste in children. I. Results after one year in the Virgin Islands. J Am Dent Assoc. 1970;81:142-145. [pmid: 4393436].
Muhler JC, Spear LBJ, Bixler D, Stookey GK. The arrestment of incipient dental caries in adults after the use of three different forms of SnF2 therapy: results after 30 months. J Am Dent Assoc. 1967;75:1402-1406. [pmid: 4383325].
Munk PL, Morgan-Parkes J, Lee MJ, et al. Introduction to panoramic dental radiography in oncologic practice. Am J Roentgenol. 1997;168:939-943. [pmid: 9124144].
Murray JJ. Water fluoridation: a choice for the community. Community Health. 1974;6:75-83. [pmid: 4156510].
Murray JJ, Bennett DL. Topical fluorides and dental caries: a review. J Dent. 1973;2:11-17. [pmid: 4149899].
Murray JJ, Majid ZA. The prevalence and progression of approximal caries in the deciduous dentition in British children. Br Dent J. 1978;145:161-164. [pmid: 279337].
Murray JJ, Shaw L. A 3-year clinical trial into the effect of fluoride content and toothpaste abrasivity on the caries inhibitory properties of a dentifrice. Community Dent Oral Epidemiol. 1980;8:46-51. [pmid: 6989549].
Murray JJ, Shaw L. Errors in diagnosis of approximal caries on bitewing radiographs. Community Dent Oral Epidemiol. 1975;3:276-282. [pmid: 1059515].
Murray JJ, Shaw L, Campbell GA. Distribution of incisor caries in 11- and 12-year old English children. Arch Oral Biol. 1976;21:187-193. [pmid: 1065263].
Murray JJ, Winter GB, Hurst CP. Duraphat fluoride varnish. A 2-year clinical trial in 5-year-old children. Br Dent J. 1977;143:11-17. [pmid: 329846].
Murtomaa H, Al Za'abi F, Morris RE, Metsaniitty M. Caries experience in a selected group of children in Kuwait. Acta Odontol Scand. 1995;53:389-391. [pmid: 8849873].
Myllarniemi S, Kleemola-Kujala E, Hakama M. Oral and dental state in Helsinki preschool children. IV. Caries incidence in the deciduous dentition. Proc Finn Dent Soc. 1973;69:151-156. [pmid: 4148491].
Nabi N, Mukerjee C, Schmid R, Gaffar A. In vitro and in vivo studies on triclosan/PVM/MA copolymer/NaF combination as an anti-plaque agent. Am J Dent. Spec No. 1989;2:197-206. [pmid: 2561629].
Nadanovsky P. Sugar consumption and dental caries. Br Dent J. 1994;177:280-281. [pmid: 7946663].
Nadanovsky P, Sheiham A. Relative contribution of dental services to the changes in caries levels of 12-year-old children in 18 industrialized countries in the 1970s and early 1980s. Community Dent Oral Epidemiol. 1995;23:331-339. [pmid: 8681514].
Nagamine M, Itota T, Torii Y, Irie M, Staninec M, Inoue K. Effect of resin-modified glass ionomer cements on secondary caries. Am J Dent. 1997;10:173-178. [pmid: 9590903].
Nainar SM, Crall JJ. Caries experience in inner-city preschoolers at the time of their initial dental visit. ASDC J Dent Child. 1997;64:421-424. [pmid: 9466014].
Nair MK, Tyndall DA, Ludlow JB, May K. Tuned aperture computed tomography and detection of recurrent caries. Caries Res. 1998;32:23-30. [pmid: 9438568].
Nair MK, Tyndall DA, Ludlow JB, May K, Ye F. The effects of restorative material and location on the detection of simulated recurrent caries. A comparison of dental film, direct digital radiography and tuned aperture computed tomography. Dento Maxillo Facial Radiol. 1998;27:80-84.
Naitoh M, Yuasa H, Toyama M, et al. Observer agreement in the detection of proximal caries with direct digital intraoral radiography. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 1998;85:107-112. [pmid: 9474624].
Nakajima M, Sano H, Burrow MF, et al. Tensile bond strength and SEM evaluation of caries-affected dentin using dentin adhesives. J Dent Res. 1995;74:1679-1688. [pmid: 7499591].
Nakazawa I. A clinical survey of removable partial dentures.--Analysis of follow-up examinations over a sixteen-year period--. Bull Tokyo Med Dent Univ. 1977;24:125-137. [pmid: 322885].
Nance MA, Berry SA. Cockayne Syndrome: Review of 140 cases. Am J Med Genet. 1992;42:68-84. [pmid: 1308368].
Nancy J, Dorignac G. Lactobacilli from the dentin and saliva in children. J Clin Pediatr Dent. 1992;16:107-111. [pmid: 1498044].
Insights on human health. Biofilms, microbial ecology and Antoni van Leeuwenhoek. accessed October 18, 1999. Web Page. Available at: http://www.nidcr.nih.gov/slavkin/biofilms.htm.
Naylor MN, Glass RL. A 3-year clinical trial of calcium carbonate dentifrice containing calcium glycerophosphate and sodium monofluorophosphate. Caries Res. 1979;13:39-46. [pmid: 369697].
Naylor MN, Mainwaring PJ. Clinical trials of dentifrices. Community Dent Oral Epidemiol. 1980;8:273-277. [pmid: 6936130].
Neilson A, Pitts NB. The clinical behaviour of free smooth surface carious lesions monitored over 2 years in a group of Scottish children. Br Dent J. 1991;171:313-318. [pmid: 1742106].
Neilson A, Pitts NB. Development and application of a quantitative method of monitoring macroscopic cavitation in smooth surface carious lesions in vivo. Caries Res. 1993;27:140-146. [pmid: 8319258].
Nemes J, Banoczy J, Wierzbicka M, Rost M. Clinical study on the effect of amine fluoride/stannous fluoride on exposed root surfaces. J Clin Dent. 1992;3:51-53. [pmid: 1524686].
Nevalainen M, Ruokolainen T, Rantanen T, Makila E, Kononen M. Comparison of partial and full crowns as retainers in the same bridge. J Oral Rehabil. 1995;22:673-677. [pmid: 7490666].
Newbrun E. Problems in caries diagnosis [published erratum appears in Int Dent J 1993 Oct;43(5):454]. Int Dent J. 1993;43:133-142. [pmid: 8320007].
Newbrun E. Water fluoridation and dietary fluoride ingestion-an editorial comment. West J Med. 1975;122:437-442. [pmid: 1130042]. [pmcid: 1129769].
Ngo H, Ruben J, Arends J, et al. Electron probe microanalysis and transverse microradiography studies of artificial lesions in enamel and dentin: a comparative study. Adv Dent Res. 1997;11:426-432. [pmid: 9470500].
Nicolatou-Galitis O The role of oral pathology in the radiotherapy of head and neck malignancies ARCH HELL MED Vol 15(5)1998 pp 440 447
Nielsen LL, Hoernoe M, Wenzel A. Radiographic detection of cavitation in approximal surfaces of primary teeth using a digital storage phosphor system and conventional film, and the relationship between cavitation and radiographic lesion depth: an in vitro study. Int J Paediatr Dent. 1996;6:167-172. [pmid: 9115972].
Nikiforuk G, Pulver F. Practical aspects of current caries research and epidemiological data. ASDC J Dent Child. 1969;36:249-252. [pmid: 4893598].
Nirschl RF, Avery DR. Evaluation of a new pulp capping agent in indirect pulp therapy. ASDC J Dent Child. 1983;50:25-30. [pmid: 6572196].
Nishi M, Miyake H. A case-control study of non-T cell acute lymphoblastic leukaemia of children in Hokkaido, Japan. J Epidemiol Community Health. 1989;43:352-355. [pmid: 2614325].
Nishihara E. Comparative study of injury and microhardness to human permanent anterior maxillary and mandibular teeth. Bull Tokyo Dent Coll. 1986;27:135-138. [pmid: 3465475].
Nishihara M, Satoh KI, Yokoyama K, et al. Propofol anesthesia for a patient with nemaline myopathy. Journal of Japanese Dental Society of Anesthesiology. 1999;27:165-169.
Nixon RM, Hembree JHJ, McKnight JP. In vitro effectiveness of topical fluoride under amalgam restorations. J Pedod. 1978;2:106-113. [pmid: 289746].
Noar SJ, Smith BG. Diagnosis of caries and treatment decisions in approximal surfaces of posterior teeth in vitro. J Oral Rehabil. 1990;17:209-218. [pmid: 2348267].
Noorda WD, Purdell-Lewis DJ, van Montfort AM, Weerkamp AH. Monobacterial and mixed bacterial plaques of Streptococcus mutans and Veillonella alcalescens in an artificial mouth: development, metabolism, and effect on human dental enamel. Caries Res. 1988;22:342-347. [pmid: 3214847].
Nordblad A, Larmas M. A 3-year longitudinal caries study of permanent tooth surfaces at risk in Finnish school children. Caries Res. 1985;19:271-277. [pmid: 3873277].
Nordblad A, Larmas M. A cross-sectional study of caries prevalence in Finnish children 6-17 years of age. Proc Finn Dent Soc. 1980;76:245-342. [pmid: 6973152].
Nordblad A, Suominen-Taipale L, Murtomaa H, Vartiainen E, Koskela K. Smart Habit Xylitol campaign, a new approach in oral health promotion. Community Dent Health. 1995;12:230-234. [pmid: 8536087].
Nordbo H, Leirskar J, von der Fehr FR. Saucer-shaped cavity preparations for posterior approximal resin composite restorations: observations up to 10 years. Quintessence Int. 1998;29:5-11. [pmid: 9611469].
Nordenram G, Bergkvist A, Johnson G, Henriksson CO, Anneroth G. Macroscopic and radiographic examination of proximal root surface caries. Acta Odontol Scand. 1988;46:95-99. [pmid: 3164567].
Normark S. Social indicators of dental caries among Sierra Leonean schoolchildren. Scand J Dent Res. 1993;101:121-129. [pmid: 8322004].
Northway WM, Wainright RL, Demirjian A. Effects of premature loss of deciduous molars. Angle Orthod. 1984;54:295-329. [pmid: 6594960].
Novak L, Kvapilova J, Strnad L. Choice of optimum therapeutical strategy in the treatment of complicated tooth caries. Sb Ved Pr Lek Fak Karlovy Univerzity Hradci Kralove. 1971;14:487-620. [pmid: 4946685].
Nowjack-Raymer RE, Selwitz RH, Kingman A, Driscoll WS. The prevalence of dental fluorosis in a school-based program of fluoride mouthrinsing, fluoride tablets, and both procedures combined. J Public Health Dent. 1995;55:165-170. [pmid: 7562730].
Nummikoski PV, Martinez TS, Matteson SR, McDavid WD, Dove SB. Digital subtraction radiography in artificial recurrent caries detection. Dento Maxillo Facial Radiol. 1992;21:59-64.
Nuttall NM. Capability of a national epidemiological survey to predict general dental service treatment. Community Dent Oral Epidemiol. 1983;11:296-301. [pmid: 6578898].
Nuttall NM, Pitts NB. Restorative treatment thresholds reported to be used by dentists in Scotland. Br Dent J. 1990;169:119-126. [pmid: 2206665].
Nuttall NM, Pitts NB, Fyffe HE. Assessment of reports by dentists of their restorative treatment thresholds. Community Dent Oral Epidemiol. 1993;21:273-278. [pmid: 8222600].
Nylen M. Ultrastructure of carious lesions. J Dent Res. 1974;53:290-292. [pmid: 4521684].
Nytun RB, Raadal M, Espelid I. Diagnosis of dentin involvement in occlusal caries based on visual and radiographic examination of the teeth. Scand J Dent Res. 1992;100:144-148. [pmid: 1631482].
Nyvad B, Fejerskov O. Active root surface caries converted into inactive caries as a response to oral hygiene. Scand J Dent Res. 1986;94:281-284. [pmid: 3461550].
Nyvad B, Fejerskov O. Assessing the stage of caries lesion activity on the basis of clinical and microbiological examination. Community Dent Oral Epidemiol. 1997;25:69-75. [pmid: 9088694].
Nyvad B, ten Cate JM, Fejerskov O. Arrest of root surface caries in situ. J Dent Res. 1997;76:1845-1853. [pmid: 9390478].
Nyyssonen V. Epidemiology of dental caries in Finland and the Soviet Union--a joint study. Community Dent Oral Epidemiol. 1983;11.
Nyyssonen V, Paunio I, Borovsky J. Oral health in Finland and the Soviet Union. A joint study. Scand J Soc Med. 1984;12:195-199. [pmid: 6523092].
Nzioka BM, Nyaga JK, Wagaiyu EG. The relationship between tooth brushing frequency and personal hygiene habits in teenagers. East Afr Med J. 1993;70:445-448. [pmid: 8293705].
O'Mullane DM, Clarkson J, Holland T, O'Hickey S, Whelton H. Effectiveness of water fluoridation in the prevention of dental caries in Irish children. Community Dent Health. 1988;5:331-344. [pmid: 3214789].
O'Mullane DM, Kavanagh D, Ellwood RP, et al. A three-year clinical trial of a combination of trimetaphosphate and sodium fluoride in silica toothpastes. J Dent Res. 1997;76:1776-1781. [pmid: 9372795].
O'Neill PA, Brown LR, Dreizen S, Riggan LJ, Handler SF, Perkins DH. Immunoglobulin class of agglutinins to oral microorganisms in post-irradiation cancer patients. J Dent Res. 1981;60:1639-1647. [pmid: 6943156].
O'Reilly MM, Featherstone JD. Demineralization and remineralization around orthodontic appliances: an in vivo study. Am J Orthod Dentofacial Orthop. 1987;92:33-40. [pmid: 3300270].
O'Sullivan DM, Tinanoff N. Maxillary anterior caries associated with increased caries risk in other primary teeth. J Dent Res. 1993;72:1577-1580. [pmid: 8254125].
Oba T, Katayama H. Comparison of orthopantomography with conventional periapical dental radiography. Oral Surg Oral Med Oral Pathol. 1972;34:524-530. [pmid: 4505763].
Obersztyn A, Kolwinski K. Amine fluoride gel in a caries prophylaxis program for soldiers in Poland. Community Dent Oral Epidemiol. 1984;12:288-291. [pmid: 6593147].
Obry-Musset AM, Cahen PM, Turlot JC, Frank RM. Approximal caries diagnosis in epidemiological studies: transillumination or bitewing radiographs?. J Biol Buccale. 1988;16:13-17. [pmid: 3165088].
Ogaard B. Prevalence of white spot lesions in 19-year-olds: a study on untreated and orthodontically treated persons 5 years after treatment. Am J Orthod Dentofacial Orthop. 1989;96:423-427. [pmid: 2816842].
Ogaard B, Arends J, Helseth H, Dijkman G, van der Kuijl M. Fluoride level in saliva after bonding orthodontic brackets with a fluoride containing adhesive. Am J Orthod Dentofacial Orthop. 1997;111:199-202. [pmid: 9057620].
Ogaard B, Duschner H, Ruben J, Arends J. Microradiography and confocal laser scanning microscopy applied to enamel lesions formed in vivo with and without fluoride varnish treatment. Eur J Oral Sci. 1996;104:378-383. [pmid: 8930586].
Ogaard B, Rolla G. Intra-oral models: comparison of in situ substrates. J Dent Res. 1992;71 Spec No:920-923. [pmid: 1592987].
Ogaard B, Rolla G, Ruben J, Arends J. Relative cariostatic effects of KOH-soluble and KOH-insoluble fluoride in situ. J Dent Res. 1990;69:1505-1507. [pmid: 2384626].
Ogaard B, Rolla G, Ruben J, Dijkman T, Arends J. Microradiographic study of demineralization of shark enamel in a human caries model. Scand J Dent Res. 1988;96:209-211. [pmid: 2839893].
Ogaard B, Rosler M. Incidence and prediction of filled teeth from 12 to 18 years of age in a district in Norway. Scand J Dent Res. 1991;99:106-112. [pmid: 2052891].
Ogushi K, Fusayama T. Electron microscopic structure of the two layers of carious dentin. J Dent Res. 1975;54:1019-1026. [pmid: 1058852].
Ohito FA, Opinya GN, Wang'ombe J. Dental caries, gingivitis and dental plaque in handicapped children in Nairobi, Kenya. East Afr Med J. 1993;70:71-74. [pmid: 8513744].
Ohki M, Okano T, Nakamura T. Factors determining the diagnostic accuracy of digitized conventional intraoral radiographs. Dento Maxillo Facial Radiol. 1994;23:77-82.
Ohmori I, Kikuchi K, Masuhara E, Nakabayashi N, Tanaka S. Effect of the methyl methacrylate-tributylborane sealant in preventing occlusal caries. Bull Tokyo Med Dent Univ. 1976;23:149-155. [pmid: 1071430].
Ohrn K, Crossner CG, Borgesson I, Taube A. Accuracy of dental hygienists in diagnosing dental decay. Community Dent Oral Epidemiol. 1996;24:182-186. [pmid: 8871016].
Ohrn R, Enzell K, Angmar-Mansson B. Oral status of 81 subjects with eating disorders. Eur J Oral Sci. 1999;107:157-163. [pmid: 10424378].
Okada K. A study on the preventive effect of dental caries by chlorhexidine mouthwash. J Nihon Univ Sch Dent. 1980;22:65-69. [pmid: 6934272].
Okano T, Huang HJ, Nakamura T. Diagnostic accuracy on detection of proximal enamel lesions in nonscreen radiographic performance. Oral Surg Oral Med Oral Pathol. 1985;59:543-547. [pmid: 3859815].
Oldenburg TR, Vann WFJ, Dilley DC. Composite restorations for primary molars: results after four years. Pediatr Dent. 1987;9:136-143. [pmid: 3475683].
Oliver RG, Oliver SJ, Dummer PM, et al. Loss of the first permanent molar and caries experience of adjacent teeth. Community Dent Health. 1992;9:225-233. [pmid: 1450996].
Olivier M, Brodeur JM, Simard PL. Efficacy of APF treatments without prior toothcleaning targeted to high-risk children. Community Dent Oral Epidemiol. 1992;20:38-42. [pmid: 1547611].
Olson GA, Bleiweis AS, Small PAJ. Adherence inhibition of Streptococcus mutans: an assay reflecting a possible role of antibody in dental caries prophylaxis. Infect Immun. 1972;5:419-427. [pmcid: 422387]. [pmid: 4564674].
Onozawa H, Yasui T, Nakao S. A study on the relationship between selected oral environmental factors and the caries type in infants. Meikai Daigaku Shigaku Zasshi [Journal of Meikai University School of Dentistry]. 1990;19:122-126.
Orams HJ, Sanders JV. Electron diffraction studies of carious and non-carious human enamel. Aust Dent J. 1972;17:9-16. [pmid: 4504770].
Ortendahl T, Thilander B, Svanberg M. Mutans streptococci and incipient caries adjacent to glass ionomer cement or resin-based composite in orthodontics. Am J Orthod Dentofacial Orthop. 1997;112:271-274. [pmid: 9294355].
Ostrom CA. Effectiveness of preventive dentistry delivery system. J Am Dent Assoc. 1978;97:29-36. [pmid: 277572].
Ostrom CA, Koulourides T. The intraoral cariogenicity test in young subjects. Caries Res. 1976;10:442-452. [pmid: 1066186].
Ostrom CA, Koulourides T, Hickman F, McGhee JR. Microbial characterization of an experimental cariogenic plaque in man. J Dent Res. 1977;56:550-558. [pmid: 268335].
Ovrebo RC, Raadal M. Microleakage in fissures sealed with resin or glass ionomer cement. Scand J Dent Res. 1990;98:66-69. [pmid: 2183346].
Owall B. A retrospective 5-year study of dental treatment in a group of elderly persons. Swed Dent J. 1988;12:173-179. [pmid: 3064332].
Ozaki K, Matsuo T, Nakae H, Noiri Y, Yoshiyama M, Ebisu S. A quantitative comparison of selected bacteria in human carious dentine by microscopic counts. Caries Res. 1994;28:137-145. [pmid: 8033185].
Pajari U. Effect of anti-neoplastic therapy on dental hard tissues and saliva in children and adolescents. A clinical and experimental study. Proc Finn Dent Soc. 1988;84 (suppl) 10:1-59. [pmid: 3265518].
Pajari U, Ahola R, Backman T, Hietala EL, Tjaderhane L, Larmas M. Evaluation of Gram's method of staining for the prognosis of root canal treatment in nonvital dental pulps. Oral Surg Oral Med Oral Pathol. 1993;76:91-96. [pmid: 7688887].
Pakhomov GN, Ivanova K, Moller IJ, Vrabcheva M. Dental caries-reducing effects of a milk fluoridation project in Bulgaria. J Public Health Dent. 1995;55:234-237. [pmid: 8551463].
Pakhomov GN, Moller IJ, Atanassov NP, Kabackchieva RI, Sharkov NI. Effect of an amine fluoride dentifrice on dental caries used in a community-based oral health education program. J Public Health Dent. 1997;57:181-183. [pmid: 9383758].
Palamara J, Phakey PP, Rachinger WA, Orams HJ. Laminated zones in carious human dental enamel. J Oral Pathol. 1986;15:109-114. [pmid: 3083060].
Pamuk E, Makuc D, Heck K, Reuben C, Lochner K. Health, United States, 1998. Socioeconomic Status and Health Chartbook. 1998: Hyattsville, MD; National Center for Health Statistics.
Paola PFd, Alman J. Assessment of the reliability of radiographic diagnosis in a clinical caries trial. J Dent Res. 1972;51:1431-1437. [pmid: 4506569].
Papa J, Cain C, Messer HH, Wilson PR. Tunnel restorations versus class II restorations for small proximal lesions: a comparison of tooth strengths. Quintessence Int. 1993;24:93-98. [pmid: 8511270].
Papas A, Joshi A, Giunta J. Prevalence and intraoral distribution of coronal and root caries in middle-aged and older adults. Caries Res. 1992;26:459-465. [pmid: 1294307].
Pape HRJ, Makinen KK. Verification and maintenance of dental explorer sharpness. Oper Dent. 1994;19:221-223. [pmid: 9028241].
Parajas IL. Caries preventive effect of wild tea (tsaang-gubat) among school children. J Philipp Dent Assoc. 1995-1996;47:3-13. [pmid: 9462048].
Pardo GI, Sreebny LM. Management for the highly caries-susceptible patient. J Prosthet Dent. 1992;67:637-644. [pmid: 1527747].
Park SH, Kim KY. The anticariogenic effect of fluoride in primer, bonding agent, and composite resin in the cavosurface enamel area. Oper Dent. 1997;22:115-120. [pmid: 9484149].
Parkins FM. Retention of fluoride with chewable tablets and a mouthrinse. J Dent Res. 1972;51:1346-1349. [pmid: 4560292].
Parks ET, Miles DA, Van Dis ML, Williamson GF, Razmus TF, Bricker SL. Effects of filtration, collimation, and target-receptor distance on artificial approximal enamel lesion detection with the use of RadioVisioGraphy. Oral Surg Oral Med Oral Pathol. 1994;77:419-426. [pmid: 8015809].
Partington MW. Rubinstein-Taybi syndrome: a follow-up study. Am J Med Genet. 1990;(suppl). 6:65-68.
Pass B, Furkart AJ, Dove SB, McDavid WD, Gregson PH. 6-bit and 8-bit digital radiography for detecting simulated periodontal lesions. Oral Surg Oral Med Oral Pathol. 1994;77:406-411. [pmid: 8015807].
Patalay A, Shubhada C, Nadiger SL. Oratest:--a simple, chair-side caries activity test. J Indian Soc Pedod Prev Dent. 1996;14:6-9. [pmid: 9522746].
Patterson CM, Weatherell JA, Robinson C. Sampling of porous hard tissues in vitro by acid etching. Caries Res. 1984;18:231-236. [pmid: 6367988].
Pawilowska-Michalik H, Halawa B, Potoczek S. Proteolytic activity of saliva. Pol Med J. 1969;8:694-698. [pmid: 5807576].
Payne BJ, Ford JC, Locker D. Loss to follow-up in a longitudinal oral health survey of older adults. Community Dent Oral Epidemiol. 1995;23:297-302. [pmid: 8529344].
Pearce EI, Nelson DG. In vivo comparison of caries inhibition by a plaque mineral enriching mouthrinse and a fluoride dentifrice. Caries Res. 1988;22:362-370. [pmid: 3214851].
Peck SD, Briggs GA. A scanning acoustic microscope study of the small caries lesion in human enamel. Caries Res. 1986;20:356-360. [pmid: 3521861].
Peers A, Hill FJ, Mitropoulos CM, Holloway PJ. Validity and reproducibility of clinical examination, fibre-optic transillumination, and bite-wing radiology for the diagnosis of small approximal carious lesions: an in vitro study. Caries Res. 1993;27:307-311. [pmid: 8402807].
Pelagalli J, Gimbel CB, Hansen RT, Swett A, Winn DW2. Investigational study of the use of Er:YAG laser versus dental drill for caries removal and cavity preparation--phase I. J Clin Laser Med Surg. 1997;15:109-115. [pmid: 9612157].
Peltola J, Wolf J. Fibre optics transillumination in caries diagnosis. Proc Finn Dent Soc. 1981;77:240-244. [pmid: 7267640].
Pelton WJ, Bethart H. Student dental health program of the University of Alabama in Birmingham. X. The value of panoramic radiographs. Ala J Med Sci. 1973;10:21-25. [pmid: 4703032].
Peng B, Petersen PE, Tai BJ, Yuan BY, Fan MW. Changes in oral health knowledge and behaviour 1987-95 among inhabitants of Wuhan City, PR China. Int Dent J. 1997;47:142-147. [pmid: 9448800].
Penning C, van Amerongen JP, Seef RE, ten Cate JM. Validity of probing for fissure caries diagnosis. Caries Res. 1992;26:445-449. [pmid: 1294305].
Percinoto C, Cunha RF, Delbem AC, Aragones A. Penetration of a light-cured glass ionomer and a resin sealant into occlusal fissures and etched enamel. Am J Dent. 1995;8:20-22. [pmid: 7546467].
Pereira AC, Basting RT, Pinelli C, de Castro Meneghim M, Werner CW. Retention and caries prevention of Vitremer and Ketac-bond used as occlusal sealants. Am J Dent. 1999;12:62-64. [pmid: 10477984].
Persson LG, Kiliaridis S. Dental injuries, temporomandibular disorders, and caries in wrestlers. Scand J Dent Res. 1994;102:367-371. [pmid: 7871361].
Peters TC, Roeters JJ, Frankenmolen FW. Clinical evaluation of Dyract in primary molars: 1-year results. Am J Dent. 1996;9:83-88. [pmid: 9522693].
Petersen PE, Mzee MO. Oral health profile of schoolchildren, mothers and schoolteachers in Zanzibar. Community Dent Health. 1998;15:256-262. [pmid: 9973727].
Peterson CA, Mauriello SM, Overman VP, Platin E, Tangen CM. Effects of beam collimation on image quality. J Dent Hyg. 1997;71:61-70. [pmid: 9470560].
Peterson JK. A supervised brushing trial of sodium monofluorophosphate dentifrices in a fluoridated area. Caries Res. 1979;13:68-72. [pmid: 285752].
Peterson JK, Horowitz HS, Jordan WA, Pugnier V. Effectiveness of an acidulated phosphate fluoride-pumice prophylactic paste: a two-year report. J Dent Res. 1969;48:346-350. [pmid: 4389149].
Peterson JK, Williamson L. Field test of a sodium fluoride dentifrice containing acid orthophosphate and an insoluble metaphosphate abrasive--second year report. J Oral Ther Pharmacol. 1967;4:1-4. [pmid: 4383235].
Peterson LR, Thomson RBJ. Use of the clinical microbiology laboratory for the diagnosis and management of infectious diseases related to the oral cavity. Infect Dis Clin North Am. 1999;13:775-795. [pmid: 10579108].
Petersson LG, Arthursson L, Ostberg C, Jonsson G, Gleerup A. Caries-inhibiting effects of different modes of Duraphat varnish reapplication: a 3-year radiographic study. Caries Res. 1991;25:70-73. [pmid: 2070384].
Petersson LG, Birkhed D, Gleerup A, Johansson M, Jonsson G. Caries-preventive effect of dentifrices containing various types and concentrations of fluorides and sugar alcohols. Caries Res. 1991;25:74-79. [pmid: 2070385].
Petersson LG, Derand T. Development of artificial carious lesions in enamel after F-varnish (Duraphat) and F-Fe-Al-solution treatment. Swed Dent J. 1981;5:219-223. [pmid: 6949330].
Petersson LG, Kashani H, Birkhed D. In vitro and in vivo studies of an NaF impregnated toothpick. Swed Dent J. 1994;18:69-73. [pmid: 8085219].
Petersson LG, Koch G, Rasmusson CG, Stanke H. Effect on caries of different fluoride prophylactic programs in preschool children. A two year clinical study. Swed Dent J. 1985;9:97-104. [pmid: 3895545].
Petersson LG, Magnusson K, Andersson H, Deierborg G, Twetman S. Effect of semi-annual applications of a chlorhexidine/fluoride varnish mixture on approximal caries incidence in schoolchildren. A three-year radiographic study. Eur J Oral Sci. 1998;106:623-627. [pmid: 9584908].
Petersson LG, Rasmusson CG, Hagborg S, Isacsson P. Fluoride supplemented and non gamma 2 amalgam. A comparative clinical st1889udy into the primary and permanent dentition in children. Swed Dent J. 1985;9:49-53. [pmid: 3892749].
Petersson LG, Svanholm I, Andersson H, Magnusson K. Approximal caries development following intensive fluoride mouthrinsing in teenagers. A 3-year radiographic study [published erratum appears in Eur J Oral Sci 1999 Apr;107(2):154]. Eur J Oral Sci. 1998;106:1048-1051. [pmid: 9879918].
Petersson LG, Twetman S, Pakhomov GN. The efficiency of semiannual silane fluoride varnish applications: a two-year clinical study in preschool children. J Public Health Dent. 1998;58:57-60. [pmid: 9608447].
Petersson LG, Westerberg I. Intensive fluoride varnish program in Swedish adolescents: economic assessment of a 7-year follow-up study on proximal caries incidence. Caries Res. 1994;28:59-63. [pmid: 8124699].
Petti S, Tarsitani G, Panfili P, Simonetti D'Arca A. Oral hygiene, sucrose consumption and dental caries prevalence in adolescent systemic fluoride non-users. Community Dent Oral Epidemiol. 1997;25:334-336. [pmid: 9332814].
Peumans M, Van Meerbeek B, Lambrechts P, Vuylsteke-Wauters M, Vanherle G. Five-year clinical performance of porcelain veneers. Quintessence Int. 1998;29:211-221. [pmid: 9643259].
Peyron M, Mattsson L, Birkhed D. Progression of approximal caries in primary molars and the effect of Duraphat treatment. Scandanavian Journal of Dental Research. 1992;100:314-318.
Phankosol P, Ettinger RL, Hicks MJ, Wefel JS. Depth of penetration of in vitro root surface lesions. J Dent Res. 1985;64:897-899. [pmid: 3858314].
Phantumvanit P, Songpaisan Y, Pilot T, Frencken JE. Atraumatic restorative treatment (ART): a three-year community field trial in Thailand--survival of one-surface restorations in the permanent dentition. J Public Health Dent. 1996;56:141-145. discussion 161-163. [pmid: 8915959].
Phelan JA. Dental lesions: Diagnosis and treatment. Oral Dis. 1997;3:S235-S237. [pmid: 9456696].
Pickles TH. The relationship of caries prevalence data and diagnosed treatment needs in a child population. Med Care. 1970;8:463-473. [pmid: 4395203].
Picton DC. Basis for the use of topical and systemic fluorides in caries prevention. J R Soc Med. 1986;79:18-21. [pmid: 3543354].
Pienihakkinen K, Nemes J, Scheinin A, Banoczy J. Salivary buffering capacity and its relation to caries increment in children. Proc Finn Dent Soc. 1987;83:47-54. [pmid: 3588590].
Pienihakkinen K, Scheinin A, Banoczy J. Screening of caries in children through salivary lactobacilli and yeasts. Scand J Dent Res. 1987;95:397-404. [pmid: 3477853].
Pilebro CE, van Dijken JW, Stenberg R. Durability of tunnel restorations in general practice: a three-year multicenter study. Acta Odontol Scand. 1999;57:35-39. [pmid: 10207534].
Pimenta LA, Fontana UF, Cury JA, Serra MC, Elderton RJ. Inhibition of demineralization in vitro around amalgam restorations. Quintessence Int. 1998;29:363-367. [pmid: 9728147].
Pine CM, Pitts NB, Nugent ZJ. British Association for the Study of Community Dentistry (BASCD) guidance on the statistical aspects of training and calibration of examiners for surveys of child dental health. A BASCD coordinated dental epidemiology programme quality standard. Community Dent Health. 1997;14:18-29.
Pine CM, ten Bosch JJ. Dynamics of and diagnostic methods for detecting small carious lesions. Caries Res. 1996;30:381-388. [pmid: 8946093].
Pink FE, Minden NJ, Simmonds S. Decisions of practitioners regarding placement of amalgam and composite restorations in general practice settings. Oper Dent. 1994;19:127-132. [pmid: 9028231].
Pinkham JR, Kerber PE, Christiansen KC. Fear of dentistry and its possible effects on the success of a preschool prevention program. J Int Assoc Dent Child. 1976;7:3-8.
Pitts NB. Detection of approximal radiolucencies in enamel: a preliminary comparison between experienced clinicians and an image analysis method. J Dent. 1987;15:191-197. [pmid: 3479462].
Pitts NB. The diagnosis of dental caries: 2. The detection of approximal, root surface and recurrent lesions. Dent Update. 1991;18:436-438, 440-442. [pmid: 1843819].
Pitts NB. Diagnostic tools and measurements--impact on appropriate care. Community Dent Oral Epidemiol. 1997;25:24-35. [pmid: 9088689].
Pitts NB. Monitoring of caries progression in permanent and primary posterior approximal enamel by bitewing radiography. Community Dent Oral Epidemiol. 1983;11:228-235. [pmid: 6349915].
Pitts NB, Evans DJ, Nugent ZJ. The dental caries experience of 12-year-old children in the United Kingdom. Surveys coordinated by the British Association for the Study of Community Dentistry in 1996/97. Community Dent Health. 1998;15:49-54. [pmid: 9791616].
Pitts NB, Fyffe HE. The effect of varying diagnostic thresholds upon clinical caries data for a low prevalence group. J Dent Res. 1988;67:592-596. [pmid: 3049719].
Pitts NB, Longbottom C. 'A comparison of bitewing radiography and interdental transillumination as adjuncts to the clinical identification of approximal caries in posterior teeth'. Br Dent J. 1988;164.
Pitts NB, Renson CE. Image analysis of bitewing radiographs: a histologically validated comparison with visual assessments of radiolucency depth in enamel. Br Dent J. 1986;160:205-209. [pmid: 3456782].
Pitts NB, Renson CE. Monitoring the behaviour of posterior approximal carious lesions by image analysis of serial standardised bitewing radiographs. Br Dent J. 1987;162:15-21. [pmid: 3467768].
Pitts NB, Rimmer PA. An in vivo comparison of radiographic and directly assessed clinical caries status of posterior approximal surfaces in primary and permanent teeth. Caries Res. 1992;26:146-152. [pmid: 1521308].
Plackova A. Pathologic changes in the innervation of the dental pulp during the carious process. J Dent Res. 1966;45:62-65. [pmid: 5216800].
Plasschaert AJ, Konig KG. The effect of information and motivation towards dental health, and of fluoride tablets on caries in schoolchildren. I. Increment over the initial 2-year experimental period. Int Dent J. 1974;24:50-65. [pmid: 4151998].
Platin E, Mauriello S, Ludlow JB. Effects of focal spot size on caries diagnosis with D and E speed images. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 1996;81:235-239. [pmid: 8665321].
Pochanugool L, Manomaiudom W, Im-Erbsin T, Suwannuraks M, Kraiphibul P. Dental management in irradiated head and neck cancers. J Med Assoc Thai. 1994;77:261-265. [pmid: 7869009].
Poche C, McCubbrey H, Munn T. The development of correct toothbrushing technique in preschool children. J Appl Behav Anal. 1982;15:315-320. [pmid: 7118761]. [pmcid: 1308274].
Pollack RP. Non-crown and bridge stabilization of severely mobile, periodontally involved teeth. A 25-year perspective. Dent Clin North Am. 1999;43:77-103. [pmid: 9929800].
Poole DF, Shellis RP, Tyler JE. Rates of formation in vitro of dental caries-like enamel lesions in man and some non-human primates. Arch Oral Biol. 1981;26:413-417. [pmid: 6947742].
Poole DF, Silverstone LM. Observations with the scanning electron microscope on trauma-induced micro-cavities in human enamel. Arch Oral Biol. 1969;14:1323-1329. [pmid: 5260896].
Poulsen S, Agerbaek N, Melsen B, Korts DC, Glavind L, Rolla G. The effect of professional toothcleansing on gingivitis and dental caries in children after 1 year. Community Dent Oral Epidemiol. 1976;4:195-199. [pmid: 1067153].
Poulsen S, Gadegaard E, Mortensen B. Cariostatic effect of daily use of a fluoride-containing lozenge compared to fortnightly rinses with 0.2% sodium fluoride. Caries Res. 1981;15:236-242. [pmid: 6938308].
Poulsen S, Holm AK. The relation between dental caries in the primary and permament dentition of the same individual. J Public Health Dent. 1980;40:17-25. [pmid: 6928489].
Poulsen S, Horowitz HS. An evaluation of a hierarchical method of describing the pattern of dental caries attack. Community Dent Oral Epidemiol. 1974;2:7-11. [pmid: 4153274].
Poulsen S, Kirkegaard E. Interim clinical evaluations in caries clinical trials. J Dent Res. 1984;63 Spec No:736-740. [pmid: 6586778].
Poulsen S, Kirkegaard E, Bangsbo G, Bro K. Caries clinical trial of fluoride rinses in a Danish Public Child Dental Service. Community Dent Oral Epidemiol. 1984;12:283-287. [pmid: 6593146].
Poulsen S, Moller IJ, Naerum J, Pedersen PO. Prevalence of dental caries in 2383 Moroccan school children aged eight and twelve. Arch Oral Biol. 1972;17:1165-1175. [pmid: 4403568].
Powell KR, Barnard PD, Craig GG. Effect of stannous fluoride treatments on the progression of initial lesions in approximal surfaces of permanent posterior teeth. J Dent Res. 1981;60:1648-1654. [pmid: 6943157].
Powell LV. Caries prediction: a review of the literature. Community Dent Oral Epidemiol. 1998;26:361-371. [pmid: 9870535].
Powell LV. Caries risk assessment: relevance to the practitioner. J Am Dent Assoc. 1998;129:349-353. [pmid: 9529810].
Pozharitskaya MM, Makarova OV, Kopyeva TN, Morozova LV, Kondratyeva TS. Clinical picture, diagnosis, and therapy of dental manifestations of Sjogren's disease. Stomatologiia (Mosk). 1994;73:25-30. [pmid: 7846707].
Consensus report. Dan Med Bull. 1986;33:199-202. [pmid: 3743136].
Price C, Ergul N. A comparison of a film-based and a direct digital dental radiographic system using a proximal caries model. Dento Maxillo Facial Radiol. 1997;26:45-52.
Primosch RE. A report on the efficacy of fluoridated varnishes in dental caries prevention. Clin Prev Dent. 1985;7:12-22. [pmid: 3913555].
Probster L. Four year clinical study of glass-infiltrated, sintered alumina crowns. J Oral Rehabil. 1996;23:147-151. [pmid: 8667118].
Proskin HM. Statistical considerations related to a meta-analytic evaluation of published caries clinical studies comparing the anticaries efficacy of dentifrices containing sodium fluoride and sodium monofluorophosphate. Am J Dent. 1993;6 Spec No:S43-S49. [pmid: 7488354].
Proskin HM. Statistical considerations related to the use of caries model systems for the determination of clinical effectiveness of therapeutic agents. Adv Dent Res. 1995;9:270-278. discussion 279-289. [pmid: 8615948].
Proskin HM, Chilton NW, Kingman A. Interim report of the ad hoc committee for the consideration of statistical concerns related to the use of intra-oral models in submissions for product claims approval to the American Dental Association. J Dent Res. 1992;71 Spec No:949-952. [pmid: 1592992].
Proskin HM, Volpe AR. Comparison of the anticaries efficacy of dentifrices containing fluoride as sodium fluoride or sodium monofluorophosphate. Am J Dent. 1995;8:51-58. [pmid: 7546476].
Proskin HM, Volpe AR. Meta-analysis in dental research: a paradigm for performance and interpretation. J Clin Dent. 1994;5:19-26. [pmid: 8031485].
Provart SJ, Carmichael CL. The use of an index of material deprivation to identify groups of children at risk to dental caries in County Durham. Community Dent Health. 1995;12:138-142. [pmid: 7584580].
Public health focus: fluoridation of community water. MMWR Morb Mortal Wkly Rep. 1992;41:372-375, 381. [pmid: 1584196].
Puchkoff B. A five year study of the longevity of fissure sealants. ASDC J Dent Child. 1978;45:358-359. [pmid: 279562].
Pugnier VA. Cyanoacrylate resins in caries prevention: a two-year study. J Am Dent Assoc. 1972;84:829-831. [pmid: 4550755].
Purdell-Lewis DJ, Groeneveld A, Arends J. Microhardness and densitometric measurements of the effect of 4% SnF2 solution on artificial white spot lesions. Caries Res. 1976;10:216-226. [pmid: 1063603].
Purdell-Lewis DJ, Pot T. A comparison of radiographic and fibre-optic diagnoses of approximal caries lesions. J Dent. 1974;2:143-148. [pmid: 4531441].
Qu Y, Tan M, Kutner MH. Random effects models in latent class analysis for evaluating accuracy of diagnostic tests. Biometrics. 1996;52:797-810. [pmid: 8805757].
Quade D. Nonparametric analysis of covariance by matching. Biometrics. 1982;38:597-611. [pmid: 7171690].
Qvist V, Johannessen L, Bruun M. Progression of approximal caries in relation to iatrogenic preparation damage. J Dent Res. 1992;71:1370-1373. [pmid: 1629452].
Qvist V, Laurberg L, Poulsen A, Teglers PT. Longevity and cariostatic effects of everyday conventional glass-ionomer and amalgam restorations in primary teeth: three-year results. J Dent Res. 1997;76:1387-1396. [pmid: 9207772].
Qvist V, Thylstrup A, Mjor IA. Restorative treatment pattern and longevity of resin restorations in Denmark. Acta Odontol Scand. 1986;44:351-356. [pmid: 3469863].
Raadal M. Follow-up study of sealing and filling with composite resins in the prevention of occlusal caries. Community Dent Oral Epidemiol. 1978;6:176-180. [pmid: 278699].
Raadal M, Espelid I. Caries prevalence in primary teeth as a predictor of early fissure caries in permanent first molars. Community Dent Oral Epidemiol. 1992;20:30-34. [pmid: 1547609].
Raadal M, Laegreid O, Laegreid KV, Hveem H, Korsgaard EK, Wangen K. Fissure sealing of permanent first molars in children receiving a high standard of prophylactic care. Community Dent Oral Epidemiol. 1984;12:65-68. [pmid: 6584265].
Raadal M, Laegreid O, Laegreid KV, Hveem H, Wangen K. Evaluation of a routine for prevention and treatment of fissure caries in permanent first molars. Community Dent Oral Epidemiol. 1990;18:70-73. [pmid: 2110519].
Raadal M, Milgrom P, Cauce AM, Mancl L. Behavior problems in 5- to 11-year-old children from low-income families. J Am Acad Child Adolesc Psychiatry. 1994;33:1017-1025. [pmid: 7632200].
Raadal M, Utkilen AB, Nilsen OL. Fissure sealing with a light-cured resin-reinforced glass-ionomer cement (Vitrebond) compared with a resin sealant. Int J Paediatr Dent. 1996;6:235-239. [pmid: 9161190].
Raadal M, Utkilen AB, Nilsen OL. A two-year clinical trial comparing the retention of two fissure sealants. Int J Paediatr Dent. 1991;1:77-81. [pmid: 1838281].
Rabchinsky J, Donly KJ. A comparison of glass-ionomer cement and calcium hydroxide liners in amalgam restorations. Int J Periodontics Restorative Dent. 1993;13:378-383. [pmid: 8300324].
Radike AW. Criteria for diagnosis of dental caries. In: Proceedings of the conference on the clinical testing of cariostatic agents. Chicago: American Dental Association; 1968.
Radike AW, Gish CW, Peterson JK, King JD, Segreto VA. Clinical evaluation of stannous fluoride as an anticaries mouthrinse. J Am Dent Assoc. 1973;86:404-408. [pmid: 4404998].
Rahimtoola NS, van Amerongen WE. Comparison of two tooth-saving preparation techniques in a treatment approach of one-surface cavities: design of a study. ASDC J Dent Child. 1997;64:334-339. [pmid: 9391710].
Rahmatulla M, Wyne AH. Classification of cervical burnout and its distribution in the dentition. Indian J Dent Res. 1995;6:13-19. [pmid: 9495097].
Raitio M, Pienihakkinen K, Scheinin A. Assessment of single risk indicators in relation to caries increment in adolescents. Acta Odontol Scand. 1996;54:113-117. [pmid: 8739143].
Raitio M, Pienihakkinen K, Scheinin A. Multifactorial modeling for prediction of caries increment in adolescents. Acta Odontol Scand. 1996;54:118-121. [pmid: 8739144].
Rajala M, Selkainaho K, Paunio I. Relationship between reported toothbrushing and dental caries in adults. Community Dent Oral Epidemiol. 1980;8:128-131. [pmid: 6936107].
Rajasuo A, Murtomaa H, Meurman JH, Ankkuriniemi O. Oral health problems in Finnish conscripts. Mil Med. 1991;156:16-18. [pmid: 1900109].
Ramamurthy NS, Schroeder KL, McNamara TF, et al. Root-surface caries in rats and humans: inhibition by a non-antimicrobial property of tetracyclines. Adv Dent Res. 1998;12:43-50. [pmid: 9972121].
Ran F. Declining dental caries in Jerusalem schoolchildren. Community Dent Oral Epidemiol. 1989;17.
Ran F, Gedalia I, Fried M, Hadani P, Tved A. Effectiveness of fortnightly tooth brushing with amine fluorides in caries-prone subjects. J Oral Rehabil. 1991;18:311-316. [pmid: 1890532].
Randall RC, Wilson NH. Glass-ionomer restoratives: a systematic review of a secondary caries treatment effect. J Dent Res. 1999;78:628-637. [pmid: 10029460].
Rantala EV. Caries incidence in 7-9-year-old children after fissure sealing and topical fluoride therapy in Finland. Community Dent Oral Epidemiol. 1979;7:213-217. [pmid: 293239].
Rao SP, Bharambe MS. Dental caries and periodontal diseases among urban, rural and tribal school children. Indian Pediatr. 1993;30:759-764. [pmid: 8132255].
Rasheed A, Haider M. Antibacterial activity of Camellia sinensis extracts against dental caries. Arch Pharm Res. 1998;21:348-352. [pmid: 9875456].
Rask PI, Emilson CG, Krasse B, Sundberg H. Effect of preventive measures in 50-60-year-olds with a high risk of dental caries. Scand J Dent Res. 1988;96:500-504. [pmid: 3206197].
Ravald N, Birkhed D. Factors associated with active and inactive root caries in patients with periodontal disease. Caries Res. 1991;25:377-384. [pmid: 1747889].
Ravald N, Birkhed D. Prediction of root caries in periodontally treated patients maintained with different fluoride programmes. Caries Res. 1992;26:450-458. [pmid: 1294306].
Raven SJ, Schafer F, Duckworth RM, Gilbert RJ, Parr TA. Comparison between evaluation methods for the anti-caries efficacy of monofluorophosphate-containing dentifrices. Caries Res. 1991;25:130-137. [pmid: 2059974].
Rawls HR, Robert KQJ. GSRI defends dental research program. J La Dent Assoc. 1975;33.
Rayner JA. A dental health education programme, including home visits, for nursery school children. Br Dent J. 1992;172:57-62. [pmid: 1739501].
Rayner JA, Southam JC. Pulp changes in deciduous teeth associated with deep carious dentine. J Dent. 1979;7:39-42. [pmid: 285097].
Razak IA, Esa R, Jalallundin RL, Jaafar N. Utilization, knowledge and attitudes concerning sealants among Malaysian dentists: A national survey. J PEDODONTICS. 1990;14:242-245.
Rebich TJ. School-based preventive dental care: a different view. Am J Public Health. 1985;75:392-394. [pmid: 3976965]. [pmcid: 1646238].
Rebitski G, Donly KJ. Dentin pretreatment and caries inhibition by a fluoride-releasing resin. Am J Dent. 1993;6:204-206. [pmid: 7803010].
Reddy VV, Sugandhan S. A comparison of bitewing radiography and fibreoptic illumination as adjuncts to the clinical identification of approximal caries in primary and permanent molars. Indian J Dent Res. 1994;5:59-64. [pmid: 9495152].
Redman RS, Guccion JG, Spector CJ, Keegan BP. Cellular Schwannoma of the mandible: A case report with ultrastructural and immunohistochemical observations. J Oral Maxillofac Surg. 1996;54:339-344. [pmid: 8600243].
Reed GF. The use of misclassification models in the evaluation of caries clinical trials. J Dent Res. 1984;63 Spec No:727-730. [pmid: 6586776].
Reed MW. Clinical evaluation of three concentrations of sodium fluoride in dentifrices. J Am Dent Assoc. 1973;87:1401-1403. [pmid: 4148037].
Reed MW, King JD. A clinical evaluation of a sodium fluoride dentifrice. Pharmacol Ther Dent. 1975;2:77-82. [pmid: 170634].
Rees JS. Conservative management of a large maxillary cyst. Int Endod J. 1997;30:64-67. [pmid: 9477796].
Reichl P, Farman AG, Scarfe WC, Goldsmith LJ. RVG-S, VIXA, and Ektaspeed film in detection of proximal enamel defects under orthodontic bands. Angle Orthod. 1996;66:65-72. [pmid: 8678348].
Reid JA, Ruprecht A. RAdiologic investigation of caries. Ont Dent. 1975;52:5-11.
Reinhardt JW, Douglass CW, Alman JE, Chauncey HH. The associations of age and dentition status with caries treatment in adult males. J Dent Educ. 1988;52:609-614. [pmid: 3183169].
Reintsema H, Lodding A, Arends J. Fluoridation of partially demineralized human enamel in vivo. A comparison of SIMS and microdrill fluoride analysis. Caries Res. 1986;20:419-423. [pmid: 3463421].
Reisine S, Litt M, Tinanoff N. A biopsychosocial model to predict caries in preschool children. Pediatr Dent. 1994;16:413-418. [pmid: 7854947].
Reisine ST. Dental health and public policy: the social impact of dental disease. Am J Public Health. 1985;75:27-30. [pmid: 3966594]. [pmcid: 1646134].
Rekola M. Correlation between caries incidence and frequency of chewing gum sweetened with sucrose or xylitol. Proc Finn Dent Soc. 1989;85:21-24. [pmid: 2734285].
Rekola M. A planimetric evaluation of approximal caries progression during one year of consuming sucrose and xylitol chewing gums. Proc Finn Dent Soc. 1986;82:213-218. [pmid: 3809161].
Researchers investigate methods to prevent caries on roots and crowns. J Am Dent Assoc. 1992;123.
Restrepo D. Salt fluoridation: an alternate measure to water fluoridation. Int Dent J. 1967;17:4-9. [pmid: 4381629].
Review of the National Preventive Dentistry Demonstration Program. Am J Public Health. 1986;76:434-347. [pmid: 3953922]. [pmcid: 1646509].
Rezk-Lega F, Ogaard B, Arends J. An in vivo study on the merits of two glass ionomers for the cementation of orthodontic bands. Am J Orthod Dentofacial Orthop. 1991;99:162-167. [pmid: 1990826].
Richardson AS, Gibson GB, Waldman R. Chemically polymerized sealant in preventing occlusal caries. J Can Dent Assoc. 1980;46:259-260. [pmid: 6444841].
Richardson AS, Gibson GB, Waldman R. The effectiveness of a chemically polymerized sealant: four-year results. Pediatr Dent. 1980;2:24-26. [pmid: 7001392].
Richardson AS, Hole L, Williams JF. The role of radiographs in clinical studies of caries-inhibitory agents. J Public Health Dent. 1971;31:158-165. [pmid: 4397301].
Richardson AS, Hole LW, McCombie F, Kolthammer J. Anticariogenic effect of dicalcium phosphate dihydrate chewing gum: results after two years. J Can Dent Assoc. 1972;38:213-218. [pmid: 4402288].
Richardson BA, Smith DC, Hargreaves JA. Study of a fissure sealant in mentally retarded Canadian children. Community Dent Oral Epidemiol. 1977;5:220-226. [pmid: 269768].
Richardson PS, McIntyre IG. Dental treatment needs of a cohort of Royal Air Force recruits over 5 years. Community Dent Health. 1996;13:11-16. [pmid: 8634890].
Richardson PS, McIntyre IG. The difference between clinical and bitewing detection of approximal and occlusal caries in Royal Air Force recruits. Community Dent Health. 1996;13:65-69. [pmid: 8763134].
Richmond NL, Stookey GK, Gilmore HW. In vitro and in vivo studies concerning the potential therapeutic effectiveness of a tin-phosphate mouthwash. J Oral Ther Pharmacol. 1967;4:205-213. [pmid: 4865765].
Ricketts D, Kidd E, Smith B, Wilson R. Radiographic detection of occlusal caries: effect of X-ray beam factors on diagnosis. Eur J Prosthodont Restor Dent. 1994;2:149-154. [pmid: 8603138].
Ricketts DN, Kidd EA, Beighton D. Operative and microbiological validation of visual, radiographic and electronic diagnosis of occlusal caries in non-cavitated teeth judged to be in need of operative care. Br Dent J. 1995;179:214-220. [pmid: 8541152].
Ricketts DN, Kidd EA, Liepins PJ, Wilson RF. Histological validation of electrical resistance measurements in the diagnosis of occlusal caries. Caries Res. 1996;30:148-155. [pmid: 8833140].
Ricketts DN, Kidd EA, Smith BG, Wilson RF. Clinical and radiographic diagnosis of occlusal caries: a study in vitro. J Oral Rehabil. 1995;22:15-20. [pmid: 7897553].
Ricketts DN, Kidd EA, Wilson RF. The effect of airflow on site-specific electrical conductance measurements used in the diagnosis of pit and fissure caries in vitro. Caries Res. 1997a;31:111-118. [pmid: 9118182].
Ricketts DN, Kidd EA, Wilson RF. The electronic diagnosis of caries in pits and fissures: site-specific stable conductance readings or cumulative resistance readings?. Caries Res. 1997b;31:119-124. [pmid: 9118183].
Ricketts DN, Kidd EA, Wilson RF. Electronic diagnosis of occlusal caries in vitro: adaptation of the technique for epidemiological purposes. Community Dent Oral Epidemiol. 1997c;25:238-241. [pmid: 9192154].
Ricketts DN, Kidd EA, Wilson RF. A re-evaluation of electrical resistance measurements for the diagnosis of occlusal caries. Br Dent J. 1995;178:11-17. [pmid: 7841012].
Ricketts DN, Watson TF, Liepins PJ, Kidd EA. A comparison of two histological validating techniques for occlusal caries. J Dent. 1998;26:89-96. [pmid: 9540304].
Ricketts DN, Whaites EJ, Kidd EA, Brown JE, Wilson RF. An evaluation of the diagnostic yield from bitewing radiographs of small approximal and occlusal carious lesions in a low prevalence sample in vitro using different film types and speeds. Br Dent J. 1997d;182:51-58. [pmid: 9033139].
Riekman GA. Oral findings of fetal alcohol syndrome patients. J Can Dent Assoc. 1984;50:841-842. [pmid: 6391625].
Riley JC, Lennon MA, Ellwood RP. The effect of water fluoridation and social inequalities on dental caries in 5-year-old children. Int J Epidemiol. 1999;28:300-305. [pmid: 10342695].
Rimmer PA, Pitts NB. Effects of diagnostic threshold and overlapped approximal surfaces on reported caries status. Community Dent Oral Epidemiol. 1991;19:205-212. [pmid: 1889192].
Rimmer PA, Pitts NB. Temporary elective tooth separation as a diagnostic aid in general dental practice. Br Dent J. 1990;169:87-92. [pmid: 2206652].
Ringelberg ML, Webster DB, Dixon DO, LeZotte DC. The caries-preventive effect of amine fluorides and inorganic fluorides in a mouthrinse or dentifrice after 30 months of use. J Am Dent Assoc. 1979;98:202-208. [pmid: 284065].
Ringelberg ML, Webster DBJ, Dixon DO. Effects of an amine fluoride dentifrice and mouthrinse on the dental caries of school children after 18 months. J Prev Dent. 1978;5:26-30.
Ringleberg ML, Conti AJ, Webster DB. An evaluation of single and combined self-applied fluoride programs in schools. J Public Health Dent. 1976;36:229-236. [pmid: 1067428].
Riordan PJ. Fluoride supplements for young children: an analysis of the literature focusing on benefits and risks. Community Dent Oral Epidemiol. 1999;27:72-83. [pmid: 10086929].
Riordan PJ. The place of fluoride supplements in caries prevention today. Aust Dent J. 1996;41:335-342. [pmid: 8961608].
Riordan PJ, Dalton-Ecker L, Edwards TS. Dental status of 12-year-olds treated in private practice and a school dental service. Community Dent Oral Epidemiol. 1993;21:198-202. [pmid: 8370255].
Riordan PJ, Espelid I, Tveit AB. Radiographic interpretation and treatment decisions among dental therapists and dentists in Western Australia. Community Dent Oral Epidemiol. 1991;19:268-271. [pmid: 1742991].
Ripa LW. Clinical studies of high-potency fluoride dentifrices: a review. J Am Dent Assoc. 1989;118:85-91. [pmid: 2643652].
Ripa LW. An evaluation of the use of professional (operator-applied) topical fluorides. J Dent Res. 1990;69:786-796. [pmid: 2179342].
Ripa LW. The histology of the early carious lesion in primary teeth with special reference to a 'prismless' outer layer of primary ename. l. J Dent Res. 1966;45:5-11. [pmid: 5216799].
Ripa LW. Occlusal sealants: rationale and review of clinical trials. Int Dent J. 1980;30:127-139. [pmid: 6997215].
Ripa LW. Professionally (operator) applied topical fluoride therapy: a critique. Int Dent J. 1981;31:105-120. [pmid: 7019097].
Ripa LW, Leske GS, Forte F. The combined use of pit and fissure sealants and fluoride mouthrinsing in second and third grade children: final clinical results after two years. Pediatr Dent. 1987;9:118-120. [pmid: 2956578].
Ripa LW, Leske GS, Forte F, Varma A. Caries inhibition of mixed NaF-Na2PO3F dentifrices containing 1,000 and 2,500 ppm F: 3-year results. J Am Dent Assoc. 1988;116:69-73. [pmid: 3422667].
Ripa LW, Leske GS, Forte F, Varma A. Effect of a 0.05% neutral NaF mouthrinse on coronal and root caries of adults. Gerodontology. 1987;6:131-136. [pmid: 3508750].
Ripa LW, Leske GS, Kaufman HW. Caries prevalence, treatment level, and sealant use related to school lunch program participation. J Public Health Dent. 1991;51:78-81. [pmid: 2072353].
Ripa LW, Leske GS, Levinson A. Supervised weekly rinsing with a 0.2% neutral NaF solution: results from a demonstration program after two school years. J Am Dent Assoc. 1978;97:793-798. [pmid: 281418].
Ripa LW, Leske GS, Sposato A. Relative contributions of the dental examiner and local dentists in determining the caries status of subjects in field studies. Caries Res. 1983;17:152-155. [pmid: 6337713].
Ripa LW, Leske GS, Sposato A. The surface-specific caries pattern of participants in a school-based fluoride mouthrinsing program with implications for the use of sealants. J Public Health Dent. 1985;45:90-94. [pmid: 3859663].
Ripa LW, Leske GS, Sposato A, Varma A. Clinical comparison of the caries inhibition of two mixed NaF-Na2PO3F dentifrices containing 1,000 and 2,500 ppm F compared to a conventional Na2PO3F dentifrice containing 1,000 ppm F: results after two years. Caries Res. 1987;21:149-157. [pmid: 3469030].
Ripa LW, Leske GS, Sposato A, Varma A. Effect of prior toothcleaning on biannual professional APF topical fluoride gel-tray treatments. Results after two years. Clin Prev Dent. 1983;5:3-7.
Ripa LW, Leske GS, Triol CW, Volpe AR. Clinical study of the anticaries efficacy of three fluoride dentifrices containing anticalculus ingredients: three-year (final) results. J Clin Dent. 1990;2:29-33. [pmid: 1965288].
Ripa LW, Leske GS, Varma AO. Longitudinal study of the caries susceptibility of occlusal and proximal surfaces of first permanent molars. J Public Health Dent. 1988;48:8-13. [pmid: 3422320].
Ripa LW, Levinson A, Leske GS. Supervised weekly rinsing with a 0.2% neutral NaF solution: results from a demonstration program after three school years. J Am Dent Assoc. 1980;100:544-546. [pmid: 6928894].
Risager J, Poulsen S. Fissure sealing with Nuva-Seal in a public health program for Danish schoolchildren after 12 months' observation. Scand J Dent Res. 1974;82:570-573. [pmid: 4156089].
Rizoiu I, Kohanghadosh F, Kimmel AI, Eversole LR. Pulpal thermal responses to an erbium,chromium: YSGG pulsed laser hydrokinetic system. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 1998;86:220-223. [pmid: 9720098].
Robbins A. Efficacy of GK101E solution (Caridex 100) for caries removal. Gen Dent. 1987;35:392-396. [pmid: 3481725].
Roberts JF, Sherriff M. The fate and survival of amalgam and preformed crown molar restorations placed in a specialist paediatric dental practice [published erratum appears in Br Dent J 1990 Nov 10;169(9):285]. Br Dent J. 1990;169:237-244. [pmid: 2147106].
Roberts MW, Folio J, Moffa JP, Guckes AD. Clinical evaluation of a composite resin system with a dentin bonding agent for restoration of permanent posterior teeth: a 3-year study. J Prosthet Dent. 1992;67:301-306. [pmid: 1507089].
Robinson C, Hallsworth AS, Shore RC, Kirkham J. Effect of surface zone deproteinisation on the access of mineral ions into subsurface carious lesions of human enamel. Caries Res. 1990;24:226-230. [pmid: 2276155].
Robinson PG, Nadanovsky P, Sheiham A. Can questionnaires replace clinical surveys to assess dental treatment needs of adults?. J Public Health Dent. 1998;58:250-253. [pmid: 10101703].
Robison VA, Rozier RG, Weintraub JA. Dental caries and treatment need in schoolchildren related to Medicaid enrollment. J Public Health Dent. 1997;57:163-170. [pmid: 9383755].
Robison VA, Rozier RG, Weintraub JA, Koch GG. The relationship between clinical tooth status and receipt of sealants among child Medicaid recipients. J Dent Res. 1997;76:1862-1868. [pmid: 9390480].
Rock WP. Fissure sealants. Further results of clinical trials. Br Dent J. 1974;136:317-21. [pmid: 4616709].
Rock WP. Fissure sealants. Results obtained with two different bis-GMA type sealants after one year. Br Dent J. 1973;134:193-196. [pmid: 4572363].
Rock WP. Fissure sealants. Results obtained with two different sealants after one year. Br Dent J. 1972;133:146-151. [pmid: 4561788].
Rock WP, Bradnock G. Effect of operator variability and patient age on the retention of fissure sealant resin: 3-year results. Community Dent Oral Epidemiol. 1981;9:207-209. [pmid: 7044665].
Rock WP, Evans RI. A comparative study between a chemically polymerised fissure sealant resin and a light cured resin. Br Dent J. 1982;152:232-234. [pmid: 6212072].
Rock WP, Foulkes EE, Perry H, Smith AJ. A comparative study of fluoride-releasing composite resin and glass ionomer materials used as fissure sealants. J Dent. 1996;24:275-280. [pmid: 8783533].
Rock WP, Gordon PH, Bradnock G. Caries experience in West Midland school children following fluoridation of Birmingham water in 1964. Caries of first permanent molars. Br Dent J. 1981;150:269-273. [pmid: 6940608].
Rock WP, Gordon PH, Bradnock G. Dental caries experience in Birmingham and Wolverhampton school children following the fluoridation in Birmingham water in 1964. Method and overall caries experience in the two populations. Br Dent J. 1981;150:61-66. [pmid: 6936038].
Rock WP, Kidd EA. The electronic detection of demineralisation in occlusal fissures. Br Dent J. 1988;164:243-247. [pmid: 3164192].
Rodda JC. Impregnation of caries-like lesions with dental resins. N Z Dent J. 1983;79:114-117. [pmid: 6582400].
Rodda JC, McGregor IG, McDowell JM. Remineralisation of artificial enamel lesions with a phosphate-fluoride solution. N Z Dent J. 1979;75:80-86. [pmid: 289000].
Roder DM. Diagnosis, treatment planning and referral by school dental therapists. Aust Dent J. 1974;19:242-249. [pmid: 4155944].
Roeters FJ, van der Hoeven JS, Burgersdijk RC, Schaeken MJ. Lactobacilli, mutants streptococci and dental caries: a longitudinal study in 2-year-old children up to the age of 5 years. Caries Res. 1995;29:272-279. [pmid: 7656296].
Roeters FJ, Verdonschot EH, Bronkhorst EM, van 't Hof MA. Prediction of the need for bitewing radiography in detecting caries in the primary dentition. Community Dent Oral Epidemiol. 1994;22:456-460. [pmid: 7882663].
Roeters J, Burgersdijk R, Truin GJ, van 't Hof M. Dental caries and its determinants in 2-to-5-year-old children. ASDC J Dent Child. 1995;62:401-408. [pmid: 8636475].
Rolla G, Saxegaard E. Critical evaluation of the composition and use of topical fluorides, with emphasis on the role of calcium fluoride in caries inhibition. J Dent Res. 1990;69:780-785. [pmid: 2179341].
Romcke RG, Lewis DW, Maze BD, Vickerson RA. Retention and maintenance of fissure sealants over 10 years. J Can Dent Assoc. 1990;56:235-237. [pmid: 2184918].
Roncone RM. A study of remineralization of carious dentin with CMC. A progress report. Dental Images. 1969;8:18-19. [pmid: 4952712].
Rosen B, Birkhed D, Nilsson K, Olavi G, Egelberg J. Reproducibility of clinical caries diagnoses on coronal and root surfaces. Caries Res. 1996;30:1-7. [pmid: 8850576].
Rosen H. Salvaging abutment teeth undermined by root surface caries. Oral Health. 1997;87:30-36. [pmid: 9468970].
Rosenberg HM. Dental radiology: Role of plain radiographic examination. Radiol Clin North Am. 1993;31:91-100. [pmid: 8419982].
Rosin-Grget K, Lincir I. Anticaries effect of different amine fluoride concentrations in schoolchildren. Caries Res. 1995;29:168-171. [pmid: 7621490].
Roth AG, Conry JP. A retrospective cohort evaluation of preventive resin restorations. J Can Dent Assoc. 1992;58:223-226. [pmid: 1555126].
Rothman MS. Formocresol pulpotomy: a practical procedure for permanent teeth. Gen Dent. 1977;25:39-41. [pmid: 332583].
Rotta J, Tikhomirov E. Streptococcal diseases worldwide: Present status and prospects. Bull World Health Organ. 1987;65:769-777. [pmid: 3325183].
Rowles SL, Levine RS. The inorganic composition of arrested carious dentine. Caries Res. 1973;7:360-367. [pmid: 4518090].
Roydhouse RH. Possible caries prevention by fissure sealants. Aust Dent J. 1973;18:63-67. [pmid: 4515703].
Rozier RG, Spratt CJ, Koch GG, Davies GM. The prevalence of dental sealants in North Carolina schoolchildren. J Public Health Dent. 1994;54:177-183. [pmid: 7932354].
Rudney JD, Katz RV, Brand JW. Interobserver reliability of methods for paleopathological diagnosis of dental caries. Am J Phys Anthropol. 1983;62:243-248. [pmid: 6362425].
Rudolphy MP, Gorter Y, van Loveren C, Poorterman JH, van Amerongen JP. Progression of radiopacities and radiolucencies under amalgam restorations on bite-wing radiographs. Caries Res. 1997;31:19-23. [pmid: 8955989].
Rudolphy MP, Gorter Y, van Loveren C, van Amerongen JP. Validity of radiographs for diagnosis of secondary caries in teeth with class II amalgam restorations in vitro. Caries Res. 1997;31:24-29. [pmid: 8955990].
Rudolphy MP, van Amerongen JP, Penning C, ten Cate JM. Grey discolouration and marginal fracture for the diagnosis of secondary caries in molars with occlusal amalgam restorations: an in vitro study. Caries Res. 1995;29:371-376. [pmid: 8521439].
Rudolphy MP, van Amerongen JP, Penning C, ten Cate JM. Validity of bite-wings for diagnosis of secondary caries in teeth with occlusal amalgam restorations in vitro. Caries Res. 1993;27:312-316. [pmid: 8402808].
Rudolphy MP, van Loveren C, van Amerongen JP. Grey discoloration for the diagnosis of secondary caries in teeth with class II amalgam restorations: an in vitro study. Caries Res. 1996;30:189-193. [pmid: 8860028].
Ruffalo RC, Nazif MM, Zullo T, Winkler ME. A comparative study of three radiographic surveys in preschool children. ASDC J Dent Child. 1983;50:422-424. [pmid: 6581181].
Rugarabamu P, Frencken JE, Amuli JA, Lihepa A. Caries experience amongst 12- and 15-year-old Tanzanian children residing on a sugar estate. Community Dent Health. 1990;7:53-58. [pmid: 2357608].
Rugg-Gunn AJ. Approximal carious lesions. A comparison of the radiological and clinical appearances. Br Dent J. 1972;133:481-484. [pmid: 4511888].
Rugg-Gunn AJ, Carmichael CL, French AD, Furness JA. Fluoridation in Newcastle and Northumberland. A clinical study of 5-year-old children. Br Dent J. 1977;142:395-402. [pmid: 267489].
Rugg-Gunn AJ, Downer MC, Ashley FP. Reliability of caries data in three clinical trials. Community Dent Oral Epidemiol. 1976;4:15-18. [pmid: 1061647].
Rugg-Gunn AJ, Holloway PJ, Davies TG. Caries prevention by daily fluoride mouthrinsing. Report of a three-year clinical trial. Br Dent J. 1973;135:353-360. [pmid: 4147708].
Ruiken R, Truin GJ, Konig K, Vogels A, van 't Hof M. Clinical cariostatic effectiveness of a NaF rinse in a low prevalence child population. Community Dent Oral Epidemiol. 1987;15:57-59. [pmid: 3471376].
Rule JT, Smith MR, Truelove RB, Macko DJ, Castaldi CR. Caries inhibition of a dentifrice containing 0.78% sodium monofluorophosphate in a silica base. Community Dent Oral Epidemiol. 1984;12:213-217. [pmid: 6088166].
Rushton VE, Horner K. The use of panoramic radiology in dental practice. J Dent. 1996;24:185-201. [pmid: 8675790].
Rushton VE, Horner K, Worthington HV. A two-centre study to determine dentists' agreement with current guidelines on the frequency of bitewing radiography. Community Dent Oral Epidemiol. 1996;24:175-181. [pmid: 8871015].
Russell BA, Horowitz AM, Frazier PJ. School-based preventive regimens and oral health knowledge and practices of sixth graders. J Public Health Dent. 1989;49:192-200. [pmid: 2810213].
Russell M, Pitts NB. Radiovisiographic diagnosis of dental caries: initial comparison of basic mode videoprints with bitewing radiography. Caries Res. 1993;27:65-70. [pmid: 8448777].
Rutherford RB. Technology transfer: Incentives and disincentives. Technol Health Care. 1996;4:347-351. [pmid: 8931246].
Ryge G. The future of pit & fissure sealants. J Am Soc Prev Dent. 1973;3:54-57. [pmid: 4620520].
Rytomaa I. Diagnostic criteria in epidemiological caries studies. Proc Finn Dent Soc. 1986;82:245-253. [pmid: 3547397].
Rytomaa I, Jarvinen V, Calonius PE. 44-year dental health survey of Helsinki schoolchildren. Community Dent Oral Epidemiol. 1980;8:66-67. [pmid: 6929245].
Rytomaa I, Jarvinen V, Kanerva R, Heinonen OP. Bulimia and tooth erosion. Acta Odontol Scand. 1998;56:36-40. [pmid: 9537733].
Sabelli CA, Moguillansky E, Bernat MI, et al. Is Streptococcus mutans adherence saliva test predictive for caries?. Acta De Odontologia Pediatrica. 1987;8:53-56. [pmid: 3483323].
Sadowsky PL, Retief DH, Bradley ELJ. Acid resistance of enamel exposed to fluoride-containing orthodontic cements. Am J Orthod. 1983;83:33-37. [pmid: 6571769].
Saemundsson SR, Bergmann H, Magnusdottir MO, Holbrook WP. Dental caries and Streptococcus mutans in a rural child population in Iceland. Scand J Dent Res. 1992;100:299-303. [pmid: 1411275].
Sakkab NY, Cilley WA, Haberman JP. Fluoride in deciduous teeth from an anti-caries clinical study. J Dent Res. 1984;63:1201-1205. [pmid: 6592201].
Sakki TK, Knuuttila ML, Vimpari SS, Kivela SL. Lifestyle, dental caries and number of teeth. Community Dent Oral Epidemiol. 1994;22:298-302. [pmid: 7813180].
Salapata GJ, Bakoula C, Hawley GM, Blinkhorn AS. A five year follow up into changes in caries experience amongst a sample of 12 year old children from Athens. Int Dent J. 1995;45:160-162. [pmid: 7558353].
Saleh N, Peretz B, Rehany Al, Zyskind D, Hirschfeld Z, Stark M. One-year clinical evaluation of an anterior composite resin. Quintessence Int. 1992;23:559-567. [pmid: 1410261].
Salonen L, Allander L, Bratthall D, Togelius J, Hellden L. Oral health status in an adult Swedish population. Prevalence of caries. A c2123ross-sectional epidemiological study in the Northern Alvsborg county. Swed Dent J. 1989;13:111-123. [pmid: 2787937].
Salvolini E, Di Giorgio R, Curatola A, Mazzanti L, Fratto G. Biochemical modifications of human whole saliva induced by pregnancy. Br J Obstet Gynaecol. 1998;105:656-660. [pmid: 9647157].
Samuelson G, Blomquist HK, Crossner CG, Holm AK, Grahnen H. An epidemiological study of child health and nutrition in a northern Swedish county. VII. A comparative study of general and dental health, food habits and socio-economic conditions in 4-year-old children. Acta Paediatr Scand. 1975;64:241-247. [pmid: 1130180].
Sanders BJ, Smith CE. The use of sealants by Indiana dentists. J Indiana Dent Assoc. 1997;76:11-12, 14. [pmid: 9517337].
Sandham HJ, Brown J, Chan KH, Phillips HI, Burgess RC, Stokl AJ. Clinical trial in adults of an antimicrobial varnish for reducing mutans streptococci. J Dent Res. 1991;70:1401-1408. [pmid: 1960249].
Sandy J, Williams A, Mildinhall S, et al. The Clinical Standards Advisory Group (CSAG) Cleft Lip and Palate Study. Br J Orthod. 1998;25:21-30. [pmid: 9547971].
Sanjo D. Changes in decalcified carious dentin beneath amalgam restorations. J Dent Res. 1971;50.
Santini A. The clinical assessment of the pulpotomy technique on teeth of various post-eruptive age groups. A four year assessment using standardized clinical methods (I). Quintessence Int. 1980;11:73-77. [pmid: 6940206].
Santini A. The diagnosis, classification and treatment of acute pulpal pain by UK general dental practitioners: results of a survey. Prim Dent Care. 1996;3:24-27. [pmid: 8941806].
Sawle RF, Andlaw RJ. Has occlusal caries become more difficult to diagnose? A study comparing clinically undetected lesions in molar teeth of 14-16-year old children in 1974 and 1982 [published erratum appears in Br Dent J 1988 Jun 11;164(11):361]. Br Dent J. 1988;164:209-211. [pmid: 3163930].
Sawusch RH. Direct and indirect pulp capping with two new products. J Am Dent Assoc. 1982;104:459-462. [pmid: 6950974].
Sayegh A, Shehabi A, Hilow H. Multifactorial modelling for caries prediction in Jordanian university students. Community Dent Health. 1997;14:97-101. [pmid: 9225539].
Scarfe WC, Langlais RP, Nummikoski P, et al. Clinical comparison of two panoramic modalities and posterior bite-wing radiography in the detection of proximal dental caries. Oral Surg Oral Med Oral Pathol. 1994;77:195-207. [pmid: 8139839].
Schaeken MJ, Keltjens HM, Van Der Hoeven JS. Effects of fluoride and chlorhexidine on the microflora of dental root surfaces and progression of root-surface caries. J Dent Res. 1991;70:150-153. [pmid: 1991872].
Schafer F. Evaluation of the anticaries benefit of fluoride toothpastes using an enamel insert model. Caries Res. 1989;23:81-86. [pmid: 2743379].
Schafer F, Raven SJ, Parr TA. The effect of lesion characteristic on remineralization and model sensitivity. J Dent Res. 1992;71 Spec No:811-813. [pmid: 1592964].
Schatz A. Failure of fluoridation in Chile. A critical analysis after eleven years. J Nihon Univ Sch Dent. 1967;9:209-212. [pmid: 4386161].
Scheie AA, Fejerskov OB. Xylitol in caries prevention: what is the evidence for clinical efficacy?. Oral Dis. 1998;4:268-278. [pmid: 10200706].
Scheie AA, Selikowitz HS, Arneberg P. A comparison of S. mutans prevalence in relation to caries experience in Norwegian and immigrant Vietnamese children. J Dent Res. 1984;63:1383-1386. [pmid: 6595290].
Scheinin A. Caries control through the use of sugar substitutes. Int Dent J. 1976;26:4-13. [pmid: 1062357].
Scheinin A. Dietary carbohydrates and dental disorders. Am J Clin Nutr. 1987;45:1218-1225. [pmid: 3554970].
Scheinin A. Field studies on sugar substitutes. Int Dent J. 1985;35:195-200. [pmid: 3902660].
Scheinin A. Sugar substitutes in relation to the incidence of clinical and experimental caries. Pharmacol Ther Dent. 1978;3:95-100. [pmid: 286374].
Scheinin A. Xylitol in relation to the incidence of dental caries. Int Z Vitam Ernahrungsforsch Beih. 1976;15:358-67. [pmid: 1066333].
Scheinin A, Banoczy J. Xylitol and caries: the collaborative WHO oral disease preventive programme in Hungary. Int Dent J. 1985;35:50-57. [pmid: 3858229].
Scheinin A, Makinen KK, Tammisalo E, Rekola M. Turku sugar studies XVIII. Incidence of dental caries in relation to 1-year consumption of xylitol chewing gum. Acta Odontol Scand. 1975;33:269-278. [pmid: 1067728].
Scheinin A, Makinen KK, Ylitalo K. Turku sugar studies. V. Final report on the effect of sucrose, fructose and xylitol diets on the caries incidence in man. Acta Odontol Scand. 1976;34:179-216. [pmid: 795260].
Scheinin A, Pienihakkinen K, Tiekso J, Holmberg S, Fukuda M, Suzuki A. Multifactorial modeling for root caries prediction: 3-year follow-up results. Community Dent Oral Epidemiol. 1994;22:126-129. [pmid: 8205779].
Scheinin A, Soderling E, Scheinin U, Glass RL, Kallio ML. Xylitol-induced changes of enamel microhardness paralleled by microradiographic observations. Acta Odontol Scand. 1993;51:241-246. [pmid: 8237308].
Scheinin U. Incidence of dental caries among a group of university students in Turku. Acta Odontol Scand. 1974;32:335-344. [pmid: 4156452].
Scheinin U, Honka K, Kankkunen S. Dental conditions and need for dental treatment among university students in Turku. I. Operative and endodontic treatments. Acta Odontol Scand. 1970;28:505-521. [pmid: 5271262].
Scheirer MA. The life cycle of an innovation: adoption versus discontinuation of the fluoride mouth rinse program in schools. Journal of Health & Social Behavior. 1990;31:203-215. [pmid: 2102498].
Schepartz SA. Orphan products activities of the National Institutes of Health. Prog Clin Biol Res. 1983;127:173-186. [pmid: 6889399].
Schneiderman A, Elbaum M, Shultz T, Keem S, Greenebaum M, Driller J. Assessment of dental caries with Digital Imaging Fiber-Optic TransIllumination (DIFOTI): in vitro study. Caries Res. 1997;31:103-110. [pmid: 9118181].
Schroder U, Widenheim J, Peyron M, Hagg E. Prediction of caries in 1 1/2-year-old children. Swed Dent J. 1994;18:95-104. [pmid: 8085221].
Schulte A, Gente M, Pieper K. Posteruptive changes of electrical resistance values in fissure enamel of premolars. Caries Res. 1999;33:242-247. [pmid: 10207201].
Schulte JR, Druyan ME, Hagen JC. Early childhood tooth decay. Pediatric interventions. Clin Pediatr (Phila). 1992;31:727-730. [pmcid: 358331]. [pmid: 1451381].
Schultz WF. Multiple pathologic entities on a single film. Oral Surg Oral Med Oral Pathol. 1970;29:223-224. [pmid: 5262842].
Schupbach P, Neeser JR, Golliard M, Rouvet M, Guggenheim B. Incorporation of caseinoglycomacropeptide and caseinophosphopeptide into the salivary pellicle inhibits adherence of mutans streptococci. J Dent Res. 1996;75:1779-1788. [pmid: 8955673].
Schupbach P, Osterwalder V, Guggenheim B. Human root caries: microbiota of a limited number of root caries lesions. Caries Res. 1996;30:52-64. [pmid: 8850584].
Schutzbank SG, Galaini J, Kronman JH, Goldman M, Clark RE. A comparative in vitro study of GK-101 and GK-101E in caries removal. J Dent Res. 1978;57:861-864. [pmid: 281357].
Schutzbank SG, Marchwinski M, Kronman JG, Goldman M, Clark RE. In vitro study of the effect of GK-101 on the removal of carious material. J Dent Res. 1975;54.
Schutze HJJ, Forrester DJ, Balis SB. Evaluation of a fluoride prophylaxis paste in a fluoridated community. J Can Dent Assoc. 1974;40:675-683. [pmid: 4154056].
Schwarz E, Lo EC, Wong MC. Prevention of early childhood caries--results of a fluoride toothpaste demonstration trial on Chinese preschool children after three years. J Public Health Dent. 1998;58:12-18. [pmid: 9608441].
Scola FP. Self-preparation stannous fluoride prophylactic technique in preventive dentistry: report after two years. J Am Dent Assoc. 1970;81:1369-1372. [pmid: 4394526].
Scola FP, Ostrom CA. Clinical evaluation of stannous fluoride when used as a constituent of a compatible prophylactic paste, as a topical solution, and in a dentifrice in naval personnel. I. Report of findings after first year. J Am Dent Assoc. 1966;73:1306-1311. [pmid: 4380760].
Scott DB, Simmelink JW, Nygaard V. Structural aspects of dental caries. J Dent Res. 1974;53:165-178. [pmid: 4591965].
Segal AH, Stiff RH, George WA, Picozzi A. Cariostatic effect of a stannous fluoride-containing dentifrice on children: two-year report of a supervised toothbrushing study. J Oral Ther Pharmacol. 1967;4:175-180. [pmid: 4295135].
Selwitz RH, Nowjack-Raymer R, Driscoll WS, Li SH. Evaluation after 4 years of the combined use of fluoride and dental sealants. Community Dent Oral Epidemiol. 1995;23:30-35. [pmid: 7774174].
Selwitz RH, Nowjack-Raymer RE, Kingman A, Driscoll WS. Dental caries and dental fluorosis among schoolchildren who were lifelong residents of communities having either low or optimal levels of fluoride in drinking water. J Public Health Dent. 1998;58:28-35. [pmid: 9608443].
Selwitz RH, Nowjack-Raymer RE, Kingman A, Driscoll WS. Prevalence of dental caries and dental fluorosis in areas with optimal and above-optimal water fluoride concentrations: a 10-year follow-up survey. J Public Health Dent. 1995;55:85-93. [pmid: 7643332].
Selwitz RH, Winn DM, Kingman A, Zion GR. The prevalence of dental sealants in the US population: findings from NHANES III, 1988-1991. J Dent Res. 1996;75 Spec No:652-660. [pmid: 8594089].
Seow WK, Wan A, McAllan LH. The prevalence of pre-eruptive dentin radiolucencies in the permanent dentition. Pediatr Dent. 1999;21:26-33. [pmid: 10029964].
Sepet E, Aytepe Z, Guven Y. Artificially formed caries-like lesions around Class II glass ionomer restorations in primary molars. J Clin Pediatr Dent. 1995;20:37-40. [pmid: 8634193].
Seppa L. Effects of a sodium fluoride solution and a varnish with different fluoride concentrations on enamel remineralization in vitro. Scand J Dent Res. 1988;96:304-309. [pmid: 3166194].
Seppa L. Fluoride varnishes in caries prevention. Proc Finn Dent Soc. 1982;78 (suppl) 8:1-50. [pmid: 7184018].
Seppa L, Hausen H, Karkkainen S. Plaque fluoride and mutans streptococci in plaque and saliva before and after discontinuation of water fluoridation. Eur J Oral Sci. 1996;104:353-358. [pmid: 8930582].
Seppa L, Hausen H, Pollanen L, Karkkainen S, Helasharju K. Effect of intensified caries prevention on approximal caries in adolescents with high caries risk. Caries Res. 1991;25:392-395. [pmid: 1747891].
Seppa L, Leppanen T, Hausen H. Fluoride varnish versus acidulated phosphate fluoride gel: a 3-year clinical trial. Caries Res. 1995;29:327-330. [pmid: 8521431].
Seppa L, Pollanen L. Caries preventive effect of two fluoride varnishes and a fluoride mouthrinse. Caries Res. 1987;21:375-379. [pmid: 3475184].
Seppa L, Pollanen L, Hausen H. Caries-preventive effect of fluoride varnish with different fluoride concentrations. Caries Res. 1994;28:64-67. [pmid: 8124700].
Seppa L, Tolonen T. Caries preventive effect of fluoride varnish applications performed two or four times a year. Scand J Dent Res. 1990;98:102-105. [pmid: 2343272].
Seppa L, Tuutti H, Luoma H. A 2-year report on caries prevention by fluoride varnishes in a community with fluoridated water. Scand J Dent Res. 1981;89:143-148. [pmid: 6943661].
Seppa L, Tuutti H, Luoma H. Three-year report on caries prevention of using fluoride varnishes for caries risk children in a community with fluoridated water. Scand J Dent Res. 1982;90:89-94. [pmid: 6951261].
Serdar Cotert H, Ozturk B. Posterior bridges retained by resin-bonded cast metal inlay retainers: a report of 60 cases followed for 6 years. J Oral Rehabil. 1997;24:697-704. [pmid: 9357751].
Serman N. Restorative needs and pathological findings in northern Manhattan dentate community. N Y State Dent J. 1991;57:67-71. [pmid: 1749569].
Serra MC, Cury JA. The in vitro effect of glass-ionomer cement restoration on enamel subjected to a demineralization and remineralization model. Quintessence Int. 1992;23:143-147. [pmid: 1641453].
Serra Majem L, Garcia Closas R, Ramon JM, Manau C, Cuenca E, Krasse B. Dietary habits and dental caries in a population of Spanish schoolchildren with low levels of caries experience. Caries Res. 1993;27:488-494. [pmid: 8281564].
Seto BG, Beumer J3, Kagawa T, Klokkevold P, Wolinsky L. Analysis of endodontic therapy in patients irradiated for head and neck cancer. Oral Surg Oral Med Oral Pathol. 1985;60:540-545. [pmid: 3864116].
Seward G. 'Caries and periapical pathology in an unerupted tooth'. Br Dent J. 1993;174:193-194. [pmid: 8448052].
Sgan-Cohen HD, Gat E, Schwartz Z. The effectiveness of an amine fluoride/stannous fluoride dentifrice on the gingival health of teenagers: results after six months. Int Dent J. 1996;46:340-345. [pmid: 9147122].
Shapira J, Stabholz A. A comprehensive 30-month preventive dental health program in a pre-adolescent population with Down's syndrome: a longitudinal study. Spec Care Dentist. 1996;16:33-37. [pmid: 9084333].
Shaw L, Murray JJ. Inter-examiner and intra-examiner reproducibility in clinical and radiographic diagnosis. Int Dent J. 1975;25:280-288. [pmid: 1058838].
Shaw MJ. Attachment retained overdentures: a report on their maintenance requirements. J Oral Rehabil. 1984;11:373-379. [pmid: 6589382].
Shay K. Root caries in the older patient: significance, prevention, and treatment. Dent Clin North Am. 1997;41:763-793. [pmid: 9344277].
Sheehy E, Hirayama K, Tsamtsouris A. A survey of parents whose children had full-mouth rehabilitation under general anesthesia regarding subsequent preventive dental care. Pediatr Dent. 1994;16:362-364. [pmid: 7831142].
Sheldon WR. Unexpected dental caries. Oral Surg Oral Med Oral Pathol. 1990;70.
Sheller B, Williams BJ, Lombardi SM. Diagnosis and treatment of dental caries-related emergencies in a children's hospital. Pediatr Dent. 1997;19:470-475. [pmid: 9442540].
Shellis RP. Effects of a supersaturated pulpal fluid on the formation of caries-like lesions on the roots of human teeth. Caries Res. 1994;28:14-20. [pmid: 8124692].
Shen EC, Fu E. Carious lesions in the heroin addicted patient. A case report. J Periodontol. 1998;69:938-940. [pmid: 9736377].
Shern RJ, Driscoll WS, Korts DC. Enamel biopsy results of children receiving fluoride tablets. J Am Dent Assoc. 1977;95:310-314. [pmid: 268377].
Shern RJ, Duany LF, Senning RS, Zinner DD. Clinical study of an amine fluoride gel and acidulated phosphate fluoride gel. Community Dent Oral Epidemiol. 1976;4:133-136. [pmid: 782777].
Sheykholeslam Z, Houpt M. Clinical effectiveness of an autopolymerized fissure sealant after 2 years. Community Dent Oral Epidemiol. 1978;6:181-184. [pmid: 278700].
Shi W, Jewett A, Hume WR. Rapid and quantitative detection of Streptococcus mutans with species- specific monoclonal antibodies. Hybridoma. 1998;17:365-371. [pmid: 9790071].
Shiau YY, Wang JS. The effects of dental condition on hand strength and maximum bite force. Cranio. 1993;11:48-54. discussion 54. [pmid: 8358807].
Shiller WR, Dittmer JC, McElwaine LP, Scola FP. Dental caries increments evaluated by use of bite-wing roentgenograms. Mil Med. 1967;132:298-305. [pmid: 4382775].
Shimizu T, Kitano T, Inoue M, Narikawa K, Fujii B. Ten-year longitudinal clinical evaluation of a visible light cured posterior composite resin. Dent Mater J. 1995;14:120-134. [pmid: 8940551].
Ship II, Jones EM, Laster LL. Errors, reversals, and questionable dental caries diagnoses based on a longitudinal study in children. J Dent Res. 1966;45:323-331. [pmid: 4380016].
Shobha T, Nandlal B, Prabhakar AR, Sudha P. Fluoride varnish versus acidulated phosphate fluoride for schoolchildren in Manipal. J Inidan Dent Assoc. 1987;59:157-160.
Shovelton DS. A study of deep carious dentine. Int Dent J. 1968;18:392-405. [pmid: 5243048].
Shrout MK, Russell CM, Potter BJ, Hildebolt CF. Spatial resolution in radiometric analysis of enamel loss. A pilot study. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 1996;81:245-250. [pmid: 8665323].
Shu M, Pearce EI, Sissons CH, Coote GE, Miller JH. Fluoride distribution in sound and carious root tissues of human teeth. Caries Res. 1998;32:239-246. [pmid: 9643365].
Shugars DA, Bader JD. Cost implications of differences in dentists' restorative treatment decisions. J Public Health Dent. 1996;56:219-222. [pmid: 8906706].
Shwartz M, Grondahl HG, Pliskin JS, Boffa J. A longitudinal analysis from bite-wing radiographs of the rate of progression of approximal carious lesions through human dental enamel. Arch Oral Biol. 1984;29:529-536. [pmid: 6591884].
Shwartz M, Pliskin JS, Grondahl HG, Boffa J. A deep model of the incidence of dental caries on proximal surfaces. Med Decis Making. 1986;6:42-48. [pmid: 3484800].
Sidhu SK, Henderson LJ. Dentin adhesives and microleakage in cervical resin composites. Am J Dent. 1992;5:240-244. [pmid: 1299247].
Sidi AD, Naylor MN. A comparison of bitewing radiography and interdental transillumination as adjuncts to the clinical identification of approximal caries in posterior teeth. Br Dent J. 1988;164:15-18. [pmid: 3422155].
Siegal MD, Farquhar CL, Bouchard JM, Kleinman DV. Sealants them?. Public Health Rep. 1997;112:98-107. [pmid: 9071271]. [pmcid: 1381853].
Sigurjons H, Magnusdottir MO, Holbrook WP. Cariogenic bacteria in a longitudinal study of approximal caries. Caries Res. 1995;29:42-45. [pmid: 7867049].
Silberman SL, Trubman A, Duncan WK, Meydrech EF. A simplified hypoplasia index. J Public Health Dent. 1990;50:282-284. [pmid: 2391677].
Silverstone LM. The histopathology of early approximal caries in the enamel of primary teeth. ASDC J Dent Child. 1970;37:201-210 passim. [pmid: 4909894].
Silverstone LM. The primary translucent zone of enamel caries and of artificial caries-like lesions. Br Dent J. 1966;120:461-471. [pmid: 5219255].
Silverstone LM. Should I be using pit and fissure sealants or amalgam?. Int Dent J. 1976;26:29-40. [pmid: 767258].
Silverstone LM. Structure of carious enamel, including the early lesion. Oral Sciences Reviews. 1973;3:100-160.
Silverstone LM. The use of pit and fissure sealants in dentistry, present status and future developments. Pediatr Dent. 1982;4:16-21. [pmid: 6757879].
Silverstone LM, Poole DF. Histologic and ultrastructural features of remineralized carious enamel. J Dent Res. 1969;48:766-770. [pmid: 5259415].
Simon JFJ. Pediatric preventive dentistry. Am Fam Physician. 1974;10:173-177. [pmid: 4278216].
Simons D, Kidd EA, Beighton D, Jones B. The effect of chlorhexidine/xylitol chewing-gum on cariogenic salivary microflora: a clinical trial in elderly patients. Caries Res. 1997;31:91-96. [pmid: 9118190].
Simonsen RJ. Retention and effectiveness of a single application of white sealant after 10 years. J Am Dent Assoc. 1987;115:31-36. [pmid: 3112207].
Simonsen RJ. Retention and effectiveness of dental sealant after 15 years. J Am Dent Assoc. 1991;122:34-42. [pmid: 1835987].
Sims W. The interpretation and use of Snyder tests and lactobacillus counts. J Am Dent Assoc. 1970;80:1315-1319. [pmid: 5266121].
Sims W. A modified Snyder test for caries-activity in humans. Arch Oral Biol. 1968;13:853-856. [pmid: 4887193].
Sintes JL, Escalante C, Stewart B, et al. Enhanced anticaries efficacy of a 0.243% sodium fluoride/10% xylitol/silica dentifrice: 3-year clinical results. Am J Dent. 1995;8:231-235. [pmid: 8634157].
Sjogren K, Birkhed D, Rangmar B. Effect of a modified toothpaste technique on approximal caries in preschool children. Caries Res. 1995;29:435-441. [pmid: 8556745].
Sjogren K, Birkhed D, Ruben J, Arends J. Effect of post-brushing water rinsing on caries-like lesions at approximal and buccal sites. Caries Res. 1995;29:337-342. [pmid: 8521433].
Skartveit L, Halse A. Radiopacity of glass ionomer materials. J Oral Rehabil. 1996;23:1-4. [pmid: 8850153].
Skartveit L, Riordan PJ, al Dallal E. Effect of fluoride in amalgam on secondary caries incidence. Community Dent Oral Epidemiol. 1994;22:122-125. [pmid: 8205778].
Skodje F, Espelid I, Kvile K, Tveit AB. The influence of radiographic exposure factors on the diagnosis of occlusal caries. Dento Maxillo Facial Radiol. 1998;27:75-79.
Skogedal O, Tronstad L. An attempt to correlate dentin and pulp changes in human carious teeth. Oral Surg Oral Med Oral Pathol. 1977;43:135-140. [pmid: 264339].
Skold L, Sundquist B, Eriksson B, Edeland C. Four-year study of caries inhibition of intensive Duraphat application in 11-15-year-old children. Community Dent Oral Epidemiol. 1994;22:8-12. [pmid: 8143448].
Skold UM, Klock B, Lindvall AM. Differences in caries recording with and without bitewing radiographs. A study on 5-year old children in the County of Bohuslan, Sweden. Swed Dent J. 1997;21:69-75. [pmid: 9291554].
Skold UM, Klock B, Rasmusson CG, Torstensson T. Is caries prevalence underestimated in today's caries examination? A study on 16-year-old children in the county of Bohuslan, Sweden. Swed Dent J. 1995;19:213-217. [pmid: 8614902].
Slack GL, Bulman JS, Osborn JF. Clinical testing of fluoride and non-fluoride containing dentifrices in Hounslow school children. Br Dent J. 1971;130:154-158. [pmid: 4396165].
Slade GD, Caplan DJ. Methodological issues in longitudinal epidemiologic studies of dental caries. Community Dent Oral Epidemiol. 1999;27:236-248. [pmid: 10403083].
Slade GD, Gansky SA, Spencer AJ. Two-year incidence of tooth loss among South Australians aged 60+ years. Community Dent Oral Epidemiol. 1997;25:429-437. [pmid: 9429816].
Slade GD, Spencer AJ. Distribution of coronal and root caries experience among persons aged 60+ in South Australia. Aust Dent J. 1997;42:178-184. [pmid: 9241929].
Slade GD, Spencer AJ, Davies MJ, Burrow D. Intra-oral distribution and impact of caries experience among South Australian school children. Aust Dent J. 1996;41:343-350. [pmid: 8961609].
Slade GD, Spencer AJ, Davies MJ, Stewart JF. Caries experience among children in fluoridated Townsville and unfluoridated Brisbane. Aust N Z J Public Health. 1996;20:623-629. [pmid: 9117970].
Slade GD, Spencer AJ, Davies MJ, Stewart JF. Influence of exposure to fluoridated water on socioeconomic inequalities in children's caries experience. Community Dent Oral Epidemiol. 1996;24:89-100. [pmid: 8654039].
Slavkin, Harold C, Director, National Institute of Dental and Craniofacial Research. Statement on President's Budget Request for NIDCR Fiscal Year 2000. accessed October 18, 1999. Web Page. Available at: http://www.senate.gov/~appropriations/labor/IDCR2_23.htm.
Slome BA, Rozier RG, Seidel JS. A survey of dental disease in children of Wuvulu Island, Papua New Guinea. Community Dent Oral Epidemiol. 1980;8:146-150. [pmid: 6936112].
Sluiter JA, Purdell-Lewis DJ. Lower fluoride concentrations for topical application. In vitro study on human d2255ental enamel. Caries Res. 1984;18:56-62. [pmid: 6580955].
Smales RJ. Fissure sealants versus amalgams: clinical results over five years. J Dent. 1982;10:95-102. [pmid: 6213683].
Smales RJ, Gerke DC. The use of glass ionomer cements for restoring occlusal tooth surfaces. Aust Dent J. 1990;35:181-182. [pmid: 2111983].
Smales RJ, Wong KC. 2-year clinical performance of a resin-modified glass ionomer sealant. Am J Dent. 1999;12:59-61. [pmid: 10477983].
Smith DC. The appropriateness of comparing sealants with restorations. J Dent Educ. 1984;48:103-106. [pmid: 6583261].
Smith GA, Wilson NH. A visible light-cured composite restorative. A clinical trial. Br Dent J. 1979;147:185-187. [pmid: 393285].
Smith GE. Is fluoridation a fraud?. Sci Total Environ. 1988;76:167-184. [pmid: 3238423].
Smith NJ. Radiography and radiology for the dental practitioner. 7. Radiology in restorative dentistry. Br Dent J. 1973;135:159-163. [pmid: 4518158].
Smits MT, Arends J. In vitro demineralization of human enamel in artificial U-shaped grooves. Caries Res. 1986;20:217-222. [pmid: 3456845].
Smits MT, Arends J. Influence of extraoral xylitol and sucrose dippings on enamel demineralization in vivo. Caries Res. 1988;22:160-165. [pmid: 3163523].
Sobkowiak EM, Szabo Z, Radtke G, Adler P. Analysis of cumulative caries prevalence in primary molars. Community Dent Oral Epidemiol. 1973;1:127-131. [pmid: 4528420].
Soetiarto F. The relationship between habitual clove cigarette smoking and a specific pattern of dental decay in male bus drivers in Jakarta, Indonesia. Caries Res. 1999;33:248-250. [pmid: 10207202].
Sogaard AJ, Grytten J, Holst D. Recent changes in health related dental behaviors in Norway. Community Dent Oral Epidemiol. 1991;19:241-245. [pmid: 1742984].
Solanki GC, Sheiham A. Comparison of intra-examiner reproducibility in scoring caries in primary teeth of two scoring systems used to monitor caries progression. Community Dent Oral Epidemiol. 1992;20:57-59. [pmid: 1555388].
Solanki GC, Sheiham A. Progression of proximal caries in primary teeth in relation to radiographic scoring codes. Community Dent Oral Epidemiol. 1992;20:60-63. [pmid: 1555389].
Songpaisan Y, Bratthall D, Phantumvanit P, Somridhivej Y. Effects of glass ionomer cement, resin-based pit and fissure sealant and HF applications on occlusal caries in a developing country field trial. Community Dent Oral Epidemiol. 1995;23:25-29. [pmid: 7774173].
Songpaisan Y, Serinirach R, Kuvatanasuchati J, Bratthall D. Mutans streptococci in a Thai population: relation to caries and changes in prevalence after application of fissure sealants. Caries Res. 1994;28:161-168. [pmid: 8033189].
Sonis AL, Snell W. An evaluation of a fluoride-releasing, visible light-activated bonding system for orthodontic bracket placement. Am J Orthod Dentofacial Orthop. 1989;95:306-311. [pmid: 2650531].
Sonju Clasen AB, Ogaard B, Duschner H, Ruben J, Arends J, Sonju T. Caries development in fluoridated and non-fluoridated deciduous and permanent enamel in situ examined by microradiography and confocal laser scanning microscopy. Adv Dent Res. 1997;11:442-447. [pmid: 9470502].
Sonju Clasen AB, von der Fehr FR, Kant van Daal JM. Caries prevalence of kindergarten children in Salzgitter and Oslo. Caries Res. 1992;26:201-204. [pmid: 1628295].
Souto M, Donly KJ. Caries inhibition of glass ionomers. Am J Dent. 1994;7:122-124. [pmid: 8054186].
Spak CJ, Johnson G, Ekstrand J. Caries incidence, salivary flow rate and efficacy of fluoride gel treatment in irradiated patients. Caries Res. 1994;28:388-393. [pmid: 8001064].
Spears GF. Fluoride and dental caries. N Z Dent J. 1989;85.
Spears ND. Caries patterns in suboptimally fluoridated areas. A study of the teeth of schoolchildren in areas of the Southwest. CDA Journal. 1978;6:62-66. [pmid: 288528].
Spencer AJ. Skewed distributions--new outcome measures. Community Dent Oral Epidemiol. 1997;25:52-59. [pmid: 9088692].
Spencer AJ, Davies M, Slade G, Brennan D. Caries prevalence in Australasia. Int Dent J. 1994;44:415-423. [pmid: 7814109].
Spets-Happonen S, Luoma H, Forss H, et al. Effects of a chlorhexidine-fluoride-strontium rinsing program on caries, gingivitis and some salivary bacteria among Finnish schoolchildren. Scand J Dent Res. 1991;99:130-138. [pmid: 2052894].
Spets-Happonen S, Markkanen H, Pollanen L, Kauppinen T, Luoma H. Salivary Streptococcus mutans count and gingivitis in children after rinsing with a chlorhexidine-fluoride solution with and without strontium. Scand J Dent Res. 1985;93:329-335. [pmid: 3862233].
Splieth C, Bernhardt O. Prediction of caries development for molar fissures with semiquantitative mutans streptococci test. Eur J Oral Sci. 1999;107:164-169. [pmid: 10424379].
Splieth C, Meyer G. Factors for changes of caries prevalence among adolescents in Germany. Eur J Oral Sci. 1996;104:444-451. [pmid: 8930596].
Stadtler P. A 3-year clinical study of a hybrid composite resin as fissure sealant and as restorative material for Class I restorations. Quintessence Int. 1992;23:759-762. [pmid: 1305291].
Stadtler P. Five-year survival rate of fissure sealings and fissure restorations. Int J Clin Pharmacol Ther Toxicol. 1993;31:361-364. [pmid: 8370635].
Stadtler P, Muller-Bruckschwaiger K, Schafer F, Huntington E. The effect of sodium trimetaphosphate on caries: a 3-year clinical toothpaste trial. Caries Res. 1996;30:418-422. [pmid: 8946103].
Stahl JW, Katz RV. Occlusal dental caries incidence and implications for sealant programs in a US college student population. J Public Health Dent. 1993;53:212-218. [pmid: 8258782].
Stalewski AJ, Wild JR. Fluoride tablet trial: use of measure PDMFS and PDMFT. Br Dent J. 1980;149.
Stamm JW. Is there a need for dental sealants? Epidemiological indications in the 1980s. J Dent Educ. 1984;48:9-17. [pmid: 6583270].
Stamm JW. Types of clinical caries studies: epidemiological surveys, randomized clinical trials, and demonstration programs. J Dent Res. 1984;63 Spec No:701-8. [pmid: 6373865].
Stamm JW. The use of fissure sealants in public health programs: a reactor's comments. J Public Health Dent. 1983;43:243-246. [pmid: 6415272].
Stamm JW, Bohannan HM, Graves RC, Disney JA. The efficiency of caries prevention with weekly fluoride mouthrinses. J Dent Educ. 1984;48:617-626. [pmid: 6436348].
Staninec M, Eakle WS, Silverstein S, Marshall GW, Artiga N. Bonded amalgam sealants: two-year clinical results. J Am Dent Assoc. 1998;129:323-329. [pmid: 9529807].
Staninec M, Giles WS, Saiku JM, Hattori M. Caries penetration and cement thickness of three luting agents. Int J Prosthodont. 1988;1:259-263. [pmid: 3254178].
Stanmeyer WR, Smith WF. Serial bitewings - two films versus four films. Oral Surg Oral Med Oral Pathol. 1967;23:403-406. [pmid: 5226452].
Stannard JG, Cook AH. Demineralization resistance of cavity varnish, bonding agent, and variation in gingival line angle. J Mass Dent Soc. 1989;38:177-180. [pmid: 2639934].
Stannard JG, Viazis AD. Effect of fluoride from dental materials on acid demineralization of enamel. Oper Dent. 1988;13:58-65. [pmid: 3270040].
Stark MM, Hall NC, Nicholson RJ, Soelberg K. 9-Aminoacridine, an effective antibacterial agent with caries-disclosing features. Oral Surg Oral Med Oral Pathol. 1968;26:560-562. [pmid: 5244782].
Stecksen-Blicks C, Gustafsson L. Impact of oral hygiene and use of fluorides on caries increment in children during one year. Community Dent Oral Epidemiol. 1986;14:185-189. [pmid: 3527546].
Stecksen-Blicks C, Holm AK, Mayanagi H. Dental caries in Swedish 4-year-old children. Changes between 1967 and 1987. Swed Dent J. 1989;13:39-44. [pmid: 2786649].
Steinberg D, Sgan-Cohen HD, Stabholz A, Pizanty S, Segal R, Sela MN. The anticariogenic activity of glycyrrhizin: preliminary clinical trials. Isr J Dent Sci. 1989;2:153-157. [pmid: 2490930].
Steiner M, Helfenstein U, Marthaler TM. Dental predictors of high caries increment in children. J Dent Res. 1992;71:1926-1933. [pmid: 1452896].
Stephen KW. The erupting first permanent molar--its place in stratified clinical field studies. J Dent Res. 1977;56 Spec No:104-111. [pmid: 344370].
Stephen KW. Use of fluoride. Lancet. 1999;354:74-75. [pmid: 10406392].
Stephen KW. The value of anti-caries and anti-plaque dentifrices at a community level. Adv Dent Res. 1995;9:127-128. [pmid: 7546131].
Stephen KW, Boyle IT, Campbell D, McNee S, Boyle P. Five-year double-blind fluoridated milk study in Scotland. Community Dent Oral Epidemiol. 1984;12:223-229. [pmid: 6590173].
Stephen KW, Boyle IT, Campbell D, et al. A 4-year double-blind fluoridated school milk study in a vitamin-D deficient area. Br Dent J. 1981;151:287-292. [pmid: 7025869].
Stephen KW, Campbell D. Caries reduction and cost benefit after 3 years of sucking fluoride tablets daily at school. A double-blind trial. Br Dent J. 1978;144:202-206. [pmid: 416842].
Stephen KW, Chestnutt IG, Jacobson AP, et al. The effect of NaF and SMFP toothpastes on three-year caries increments in adolescents. Int Dent J. 1994;44:287-295. [pmid: 7960167].
Stephen KW, Creanor SL, Russell JI, Burchell CK, Huntington E, Downie CF. A 3-year oral health dose-response study of sodium monofluorophosphate dentifrices with and without zinc citrate: anti-caries results. Community Dent Oral Epidemiol. 1988;16:321-325. [pmid: 3060308].
Stephen KW, Creanor SL, Russell JI, Burchell CK, Strang DM. The prevalence of fissure sealants in Lanarkshire, Scotland. A 3-year study. Br Dent J. 1989;167:390-394. [pmid: 2688726].
Stephen KW, Kay EJ, Tullis JI. Combined fluoride therapies. A 6-year double-blind school-based preventive dentistry study in Inverness, Scotland. Community Dent Oral Epidemiol. 1990;18:244-248. [pmid: 2249406].
Stephen KW, Kirkwood M, Main C, Gillespie FC, Campbell D. A clinical comparison of two filled fissure sealants after one year. Br Dent J. 1981;150:282-284. [pmid: 7016146].
Stephen KW, MacFadyen EE. Three years of clinical caries prevention for cleft palate children. Br Dent J. 1977;143:111-116. [pmid: 268202].
Stephen KW, Macpherson LM, Gorzo I, Gilmour WH. Effect of fluoridated salt intake in infancy: a blind caries and fluorosis study in 8th grade Hungarian pupils. Community Dent Oral Epidemiol. 1999;27:210-215. [pmid: 10385359].
Stephen KW, Russell JI, Creanor SL, Burchell CK. Comparison of fibre optic transillumination with clinical and radiographic caries diagnosis. Community Dent Oral Epidemiol. 1987;15:90-94. [pmid: 3552397].
Stephens RG, Kogon SL, Reid JA, Ruprecht A. A comparison of panorex and intraoral surveys for routine dental radiography. Dent J. 1977;43:281-286. [pmid: 267587].
Stephenson D. Dental caries environment and diet in Jamaica. West Indian Med J. 1969;18:116-118. [pmid: 5402552].
Sterritt GR, Frew RA. Evaluation of a clinic-based sealant program. J Public Health Dent. 1988;48:220-224. [pmid: 3184027].
Sterritt GR, Frew RA, Rozier RG. Evaluation of Guamanian dental caries preventive programs after 13 years. J Public Health Dent. 1994;54:153-159. [pmid: 7932351].
Sterritt GR, Frew RA, Rozier RG, Brunelle JA. Evaluation of a school-based fluoride mouthrinsing and clinic-based sealant program on a non-fluoridated island. Community Dent Oral Epidemiol. 1990;18:288-293. [pmid: 2090379].
Stewart PW, Stamm JW. Classification tree prediction models for dental caries from clinical, microbiological, and interview data. J Dent Res. 1991;70:1239-1251. [pmid: 1918574].
Stoner JE. The value of the bitewing radiograph in the diagnosis of dental diseases in young subjects. ASDC J Dent Child. 1974;41:190-193. [pmid: 4597241].
Stookey GK. Critical evaluation of the composition and use of topical fluorides. J Dent Res. 1990;69:805-812. [pmid: 2179344].
Stookey GK, Beiswanger BB. Influence of an experimental sodium fluoride dentifrice on dental caries incidence in children. J Dent Res. 1975;54:53-58. [pmid: 234130].
Stookey GK, Carroll RA, Muhler JC. The clinical effectiveness of phosphate-enriched breakfast cereals on the incidence of dental caries in children: results after 2 years. J Am Dent Assoc. 1967;74:752-758. [pmid: 4381114].
Stookey GK, DePaola PF, Featherstone JD, et al. A critical review of the relative anticaries efficacy of sodium fluoride and sodium monofluorophosphate dentifrices. Caries Res. 1993;27:337-360. [pmid: 8402812].
Straffon LH, Dennison JB. Clinical evaluation comparing sealant and amalgam after 7 years: final report. J Am Dent Assoc. 1988;117:751-755. [pmid: 3198882].
Straffon LH, Dennison JB, More FG. Three-year evaluation of sealant: effect of isolation on efficacy. J Am Dent Assoc. 1985;110:714-717. [pmid: 3159777].
Strand GV, Nordbo H, Tveit AB, Espelid I, Wikstrand K, Eide GE. A 3-year clinical study of tunnel restorations. Eur J Oral Sci. 1996;104:384-389. [pmid: 8930587].
Strang R, Damato FA, Stephen KW. Comparison of in vitro demineralization of enamel sections and slabs. Caries Res. 1988;22:348-349. [pmid: 3214848].
Studies on the determinants of surface enamel fluoride and its relationship to dental caries. Nor Tannlaegeforen Tid. 1976;86:42-53. [pmid: 1061948].
Styner D, Kuyinu E, Turner G. Addressing the caries dilemma: detection and intervention with a disclosing agent. Gen Dent. 1996;44:446-449. [pmid: 9171046].
Suhonen J, Sener B, Bucher W, Lutz F. Release of preventive agents from pacifiers in vitro. An introduction to a novel preventive measure. Schweiz Monatsschr Zahnmed. 1994;104:946-951. [pmid: 8091173].
Sullivan A, Borgstrom MK, Granath L, Nilsson G. Number of mutans streptococci or lactobacilli in a total dental plaque sample does not explain the variation in caries better than the numbers in stimulated whole saliva. Community Dent Oral Epidemiol. 1996;24:159-163. [pmid: 8871012].
Sullivan RJ, Fletcher R, Bachiman R, Penugonda B, LeGeros RZ. Intra-oral comparison and evaluation of the ability of fluoride dentifrices to promote the remineralization of caries-like lesions in dentin and enamel. J Clin Dent. 1995;6:135-138. [pmid: 8624224].
Sumney DL, Jordan HV. A roentgenological grid technique for the bacteriological sampling of root surface caries. Caries Res. 1973;7:374-377. [pmid: 4518092].
Sundberg H, Bjerner B, Sjogren K. Estimation of prophylactic measures in Swedish public dental health care. Results from a questionnaire. Eur J Oral Sci. 1996;104:477-479. [pmid: 8930600].
Sundstrom B, Zelander T, Lobo R. Some observations on the morphology of in vitro decalcified incipient enamel caries. Odontol Revy. 1972;23:1-7. [pmid: 4556598].
Sundstrom F, Hafstrom-Bjorkman U, Strom J, Angmar-Mansson B, Frostell G, Takazoe I. Evaluation of a model for short-term clinical testing of cariogenicity. J Biol Buccale. 1989;17:115-120. [pmid: 2768228].
Suni J, Helenius H, Alanen P. Tooth and tooth surface survival rates in birth cohorts from 1965, 1970, 1975, and 1980 in Lahti, Finland. Community Dent Oral Epidemiol. 1998;26:101-106. [pmid: 9645403].
Sutcliffe P. A longitudinal study of caries experience and extraction of permanent first molars in English children. Community Dent Oral Epidemiol. 1974;2:182-186. [pmid: 4154821].
Suzuki M, Ohta K, Kore-eda S, et al. Generalized pustular psoriasis and capillary leak syndrome with dental caries. Hifuka Kiyo. 1997;92:1-5.
Svanaes DB, Moystad A, Risnes S, Larheim TA, Grondahl HG. Intraoral storage phosphor radiography for approximal caries detection and effect of image magnification: comparison with conventional radiography. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 1996;82:94-100. [pmid: 8843461].
Svanberg M, Krasse B, Ornerfeldt HO. Mutans streptococci in interproximal plaque from amalgam and glass ionomer restorations. Caries Res. 1990;24:133-136. [pmid: 2111222].
Sveen OB, Jensen OE. Clinical evaluation of two pit and fissure sealants: results after twelve months. N Y State Dent J. 1984;50:167-169. [pmid: 6231498].
Svenson B. The influence of image quality on radiographic diagnosis of approximal caries. Swed Dent J Suppl. 1991;74:1-62. [pmid: 2035145].
Svenson B, Grondahl HG, Lindvall AM. Influence of film fog on radiographic caries diagnosis. Dento Maxillo Facial Radiol. 1990;19:105-118.
Svenson B, Grondahl HG, Petersson A, Olving A. Accuracy of radiographic caries diagnosis at different kilovoltages and two film speeds. Swed Dent J. 1985;9:37-43. [pmid: 3859029].
Svenson B, Lindvall AM, Grondahl HG. A comparison of a new dental X-ray film, Agfa Gevaert Dentus M4, with Kodak Ektaspeed and Ultraspeed dental X-ray films. Dento Maxillo Facial Radiol. 1993;22:7-12.
Svenson B, Petersson A. Accuracy of radiographic caries diagnosis using different X-ray generators. Dento Maxillo Facial Radiol. 1989;18:68-71.
Svenson B, Petersson A. Assessment of a new processor containing a self-cleaning synthetic-web transport mechanism. Dento Maxillo Facial Radiol. 1993;22:25-27.
Svenson B, Petersson A. Influence of tube voltage on radiographic diagnosis of caries in premolars and molars. Swed Dent J. 1991;15:245-250. [pmid: 1767370].
Svenson B, Shi XQ, Stamatakis H, et al. Exposure parameters in Sens-A-Ray direct digital radiography and their effects on diagnostic accuracy of carious lesions. Oral Radiol. 1997;13:83-91.
Svenson B, Welander U, Anneroth G, Soderfeldt B. Exposure parameters and their effects on diagnostic accuracy. Oral Surg Oral Med Oral Pathol. 1994;78:544-550. [pmid: 7800386].
Svenson B, Welander U, Shi XQ, Stamatakis H, Tronje G. A sensitometric comparison of four dental X-ray films and their diagnostic accuracy. Dento Maxillo Facial Radiol. 1997;26:230-235.
Swan ES, Lewis DW. Ontario dentists: 2. Bitewing utilization and restorative treatment decisions. J Can Dent Assoc. 1993;59:68-70, 73-75. [pmid: 8443704].
Swan ES, Lewis DW. Ontario dentists: 3. Radiographs prescribed in general practice. J Can Dent Assoc. 1993;59:76-79. [pmid: 8443706].
Swedberg Y. Dental time study results in relation to a model for a dental health related patient group system. Swed Dent J. 1995;19:109-118. [pmid: 7676387].
Swedberg Y, Freden H, Noren JG. Caries extreme groups among adolescents, leaving organised dental care in Goteborg, Sweden. Swed Dent J. 1997;21:221-226. [pmid: 9505334].
Sweeney MP, Bagg J, Fell GS, Yip B. The relationship between micronutrient depletion and oral health in geriatrics. J Oral Pathol Med. 1994;23:168-171. [pmid: 8046654].
Sweeteners: nutritive and non-nutritive. Bol Assoc Med P R. 1988;80:63-65.
Swift EJJ. In vitro caries-inhibitory properties of a silver cermet. J Dent Res. 1989;68:1088-1093. [pmid: 2509525].
Swift EJJ, Bader JD, Shugars DA. Glass-ionomer cement restorations and secondary caries. Quintessence Int. 1997;28:227-229. [pmid: 10332370].
Syme SE, Fried JL. Maintaining the oral health of splinted teeth. Dent Clin North Am. 1999;43:179-196. [pmid: 9929806].
Symons NB. Electron microscopic study of the tubules in human carious dentine. Arch Oral Biol. 1970;15:239-251. [pmid: 4192762].
Symposium: Clinical Management of Root Surface Caries. San Antonio, Texas, August 5, 1995. Proceedings. Am J Dent. 1995;8:322-357.
Syriopoulos K, Velders XL, Sanderink GCH, van Ginkel FC, van Amerongen JP, van der Stelt PF. The effect of developer age on the detection of approximal caries using three dental films. Dentomaxillofacial Radiology. 1999;28:208-213.
Szwejda LF. Fluorides in community programs: a study for four years of the cariostatic effects of prophylactic pastes, rinses, and applications of various fluorides. J Public Health Dent. 1972;32:110-118. [pmid: 4402489].
Szwejda LF. Fluorides in community programs; a study of four years of various fluorides applied topically to the teeth of children in fluoridated communities. J Public Health Dent. 1972;32:25-33. [pmid: 4400348].
Szwejda LF. Fluorides in community programs: results after four years of study of various agents topically applied by two technics. J Public Health Dent. 1971;31:166-176. [pmid: 4397302].
Tabachnick TT, Levine B. Mucormycosis of the craniofacial structures. J Oral Surg. 1975;33:464-469. [pmid: 1055210].
Tadmor E, Poitou P, Gedalia I. In vitro acid decalcification of human surface enamel pretreated with toothpaste slurries. J Oral Rehabil. 1989;16:613-616. [pmid: 2600715].
Tagami J, Hosoda H, Burrow MF, Nakajima M. Effect of aging and caries on dentin permeability. Proc Finn Dent Soc. 1992;88 (suppl) 1:149-154. [pmid: 1508869].
Takagi J, Rakugi M, Nishida M, Kim Y, Asahi Y, Matsuura H. Systemic management of a patient with WPW syndrome and 7q deletion syndrome during dental treatment. Journal of Japanese Dental Society of Anesthesiology. 1997;25:739-742.
Takagi J, Rakugi M, Nishida M, et al. Systemic management during dental treatment of a patient with cerebral infarction due to antiphospholipid syndrome (APS). Journal of Japanese Dental Society of Anesthesiology. 1997;25:197-201.
Takei T, Ogawa T, Alaluusua S, et al. Latex agglutination test for detection of mutans streptococci in relation to dental caries in children. Arch Oral Biol. 1992;37:99-104. [pmid: 1622345].
Takuma S, Ogiwara H, Suzuki H. Electron-probe and electron microscope studies of carious dentinal lesions with a remineralized surface layer. Caries Res. 1975;9:278-285. [pmid: 1054304].
Tam LE, Chan GP, Yim D. In vitro caries inhibition effects by conventional and resin-modified glass-ionomer restorations. Oper Dent. 1997;22:4-14. [pmid: 9227122].
Tanaka K, Yamaga T, Kim DY, Ohara M, Uji M, Okuno Y. Effect of tannin-fluoride preparation on caries-reduction of overdenture abutment. Journal of the Osaka University Dental School. 1987;27:89-99.
Tandon S, Silas A. Caridex: dentin topography and bond strength evaluation. Indian J Dent Res. 1992;3:76-82. [pmid: 1343960].
Taubman MA, Smith DJ. A mucosal approach to immunoprophylaxis of dental infections. Adv Exp Med Biol. 1987;216B:1721-1730. [pmid: 2962473].
Taylor RC, Ware WH, McDowell JA. Illumination of the oral cavity. J Am Dent Assoc. 1967;74:1207-1209. [pmid: 5228558].
ten Cate JM. The caries preventive effect of a fluoride dentifrice containing Triclosan and zinc citrate, a compilation of in vitro and in situ studies. Int Dent J. 1993;43:407-413. [pmid: 8282423].
Ten Cate JM. In vitro studies on the effects of fluoride on de- and remineralization. J Dent Res. 1990;69:614-619. [pmid: 2179322].
ten Cate JM, Dundon KA, Vernon PG, et al. Preparation and measurement of artificial enamel lesions, a four-laboratory ring test. Caries Res. 1996;30:400-407. [pmid: 8946105].
ten Cate JM, Exterkate RA. Use of the single-section technique in caries research. Caries Res. 1986;20:525-528. [pmid: 3536109].
ten Cate JM, Marsh PD. Procedures for establishing efficacy of antimicrobial agents for chemotherapeutic caries prevention. J Dent Res. 1994;73:695-703. [pmid: 8163740].
Ten Cate JM, Nyvad B, Van de Plassche-Simons YM, Fejerskov O. A quantitative analysis of mineral loss and shrinkage of in vitro demineralized human root surfaces. J Dent Res. 1991;70:1371-1374. [pmid: 1939832].
ten Cate JM, Shariati M, Featherstone JD. Enhancement of (salivary) remineralization by 'dipping' solutions. Caries Res. 1985;19:335-341. [pmid: 3861255].
ten Cate JM, van Duinen RN. Hypermineralization of dentinal lesions adjacent to glass-ionomer cement restorations. J Dent Res. 1995;74:1266-1271. [pmid: 7629335].
Tenovuo J, Hakkinen P, Paunio P, Emilson CG. Effects of chlorhexidine-fluoride gel treatments in mothers on the establishment of mutans streptococci in primary teeth and the development of dental caries in children. Caries Res. 1992;26:275-280. [pmid: 1423442].
Teo CS. Fluoridation of public water supplies in Singapore. Ann Acad Med Singapore. 1984;13:247-251. [pmid: 6497322].
Teplitsky PE. Formocresol pulpotomies on posterior permanent teeth. J Can Dent Assoc. 1984;50:623-627. [pmid: 6386115].
ter Pelkwijk A, van Palenstein Helderman WH, van Dijk JW. Caries experience in the deciduous dentition as predictor for caries in the permanent dentition. Caries Res. 1990;24:65-71. [pmid: 2104574].
Tervonen T. Dental treatment needs of adults in Ostrobothnia, Finland. Proc Finn Dent Soc. 1988;84:1-72. [pmid: 3064090].
Tewari A, Chawla HS, Utreja A. Comparative evaluation of the role of NaF, APF & Duraphat topical fluoride applications in the prevention of dental caries--a 2 1/2 years study. J Indian Soc Pedod Prev Dent. 1991;8:28-35. [pmid: 2056344].
Thibodeau EA, O'Sullivan DM. Salivary mutans streptococci and dental caries patterns in pre-school children. Community Dent Oral Epidemiol. 1996;24:164-168. [pmid: 8871013].
Thomas AE, Jamison HC. Effect of a combination of two cariostatic agents in children: two-year clinical study of supervised brushing in children's homes. J Am Dent Assoc. 1970;81:118-124. [pmid: 4392970].
Thomas AE, Jamison HC. Effect of SnF2 dentrifices on caries in children: two-year clinical study of supervised brushing in children's homes. J Am Dent Assoc. 1966;73:844-852. [pmid: 4380623].
Thomas FD, Kassab JY. Fluoridation in Anglesey: a clinical study of dental caries in mothers at term. Br Dent J. 1992;173:136-140. [pmid: 1389600].
Thomas FD, Kassab JY, Jones BM. Fluoridation in Anglesey 1993: a clinical study of dental caries in 5-year-old children who had experienced sub-optimal fluoridation. Br Dent J. 1995;178:55-59. [pmid: 7848757].
Thompson GW, Schuller PD, Lewis DW. Dental caries knowledge in a group of Northwest Territories children. Int J Circumpolar Health. 1998;57:169-173. [pmid: 10093268].
Thylstrup A, Bille J, Bruun C. Caries prevalence in Danish children living in areas with low and optimal levels of natural water fluoride. Caries Res. 1982;16:413-420. [pmid: 6958375].
Thylstrup A, Bruun C, Holmen L. In vivo caries models--mechanisms for caries initiation and arrestment. Adv Dent Res. 1994;8:144-157. [pmid: 7865069].
Thylstrup A, Poulsen S. Retention and effectiveness of a chemically polymerized pit and fissure sealant after 2 years. Scand J Dent Res. 1978;86:21-24. [pmid: 345406].
Tickle M, Williams M, Jenner T, Blinkhorn A. The effects of socioeconomic status and dental attendance on dental caries' experience, and treatment patterns in 5-year-old children. Br Dent J. 1999;186:135-137. [pmid: 10101910].
Tinanoff N. Critique of evolving methods for caries risk assessment. J Dent Educ. 1995;59:980-985. [pmid: 7490380].
Tinanoff N. Progress regarding the use of stannous fluoride in clinical dentistry. J Clin Dent. 1995;6:37-40. [pmid: 8593191].
Tinanoff N, Daley NS, O'Sullivan DM, Douglass JM. Failure of intense preventive efforts to arrest early childhood and rampant caries: three case reports. Pediatr Dent. 1999;21:160-163. [pmid: 10355005].
Todd MA, Staley RN, Kanellis MJ, Donly KJ, Wefel JS. Effect of a fluoride varnish on demineralization adjacent to orthodontic brackets. Am J Orthod Dentofacial Orthop. 1999;116:159-167. [pmid: 10434089].
Tohda H, Fejerskov O, Yanagisawa T. Transmission electron microscopy of cementum crystals correlated with Ca and F distribution in normal and carious human root surfaces. J Dent Res. 1996;75:949-954. [pmid: 8675807].
Toljanic JA, Bedard JF, Larson RA, Fox JP. A prospective pilot study to evaluate a new dental assessment and treatment paradigm for patients scheduled to undergo intensive chemotherapy for cancer. Cancer. 1999;85:1843-1848. [pmid: 10223580].
Tonn EM, Ryge G. Two-year clinical evaluation of light-cured composite resin restorations in primary molars. J Am Dent Assoc. 1985;111:44-48. [pmid: 3897334].
Toolson LB, Smith DE. A 2-year longitudinal study of overdenture patients. Part I: incidence and control of caries on overdenture abutments. J Prosthet Dent. 1978;40:486-491. [pmid: 364010].
Toolson LB, Smith DE. A five-year longitudinal study of patients treated with overdentures. J Prosthet Dent. 1983;49:749-756. [pmid: 6348256].
Torell P. Reversals in caries diagnosis. Acta Odontol Scand. 1967;25:191-203. [pmid: 4383251].
Torell P, Ericsson Y. The value in caries prevention of methods for applying fluorides topically to the teeth. Int Dent J. 1967;17:564-581. [pmid: 4383270].
Torell P, Gromark PO, Edward S. Fortnightly fluoride rinsing combined with topical paintings with a fluoride solution containing Fe- and Al-ions. Swed Dent J. 1983;7:23-31. [pmid: 6574611].
Torneck CD. Changes in the fine structure of the dental pulp in human caries pulpitis. 1. Nerves and blood vessels. J Oral Pathol. 1974;3:71-82. [pmid: 4213911].
Torneck CD. Changes in the fine structure of the dental pulp in human caries pulpitis. 2. Inflammatory infiltration. J Oral Pathol. 1974;3:83-99. [pmid: 4213912].
Torstenson B. Pulpal reaction to a dental adhesive in deep human cavities. Endod Dent Traumatol. 1995;11:172-176. [pmid: 7588340].
Tosti A, Piraccini BM, Pazzaglia M, Ghedini G, Papadia F. Severe facial edema following root canal treatment. Arch Dermatol. 1996;132:231-233.
Toth K. A study of 8 years' domestic salt fluoridation for prevention of caries. Community Dent Oral Epidemiol. 1976;4:106-110. [pmid: 1063607].
Toto PD. Dentine caries. Oral Surg Oral Med Oral Pathol. 1967;23:215-220. [pmid: 4163339].
Toto PD. Softening of dentin in caries. J Dent Res. 1966;45.
Toto PD, Sawinski VJ, Evans C. The effects of instructed toothbrushing on the cleanliness of teeth and DMF: an eighteen-month study. J Oral Ther Pharmacol. 1967;3:354-358. [pmid: 4381934].
Travis RT, Steinle CJ. The effects of odontogenic infection on the complete blood count in children and adolescents. Pediatr Dent. 1984;6:214-219. [pmid: 6596568].
Treasure ET. The effect of fluoridation on populations in New Zealand. Community Dent Oral Epidemiol. 1996;24.
Treasure ET, Dever JG. Relationship of caries with socioeconomic status in 14-year-old children from communities with different fluoride histories. Community Dent Oral Epidemiol. 1994;22:226-230. [pmid: 7924236].
Trimpeneers LM, Dermaut LR. A clinical evaluation of the effectiveness of a fluoride-releasing visible light-activated bonding system to reduce demineralization around orthodontic brackets. Am J Orthod Dentofacial Orthop. 1996;110:218-222. [pmid: 8760850].
Triol CW, Mandanas BY, Juliano GF, Yraolo B, Cano-Arevalo M, Volpe AR. A clinical study of children comparing anticaries effect of two fluoride dentifrices. A 31-month study. Clin Prev Dent. 1987;9:22-24. [pmid: 3494563].
Triol CW, Ripa LW, Leske GS, Volpe AR. A clinical study of the anticaries efficacy of three fluoride dentifrices containing anticalculus ingredients: one and two-year results. J Clin Dent. 1988;1:48-50. [pmid: 2855463].
Triolo PT, Wefel JS, Jensen ME. Fluoride-releasing core build-up materials and artificial caries. Am J Dent. 1991;4:207-210. [pmid: 1810328].
Tronstad L. Scanning electron microscopy of attrited dentinal surfaces and subajacent dentin in human teeth. Scand J Dent Res. 1973;81:112-122. [pmid: 4513438].
Truin GJ, Konig KG, Bronkhorst EM, Frankenmolen F, Mulder J, van't Hof MA. Time trends in caries experience of 6- and 12-year-old children of different socioeconomic status in The Hague. Caries Res. 1998;32:1-4. [pmid: 9438564].
Truin GJ, van't Hof MA, Kalsbeek H, Frencken JE, Konig KG. Secular trends of caries prevalence in 6- and 12-year-old Dutch children. Community Dent Oral Epidemiol. 1993;21:249-252. [pmid: 8222596].
Tsubouchi J, Yamamoto S, Shimono T, Domoto PK. A longitudinal assessment of predictive value of a caries activity test in young children. ASDC J Dent Child. 1995;62:34-37. [pmid: 7775681].
Tsuchiya H, Sato M, Kato H, Okubo T, Juneja LR, Kim M. Simultaneous determination of catechins in human saliva by high-performance liquid chromatography. J Chromatogr B Biomed Appl. 1997;703:253-258.
Tubert-Jeannin S, Morel A. A program of preventive dentistry carried out in Auvergne, France: One year results. Rev Epidemiol Sante Publique. 1994;42:512-519. [pmid: 7816964].
Tubert-Jeannin S, Morel-Papernot A, Woda A. Evaluation of a dental benefit plan for children conducted in Auvergne, France, since 1992. Community Dent Oral Epidemiol. 1998;26:272-282. [pmid: 9758428].
Tucker GJ, Andlaw RJ, Burchell CK. The relationship between oral hygiene and dental caries incidence in 11-year-old children. A 3-year study. Br Dent J. 1976;141:75-79. [pmid: 786335].
Tulloch JF, Antczak-Bouckoms AA, Berkey CS, Douglass CW. Selecting the optimal threshold for the radiographic diagnosis of interproximal caries. J Dent Educ. 1988;52:630-636. [pmid: 3183172].
Turpin-Mair JS, Rawls HR, Christensen LV. An in vitro study of caries prevention, cavity adaptation, homogeneity and microleakage of a new fluoride-releasing resin. J Oral Rehabil. 1982;9:523-530. [pmid: 6217305].
Tveit AB, Espelid I. Class II amalgams: interobserver variations in replacement decisions and diagnosis of caries and crevices. Int Dent J. 1992;42:12-18. [pmid: 1563816].
Tveit AB, Espelid I, Erickson RL, Glasspoole EA. Vertical angulation of the X-ray beam and radiographic diagnosis of secondary caries. Community Dent Oral Epidemiol. 1991;19:333-335. [pmid: 1837258].
Tveit AB, Espelid I, Fjelltveit A. Clinical diagnosis of occlusal dentin caries. Caries Res. 1994;28:368-372. [pmid: 8001060].
Tveit AB, Hals E. Inhibitory effect of a fluoride-containing amalgam on development of cavity wall lesions in vitro. Acta Odontol Scand. 1980;38:29-39. [pmid: 6929637].
Twetman S, McWilliam JS, Hallgren A, Oliveby A. Cariostatic effect of glass ionomer retained orthodontic appliances. An in vivo study. Swed Dent J. 1997;21:169-175. [pmid: 9472145].
Twetman S, Petersson LG. Interdental caries incidence and progression in relation to mutans streptococci suppression after chlorhexidine-thymol varnish treatments in schoolchildren. Acta Odontol Scand. 1999;57:144-148. [pmid: 10480280].
Twetman S, Petersson LG. Prediction of caries in pre-school children in relation to fluoride exposure. Eur J Oral Sci. 1996;104:523-528. [pmid: 9021320].
Twetman S, Stahl B, Nederfors T. Use of the strip mutans test in the assessment of caries risk in a group of preschool children. Int J Paediatr Dent. 1994;4:245-250. [pmid: 7748864].
Tyas MJ. Cariostatic effect of glass ionomer cement: a five-year clinical study. Aust Dent J. 1991;36:236-239. [pmid: 1831607].
Tynan JJ, Komiyama K. Cystic fibrosis and oral health. J Can Dent Assoc. 1984;50:833-835. [pmid: 6391624].
Tyndall DA, Clifton TL, Webber RL, Ludlow JB, Horton RA. TACT imaging of primary caries. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 1997;84:214-225. [pmid: 9269025].
Tyndall DA, Ludlow JB, Platin E, Nair M. A comparison of Kodak Ektaspeed Plus film and the Siemens Sidexis digital imaging system for caries detection using receiver operating characteristic analysis. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 1998;85:113-118. [pmid: 9474625].
Udipi SA, Subbulakshmi G, Chandrakala P, Limaye M, Vaidya A. Influence of fluoride containing toothpaste on serum and urine fluoride levels in children. J Pierre Fauchard Acad. 1993;7:121-143. [pmid: 9791239].
Ullsfoss BN, Ogaard B, Arends J, Ruben J, Rolla G, Afseth J. Effect of a combined chlorhexidine and NaF mouthrinse: an in vivo human caries model study. Scand J Dent Res. 1994;102:109-112. [pmid: 8016555].
Oral Health in America: A Report of the Surgeon General. Rockville, MD: US Department of Health and Human Services, National Institute of Dental and Craniofacial Research, National Institutes of Health.; 2000.
Utsumi N. Oral biology in Japan 1974-1975. 3. Oral pathology. Dent Jpn (Tokyo). 1975;:12-18. [pmcid: 125885].
Vaarkamp J, ten Bosch J, Verdonschot EH, Huysmans MC. Wavelength-dependent fibre-optic transillumination of small approximal caries lesions: the use of a dye, and a comparison to bitewing radiography. Caries Res. 1997;31:232-237. [pmid: 9165196].
Vaarkamp J, Ten Bosch JJ, Verdonschot EH, Tranaeus S. Quantitative diagnosis of small approximal caries lesions utilizing wavelength-dependent fiber-optic transillumination. J Dent Res. 1997;76:875-882. [pmid: 9126184].
Valachovic RW, Douglass CW, Berkey CS, McNeil BJ, Chauncey HH. Examiner reliability in dental radiography. J Dent Res. 1986;65:432-436. [pmid: 3457049].
Valachovic RW, Douglass CW, Reiskin AB, Chauncey HH, McNeil BJ. The use of panoramic radiography in the evaluation of asymptomatic adult dental patients. Oral Surg Oral Med Oral Pathol. 1986;61:289-296. [pmid: 3458134].
Valderhaug J, Jokstad A, Ambjornsen E, Norheim PW. Assessment of the periapical and clinical status of crowned teeth over 25 years. J Dent. 1997;25:97-105. [pmid: 9105139].
Valdez IH, Fox PC. Diagnosis and management of salivary dysfunction. Crit Rev Oral Biol Med. 1993;4:271-277. [pmid: 8373984].
Valenzuela VS, Abarca AM, Silva ND, Franco ME, Huerta JM. In vitro inhibition of marginal caries-like lesions with fluoride-containing amalgam. Oper Dent. 1994;19:91-96. [pmid: 9028246].
van der Linden RP, Dermaut LR. White spot formation under orthodontic bands cemented with glass ionomer with or without Fluor Protector. Eur J Orthod. 1998;20:219-224. [pmid: 9699400].
van der Merwe WJ. Clinical evaluation of four dental amalgams over a three year period. J Dent Assoc S Afr. 1993;48:329-332. [pmid: 9511601].
van der Merwe WJ. Clinical evaluation of four dental amalgams over a two year period. J Dent Assoc S Afr. 1992;47:521-525. [pmid: 9511639].
van der Stelt PF, Ruttiman UE, Webber RL, Heemstra P. In vitro study into the influence of X-ray beam angulation on the detection of artificial caries defects on bitewing radiographs. Caries Res. 1989;23:334-341. [pmid: 2766319].
van der Veen MH, ten Bosch JJ. A fiber-optic setup for quantification of root surface demineralization. Eur J Oral Sci. 1996;104:118-122. [pmid: 8804899].
van der Veen MH, ten Bosch JJ. An in vitro evaluation of fluorescein penetration into natural root surface carious lesions. Caries Res. 1993;27:258-261. [pmid: 8402797].
van der Veen MH, Tsuda H, Arends J, ten Bosch JJ. Evaluation of sodium fluorescein for quantitative diagnosis of root caries. J Dent Res. 1996;75:588-593. [pmid: 8655764].
van Dijken JW. A clinical evaluation of anterior conventional, microfiller, and hybrid composite resin fillings. A 6-year follow-up study. Acta Odontol Scand. 1986;44:357-367. [pmid: 3469864].
van Dijken JW. Longevity of new hybrid restorative materials in class III cavities. Eur J Oral Sci. 1999;107:215-219. [pmid: 10424386].
van Dijken JW, Kieri C, Carlen M. Longevity of extensive class II open-sandwich restorations with a resin-modified glass-ionomer cement. J Dent Res. 1999;78:1319-1325. [pmid: 10403459].
Van Dis ML, Zitterbart PA. Clinical evaluation of an illuminated dental mirror. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 1996;81:180-185. [pmid: 8665312].
Van Dorp CS, Ten Cate JM. Preventive measures and caries progression: an in vitro study on fissures and smooth surfaces of human molars. ASDC J Dent Child. 1992;59:257-262. [pmid: 1430494].
van Eck AA, Theuns HM, Groeneveld A. Effect of annual application of polyurethane lacquer containing silane-fluoride. Community Dent Oral Epidemiol. 1984;12:230-232. [pmid: 6590174].
Van Herpen BP, Arends J. Mineral distributions in enamel after in vivo de- and remineralization. J Biol Buccale. 1987;15:199-204. [pmid: 3483368].
van Houte J. Microbiological predictors of caries risk. Adv Dent Res. 1993;7:87-96. [pmid: 8260016].
van Houte J, Lopman J, Kent R. The final pH of bacteria comprising the predominant flora on sound and carious human root and enamel surfaces. J Dent Res. 1996;75:1008-1014. [pmid: 8708129].
Van Meerbeek B, Conn LJJ, Duke ES, Eick JD, Robinson SJ, Guerrero D. Correlative transmission electron microscopy examination of nondemineralized and demineralized resin-dentin interfaces formed by two dentin adhesive systems. J Dent Res. 1996;75:879-888. [pmid: 8675798].
Van Meerbeek B, Peumans M, Verschueren M, et al. Clinical status of ten dentin adhesive systems. J Dent Res. 1994;73:1690-1702. [pmid: 7983255].
van Palenstein Helderman WH, Munck L, Mushendwa S, van't Hof MA, Mrema FG. Effect evaluation of an oral health education programme in primary schools in Tanzania. Community Dent Oral Epidemiol. 1997;25:296-300. [pmid: 9332807].
van Palenstein Helderman WH, ter Pelkwijk L, van Dijk JW. Caries in fissures of permanent first molars as a predictor for caries increment. Community Dent Oral Epidemiol. 1989;17:282-284. [pmid: 2686925].
van Rijkom HM, Truin GJ, van 't Hof MA. A meta-analysis of clinical studies on the caries-inhibiting effect of chlorhexidine treatment. J Dent Res. 1996;75:790-795. [pmid: 8655776].
van Rijkom HM, Truin GJ, van 't Hof MA. A meta-analysis of clinical studies on the caries-inhibiting effect of fluoride gel treatment. Caries Res. 1998;32:83-92. [pmid: 9544855].
van Rijkom HM, Verdonschot EH. Factors involved in validity measurements of diagnostic tests for approximal caries--a meta-analysis. Caries Res. 1995;29:364-370. [pmid: 8521438].
van Strijp AJ, van Steenbergen TJ, ten Cate JM. Effects of chlorhexidine on the bacterial colonization and degradation of dentin and completely demineralized dentin in situ. Eur J Oral Sci. 1997;105:27-35. [pmid: 9085026].
van Wyk I, van Wyk CW. The effectiveness of a 0.2 percent and a 0.05 percent neutral NaF mouthrinsing programme. J Dent Assoc S Afr. 1986;41:35-40. [pmid: 3462964].
Vanderas AP, Manetas C, Papagiannoulis L. Urinary catecholamine levels in children with and without dental caries. J Dent Res. 1995;74:1671-1678. [pmid: 7499590].
Varma AO. Specific non-parametric approaches to analyzing caries clinical trials. J Dent Res. 1984;63 Spec No:784-790. [pmid: 6586783].
Varpio M. Caries prevalence and therapy in the deciduous dentition from 3 to 8 years. A longitudinal study. Acta Odontol Scand. 1981;39:307-312. [pmid: 6950639].
Varpio M. Changes in comprehensive dental care of the primary dentition from 1979 to 1989. I. Caries diagnosis and prevalence in a population treated at a university dental clinic. Swed Dent J. 1992;16:33-40. [pmid: 1579886].
Varpio M. Changes in comprehensive dental care of the primary dentition from 1979 to 1989. II. Restorative treatment of primary molars in a population treated at a university dental clinic. Swed Dent J. 1993;17:35-42. [pmid: 8362361].
Varpio M. Clinical aspects of restorative treatment in the primary dentition. Swed Dent J Suppl. 1993;96:1-47. [pmid: 8310420].
Varpio M, Warfvinge J, Noren JG. Proximo-occlusal composite restorations in primary molars: marginal adaptation, bacterial penetration, and pulpal reactions. Acta Odontol Scand. 1990;48:161-167. [pmid: 2195839].
Varsio S, Vehkalahti M. Dentists' decisions on caries risk and preventive treatment by dental state among 15-year-old adolescents. Community Dent Health. 1997;14:166-170. [pmid: 9332042].
Varsio S, Vehkalahti M. Evaluation of preventive treatment by risk of caries among 13-year-olds. Community Dent Oral Epidemiol. 1996;24:277-281. [pmid: 8871037].
Vassilopoulou A, White GE. The effectiveness of a 0.4% stannous fluoride gel vs. a 0.1% stannous fluoride rinse on occlusal enamel. J Pedod. 1986;10:141-147. [pmid: 3458899].
Veerappan A, Ravisekar CV, Chandrabhushanam A, Venkatesh V, Natarajan K. Brain abscess in a tertiaty care center in India: A prospective study. International Pediatrics. 1996;11:99-102.
Veerkamp JS, Porcelijn T, Gruythuysen RJ. Intravenous sedation for outpatient treatment of child dental patients: an exploratory study. ASDC J Dent Child. 1997;64:48-54. [pmid: 9096819].
Vehkalahti M, Helminen S. Outcome of public oral health services in relation to treatment mix. Acta Odontol Scand. 1994;52:1-6. [pmid: 8184674].
Vehkalahti M, Nikula-Sarakorpi E, Paunio I. Evaluation of salivary tests and dental status in the prediction of caries increment in caries-susceptible teenagers. Caries Res. 1996;30:22-28. [pmid: 8850579].
Vehkalahti M, Paunio I. Association between root caries occurrence and periodontal state. Caries Res. 1994;28:301-306. [pmid: 8069889].
Vehkalahti M, Rytomaa I, Helminen S. Decline in dental caries and public oral health care of adolescents. Acta Odontol Scand. 1991;49:323-328. [pmid: 1776398].
Vehkalahti M, Tarkkonen L, Varsio S, Heikkila P. Decrease in and polarization of dental caries occurrence among child and youth populations, 1976-1993. Caries Res. 1997;31:161-165. [pmid: 9165184].
Vehkalahti MM, Solavaara L, Rytomaa I. An eight-year follow-up of the occlusal surfaces of first permanent molars. J Dent Res. 1991;70:1064-1067. [pmid: 2066488].
Venta I, Meurman JH, Murtomaa H, Turtola L. Effect of erupting third molars on dental caries and gingival health in Finnish students. Caries Res. 1993;27:438-443. [pmid: 8242683].
Verdonschot EH, Angmar-Mansson B, ten Bosch JJ, et al. Developments in caries diagnosis and their relationship to treatment decisions and quality of care. ORCA Saturday Afternoon Symposium 1997. Caries Res. 1999;33:32-40. [pmid: 9831778].
Verdonschot EH, Bronkhorst EM, Burgersdijk RC, Konig KG, Schaeken MJ, Truin GJ. Performance of some diagnostic systems in examinations for small occlusal carious lesions. Caries Res. 1992;26:59-64. [pmid: 1568239].
Verdonschot EH, Bronkhorst EM, Wenzel A. Approximal caries diagnosis using fiber-optic transillumination: a mathematical adjustment to improve validity. Community Dent Oral Epidemiol. 1991;19:329-332. [pmid: 1837257].
Verdonschot EH, Kuijpers JM, Polder BJ, De Leng-Worm MH, Bronkhorst EM. Effects of digital grey-scale modification on the diagnosis of small approximal carious lesions. J Dent. 1992;20:44-49. [pmid: 1548386].
Verdonschot EH, van de Rijke JW, Brouwer W, ten Bosch JJ, Truin GJ. Optical quantitation and radiographic diagnosis of incipient approximal caries lesions. Caries Res. 1991;25:359-364. [pmid: 1747886].
Verdonschot EH, Wenzel A, Bronkhorst EM. Applicability of Receiver Operating Characteristic (ROC) analysis on discrete caries depth ratings. Community Dent Oral Epidemiol. 1993;21:269-272. [pmid: 8222599].
Verdonschot EH, Wenzel A, Bronkhorst EM. Assessment of diagnostic accuracy in caries detection: an analysis of two methods. Community Dent Oral Epidemiol. 1993;21:203-208. [pmid: 8370256].
Verdonschot EH, Wenzel A, Truin GJ, Konig KG. Performance of electrical resistance measurements adjunct to visual inspection in the early diagnosis of occlusal caries. J Dent. 1993;21:332-337. [pmid: 8258582].
Verrips GH, Kalsbeek H, Eijkman MA. Ethnicity and maternal education as risk indicators for dental caries, and the role of dental behavior. Community Dent Oral Epidemiol. 1993;21:209-214. [pmid: 8370257].
Verrips GH, Kalsbeek H, Van Woerkum CM, Koelen M, Kok-Weimar TL. Correlates of toothbrushing in preschool children by their parents in four ethnic groups in The Netherlands. Community Dent Health. 1994;11:233-239. [pmid: 7850643].
Versteeg KH, Sanderink GC, Velders XL, van Ginkel FC, van der Stelt PF. In vivo study of approximal caries depth on storage phosphor plate images compared with dental x-ray film. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 1997;84:210-213. [pmid: 9269024].
Vestergaard V, Moss A, Pedersen HO, Poulsen S. The effect of supervised tooth cleansing every second week on dental caries in Danish school children. Acta Odontol Scand. 1978;36:249-252. [pmid: 81586].
Via WFJ. Radiology of the jaws: diseases involving the teeth. Semin Roentgenol. 1971;6:370-380. [pmid: 5152660].
Videroni W, Sternberg GS, Davies GN. Effect on caries experience of lifetime residents after 10 years of fluoridation in Townsville, Australia. Community Dent Oral Epidemiol. 1976;4:248-253. [pmid: 1069614].
Vieira AR, de Souza IP, Modesto A, Castro GF, Vianna R. Gingival status of HIV+ children and the correlation with caries incidence and immunologic profile. Pediatr Dent. 1998;20:169-172. [pmid: 9635311].
Vigild M, Skougaard M, Hadi RA, al-Zaabi F, al-Yasseen I. Dental caries and dental fluorosis among 4-, 6-, 12- and 15-year-old children in kindergartens and public schools in Kuwait. Community Dent Health. 1996;13:47-50.
Vignarajah S. Dental caries experience and enamel opacities in children residing in urban and rural areas of Antigua with different levels of natural fluoride in drinking water. Community Dent Health. 1993;10:159-166. [pmid: 8402302].
Villa AE, Guerrero S, Villalobos J. Estimation of optimal concentration of fluoride in drinking water under conditions prevailing in Chile. Community Dent Oral Epidemiol. 1998;26:249-255. [pmid: 9758425].
Virtanen JI, Bloigu RS, Larmas MA. Effect of early restorations of permanent molars on filling increments of individual teeth. J Dent. 1997;25:17-24. [pmid: 9080735].
Virtanen JI, Bloigu RS, Larmas MA. Timing of first restorations before, during, and after a preventive xylitol trial. Acta Odontol Scand. 1996;54:211-216. [pmid: 8876730].
Virtanen JI, Larmas MA. Timing of first fillings on different permanent tooth surfaces in Finnish schoolchildren. Acta Odontol Scand. 1995;53:287-292. [pmid: 8553804].
Vizioli MR. Dichroism and birefringence in human carious dentine. Ann Histochim. 1970;15:131-140. [pmid: 4249399].
Volpe AR, Petrone ME, Davies R, Proskin HM. Clinical anticaries efficacy of NaF and SMFP dentifrices: overview and resolution of the scientific controversy. J Clin Dent. Spec No. 1995;6:1-28. [pmid: 8602906].
Volpe AR, Petrone ME, Davies RM. A critical review of the 10 pivotal caries clinical studies used in a recent meta-analysis comparing the anticaries efficacy of sodium fluoride and sodium monofluorophosphate dentifrices. Am J Dent. 1993;6 Spec No:S13-42. [pmid: 7488352].
Volpe AR, Petrone ME, DeVizio W, Davies RM. A review of plaque, gingivitis, calculus and caries clinical efficacy studies with a dentifrice containing triclosan and PVM/MA Copolymer. J Clin Dent. 1993;4 Spec No:31-41. [pmid: 8397834].
von der Fehr FR. Caries prevalence in the Nordic countries. Int Dent J. 1994;44:371-378. [pmid: 7814104].
von der Fehr FR, Gropen AM. Caries treatment through 30 years in children and adolescents in Asker, Norway. Community Dent Oral Epidemiol. 1995;23:193-199. [pmid: 7587138].
Vrbic V, Kosmelj B+KOSMELJ B, Ravnik C. A 3-year study among Yugoslavian schoolchildren on caries reduction after topical application of 4% NaF-PO_4_. Community Dent Oral Epidemiol. 1974;2:163-165. [pmid: 4154818].
Waggoner WF, Ashton JJ. Comparison of Kodak D-speed and E-speed x-ray film in detection of proximal caries. ASDC J Dent Child. 1988;55:459-462. [pmid: 3198837].
Waggoner WF, Ashton JJ. Predictability of cavitation based upon radiographic appearance: comparison of two film types. Quintessence Int. 1989;20:55-60. [pmid: 2762498].
Waggoner WF, Crall JJ. A study of the carious lesion utilizing radiography, polarized light microscopy, and scanning electron microscopy. Quintessence Int. 1984;15:1163-1174. [pmid: 6597466].
Wakoh M, Kitagawa H, Harada T, Shibuya H, Kuroyanagi K. Computed dental radiography system versus conventional dental x-ray films for detection of simulated proximal caries. Oral Radiol. 1997;13:73-82.
Walder Junior O, Moreira BH. Effectiveness of acetic acid and chromic anhydride in prevention of dental caries. ASDC J Dent Child. 1971;38:134-136. [pmid: 4926692].
Waldman HB. Dental care needs and services for children: England, Wales, and United States compared. ASDC J Dent Child. 1983;50:48-54. [pmid: 6572199].
Walker J, Floyd K, Jakobsen J. The effectiveness of sealants in pediatric patients. ASDC J Dent Child. 1996;63:268-270. [pmid: 8893980].
Walker JD, Jensen ME, Pinkham JR. A clinical review of preventive resin restorations. ASDC J Dent Child. 1990;57:257-259. [pmid: 2197305].
Wallace MC, Retief DH, Bradley EL. The 48-month increment of root caries in an urban population of older adults participating in a preventive dental program. J Public Health Dent. 1993;53:133-137. [pmid: 8371190].
Wallenstein S, Fleiss JL, Kingman A. Repeat measurements analysis of dental data. J Dent Res. 1980;59:2021-2024. [pmid: 6933193].
Wallis CP. Preventive treatment of fissure caries. J Dent. 1973;1:207-210. [pmid: 4522323].
Walls AW, Murray JJ, McCabe JF. The management of occlusal caries in permanent molars. A clinical trial comparing a minimal composite restoration with an occlusal amalgam restoration. Br Dent J. 1988;164:288-292. [pmid: 3164204].
Walton JL, Messer LB. Dental caries and fluorosis in breast-fed and bottle-fed children. Caries Res. 1981;15:124-137. [pmid: 6937260].
Waly NG. Assessment of salivary Lactobacillus and Streptococcus mutans counts following sodium fluoride mouthrinsing in Egyptian children. Egypt Dent J. 1995;41:1179-1188. [pmid: 9497654].
Waly NG. Evaluation of three diagnostic methods for initial proximal caries detection in primary molars. Egypt Dent J. 1995;41:1441-1449. [pmid: 9497695].
Waly NG. A five-year comparative study of calcium hydroxide-glutaraldehyde pulpotomies versus calcium hydroxide pulpotomies in young permanent molars. Egypt Dent J. 1995;41:993-1000. [pmid: 9497631].
Waly NG. Long-term follow-up of glutaraldehyde pulpotomies in young permanent molars. Egypt Dent J. 1994;40:927-932. [pmid: 9588137].
Wandera A. In vitro enamel effects of a resin-modified glass ionomer: fluoride uptake and resistance to demineralization. Pediatr Dent. 1998;20:411-417. [pmid: 9866145].
Wang NJ. Preventive dental care of children and adolescents in the 1990s: Denmark, Iceland, Norway, and Sweden. Acta Odontol Scand. 1998;56:169-172. [pmid: 9688227].
Wang NJ, Kalletstal C, Petersen PE, Arnadottir IB. Caries preventive services for children and adolescents in Denmark, Iceland, Norway and Sweden: strategies and resource allocation. Community Dent Oral Epidemiol. 1998;26:263-271. [pmid: 9758427].
Wang NJ, Riordan PJ. Recall intervals, dental hygienists and quality in child dental care. Community Dent Oral Epidemiol. 1995;23:8-14. [pmid: 7774181].
Wanman A, Wigren L. Need and demand for dental treatment. A comparison between an evaluation based on an epidemiologic study of 35-, 50-, and 65-year-olds and performed dental treatment of matched age groups. Acta Odontol Scand. 1995;53:318-324. [pmid: 8553809].
Watt ME, Lunt DA, Gilmour WH. Caries prevalence in the deciduous dentition of a mediaeval population from the south-west of Scotland. Arch Oral Biol. 1997;42:811-820. [pmid: 9460534].
Watt ME, Lunt DA, Gilmour WH. Caries prevalence in the permanent dentition of a mediaeval population from the south-west of Scotland. Arch Oral Biol. 1997;42:601-620. [pmid: 9403114].
Way JL, Caputo AA, Jedrychowski JR. Bond strength of light-cured glass ionomers to carious primary dentin. ASDC J Dent Child. 1996;63:261-264. [pmid: 8893978].
Webber RL, Stark L. Influence of fogging radiation and mode of display on the interpretation of dental caries from conventional radiographs. Invest Radiol. 1972;7:506-516. [pmid: 4644895].
Weber DF. Human dentine sclerosis: a microradiographic survey. Arch Oral Biol. 1974;19:163-169. [pmid: 4527828].
Weber DF, Glick PL. Correlative microscopy of enamel prism orientation. Am J Anat. 1975;144:407-419. [pmid: 1199959].
Weems RA, Firestone AR, Heaven TJ. Preliminary evaluation of an educational outcomes assessment process for dental interpretive radiography. J Dent Educ. 1992;56:746-750. [pmid: 1430531].
Weerheijm KL, de Soet JJ, van Amerongen WE, de Graaff J. The effect of glass-ionomer cement on carious dentine: an in vivo study. Caries Res. 1993;27:417-423. [pmid: 8242680].
Weerheijm KL, Groen HJ, Bast AJ, Kieft JA, Eijkman MA, van Amerongen WE. Clinically undetected occlusal dentine caries: a radiographic comparison. Caries Res. 1992;26:305-309. [pmid: 1423448].
Weerheijm KL, Kreulen CM, de Soet JJ, Groen HJ, van Amerongen WE. Bacterial counts in carious dentine under restorations: 2-year in vivo effects. Caries Res. 1999;33:130-134. [pmid: 9892780].
Weerheijm KL, Uyttendaele-Speybrouck BF, Euwe HC, Groen HJ. Prolonged demand breast-feeding and nursing caries. Caries Res. 1998;32:46-50. [pmid: 9438571].
Weerheijm KL, van Amerongen WE, Eggink CO. The clinical diagnosis of occlusal caries: a problem. ASDC J Dent Child. 1989;56:196-200. [pmid: 2723206].
Wefel JS. Root caries histopathology and chemistry. Am J Dent. 1994;7:261-265. [pmid: 7986449].
Wefel JS. Working Group Report 2: In situ caries models, saliva, microbiology, and statistical considerations. Adv Dent Res. 1995;9:335-337. [pmid: 8615953].
Wefel JS, Clarkson BH, Heilman JR. Natural root caries: a histologic and microradiographic evaluation. J Oral Pathol. 1985;14:615-623. [pmid: 3930671].
Wefel JS, Harless JD. Comparison of artificial white spots by microradiography and polarized light microscopy. J Dent Res. 1984;63:1271-1275. [pmid: 6094633].
Wefel JS, Harless JD. The effect of several topical fluoride agents on artificial lesion formation. J Dent Res. 1982;61:1169-1171. [pmid: 6956599].
Wefel JS, Harless JD. Topical fluoride application and lesion progression in vitro. J Dent Res. 1984;63:1276-1278. [pmid: 6594368].
Wefel JS, Harless JD. The use of saturated DCPD in remineralization of artificial caries lesions in vitro. J Dent Res. 1987;66:1640-1643. [pmid: 10872398].
Wefel JS, Heilman JR, Jordan TH. Comparisons of in vitro root caries models. Caries Res. 1995;29:204-209. [pmid: 7621496].
Wefel JS, Jensen ME, Triolo PT, Faller RV, Hogan MM, Bowman WD. De/remineralization from sodium fluoride dentifrices. Am J Dent. 1995;8:217-220. [pmid: 7576392].
Wegner H. The clinical effect of application of fluoride varnish. Caries Res. 1976;10:318-320. [pmid: 1065476].
Wei SH, Yiu CKY. Evaluation of the use of topical fluoride gel. Caries Res. 1993;27:29-34. [pmid: 8500122].
Weinstein P, Domoto P, Koday M, Leroux B. Results of a promising open trial to prevent baby bottle tooth decay: a fluoride varnish study. ASDC J Dent Child. 1994;61:338-341. [pmid: 7897002].
Weinstein P, Domoto P, Wohlers K, Koday M. Mexican-American parents with children at risk for baby bottle tooth decay: pilot study at a migrant farmworkers clinic. ASDC J Dent Child. 1992;59:376-383. [pmid: 1401413].
Weintraub JA, Burt BA. Prevention of dental caries by the use of pit-and-fissure sealants. J Public Health Policy. 1987;8:542-560. [pmid: 3323239].
Weintraub JA, Stearns SC, Burt BA, Beltran E, Eklund SA. A retrospective analysis of the cost-effectiveness of dental sealants in a childrens health center. Soc Sci Med. 1993;36:1483-1493. [pmid: 8511636].
Weisenstein PR, Zacherl WA. A multiple-examiner clinical evaluation of a sodium fluoride dentifrice. J Am Dent Assoc. 1972;84:621-623. [pmid: 4400046].
Weiss EI, Tzohar A, Kaffe I, Littner MM, Gelernter I, Eli I. Interpretation of bitewing radiographs. Part 2. Evaluation of the size of approximal lesions and need for treatment. J Dent. 1996;24:385-388. [pmid: 8990681].
Welbury RR, Walls AW, Murray JJ, McCabe JF. The 5-year results of a clinical trial comparing a glass polyalkenoate (ionomer) cement restoration with an amalgam restoration. Br Dent J. 1991;170:177-181. [pmid: 2018693].
Welch NM, Saulsbury FT, Kesler RW. The value of the preschool examination in screening for health problems. J Pediatr. 1982;100:232-234. [pmid: 7057331].
Wendt LK, Hallonsten AL, Koch G, Birkhed D. Oral hygiene in relation to caries development and immigrant status in infants and toddlers. Scand J Dent Res. 1994;102:269-273. [pmid: 7817151].
Wendt LK, Koch G. Fissure sealant in permanent first molars after 10 years. Swed Dent J. 1988;12:181-185. [pmid: 2975403].
Wendt LK, Koch G, Hallonsten AL. Parental awareness of dental caries in toddlers. Swed Dent J. 1996;20:161-164. [pmid: 8899953].
Wenzel A. Current trends in radiographic caries imaging. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 1995;80:527-539. [pmid: 8556463].
Wenzel A. Digital radiography and caries diagnosis. Dento Maxillo Facial Radiol. 1998;27:3-11.
Wenzel A, Andersen L. A quantitative analysis of subtraction images based on bite-wing radiographs for simulated victim identification in forensic dentistry. J Forensic Odontostomatol. 1994;12:1-5. [pmid: 9227082].
Wenzel A, Borg E, Hintze H, Grondahl HG. Accuracy of caries diagnosis in digital images from charge-coupled device and storage phosphor systems: an in vitro study. Dento Maxillo Facial Radiol. 1995;24:250-254.
Wenzel A, Fejerskov O. Validity of diagnosis of questionable caries lesions in occlusal surfaces of extracted third molars. Caries Res. 1992;26:188-194. [pmid: 1628293].
Wenzel A, Fejerskov O, Kidd E, Joyston-Bechal S, Groeneveld A. Depth of occlusal caries assessed clinically, by conventional film radiographs, and by digitized, processed radiographs. Caries Res. 1990;24:327-333. [pmid: 2261604].
Wenzel A, Gotfredsen E, Borg E, Grondahl HG. Impact of lossy image compression on accuracy of caries detection in digital images taken with a storage phosphor system. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 1996;81:351-355. [pmid: 8653470].
Wenzel A, Halse A. Digital subtraction radiography after stannous fluoride treatment for occlusal caries diagnosis. Oral Surg Oral Med Oral Pathol. 1992;74:824-828. [pmid: 1488242].
Wenzel A, Hintze H. Perception of image quality in direct digital radiography after application of various image treatment filters for detectability of dental disease. Dento Maxillo Facial Radiol. 1993;22:131-134.
Wenzel A, Hintze H, Horsted-Bindslev P. Accuracy of radiographic detection of residual caries in connection with tunnel restorations. Caries Res. 1998;32:17-22. [pmid: 9438567].
Wenzel A, Hintze H, Horsted-Bindslev P. Discrimination between restorative dental materials by their radiopacity measured in film radiographs and digital images. J Forensic Odontostomatol. 1998;16:8-13. [pmid: 9922755].
Wenzel A, Hintze H, Mikkelsen L, Mouyen F. Radiographic detection of occlusal caries in noncavitated teeth. A comparison of conventional film radiographs, digitized film radiographs, and RadioVisioGraphy. Oral Surg Oral Med Oral Pathol. 1991;72:621-626. [pmid: 1745523].
Wenzel A, Larsen MJ, Fejerskov O. Detection of occlusal caries without cavitation by visual inspection, film radiographs, xeroradiographs, and digitized radiographs. Caries Res. 1991;25:365-371. [pmid: 1747887].
Wenzel A, Pitts N, Verdonschot EH, Kalsbeek H. Developments in radiographic caries diagnosis. J Dent. 1993;21:131-140. [pmid: 8315086].
Wenzel A, Verdonschot EH. Some considerations in the evaluation of diagnostic tests in dentistry. Dento Maxillo Facial Radiol. 1994;23:179-182.
Wenzel A, Verdonschot EH, Truin GJ, Konig KG. Accuracy of visual inspection, fiber-optic transillumination, and various radiographic image modalities for the detection of occlusal caries in extracted non-cavitated teeth. J Dent Res. 1992;71:1934-1937. [pmid: 1452897].
Wenzel A, Verdonschot EH, Truin GJ, Konig KG. Impact of the validator and the validation method on the outcome of occlusal caries diagnosis. Caries Res. 1994;28:373-377. [pmid: 8001061].
Wesenberg G, Hals E. The structure of experimental in vitro lesions around glass ionomer cement restorations in human teeth. J Oral Rehabil. 1980;7:175-184. [pmid: 6928451].
Westbrook JL, Miller AS, Chilton NW, Williams FL, Mumma RDJ. Root surface caries: a cinical, histopathologic and microradiographic investigation. Caries Res. 1974;8:249-255. [pmid: 4525333].
Westergren G, Krasse B. Evaluation of a micromethod for determination of Streptococcus mutans and Lactobacillus infection. J Clin Microbiol. 1978;7:82-83. [pmcid: 274862]. [pmid: 342541].
Westerman GH, Hicks MJ, Flaitz CM, Powell GL, Blankenau RJ. Surface morphology of sound enamel after argon laser irradiation: an in vitro scanning electron microscopic study. J Clin Pediatr Dent. 1996;21:55-59. [pmid: 9161208].
White BA, Albertini TF, Brown LJ, Larach-Robinson D, Redford M, Selwitz RH. Selected restoration and tooth conditions: United States, 1988-1991. J Dent Res. 1996;75 Spec No:661-671. [pmid: 8594090].
White DJ. The comparative sensitivity of intra-oral, in vitro, and animal models in the 'profile' evaluation of topical fluorides. J Dent Res. 1992;71 Spec No:884-894. [pmid: 1592980].
White DJ. Reactivity of fluiride dentifrices with artificial carries III. Quantitative aspects of acquired acid resistance (AAR): F uptake, retention, surface hardening and remineralization. J Clin Dent. 1991;3:6-14. [pmid: 1812910].
White DJ. Reactivity of fluoride dentifrices with artificial caries. I. Effects on early lesions: F uptake, surface hardening and remineralization. Caries Res. 1987;21:126-140. [pmid: 3469028].
White DJ. Reactivity of fluoride dentifrices with artificial caries. II. Effects on subsurface lesions: F uptake, F distribution, surface hardening and remineralization. Caries Res. 1988;22:27-36. [pmid: 3422058].
White GE, Tsamtsouris A, Williams DL. Early detection of occlusal caries by measuring the electrical resistance of the tooth. J Dent Res. 1978;57:195-200. [pmid: 308070].
White GE, Tsamtsouris A, Williams DL. A longitudinal study of electronic detection of occlusal caries. J Pedod. 1981;5:91-101. [pmid: 6942149].
White JM, Goodis HE, Setcos JC, Eakle S, Hulscher BE, Rose CL. Effects of pulsed Nd:YAG laser energy on human teeth: a three-year follow-up study. J Am Dent Assoc. 1993;124:45-51. [pmid: 8335798].
White SC. Caries detection with xeroradiographs: the influence of observer experience. Oral Surg Oral Med Oral Pathol. 1987;64:118-122. [pmid: 3475648].
White SC, Atchison KA, Hewlett ER, Flack VF. Clinical and historical predictors of dental caries on radiographs. Dento Maxillo Facial Radiol. 1995;24:121-127.
White SC, Atchison KA, Hewlett ER, Flack VF. Efficacy of FDA guidelines for ordering radiographs for caries detection. Oral Surg Oral Med Oral Pathol. 1994;77:531-540. [pmid: 8028878].
White SC, Gratt BM. Clinical trials of intraoral dental xeroradiography. J Am Dent Assoc. 1979;99:810-816. [pmid: 385665].
White SC, Gratt BM, Bauer JG. A clinical comparison of xeroradiography and film radiography for the detection of proximal caries. Oral Surg Oral Med Oral Pathol. 1988;65:242-248. [pmid: 3422729].
White SC, Hollender L, Gratt BM. Comparison of xeroradiographs and film for detection of proximal surface caries. J Am Dent Assoc. 1984;108:755-759. [pmid: 6588117].
White SC, Kaffe I, Gornbein JA. Prediction of efficacy of bitewing radiographs for caries detection. Oral Surg Oral Med Oral Pathol. 1990;69:506-513. [pmid: 2326040].
White SC, McMullin K. Comparison of xeroradiographs and two types of film for detecting caries in approximal surfaces of primary teeth. Caries Res. 1986;20:444-450. [pmid: 3463427].
White SC, Stafford ML, Beeninga LR. Intraoral xeroradiography. Oral Surg Oral Med Oral Pathol. 1978;46:862-870. [pmid: 282550].
White SC, Yoon DC. Comparative performance of digital and conventional images for detecting proximal surface caries. Dento Maxillo Facial Radiol. 1997;26:32-38.
Whitehurst V, Soni NN. Adhesive sealant clinical trial: results eighteen months after one application. J Prev Dent. 1976;3:20-22. [pmid: 801963].
Whittle JG, Davies KW. Dental caries in 12-year-old children in Salford, UK: changes over 28 years. Int J Paediatr Dent. 1992;2:87-91. [pmid: 1420100].
Whittle JG, Downer MC. Dental health and treatment needs of Birmingham and Salford school children. A comparison in a fluoridated and a non-fluoridated area. Br Dent J. 1979;147:67-71. [pmid: 288479].
Fluorides and oral health. World Health Organ Tech Rep Ser. 1994;846:1-37. [pmid: 7975675].
Whyte RJ, Leake JL, Howley TP. Two-year follow-up of 11,000 dental sealants in first permanent molars in the Saskatchewan Health Dental Plan. J Public Health Dent. 1987;47:177-181. [pmid: 3478488].
Widenheim J, Birkhed D, Hase JC, Olavi G. Effect on approximal caries in teenagers of interrupting a school-based weekly NaF mouthrinse program for 3 years. Community Dent Oral Epidemiol. 1989;17:83-86. [pmid: 2784087].
Widenheim J, Lindgren G, Granath L, Birkhed D. Model for the study of the preeruptive effect of NaF tablets on caries in permanent teeth. Community Dent Oral Epidemiol. 1985;13:86-92. [pmid: 3857154].
Wigdorowicz-Makowerowa N. Dental caries in children in the city of Wroclaw before the introduction of fluoridation of water supply in 1967. I. Material, methods of stomatological examination, statistical analysis and terminology. Arch Immunol Ther Exp (Warsz). 1972;20:959-965. [pmcid: 100331]. [pmid: 4146076].
Wiktorsson AM, Martinsson T, Zimmerman M. Salivary levels of lactobacilli, buffer capacity and salivary flow rate related to caries activity among adults in communities with optimal and low water fluoride concentrations. Swed Dent J. 1992;16:231-237. [pmid: 1481130].
Wilkinson SC, Higham SM, Ingram GS, Edgar WM. Visualization of root caries lesions by means of a diazonium dye. Adv Dent Res. 1997;11:515-522. [pmid: 9470512].
Willemsen WL, Truin GJ, Kalsbeek H, Mulder J. Caries prevalence in Dutch elderly people. Community Dent Health. 1991;8:39-44. [pmid: 2049655].
Willershausen B, Lenzner K, Hagedorn B, Ernst C. Oral health status of hospitalized children with cancer: a comparative study. Eur J Med Res. 1998;3:480-484. [pmid: 9753706].
Williams B, Laxton L, Holt RD, Winter GB. Fissure sealants: a 4-year clinical trial comparing an experimental glass polyalkenoate cement with a bis glycidyl methacrylate resin used as fissure sealants. Br Dent J. 1996;180:104-108. [pmid: 8746143].
Williams B, Price R, Winter GB. Fissure sealants. A 2-year clinical trial. Br Dent J. 1978;145:359-364. [pmid: 363134].
Williams B, Ward R, Winter GB. A two-year clinical trial comparing different resin systems used as fissure sealants. Br Dent J. 1986;161:367-370. [pmid: 2947603].
Williams B, Winter GB. Fissure sealants. Further results at 4 years. Br Dent J. 1981;150:183-187. [pmid: 6452150].
Wilson CJ. The effect of calcium sucrose phosphates chewing gum on caries incidence in children. Journal of the Wisconsin Dental Association. 1975;51:521-525. [pmid: 1069140].
Wilson CJ. Ready-to-eat cereals and dental caries in children: a three-year study. J Dent Res. 1979;58:1853-1858. [pmid: 290650].
Wilson NH, Burke FJ, Mjor IA. Reasons for placement and replacement of restorations of direct restorative materials by a selected group of practitioners in the United Kingdom. Quintessence Int. 1997;28:245-248. [pmid: 10332373].
Wilson RF, Ashley FP. Identification of caries risk in schoolchildren: salivary buffering capacity and bacterial counts, sugar intake and caries experience as predictors of 2-year and 3-year caries increment. Br Dent J. 1989;167:99-102. [pmid: 2765324].
Winn DM, Brunelle JA, Selwitz RH, et al. Coronal and root caries in the dentition of adults in the United States, 1988-1991. J Dent Res. 1996;75 Spec No:642-651. [pmid: 8594088].
Winston AE, Bhaskar SN. Caries prevention in the 21st century. J Am Dent Assoc. 1998;129:1579-1587. [pmid: 9818575].
Winter GB, Holt RD, Williams BF. Clinical trial of a low-fluoride toothpaste for young children. Int Dent J. 1989;39:227-235. [pmid: 2691402].
Winter GB, Murray JJ, Goose DH. Prevalence of dental caries in phenylketonuric children. Caries Res. 1974;8:256-266. [pmid: 4152098].
Wiseman JE, Shiller WR. The use of synder's caries activity test in oral hygiene effectiveness monitoring. 559. Rep US Nav Submar Med Cent. 1969;:1-4.
Wist AO, Moon P, Herr SL, Fatouros PP. Investigation of a new light imaging technique to detect incipient caries in teeth. J Clin Laser Med Surg. 1994;12:165-170. [pmid: 10147423].
Wist AO, Moon P, Meiksin Z, Herr SL, Fatouros PP. High resolution light imaging system for teeth and tissues. J Clin Laser Med Surg. 1993;11:313-321.
Wisth PJ, Nord A. Caries experience in orthodontically treated individuals. Angle Orthod. 1977;47:59-64. [pmid: 264779].
Woltgens JH, Etty EJ, Gruythuysen RJ, Geraets WG. Influence of fluoride in saliva during the early cariogenic changes in the enamel of boys and girls. ASDC J Dent Child. 1995;62:192-196. [pmid: 7560365].
Wong MC, Schwarz E, Lo EC. Patterns of dental caries severity in Chinese kindergarten children. Community Dent Oral Epidemiol. 1997;25:343-347. [pmid: 9355769].
Wood RE, Maxymiw WG, McComb D. A clinical comparison of glass ionomer (polyalkenoate) and silver amalgam restorations in the treatment of Class 5 caries in xerostomic head and neck cancer patients. Oper Dent. 1993;18:94-102. [pmid: 8415169].
Wooden EE, Kuftinec MM. Decay of unerupted premolar. Oral Surg Oral Med Oral Pathol. 1974;38:491-492. [pmid: 4528498].
Woodhouse AD. A longitudinal study of the effectiveness of self applied 10 per cent stannous fluoride paste for secondary school children. Aust Dent J. 1978;23:422-428. [pmid: 105697].
Woodward GL, Leake JL. The use of dental radiographs to estimate the probability of cavitation of carious interproximal lesions. Part I: Evidence from the literature. J Can Dent Assoc. 1996;62:731-736. [pmid: 8908876].
Woolfolk M, Hamard M, Bagramian RA, Sgan-Cohen H. Oral health of children of migrant farm workers in northwest Michigan. J Public Health Dent. 1984;44:101-105. [pmid: 6592350].
The Association of State and Territorial Dental Directors, the New York State Health Department, the Ohio Department of Health and the School of Public Health, University of Albany, State University of New York. J Public Health Dent. 1995;55:263-273. [pmid: 8854267].
A guide to oral health epidemiological investigations. ORH/EPID Guide 79.1. Geneva: World Health Organization Oral Health Unit; 1979.
Oral health surveys: basic methods. 3^rd^ ed. Geneva: World Health Organization; 1987.
Worthington H. Statistical methodology for clinical trials of caries prophylactic agents--current knowledge. Int Dent J. 1984;34:278-284. [pmid: 6597135].
Worthington H, Holloway P, Clarkson J, Davies R. Predicting which adult patients will need treatment over the next year. Community Dent Oral Epidemiol. 1997;25:273-277. [pmid: 9332803].
Worthington HV, O'Mullane DM. Covariance analysis (for comparison of caries increments) in clinical trials of caries-prophylactic agents. Community Dent Oral Epidemiol. 1978;6:43-46. [pmid: 350482].
Wright GZ, Banting DW, Feasby WH. Effect of interdental flossing on the incidence of proximal caries in children. J Dent Res. 1977;56:574-578. [pmid: 268338].
Wright GZ, Simon I. An evaluation of transillumination for caries detection in primary molars. ASDC J Dent Child. 1972;39:199-202. [pmid: 4553904].
Wright JT, Childers NK, Evans KL, Johnson LB, Fine JD. Salivary function of persons with hereditary epidermolysis bullosa. Oral Surg Oral Med Oral Pathol. 1991;71:553-559. [pmid: 2047096].
Wright JT, Cutter GR, Dasanayake AP, Stiles HM, Caufield PW. Effect of conventional dental restorative treatment on bacteria in saliva. Community Dent Oral Epidemiol. 1992;20:138-143. [pmid: 1623705].
Wright JT, Fine JD, Johnson LB, Steinmetz TT. Oral involvement of recessive dystrophic epidermolysis bullosa inversa. Am J Med Genet. 1993;47:1184-1188. [pmid: 8291553].
Xalabarde A, Garcia-Godoy F, Boj JR, Canaida C. Fissure micromorphology and sealant adaptation after occlusal enameloplasty. J Clin Pediatr Dent. 1996;20:299-304. [pmid: 9151622].
Xie J, Flaitz CM, Hicks MJ, Powers JM. Bond strength of composite to sound and artificial carious dentin. Am J Dent. 1996;9:31-33. [pmid: 9002812].
Yalcin S, Gurbuzer B. Multiple impacted teeth in the maxilla. Oral Surg Oral Med Oral Pathol. 1993;76.
Yalisove IL, Dietz JBJ. A 2-year longitudinal study of overdenture patients. Part I: incidence and control of caries on overdenture abutments. J Prosthet Dent. 1979;41:698-699. [pmid: 374723].
Yamaga T, Nokubi T. Clinical observations of noncoping overdenture abutments protected by tannin-fluoride preparation. J Prosthet Dent. 1997;78:315-319. [pmid: 9297650].
Yang G, Yin S, Zhou R, et al. Studies of safe maximal daily dietary Se-intake in a seleniferous area in China. Part II: Relation between Se-intake and the manifestation of clinical signs and certain biochemical alterations in blood and urine. J Trace Elem Electrolytes Health Dis. 1989;3:123-130. [pmid: 2535331].
Yankell SL, Paskow GW, Ram RM, Green PA, Shern RJ. The evaluation of tiodonium chloride as an antiplaque and anticaries agent. V. Effects on plaque microbiology and plaque and saliva pH. Pharmacol Ther Dent. 1979;4:87-90. [pmid: 44553].
Yankell SL, Stoller NH, Tawil G, Green PA. The evaluation of tiodonium chloride as an antiplaque and anticaries agent. IV. Effectiveness on plaque and gingivitis in a short-term clinical study. Pharmacol Ther Dent. 1979;4:81-86. [pmid: 296397].
Yardeni J. The compartmental concept of dental caries. Dental Digest. 1968;74:118-122. [pmid: 5237670].
Yardeni J. Studies on the mechanism of early dental caries. J Dent Res. 1965;44:873-884. [pmid: 4953279].
Yip HK, Stevenson AG, Beeley JA. Chemomechanical removal of dental caries in deciduous teeth: further studies in vitro. Br Dent J. 1999;186:179-182. [pmid: 10205954].
Yip HK, Stevenson AG, Beeley JA. An improved reagent for chemomechanical caries removal in permanent and deciduous teeth: an in vitro study. J Dent. 1995;23:197-204. [pmid: 7629322].
Yoneda J, Sakurai T, Nishimura K. Image quality of an intraoral storage phosphor imaging system for normal anatomical structures, proximal caries and decalcified bone changes. Oral Radiol. 1997;13:23-34.
Younis O, Hughes DO, Weber FN. Enamel decalcification in orthodontic treatment. Am J Orthod. 1979;75:678-681. [pmid: 377980].
Zacharia MA, Munshi AK. Microbiological assessment of dentin stained with a caries detector dye. J Clin Pediatr Dent. 1995;19:111-115. [pmid: 7577728].
Zacherl WA. A clinical evaluation of a stannous fluoride and a sarcosinate dentifrice. ASDC J Dent Child. 1973;40:451-453. [pmid: 4147760].
Zacherl WA. Clinical evaluation of an aged stannous fluoride-calcium pyrophosphate dentifrice. J Can Dent Assoc. 1972;38:155-157. [pmid: 4401615].
Zacherl WA. Clinical evaluation of neutral sodium fluoride, stannous fluoride, sodium monofluorophosphate and acidulated fluoride-phosphate denifrices. J Can Dent Assoc. 1972;38:35-38. [pmid: 4400318].
Zacherl WA. A three-year clinical caries evaluation of the effect of a sodium fluoride-silica abrasive dentifrice. Pharmacol Ther Dent. 1981;6:1-7. [pmid: 6264506].
Zacherl WA, McPhail CW. Final report on the efficacy of a stannous fluoride-calcium pyrophosphate dentifrice. J Can Dent Assoc. 1970;36:262-264. [pmid: 4393333].
Zahradnik RT, Propas D, Moreno EC. In vitro enamel demineralization by Streptococcus mutans in the presence of salivary pellicles. J Dent Res. 1977;56:1107-1110. [pmid: 270509].
Zahran M. Effect of topically applied acidulated phosphate fluoride on dental caries. Community Dent Oral Epidemiol. 1976;4:240-243. [pmid: 793766].
Zambon JJ, Kasprzak SA. The microbiology and histopathology of human root caries. Am J Dent. 1995;8:323-328. [pmid: 8695011].
Zamir T, Fisher D, Fishel D, Sharav Y. A longitudinal radiographic study of the rate of spread of human approximal dental caries. Arch Oral Biol. 1976;21:523-526. [pmid: 1067800].
Zarod BK, Lennon MA. The effect of school dental screening on dental attendance. The results of a randomised controlled trial. Community Dent Health. 1992;9:361-368. [pmid: 1486524].
Zasler ND, Devany CW, Jarman AL, Friedman R, Dinius A. Oral hygiene following traumatic brain injury: a programme to promote dental health. Brain Inj. 1993;7:339-345. [pmid: 8358407].
Zerfowski M, Koch MJ, Niekusch U, Staehle HJ. Caries prevalence and treatment needs of 7- to 10-year-old schoolchildren in southwestern Germany. Community Dent Oral Epidemiol. 1997;25:348-351. [pmid: 9355770].
Zero DT. Dental caries process. Dent Clin North Am. 1999;43:635-664. [pmid: 10553248].
Zero DT. In situ caries models. Adv Dent Res. 1995;9:214-230. discussion 231-234. [pmid: 8615944].
Zero DT, Fu J, Anne KM, Cassata S, McCormack SM, Gwinner LM. An improved intra-oral enamel demineralization test model for the study of dental caries. J Dent Res. Spec No. 1992;71:871-878. [pmid: 1592978].
Zero DT, Raubertas RF, Fu J, Pederson AM, Hayes AL, Featherstone JDB. Fluoride concentrations in plaque, whole saliva, and ductal saliva after application of home-use topical fluorides. J Dent Res. 1992;71:1768-1775. [pmid: 1401438].
Zerosi C. Critical appraisal of the literature on deep carious lesions. Int Dent J. 1970;20:297-308. [pmid: 4913698].
Ziccardi VB, Feretti A, Schneider W. Management of sickle cell/beta thalassemia patient with severe odontogenic infection. N Y State Dent J. 1996;62:28-32.
Zickert I, Emilson CG, Ekblom K, Krasse B. Prolonged oral reduction of Streptococcus mutans in humans after chlorhexidine disinfection followed by fluoride treatment. Scand J Dent Res. 1987;95:315-319. [pmid: 3476985].
Zickert I, Emilson CG, Krasse B. Effect of caries preventive measures in children highly infected with the bacterium Streptococcus mutans. Arch Oral Biol. 1982;27:861-868. [pmid: 6961900].
Zickert I, Emilson CG, Krasse B. Microbial conditions and caries increment 2 years after discontinuation of controlled antimicrobial measures in Swedish teenagers. Community Dent Oral Epidemiol. 1987;15:241-244. [pmid: 3477353].
Zimmer S, Robke FJ, Roulet JF. Caries prevention with fluoride varnish in a socially deprived community. Community Dent Oral Epidemiol. 1999;27:103-108. [pmid: 10226719].
Zimmerman BF, Rawls HR, Querens AE. Prevention of in vitro secondary caries with an experimental fluoride-exchanging restorative resin. J Dent Res. 1984;63:689-692. [pmid: 6584474].
Zoitopoulos L, Athanassouli T, Gelbier S, Apostolopoulos A. Caries prevalence of 5-year-old children in Athens and in South London. Int J Paediatr Dent. 1996;6:3-6. [pmid: 8695587].
Zschieschack B, Grabowski R. The influence of caries of the deciduous teeth upon development of the dentition in patients with cleft lip, jaw and palate. J Orofac Orthop. 1999;60:215-224. [pmid: 10394215].
Zubery Y, Dove SB, Ebersole J. An in vitro study of the characteristics of a computer-aided radiographic evaluation (CARE) system for longitudinal assessment of density changes. J Periodontal Res. 1993;28:233-240. [pmid: 8336244].
Zuidgeest TG, Herkstroter FM, Arends J. Mineral density and mineral loss after demineralization at various locations in human root dentine. A longitudinal microradiographic study. Caries Res. 1990;24:159-163. [pmid: 2364399].