# Results

Based on information presented in the evidence tables, this chapter describes the principal findings of the reviews for the three key questions concerning the diagnosis and management of dental caries. The chapter presents the results of the three reviews separately starting with the review of diagnostic methods, continuing with the review of the management of noncavitated lesions, and ending with the review of the management of caries-active individuals.

## Diagnosis of Carious Lesions

As noted, the charge to review methods for the diagnosis of carious lesions was a broad one. The review was to include all commercially available methods for the diagnosis of primary carious lesions (first occurrence on a surface) on coronal and root surfaces of permanent teeth and coronal surfaces of primary teeth. The systematic review of the literature for studies evaluating the validity of six methods for diagnosing carious lesions yielded 39 studies -- 5 conducted in vivo, 32 conducted in vitro, and 2 reporting both in vivo and in vitro results. Many of these studies reported multiple assessments (usually either several diagnostic methods or several variations of one diagnostic method, all using the same sample of teeth), and many also reported results for multiple types of lesions (cavitated, dentinal, enamel, and coronal) so that the total number of assessments reported in Evidence Tables 1 and 2 is 126.

Table 11 displays the distribution of the assessments across the categories of tooth surfaces, tooth types, lesion types, diagnostic methods, and study settings (in vivo, in vitro) considered in this review, with the exception of three assessments of visual and radiographic methods used concurrently. The assessments predominately concerned posterior teeth (n=113). There were 10 assessments of diagnostic methods applied to permanent anterior teeth and primary teeth of any type, and there were no studies evaluating diagnostic methods for root caries. Eleven assessments addressed the validity of diagnostic methods for detecting carious lesions confined to enamel. As noted, in vitro assessments were more frequent than in vivo studies. Finally, the assessments disproportionately involved the validity of radiographic methods (51 percent of assessments), whereas fewer than 10 percent of assessments evaluated the validity of arguably the most common diagnostic method in the United States, the visual/tactile examination.

Table 11. Number of diagnostic assessments by tooth surface, tooth type, lesion type, diagnostic method, and study setting

Proximal surfaces
Tooth Type | Lesion Type | Radio | | Visual/Tactile | | Visual | | FOTI ^1^ | | ECM ^2^ | | LS ^3^
Tooth Type | Lesion Type | vivo | vitro | vivo | vitro | vivo | vitro | vivo | vitro | vivo | vitro | vivo | vitro
Occlusal Surfaces
Posterior | Cavitation | 5 | 1 | 2 | 1 | 1 | 1
| Dentin | | 6 | | 1
| Any lesion | | 8
| Enamel only
| Root surface
Anterior & posterior | Cavitation
| Dentin | | 2
| Any lesion | | 3
| Enamel only | | 2
| Root surface
Primary | Cavitation | | 1
| Dentin
| Any lesion
| Enamel only
Posterior | Cavitation | | | | 1 | 1 | 2
| Dentin | | 25 | | 2 | 1 | 9 | | 1 | 2 | 12 | | 2
| Any lesion | | 7 | | 2 | 1 | 3 | | | 1 | 7
| Enamel only | | 4 | | | | 2 | | 1 | | 1
| Root surface
Anterior & posterior | Cavitation
| Dentin
| Any lesion
| Enamel only
| Root surface
Primary | Cavitation | | | | | 1
| Dentin | | 1
| Any lesion
| Enamel only

1 fiberoptic transillumination

2 electrical conductance

3 laser fluoresence

The studies included in the review represented a limited proportion of all assessments of methods for diagnosis of carious lesions, i.e., those with a histologic reference criterion, or "gold standard." An exception was made for cavitated lesions, where direct visual inspection was an acceptable reference criterion. There was a larger group of studies that compared two or more diagnostic methods without a histologic reference standard. It is the team's impression that the distribution of tooth types and lesion types assessed in this larger group of studies was not markedly different from that displayed in Table 11. Also, a small group of studies with histologic reference standards was excluded because sensitivity and specificity outcomes were not reported and could not be calculated, and these studies also reflected similar distributions of tooth and lesion types.

The study results are described and aggregated by tooth surface (proximal or occlusal) and type of lesion being identified (cavitation, penetration into dentin, any lesion, enamel only). The category of any lesion includes all lesions detected by the examiner(s) applying the criteria employed in the study. Thus, the category of any lesions typically includes all lesions penetrating into dentin and some, but not necessarily all, lesions in enamel. Summary tables for posterior teeth that show sensitivity and specificity values for assessments grouped by diagnostic method and setting are presented. Details of the studies appear in Evidence Table 1 for in vivo studies and in Evidence Table 2 for in vitro studies.

### Cavitated Lesions on Proximal Surfaces

Table 12 shows the 11 assessments of the diagnosis of cavitated lesions on proximal surfaces of posterior teeth. Specificity (depicted as O) in these assessments tended to be high, ranging from 0.89 to 1.00, indicating that false positive diagnoses were uncommon. Sensitivities (depicted as X) ranged much more widely, from 0.04 to 0.94, with the highest values recorded in two assessments reported in the same in vitro study, one for visual/tactile diagnosis and the other for visual diagnosis. This study employed a single experienced examiner and used criteria for cavitation that may have allowed lesions with enamel discontinuities to be considered sound.^ 35 ^ Sensitivity levels for radiographic methods were uniformly higher than for the remaining two assessments of visual/tactile diagnosis, or for the single assessment of FOTI which was highly insensitive.^ 36 ^

Table 12. Sensitivity and specificity values for the detection of proximal cavitated lesions

| 0 | 5 | 10 | 15 | 20 | 25 | 30 | 35 | 40 | 45 | 50 | 55 | 60 | 65 | 70 | 75 | 80 | 85 | 90 | 95 | 100
Radiographic -- in vivo
Rugg-Gunn, 1972^ 37 ^ | | | | | | | | X | | | | | | | | | | | | | O
Downer, 1975^ 109 ^ | | | | | | | | | | | | | | | | X | | | | O
Mejare, 1985^ 38 ^ | | | | | | | | X | | | | | | | | | | | | | O
Pitts, 1992^ 63 ^ | | | | | | | | | | | | | | | | | | X | | | O
Hintze, 1998^ 36 ^ | | | | | | | | | | | | | | X | | | | | | O
Radiographic -- in vitro
Espelid, 1986^ 110 ^ | | | | | | | | | | | | | | | X | | | | | O
Visual/Tactile -- in vivo
Mejare, 1985^ 38 ^ | | | | | | | X | | | | | | | | | | | | | | O
Hintze, 1998^ 36 ^ | | | | | | | | X | | | | | | | | | | | | | O
Visual/Tactile -- in vitro
Downer, 1975^ 35 ^ | | | | | | | | | | | | | | | | | | | | X | O
Visual -- in vitro
Downer, 1975^ 35 ^ | | | | | | | | | | | | | | | | | | | O | X
FOTI -- in vivo
Hintze, 1998^ 36 ^ | | X | | | | | | | | | | | | | | | | | | | O

X = sensitivity, O = specificity

Among the assessments of radiographic techniques, two reported sensitivity levels substantially lower (0.34, 0.35) than the remainder, (0.63 to 0.87).^37,38^ There were no obvious characteristics of these two studies that could explain the difference. Although one study^ 37 ^ required lesion penetration only to two-thirds of the thickness of the enamel, the other employed a criterion essentially similar to the remaining studies, with lesion penetration into the dentin. Both assessments used D-speed film as did three of the four other assessments, and both were conducted in samples with low caries prevalence (5 and 9 percent), similar to three of the four other radiographic studies.

The variation in sensitivities displayed among studies of radiographic and visual/tactile methods and the availability of only single studies of visual and FOTI methods for the diagnosis of cavitated lesions on proximal surfaces of permanent posterior teeth results in a poor rating for the strength of the evidence for assessing the validity of these diagnostic methods. All of the assessments display high specificity, but the range of sensitivities is wide within methods. However, one pattern evident in these results is the tendency for sensitivity to be higher in in vitro than in in vivo assessments.

### Lesions Penetrating into Dentin on Proximal Surfaces

Table 13 shows the seven assessments of the diagnosis of lesions penetrating into dentin on proximal surfaces of posterior permanent teeth. These assessments were reported in four studies. Six assessments from four studies involved radiographic methods and one involved visual/tactile examination, all in vitro. Only two of the studies reported the prevalence of lesions in the sample, 43 and 13 percent, respectively.^39,40^ One study summarized the performance of 276 general practitioners, who reviewed duplicated films in a mailed survey,^ 39 ^ two studies used three examiners,^41,42^ and one used five examiners.^ 40 ^

Table 13. Sensitivity and specificity values for the detection of proximal carious lesions penetrating into dentin

| 0 | 5 | 10 | 15 | 20 | 25 | 30 | 35 | 40 | 45 | 50 | 55 | 60 | 65 | 70 | 75 | 80 | 85 | 90 | 95 | 100
Radiographic -- in vitro
Mileman, 1990^ 39 ^ | | | | | | | | | | | | X | | | | | | | | O
Verdonschot, 1991^ 41 ^ | | | | | | | | | | | X | | | | | | | | | O
Russell, 1993^ 42 ^ | | | | X | | | | | | | | | | | | | | | | O
Russell, 1993^ 42 ^ | | | | | | | X | | | | | | | | | | | | O
Russell, 1993^ 42 ^ | | | | | | | X | | | | | | | | | | | | | O
Ricketts, 1997d^ 40 ^ | | | | X | | | | | | | | | | | | | | | | | O
Visual/Tactile -- in vitro
Verdonschot, 1991^ 41 ^ | | | | | | | | | | | X | | | | O

X = sensitivity

O = specificity

The radiographic assessments all showed high specificity values, ranging from 0.92 to 0.99, whereas sensitivity values were lower and more variable, ranging from 0.16 to 0.54. One of the two studies with the lowest sensitivity employed a direct digital radiographic technique.^ 42 ^ The single visual/tactile assessment^ 41 ^ showed lower specificity (0.71) and sensitivity equivalent to the better radiographic assessments (0.56). The diagnostic criteria for this visual/tactile study stressed the cavitation of the lesion in addition to penetration to dentin, which may have caused more frequent misidentification of enamel lesions as having penetrated dentin.

The strength of the evidence for assessing the validity of methods for detecting proximal lesions penetrating into dentin is rated as poor for both methods. Although the number of studies was too small for conclusions, the available studies suggested that the radiographic method features high specificity, but a range of sensitivity levels, from low values of 0.16 to 0.30 to moderate levels around 0.55. Thus, in any given assessment, little more than one-half of all lesions extending into dentin will be identified radiographically. The single visual/tactile study precludes any conclusions about this method for diagnosing proximal lesions penetrating into dentin.

### Any Carious Lesions on Proximal Surfaces

Table 14 shows the eight assessments of the diagnosis of any carious lesion on proximal surfaces of posterior permanent teeth. These assessments stemmed from four studies, and all assessed the performance of radiographic methods in vitro. Prevalence of carious lesions was reported in three studies and ranged from 37 to 75 percent. Two of the studies used a single "examiner," a computer-based image analysis program;^43,44^ one used 3 examiners,^ 42 ^ one used 5,^ 40 ^ and two used 16 examiners.^ 44 ^

Table 14. Sensitivity and specificity values for the detection of any proximal carious lesions

| 0 | 5 | 10 | 15 | 20 | 25 | 30 | 35 | 40 | 45 | 50 | 55 | 60 | 65 | 70 | 75 | 80 | 85 | 90 | 95 | 100
Radiographic -- in vitro
Heaven, 1992^ 43 ^ | | | | | | | | | | | | | | | | | | | | | OX
Russell, 1993^ 42 ^ | | | X | | | | | | | | | | | | | | | | O
Russell, 1993^ 42 ^ | | | X | | | | | | | | | | | | | | | | O
Russell, 1993^ 42 ^ | | | | X | | | | | | | | | | | | | | | O
Ricketts, 1997d^ 40 ^ | | | | | | X | | | | | | | | | | | | | | O
Firestone, 1998^ 44 ^ | | | | | | | | | | | | | | | | O | X
Firestone, 1998^ 44 ^ | | | | | | | | | | | | | X | | | | | O
Firestone, 1998^ 44 ^ | | | | | | | | | | | | | | | | X | O

X = sensitivity

O = specificity

The specificities were generally high, although there was a greater range than was seen for diagnosis of cavitated lesions and lesions penetrating the dentin (74 to 100 percent). The assessment with perfect specificity also reported perfect sensitivity. This assessment, which employed image analysis software, evaluated only 16 surfaces, 75 percent of which were carious. Three other assessments reported moderately high sensitivity levels, all stemming from a single study that evaluated automatic image analysis software, D-speed film, and a digital image of the D-speed film read with the results of the automatic image analysis displayed.^ 44 ^ Lesion prevalence in this study was also high at 66 percent. The remaining four assessments returned low sensitivity levels, 0.15 to 0.27. One of these assessments also employed digital imaging techniques.^ 42 ^

Three of the studies reflected the same patterns seen in the performance of radiographs in detecting lesions extending into dentin. Two studies reported assessments with relatively low sensitivity and high specificity,^40,42^ whereas one study reported assessments with higher sensitivity and reduced specificity.^ 44 ^ Again, the variation among studies limited our ability to reach firm conclusions about the performance of radiographs in detecting proximal carious lesions of any extent. The strength of the evidence for assessing the validity of the method is rated as poor. The specificity of this method appears to be slightly more variable than when it is used to diagnose lesions into dentin or cavitated lesions. Sensitivity levels varied widely and were highest when computer-based image analysis was applied to digital images.^ 30 ^

### Cavitated Lesions on Occlusal Surfaces

Table 15 summarizes the findings for four assessments from three studies of the diagnosis of cavitated lesions on occlusal surfaces. One assessment evaluated the visual/tactile method in vitro, one the visual method in vivo, and two the visual method in vitro. Specificities were high, but again displayed some variability (0.78 to 0.98). Sensitivities were also high for three assessments, but quite low for the fourth (0.31 to 0.94),^ 45 ^ which had the highest specificity. Criteria used in this study were essentially similar to those used in the other visual in vitro study.^ 35 ^ Each study used a single examiner, which may account for much of the difference between similar studies. There was little difference in performance in an intrastudy comparison of visual and visual/tactile methods.^ 35 ^ The strength of the evidence for assessing validity of the methods is rated as poor because of the limited number of studies for any given method.

Table 15. Sensitivity and specificity values for the detection of occlusal cavitated lesions

| 0 | 5 | 10 | 15 | 20 | 25 | 30 | 35 | 40 | 45 | 50 | 55 | 60 | 65 | 70 | 75 | 80 | 85 | 90 | 95 | 100
Visual/Tactile -- in vivo
Downer, 1975^ 109 ^ | | | | | | | | | | | | | | | | | O | X
Visual/Tactile -- in vitro
Downer, 1975^ 35 ^ | | | | | | | | | | | | | | | | | | O | X
Visual -- in vitro
Downer, 1975^ 35 ^ | | | | | | | | | | | | | | | | | O | | X
Ketley, 1993^ 45 ^ | | | | | | | X | | | | | | | | | | | | | | O

X = sensitivity

O = specificity

### Lesions Penetrating into Dentin on Occlusal Surfaces

Table 16 shows the 54 assessments of methods for diagnosing carious lesions extending into the dentin on occlusal surfaces. Six different methods were represented: radiographic techniques, visual/tactile examination, visual technique, FOTI, EC, and laser fluorescence. Three of the assessments, one visual and two EC, were completed in vivo.^46,47^ The studies were quite varied within method in terms of the details of the diagnostic methods employed as well as the specific diagnostic criteria used. Caries prevalence in the samples tended to be high, with 57 percent of assessments performed on samples with lesion prevalences equal to or greater than 40 percent.

Table 16. Sensitivity and specificity values for the detection of occlusal carious lesions penetrating into dentin

| 0 | 5 | 10 | 15 | 20 | 25 | 30 | 35 | 40 | 45 | 50 | 55 | 60 | 65 | 70 | 75 | 8O | 85 | 90 | 95 | 100
Radiographic -- in vitro
Wenzel, 1990^ 49 ^ | | | | | | | | | | | | | | X | | | | | | O
Wenzel, 1990^ 49 ^ | | | | | | | | | | | | | | | X | | | | | | O
Wenzel, 1991^ 50 ^ | | | | | | | | | | | | | | X | | | | O
Wenzel, 1991^ 50 ^ | | | | | | | | | | | | | | | X | | | O
Wenzel, 1991^ 50 ^ | | | | | | | | | | | | | X | | | | | O
Wenzel, 1991^ 50 ^ | | | | | | | | | | | | | | | X | | | O
Wenzel, 1991^ 50 ^ | | | | | | | | | | | | | | X | | | O
Wenzel, 1992^ 51 ^ | | | | | | | | | | | X | | | | | | O
Wenzel, 1992^ 51 ^ | | | | | | | | | | | | | | | X | | | O
Wenzel, 1992^ 51 ^ | | | | | | | | | | | | X | | | | O
Nytun, 1992^ 48 ^ | | | | | | | | | | | O | | | X
Ketley, 1993^ 45 ^ | | | | | | | | | | | | | | X | | | | | O
Russell, 1993^ 42 ^ | | | | | X | | | | | | | | | | | | | | | O
Russell, 1993^ 42 ^ | | | | | X | | | | | | | | | | | | | | | O
Russell, 1993^ 42 ^ | | | | | X | | | | | | | | | | | | | | | O
Lussi, 1993^ 55 ^ | | | | | | | | | | X | | | | | | | O
Verdonschot, 1993^ 56 ^ | | | | | | | | | | | | | X | | | | O
Lussi, 1995^ 47 ^ | | | | | | | | | | | | | X | | | O
Ricketts, 1994^ 111 ^ | | | | | | | | | | | | | X | | | O
Huysmans, 1997^ 112 ^ | | | | | | | | | | | | | X | | | | | | O
Ekstrand, 1997^ 57 ^ | | | | | | | | | | | | X | | | | | | | | | O
Ricketts, 1997d^ 40 ^ | | | | X | | | | | | | | | | | | | | | | O
Ashley, 1998^ 52 ^ | | | | | | X | | | | | | | | | | | | | O
Ashley, 1998^ 52 ^ | | | | | X | | | | | | | | | | | | | | O
Huysmans, 1997^ 112 ^ | | | | | | | | | | | | | X | | | | | | | O
Visual/Tactile -- in vitro
Penning, 1992^ 54 ^ | | | | | | X | | | | | | | | | | | | | | | O
Lussi, 1993^ 55 ^ | | | | X | | | | | | | | | | | | | | | | O
Visual -- in vivo
Ricketts, 1995^ 46 ^ | | X | | | | | | | | | | | | | | | | | | O
Visual -- in vitro
Nytun, 1992^ 48 ^ | | | | | | | | | O | | | | | | X
Wenzel, 1992^ 51 ^ | | | | | | | | | | | | X | | | | | O
Lussi, 1993^ 55 ^ | | | X | | | | | | | | | | | | | | | | | O
Lussi, 1993^ 55 ^ | | | | | X | | | | | | | | | | | | | | O
Verdonschot, 1993^ 57 ^ | | | | | | | | | | | X | | | | | | | | O
Deery, 1995^ 63 ^ | | | X | | | | | | | | | | | | | | | | | O
Ekstrand, 1997^ 57 ^ | | | | | | | | | | | | | | | | | | | O | X
Ashley, 1998^ 52 ^ | | | | | | X | | | | | | | | | | | | | | O
Huysmans, 1997^ 112 ^ | | | | | | X | | | | | | | | | | | | | | | O
EC -- in vivo
Lussi, 1995^ 47 ^ | | | | | | | | | | | | | | | | O | | | | X
Ricketts, 1995^ 46 ^ | | | | | | | | | | | | O | | | | | | | | X
Verdonschot, 1993^ 56 ^ | | | | | | | | | | | | | | X | | | O
Ricketts, 1995^ 46 ^ | | | | | | | | | | | | | | O | | | | | | X
Ricketts, 1995^ 46 ^ | | | | | | | | | | | | | O | | | | | | | X
Ricketts, 1997a^ 58 ^ | | | | | | | | | | | | | | | | | | | OX
Ricketts, 1997b^ 59 ^ | | | | | | | | | | | | | | | | | | O | X
Ricketts, 1997c^ 60 ^ | | | | | | | | | | | | | | | | OX
Ekstrand, 1997^ 57 ^ | | | | | | | | | | | | | | | | | | O | X
Lussi, 1999^ 61 ^ | | | | | | | | | | | | | | | | | | | X
Huysmans, 1998^ 53 ^ | | | | | | | | | | | | | X | | | | | | | O
Huysmans, 1998^ 53 ^ | | | | | | | | | | | | | | | | X | | | O
Huysmans, 1998^ 53 ^ | | | | | | | | | | | | | | | | | XO
Ashley, 1998^ 52 ^ | | | | | | | | | | | | | | | | | XO
FOTI -- in vitro
Ashley, 1998^ 52 ^ | | | | X | | | | | | | | | | | | | | | | O
Laser Fluorescence -- in vitro
Lussi, 1999^ 61 ^ | | | | | | | | | | | | | | | | X | | O
Lussi, 1999^ 61 ^ | | | | | | | | | | | | | | | | | O | X

X = sensitivity

O = specificity

The radiographic studies showed moderate variation in specificities, which ranged generally from 0.75 to 1.00. Sensitivities appeared in two distinct ranges of values with one value centered near 0.20 and another ranging from 0.45 to 0.70. Generally, the assessments with the lowest values for sensitivity had specificity values near the high end of the range of values. A single study reported a specificity of 0.50, with a sensitivity within the upper range at 0.66. This assessment was based on teeth selected because they showed signs of "fissure caries," and the prevalence of carious lesions penetrating into the dentin was 77 percent.^ 48 ^ Ten of these assessments involved digital techniques.^42,49-53^ Two assessments reported sensitivities in the lower range of values (0.21, 0.24)^42,52^ and eight were in the higher range (0.54 to 0.72). Five studies reporting assessments of digital methods also included assessments based on direct examination of D- or E-speed films. In three instances, the performance of the film image was not markedly different than any of the digital comparisons reported in the same study.^42,49,52^ In one study, one of the digital methods, edge enhancement of the digitized film image, yielded 0.23 and 0.04 improvement in sensitivity and specificity, respectively.^ 51 ^ This study featured a single examiner, with 1-week intervals separating diagnostic sessions where different methods were employed.

Two in vitro assessments of the visual/tactile method returned sensitivity values of 0.24, with specificities within the range established in the radiographic studies.^54,55^ One of these assessments, which reported perfect specificity, reflected standardized (mechanical) probing of 1,140 sites on three teeth.^ 54 ^ The criterion for a positive diagnosis was the force necessary to withdraw the probe from the surface of the tooth, or "tugback." The visual component of the examination was limited to directing the probe to all pits and fissures on the surface of the tooth.

Both in vivo and in vitro visual assessments were included in the review. The single in vivo assessment reported a sensitivity of 0.03 and a specificity of 0.97 for what was presumably a single examiner's diagnoses of specific sites on third molars.^ 46 ^ The in vitro assessments generally reflected the same levels of performance as were seen in the radiographic assessments. Two groups of sensitivities were reported, more commonly between 0.10 and 0.25, with two studies between 0.45 and 0.55.^51,56^ Two assessments reported higher sensitivity values. One assessment was based on the sample of teeth selected for signs of "fissure caries"^ 48 ^ and the other used a histologic criterion that required lesions to penetrate more than one-third of the width of the dentin before dentin caries was declared.^ 57 ^

The two in vivo EC assessments both showed moderate-to-high specificities (0.56, 0.77) and extremely high sensitivities (0.93, 0.97).^46,47^ The in vitro EC assessments showed much more variation in both sensitivities and specificities. In some studies, the sensitivities were equal to or greater than the linked specificities. These studies were characterized by relatively modest sample sizes, all between 76 and 107 sites, and often a single examiner. Five of the 12 assessments were reported by the same principal author,^46,58-60^ and four of these assessments were characterized by post hoc determination of the optimal values for caries criteria.

The single FOTI assessment displayed a sensitivity value of 0.14, at the lower end of the range of values in both radiographic and visual examinations, and a high specificity value of 0.95.^ 52 ^ Finally, two assessments of a laser fluorescence method utilizing newly available equipment also reported relatively high sensitivity levels compared with radiographic and visual methods (0.76, 0.84), with specificities in the lower half of the range of values for these other methods (0.87, 0.79). The assessments represented one report,^ 61 ^ with the system tested with the teeth dry and moist.

The general pattern of results suggested that radiographic and visual methods were roughly comparable in their ability to accurately indicate the presence of carious lesions penetrating into the dentin on occlusal surfaces. The two visual/tactile assessments were not markedly different than the larger number of in vitro visual assessments, and the single in vitro FOTI assessment returned a similar performance. EC and laser fluorescence methods showed better sensitivity than these other methods, with only a small penalty reflected in reduced specificities. However, the strength of the evidence for assessing the validity of each of the methods in any specific application is rated as poor because of the variation in sensitivity among studies and the small number of studies reported. The evidence presented by studies describing the EC method is the closest to meeting criteria for a fair rating and would do so if either of two studies were to be discounted. The pattern of sensitivity and specificity values for EC assessments presented a generally narrower range of variation than any other method. Further as noted, specificity values were typically lower than for other methods, and sensitivity values were typically higher, with the result that for 8 of 14 assessments, sensitivity was higher than specificity.

### Any Carious Lesions on Occlusal Surfaces

Table 17 summarizes the 21 assessments of diagnostic methods for detecting any carious lesions on occlusal surfaces. Seven assessments evaluated radiographic methods, two evaluated visual/tactile methods, one and three studies evaluated visual methods, respectively, in vivo and in vitro, and one and seven studies evaluated EC in vivo and in vitro, respectively.

Table 17. Sensitivity and specificity values for the detection of any occlusal carious lesions

| 0 | 5 | 10 | 15 | 20 | 25 | 30 | 35 | 40 | 45 | 50 | 55 | 60 | 65 | 70 | 75 | 80 | 85 | 90 | 95 | 100
Radiographic -- in vitro
Russell, 1993^ 42 ^ | | | X | | | | | | | | | | | | | | | | | O
Russell, 1993^ 42 ^ | | | X | | | | | | | | | | | | | | | | | O
Russell, 1993^ 42 ^ | | | | X | | | | | | | | | | | | | | | | O
Ricketts, 1997d^ 40 ^ | | | X | | | | | | | | | | | | | | | | | O
Wenzel, 1990^ 49 ^ | | | | | | | | | | | | | | | | | X | | O
Wenzel, 1990^ 49 ^ | | | | | | | | | | | | | | | | X | O
Lazarchik, 1995^ 113 ^ | | | | | | | | | | | | | X | | | | O
Visual/Tactile -- in vitro
Penning, 1992^ 54 ^ | | | | X | | | | | | | | | | | | | | | | | O
Lussi, 1991^ 114 ^ | | | | | | | | | | | | | X | | | | | O
Visual -- in vivo
Ricketts, 1995^ 46 ^ | | | | | | X | | | | | | | | | | | | | O
Visual -- in vitro
Wenzel, 1990^ 49 ^ | | | | | | | | | | | | | | O | | | | | X
Lussi, 1991^ 114 ^ | | | | | | | | | | | | | | X | | | | O
Deery, 1995^ 62 ^ | | | | | | | | | | | O | | X
EC -- in vivo
Ricketts, 1995^ 46 ^ | | | | | | | | | | | | | | | | OX
EC -- in vitro
Rock, 1988^ 115 ^ | | | | | | | | | | | | | | | X | | | O
Ricketts, 1995^ 46 ^ | | | | | | | | | | | | | | | X | | | O
Ricketts, 1995^ 46 ^ | | | | | | | | | | | | | | | | OX
Ricketts, 1996^ 116 ^ | | | | | | | | | | | | | | | | | | | X | | O
Ricketts, 1997a^ 58 ^ | | | | | | | | | | | | | | | X | | | O
Ricketts, 1997b^ 59 ^ | | | | | | | | | | | | | X | | | | | | | O
Ricketts, 1997c^ 60 ^ | | | | | | | | | | | | | X | | | | | O

X = sensitivity

O = specificity

The radiographic assessments displayed the two ranges of sensitivity seen in summaries of radiographic assessments on other surfaces and for other types of lesions. The lower range of sensitivities was generally associated with higher specificities. This pattern of two ranges of sensitivity levels in the aggregated results of radiographic studies was most likely not associated with a single design feature of these assessments. Principal determinants of sensitivity included the specific criteria used for identifying lesions, the criteria for selection of sample teeth, the selection and training of the examiner(s), and the extent to which the study design protected against upward performance bias through familiarity with the sample. Assessments of digital radiographic techniques reported sensitivities at the higher level for digitized film^ 49 ^ and the lower level for a direct digital method.^ 42 ^

The visual/tactile assessments reflected the radiographic performance levels, with one assessment each in the higher and lower sensitivity ranges. The in vivo visual assessment fell in the same lower sensitivity range, whereas the in vitro visual assessments reflected the higher range. In two of these three assessments,^49,62^ the sensitivity values were greater than the specificity values. In these instances, the extremely high prevalence of lesions in the samples, 89 and 97 percent, respectively, may have influenced the examiners' diagnostic decisions.

The EC assessments reflected a pattern similar to such assessments of lesions penetrating dentin, with the exception that the sensitivities tended to be slightly lower as a group. Six of the seven studies were reported by the same principal author; all featured one examiner; sample sizes were between 30 and 100 sites with the same sample used in two separate studies;^58,59^ and relatively high lesion prevalence, 64 to 80 percent, was reported.

Overall, the performance of diagnostic methods for the detection of any carious lesions on occlusal surfaces was similar to the performance of these methods in detecting lesions penetrating dentin. Again, however, the strength of the evidence is rated as poor for all radiographic visual and visual-tactile methods, as well as for in vivo EC studies because of the variation in sensitivity and/or the number of available studies. The strength of the evidence is rated as poor for in vitro EC studies because of their low quality scores.

### Enamel-Only Lesions on Occlusal Surfaces

Eight in vitro assessments of enamel lesions on occlusal surfaces were reported: four radiographic assessments, two visual, and one each EC and FOTI (Table 18). The radiographic assessments reflected somewhat lower specificity levels for given sensitivity levels than were reported for lesions into dentin. The four assessments, reported in two studies, appeared to cluster into higher and lower sensitivity ranges, but specificity levels were uniformly at or slightly below 0.80. The two assessments of visual methods reflected higher sensitivity levels, with specificity dropping to near 0.75. The sole EC assessment reflected a similar result, and the only FOTI assessment showed higher specificity with slightly lower sensitivity. Among the extremely small number of assessments available, the visual, EC, and FOTI methods seemed to offer higher sensitivities than the radiographic for the detection of enamel-only lesions on occlusal surfaces. However, the strength of the evidence is rated as poor for all methods because of the small numbers of studies.

Table 18. Sensitivity and specificity values for the detection of occlusal carious lesions confined to enamel

| 0 | 5 | 10 | 15 | 20 | 25 | 30 | 35 | 40 | 45 | 50 | 55 | 60 | 65 | 70 | 75 | 80 | 85 | 90 | 95 | 100
Radiographic -- in vitro
Wenzel, 1990^ 49 ^ | | | | | | | | | | X | | | | | O
Wenzel, 1990^ 49 ^ | | | | | | | X | | | | | | | | O
Ashley, 1998^ 52 ^ | | | | | | X | | | | | | | | | | | O
Ashley, 1998^ 52 ^ | | | | | X | | | | | | | | | | | | O
Visual -- in vitro
Wenzel, 1990^ 49 ^ | | | | | | | | | | | | | | O | X
Ashley, 1998^ 52 ^ | | | | | | | | | | | | | X | | | O
EC -- in vitro
Ashley, 1998^ 52 ^ | | | | | | | | | | | | | | X | | O
FOTI -- in vitro
Ashley, 1998^ 52 ^ | | | | | X | | | | | | | | | | | | | | O

X = sensitivity

O = specificity

### Other Assessments

Thirteen other assessments of diagnostic methods were reported. Three assessments reported the results of methods on primary teeth. Radiographs were extremely sensitive (0.99) and highly specific (0.89) in detecting cavitated lesions on primary tooth proximal surfaces in vivo,^ 63 ^ and slightly less so (sensitivity=0.93, specificity=0.89) in detecting lesions into dentin on occlusal surfaces in vitro.^ 45 ^ Visual methods for detecting cavitated surfaces on occlusal services in vitro were less sensitive (0.45) but perfectly specific (1.00).^ 45 ^ The strength of the evidence for assessing the validity of any diagnostic methods in primary teeth is rated as poor.

Seven assessments examined performance of radiographic methods in vitro on combined anterior and posterior proximal surfaces. Six of these assessments were reported in the same study^ 64 ^ and featured high specificity for dentin lesions (0.94 to 0.95) that drop somewhat for enamel lesions and any lesions (0.76 to 0.80), and moderate sensitivities for dentin and any lesions (0.49 to 0.58) that drop somewhat for enamel-only lesions (0.35 to 0.46).

The other assessment of any lesions reported high specificity (0.95) and low sensitivity (0.33). The strength of the evidence is rated as poor.

Three assessments reported results for combined methods, all visual and radiographic examinations of posterior occlusal surfaces to detect carious lesions penetrating into dentin.^48,55,65^ All of the assessments involved at least 10 examiners, and when reported, intra- and interexaminer reliability was low to moderate (kappa=0.30, 0.46). Performance of the combined methods varied, with moderately high sensitivities (0.49 to 0.86) and specificities in the lower half of the range reported for visual-only or radiographic-only methods (0.64 to 0.87). These results suggest that the combination of visual and radiographic methods returns moderate to high sensitivities, i.e., in the upper range of the dual range of sensitivity values described earlier, but that specificity may be reduced from that of either method alone. The strength of the evidence is rated as poor.

### Limitations to the Evidence Base

The literature describing the histologically determined validity of methods for diagnosing carious lesions had a variety of limitations, many of which represented potentially serious threats to internal validity, and most of which represented barriers to generalization of the reported results to dental practice. The most obvious limitation has already been noted -- the virtual absence of any assessments of diagnostic methods applied to primary teeth and to root surfaces of permanent teeth. The breadth of reported studies also seriously restricted any conclusions about differences in the validities of visual and visual/tactile examinations and possible advantages of combining examination methods. A minority of method/surface/lesion type combinations were represented by more than three studies; and for most of these combinations, the variation among reported performances was extensive. Although the team might have meta-analyzed these results for several combinations of method, surface, and lesion type, two characteristics of the assessments discouraged the use of meta-analysis. First, many were not independent assessments, reflecting common examiners and sample teeth across studies. Second, the studies did not all assess the same "outcomes," since criteria for diagnosis were different. Thus, the available literature could not support specific conclusions about the performance of various diagnostic methods and permitted only the occasional generalization about relative differences in performance.

The quality scores for these studies tended to cluster in the low to mid range of the scale of possible scores. The mean for in vivo studies was 61, and for in vitro studies it was 45. The range was 5 to 70. Most studies had sample sizes of 75 or more sites or surfaces. The choice of sites rather than surfaces may be problematic for external validity, however, because most occlusal surfaces will present multiple sites for assessment. The results of site assessment did not summarize the status of the entire surface, as is routinely done in clinical practice. As noted, most of the studies were performed in vitro, a practical necessity if histologic validation is to be easily accomplished. There is some indication that in vitro assessments tended to return higher sensitivity values than in vivo assessments, although the numbers of studies were too small and the number of study variables too large to assume that the small observed differences were the results of the setting per se. Most in vivo studies were limited to premolars and third molars, which tend to be extracted more frequently in good clinical condition. In vitro studies also often relied on these teeth for the same reason -- that they are more frequently available with intact crowns. The problem is that the teeth that most frequently experience occlusal and proximal surface decay -- the first and second molars -- differ from the premolars and third molars in ways that may affect the performance of diagnostic methods. For example, occlusal surfaces of third molars tend to have less well-coalesced fissures; and proximal enamel thicknesses, both buccolingually and mesiodistally, are less in both premolars and third molars.

The inclusion criteria for the review required a histologic validation, and a variety of validation methods were represented in the included studies, with little assurance that different methods are equivalent.^66,67^ Slightly fewer than one-half of the studies relied on light microscopy, with an identical number using other methods for evaluating the extent of caries on sectioned teeth. The remainder used visual criteria to confirm cavitated lesions. Further, a majority of studies supplied no explicit criteria for the validation, and a large majority did not report reliability information for the validation despite known variability in this procedure.^ 66 ^ The result was that the reported diagnostic performances may be biased, although not in any predictable direction, by the validation procedures employed, making comparisons problematic.

The percent of sites to be evaluated that actually included a carious lesion was less than 20 percent in only 5 percent of in vitro assessments compared with 53 percent of in vivo assessments. Further, most of the in vivo sites with lesion prevalences above 20 percent were selected sites on third molars. Lesion prevalence proportions above 20 percent across all surfaces (a D value of 40 in a fully dentate individual) are rare in clinical practice. The effect of elevated frequencies of occurrence in assessment samples raised issues about examiner bias, since unusual presentations may alter examiner alertness and behavior, albeit in an unknown manner. The criteria used for selecting teeth for the samples also raised issues about both the comparability of studies and the generalization of results to clinical practice. The criteria described for selection did not always seem intended to reflect typical presentations in clinical practice. When this limitation was coupled with the previously noted limitations resulting from restricted tooth types and the use of sites rather than surfaces, generalization to clinical practice was again problematic.

Only one-half of the studies reported the combined performance of four or more evaluators. The studies relying on a smaller number of evaluators may present difficulties in generalization because of the positive influence of particularly skilled investigator/examiners. Single examiner studies, of which there were 17 (46 percent of studies), were especially vulnerable to this phenomenon. Further, 17 studies reported no reliability information for the examiner(s). When interexaminer reliability was reported, the values often were low enough to underscore the threat to external validity represented by the use of single examiners.

Finally, 14 of the assessments described post hoc determination of the optimal criteria for lesion designation. Although the development of new diagnostic techniques often requires such procedures, it is usually expected that the criteria will then be tested in a second "validation" sample. Such a procedure was not reported in any of the 14 assessments.

## Management of Noncavitated Carious Lesions

The systematic review of the literature for clinical studies that examine methods for stopping and reversing the progression of noncavitated carious lesions yielded five studies that included 2,292 lesions. The pool of potentially eligible studies was narrowed considerably at the outset by the criterion that studies be performed in vivo. Traditionally, most forms of noncavitated lesions have been excluded from the examination criteria used in clinical trials because of the problems they present in terms of examiner reliability and lesion "reversals." Partially as a result, only one study reported a subgroup analysis of noncavitated lesions within a trial examining broader caries outcomes.^ 68 ^

The five studies, which reported seven experimental interventions, are a heterogeneous set in terms of the subjects included, the surfaces examined, and the prevention methods evaluated (Evidence Table 3). Although all of the studies were conducted on children, the ages of the subjects were disparate and not completely described in all studies. Two of the studies examined effects on lesions located on permanent posterior proximal surfaces,^69,70^ two on permanent posterior occlusal surfaces,^68,71^ and one on labial surfaces of anterior teeth.^ 72 ^ None of the studies examined management of lesions in primary teeth. Three of the studies examined the efficacy of four different fluoride rinses and solutions,^69,71,72^ and single studies examined fluoride varnish,^ 70 ^ sealants,^ 68 ^ and ammoniacal silver nitrate solution.^ 69 ^ In addition to the variety in experimental interventions, comparison agents differed among the studies, with placebos used in two studies,^69,72^ fluoride rinse in two studies (one semimonthly,^ 70 ^ the other semiannually),^ 71 ^ and no intervention in another where children not receiving parental permission for receipt of sealants constituted the comparison.^ 68 ^ Finally, fluoridation status varied from "practically none"^ 69 ^ to "fluoridated"^ 68 ^ in three studies, was not reported in one,^ 72 ^ and was reported as mixed in another.^ 71 ^

The studies used two different basic approaches for identifying and evaluating change in noncavitated lesions; visual and radiograph examinations. Three studies used similar but not identical visual criteria, including a "chalky" appearance and the absence of enamel discontinuities for identification of lesions at baseline.^68,71,72^ Two studies used dissimilar radiographic criteria.^69,70^ The systematic review of diagnostic methods identified no studies assessing the performance of visual and radiographic detection methods for carious lesions confined to the enamel, which are predominately noncavitated lesions. Thus, any comparisons between the two groups of studies using different initial detection methods must be approached with caution. Equally problematic from the perspective of comparing outcomes, the methods used to evaluate progression and regression were also quite different across studies. Criteria for progression included detection of visual cavitation,^68,71^ progression of the radiolucency either halfway to^ 70 ^ or fully to the DEJ,^ 69 ^ and side-by-side comparison of projected scaled photographs^ 72 ^. Two studies attempted to assess the reversal or regression of lesions.^70,72^

### Fluoride Rinses, Solutions, and Varnishes

The results of evaluations of professionally applied fluoride therapies were equivocal. One study examined both acidulated phosphate fluoride (APF) and stannous fluoride (SnF) solutions applied one time to mesial surfaces of permanent first molars via access created during operative treatment of adjacent teeth.^ 69 ^ Both solutions resulted in statistically significant reductions in progression, 38 percent and 18 percent, respectively, compared with placebo treatment. More than 50 percent of lesions progressed in 24 months in these experimental groups. The technique used depends on access to the mesial surface of the first molar through a cavity preparation in the second primary molar and hence has limited applicability in most clinical encounters. Because the lesions were detected and progression was assessed radiographically, it is likely that the sample was skewed toward lesions with more advanced demineralization, including clinically detectable cavitation. A second study examined lesions on facial surfaces of maxillary teeth.^ 72 ^ Rinsing with a 0.5 percent sodium fluoride (NaF) solution every 2 weeks during the school year resulted in 50 percent greater lesion progression and 22 percent less reversal in experimental group lesions compared with a placebo rinse. Approximately one-fourth of lesions in the experimental group progressed over 36 months. No statistical testing was reported.

In a third study, weekly application of a 2.0 percent NaF solution for 3 weeks, repeated after 3 months, resulted in an nonsignificant 8 percent decrease in occlusal lesion progression (progression rate of 35 percent over 20 to 32 months), compared with twice yearly rinsing with the same solution.^ 71 ^ As a field trial, this study employed relatively crude assessment techniques. School Dental Service personnel recorded lesions as a part of regular examinations, and progression was noted when these same personnel determined that the lesion required restorative treatment according to criteria in routine use in the clinics. The personnel were not blind to subject assignment to treatment group. A fourth study reported an analysis that examined the effects on noncavitated lesions of 5 percent fluoride varnish applied every 3 months to proximal surfaces of posterior teeth, compared with twice monthly rinsing with 0.2 percent NaF.^ 70 ^ Progression was similar in the experimental and comparison groups (61 percent, 60 percent, respectively, over 36 months), and regression was identical (7 percent). No statistical testing was reported. Lesions were evaluated radiographically, again raising the likelihood that the sample of lesions studied was more advanced than those included in studies with visual criteria for lesion inclusion and progression.

Given the small number of studies and the equivocal nature of the results, it is clear that there is incomplete evidence for the efficacy of professionally applied fluoride treatments for stopping and reversing noncavitated carious lesions. Because each of the studies examines a different fluoride therapy on a different set of tooth surfaces, because assessment techniques are different in the four studies, and because two of the studies compared study effects in placebos whereas two used alternative fluoride therapies for comparison, it is not possible to make any comparisons among the studies. Thus, the efficacy of neither any specific fluoride therapy nor fluoride therapies in general for arresting and/or reversing noncavitated carious lesions enjoys adequate support from the literature.

### Other Preventive Methods

Two other preventive methods were evaluated in a single study. Treatment with ammonical silver nitrate was compared with a placebo in a single direct application to mesial surfaces of first molars.^ 69 ^ The 24-month progression rate of 69 percent was 16 percent less than the comparison, which was statistically significant. The application of dental sealants to occlusal and buccolingual pits and fissures was compared with no intervention in a subanalysis of a nonrandomized clinical trial.^ 68 ^ Progression of 12 percent in the experimental group was 77 percent lower than in the comparison group, a statistically significant difference. Given that these two studies are the only reports of nonfluoride interventions meeting our inclusion criteria, the evidence is incomplete for the efficacy of methods other than fluoride therapies for stopping or reversing the progression of noncavitated carious lesions.

### Limitations to the Evidence Base

The principal limitation to the evidence base is the extremely small number of studies assessing management of noncavitated lesions. Five comparative studies would represent only limited evidence even if most aspects of the study designs were similar or identical. When the subjects, tooth surfaces, lesion criteria, progression criteria, experimental intervention, and comparison group intervention all vary across studies, as was the case with the reviewed studies, it is impossible to reach any conclusions concerning the efficacy of any single method. When the results of any five studies display as much variation in efficacy determinations as the five included in this analysis, generalizations about the merits of the entire approach of stopping and reversing noncavitated lesions are also not possible. Although there is a large literature addressing the efficacy of fluorides and dental sealants in preventing carious lesions, the studies found in this literature generally lack two requirements for inclusion in the current review. First, they typically did not analyze outcomes for noncavitated lesions separately, and second, they almost invariably presented results aggregated to the tooth surface, tooth, or individual, but did not report lesion-specific results.

The most problematic aspect among the studies included in the review was the lack of standardized criteria for initially identifying noncavitated lesions and for assessing their progression. It is not at all clear that the lesions included in these five studies were equivalent in terms of their depth of penetration or their activity status and, for the lesions identified initially using radiographs, whether they were in fact noncavitated.

Although differences in the individual arrangements of the studies were not limitations of the individual studies per se, the extensive variation in these arrangements rendered comparisons difficult. For example, results based on placebo comparisons, a feature of the earlier fluoride studies as well as the sealant study, were difficult to compare with results based on active comparison groups. The "background" individual and community preventive dentistry exposures received by subjects during the course of the investigation, when reported, also varied across studies, again rendering comparisons difficult.

The quality scores for the individual studies were generally in the middle of the range of possible scores, with a mean of 53 and a range from 40 to 65. Most of the studies did not report intra- and, when appropriate, interexaminer reliabilities. All studies employed analyses that included only those subjects with final exams. The loss to followup was either over 15 percent per year or unreported in four studies. Three studies did not describe other preventive dental exposures, either individual or community based. External generalizability was rated as limited in four studies, and internal validity was a concern in three. Conversely, three of the five studies reported appropriate blinding and also indicated that baseline assessments of treatment group equality were performed. All but one study had a duration of 2 years or more, and all but one included 50 or more lesions in the smallest analysis group. None of the studies reported a power analysis, however, and two did not analyze the reported results statistically.

## Management of Caries-Active Individuals

The systematic review of the literature for clinical studies that examine the management of individuals deemed to be caries active or at elevated risk of experiencing carious lesions yielded 22 studies that included 4,363 subjects. As was the case in our review of noncavitated lesions, the variation across this small set of studies was daunting in terms of the details of the experimental interventions and the comparison interventions, the other individual and community dental preventive services subjects received, the teeth and tooth surfaces examined, and the examination methods and criteria used.

The 22 studies described 29 experimental interventions (Evidence Table 4). Nine of the interventions involved fluoride, eight involved chlorhexidine (CHX), six were combination treatments (either CHX and fluoride or CHX and sealants), and the remaining six involved alum, chewing gum, kanamycin, sealant, or supplying information to dentists. Placebo groups were used in 9 comparisons, nil groups (no intervention) in 18 comparisons, and active treatment groups in 2 comparisons. Background (community and individual) dental preventive procedures received by subjects ranged from none to bimonthly NaF rinsing and dental sealants. Efficacy assessments were based on all permanent teeth present for 19 interventions; occlusal surfaces of molars for 4 interventions; permanent proximal surfaces for 3 interventions; and all permanent and primary teeth, all primary teeth, and primary tooth proximal surfaces for single interventions. Seventeen interventions identified carious lesions through visual/tactile examinations and radiographs (full or bitewing); 5 interventions used visual/tactile examinations alone; 3 interventions used visual/tactile, radiographic, and FOTI examinations; 2 used visual methods only; and 1 used visual/tactile examination for anterior teeth and radiographs alone for posterior teeth.

The "strictest" inclusion criterion for this systematic review, i.e., the criterion that led to the exclusion of the most studies, was the requirement that the preventive intervention be evaluated in subjects deemed at the level of the individual to be caries active or at elevated risk of new carious lesions. Twenty interventions identified such individuals at the outset of the trial, and nine interventions represented analyses of subgroups of subjects in controlled trials who were so identified post hoc using baseline examination data. Two basic approaches to the identification of subjects were used. "At-risk" subjects were generally identified through the use of mS tests. Ten interventions used mS levels greater than 10^6^ (n=6), 5 x 10^5^ (n=1), 10^5^ (n=2) or "too many to count" (n=1) colony-forming unit (CFU)/ml to designate elevated risk. Caries-active subjects were identified through their DMF or df surface or teeth scores depending on age. Five interventions reported using inexact criteria (e.g., "high DMF scores," "above average DMFS values"), and 12 used specific minimum DMF or df scores. One intervention included subjects meeting either an mS or DMFS criterion, and another study used a combination of salivary flow, Lactobacillus level, and mS level. The proportion of the local population represented by included subjects ranged widely from 7 to 87 percent among the 18 studies reporting this statistic. This wide variation in included proportions of study populations, together with the differences in the two basic approaches to identification of subjects, suggested that comparisons across studies must be made with caution.

### Fluoride Varnishes, Gels, and Rinses

Seven studies^73-79^ describe nine fluoride-based interventions, in all but one of which the preventive effect was evaluated on all permanent teeth. The percent reduction in caries increment ranged from 7 to 30 percent in the eight interventions where caries increments were compared with increments in placebo or nonintervention groups. However, only two of these reductions were statistically significant,^74,78^ both involving fluoride varnishes.

Five evaluations of fluoride varnish interventions were included in the review. One study^ 77 ^ compared thrice annual applications of full strength (2.26 percent fluoride) Duraphat varnish with a half-strength formulation (1.1 percent fluoride), finding no difference in caries increments after 36 months. Because this study offered no information on the efficacy of fluoride varnish, it will not be considered further.

Two studies evaluated full-strength Duraphat varnish against nil comparison groups. Over 36 months, a statistically significant (p<0.001) 30 percent reduction in caries increment was found in one study of twice yearly application for 11- to 13-year-olds (n=124) with "above average DMFS values."^ 74 ^ This reduction amounted to 0.61 surfaces per year. In the other study in 12- to 14-year-olds (n=92) with mS levels greater than 10^6^ CFU/ml, a nonsignificant 7 percent reduction was found for applications every 3 months over 24 months, 0.23 surfaces per year.^ 75 ^ Two aspects of these studies may help explain the difference in observed efficacy. The former study reported that subjects received "ordinary dental care" whereas the latter indicated that subjects received twice monthly fluoride rinses in schools. Additionally, the baseline DMFS score for subjects in the former study (17.7) was substantially lower than the 24.3 and 22.9 experimental and comparison group DMFS scores, respectively, in the latter study. The difference may reflect the 1-year difference in age, but may also reflect the differences in inclusion criteria (caries activity versus caries risk status) or the examination criteria, which differed in whether early signs of carious lesions were included in the visual criteria.

Two studies evaluated Fluor-Protector fluoride varnish, which was reported as containing either 0.7 percent^ 74 ^ or 0.1 percent fluoride.^ 78 ^ In both studies, subjects were identified as being caries active on the basis of baseline DMFS or dfs scores. In the former study of 11- to 13-year-olds (n=140), twice annual applications resulted in a nonsignificant 11 percent reduction in caries incidence on all permanent tooth surfaces over 36 months, 0.19 surfaces per year. In the latter study, a similar application scheme involving 4- to 5-year-olds (n=303) resulted in a statistically significant 25 percent reduction over 24 months on proximal surfaces of anterior and posterior primary teeth, amounting to 0.29 surfaces per year.

Two of these four evaluations of fluoride varnishes used a split mouth design that might have biased the estimates of the efficacy of the experimental intervention.^ 74 ^ The fluoride ions in the varnish vehicle applied to the teeth on one side of the mouth could have migrated to the teeth on the other side of the mouth and conferred some level of caries protection. Thus, these two studies may underestimate the efficacy of the experimental intervention.

Taken together, the four studies of two fluoride varnishes provide some support for efficacy. Two studies show demonstrated statistically significant effects,^74,78^ and the remaining two studies report nonsignificant reduction results.^74,75^ To consider clinical significance, it is useful to express the results in terms of NNT, although this statistic must be interpreted carefully because when applied to caries prevention, it refers to the numbers of persons who must receive treatment to prevent one tooth surface from becoming decayed over the period of 1 year. Also, the number needed to treat depends on the incidence of carious lesions in the population studied, becoming lower as incidence rises. The NNTs are 1.6 and 4.3 for the statistically significant and nonsignificant Duraphat studies, respectively, and 3.5 and 5.4 for the significant and nonsignificant Fluor Protector studies, respectively. We rate the evidence for efficacy of fluoride varnish for caries prevention in permanent teeth in individuals considered to be caries active or at elevated risk for carious lesions to be fair.

The remaining four studies of fluoride therapies all demonstrated small, nonsignificant reductions in caries incidence. Two types of topical application, ferric aluminum fluoride (FeAlF) solution applied four times per year^ 75 ^ and APF gel applied biannually^ 76 ^ were compared with nil and placebo intervention groups, respectively. In 12- to 14-year-olds (n=97), the FeAlF topical solution achieved a 13 percent reduction in caries incidence on all permanent teeth; and in 6-year-olds (n=431), the APF gel achieved a 9 percent reduction. These reductions represented NNTs of 2.5 and 6.7, respectively. Two fluoride rinse therapies, a twice daily 0.044 percent NaF rinse^ 73 ^ and a biannual 1 percent amine fluoride (AmF) rinse,^ 79 ^ were evaluated in comparisons with placebo groups. In all permanent teeth of 11- to 15-year-olds (n=72), the NaF rinse achieved a 15 percent reduction in caries incidence; and in 6-year-olds (n=91), the AmF rinse achieved a 24 percent reduction. The NNT for the AmF rinse was 10.2. A comparable NNT for the NaF study could not be calculated because the outcome measure used was decayed and filled teeth, rather than surfaces. Because the number of studies is small, the quality of the individual studies is moderate, and the results of these studies all show nonsignificant small protective effects of application, the evidence for the efficacy of topical fluoride applications and fluoride rinses in the prevention of caries in caries-active and at-risk individuals is rated as incomplete.

### Chlorhexidine Varnishes, Gels, and Rinses

Seven interventions evaluated the efficacy of CHX therapies.^75,80-84^ These interventions examined gels, rinses and varnishes, resulting in very few evaluations of any one type of intervention.

The three interventions that evaluated varnishes stemmed from two studies.^83,84^ We could not determine if the varnishes used in these two studies had the same CHX concentration. Both studies provided results for eligible study samples through subanalyses of the trial subjects stratified by mS level and one through stratification by baseline DMFS/dmfs score as well.^ 84 ^ Application was biannual in one 30-month study^ 84 ^ and occurred three times over the first 8 months of a 24-month trial period in the other.^ 83 ^ Varnish outcomes were evaluated in one study on occlusal surfaces of first or second molars of 5- to 6-year-olds and 11- to 12-year-olds (n=47, mS subjects; n=115, DMFS subjects).^ 84 ^ In the second study where results were reported separately for occlusal surfaces of first or second molars of 7- to 8-year-olds and 12- to 13-year-olds (n=18), the results for the younger children could not be used because of the team's inability to reconcile sample numbers in the relevant tables. The results in this latter study, which were not tested statistically, showed that 25 percent fewer of the test occlusal surfaces than the comparison surfaces (one each per subject) experienced carious lesions. An NNT could not be calculated from the available data. In subjects included in the stratified analysis because of high mS levels in the other study,^ 84 ^ a statistically significant 33 percent reduction in the incidence of caries was found (NNT=2.8 to prevent one lesion in four first or second molar occlusal surfaces). When subjects in this study were included in the analysis because of their previous caries history, the caries reduction was a statistically insignificant negative 9 percent. The evidence for the efficacy of CHX varnishes in individuals with high mS levels is rated as suggestive but incomplete. In individuals selected for their caries activity, the evidence is also incomplete.

Three studies reported evaluations of CHX gel.^75,80,81^ These studies all used 1-percent concentration of gels, although the patterns of application differed among the studies, ranging from every 3 months to eight treatments in 2 days whenever mS levels were higher than 2.5x10^5^CFU/ml. All studies involved approximately the same age children, used the same caries criteria but slightly different examination methods for posterior teeth, included subjects in the analyses on the basis of mS levels, and reported exposures of subjects to community and individual dental preventive procedures. The reductions in caries in these three studies ranged from 26 to 52 percent, with NNTs ranging from 0.6 to 2.0. However, only one of the studies reported that the reduction was statistically significant.^ 75 ^ Statistical testing was not reported for one result, a subgroup analysis,^ 81 ^ and the reduction was not significant in the third study involving 31 subjects.^ 80 ^ The evidence of efficacy for CHX gels in individuals with high mS levels is rated as suggestive but incomplete. There are no studies of gels in individuals selected because of previous caries activity.

A single study evaluated the effect of a CHX rinse^ 82 ^ on all permanent teeth in 11-year-olds identified as having at least one new carious lesion in the past 2 years. Experiment subjects rinsed twice per day for 5 days and repeated the pattern every 3 weeks. Subjects in the comparison group received biannual NaF varnish treatments. A nonsignificant 3 percent reduction in caries experience was found, with the NNT being 27.5. The evidence for the efficacy of CHX rinses in caries-active individuals is incomplete.

### Combination Treatments

Six studies examined the effects of combined treatments, either CHX and fluoride^82,85-88^ or CHX and sealants.^ 89 ^ This group of studies is quite varied in terms of the strategies employed in combining the preventive methods.

Three of the interventions were rinses, including a 1 percent CHX/NaF solution used daily in conjunction with a toothpaste with a similar composition,^ 73 ^ and two 0.05 percent CHX/0.04 percent NaF solutions, one with and one without 500 ppm strontium, used twice per day.^ 82 ^ When evaluated against nil comparison groups but with a background of annual professional fluoride exposure, the first of these interventions resulted in a statistically significant 43 percent reduction in caries incidence, NNT=0.9. The other two interventions resulted in statistically nonsignificant reductions of 34 percent (NNT=2.1) and 8 percent (NNT=9.2) for the strontium-free and strontium-containing rinses, respectively.

A comparison of semiannual application of a combined 1 percent CHX, 1 percent NaF against NaF varnish alone on permanent posterior proximal surfaces resulted in a nonsignificant negative 26 percent reduction in caries incidence.^ 88 ^ A combined 0.2 percent NaF/1 percent CHX rinse administered to mothers of 1-year-old children three times per day for 2 days twice per year resulted in a nonsignificant 13 percent reduction in dentinal caries incidence after 3 years^ 87 ^ (NNT could not be calculated because of tooth-level outcome measure). One study examined effects of combined therapy in adults age 50 to 60.^ 86 ^ Twenty-five subjects who met inclusion criteria involving salivary flow rates and Lactobacillius levels as well as mS levels received either no treatment or CHX gel treatments at unspecified intervals in addition to topical fluoride treatments and home fluoride rinses or gels, again at unspecified intervals.^ 86 ^ After 1 year, a statistically significant 89 percent reduction in new decayed and filled surfaces was found, NNT=0.7. Finally, subjects with high mS levels included in a subgroup analysis of an RCT participated in daily CHX gel therapy for 14 days, repeated as necessary to maintain mS levels, and received occlusal sealant treatment for all unfilled occlusal fissures.^ 89 ^ After 3 years, a statistically significant 81 percent in caries incidence was recorded, NNT=0.2, compared with a group receiving bimonthly NaF rinses.

These combination studies did not furnish sufficient evidence for determining the efficacy of any one approach. Although three CHX/NaF rinses all resulted in caries reductions, two of the reductions were statistically not significant. No conclusions can be based on the results of the remaining single evaluations of other approaches. The evidence for caries prevention through combined methods is rated as suggestive but incomplete.

### Other Methods

The remaining six studies addressed five specific therapies, including alum,^ 90 ^ chewing gum,^91,92^ kanamycin,^ 93 ^ and occlusal sealant,^ 94 ^ and a sixth intervention designed to change dentists' provision of preventive therapy by informing them of individual subjects' mS scores.^ 95 ^ All of these interventions resulted in reductions in caries incidence, although two of the reductions were small and not statistically significant (alum and dentist behavior), and two others were substantial, but not analyzed statistically (kanamycin and sealant). The two interventions that resulted in statistically significant reductions in caries incidence (one using a one-tailed test) involved the use of "sugar-free" chewing gum, in one instance containing xylitol^ 91 ^ and in the other containing sorbitol, manitol, and aspartame.^ 92 ^ In neither trial did the comparison group chew a placebo gum, so the possible effects of chewing gum on salivary flow and plaque disturbance could not be separated from effects of the sweeteners. The evidence for use of gum is suggestive, but for each of these methods the available evidence is rated as incomplete.

### Special Populations

The team examined the results of the literature search to identify studies conducted in two types of subjects who are considered to be at high risk for dental caries: patients receiving orthodontic treatment who have bands and/or brackets placed on their teeth and patients who have received radiotherapy to the head and neck. Evidence Tables 5 and 6 describe the seven studies of orthodontic patients and six studies of radiotherapy patients that were included in the review.

The studies of orthodontic patients were of two general types: short-term studies on banded teeth extracted after 4 to 5 weeks to measure depth of demineralization and longer term studies evaluating the number of lesions or percent of sites that became demineralized per subject. Among these longer term studies, six interventions evaluated the effects of daily rinsing with APF^ 96 ^ and NaF,^ 97 ^ twice daily brushing with an SnF gel,^ 97 ^ CHX rinses every 3 weeks with and without prophylaxis,^ 98 ^ and periodic prophylaxis alone.^ 98 ^ The APF rinse returned a statistically significant 53 percent reduction in the percentage of sites with detectable demineralization on two index teeth upon visual examination over a 20- to 28-month period compared with no treatment. Use of both the SnF and NaF rinses was associated with a statistically significant reduction in the number of initial lesions detected visually on all facial surfaces, 72 and 30 percent, respectively, when compared with subjects in a nil comparison group. Finally, the combination of four CHX rinses and a prophylaxis every 3 weeks resulted in a 95 percent reduction in the number of initial lesions detected visually on six index teeth compared with placebo rinsing. In this same study, prophylaxis alone every 3 weeks reduced initial lesions by 67 percent, and four CHX rinses alone every 3 weeks reduced initial lesions by 14 percent.

In short-term studies (4 weeks), titanium tetrafluoride (TiF) topical solution^ 99 ^ and fluoride varnish^ 100 ^ reduced the mean depth of demineralization on facial surfaces by a statistically significant 37 and 48 percent, respectively, compared with no treatment. Similarly, a combination of daily NaF rinsing and twice daily CHX rinsing yielded a statistically significant 69 percent reduction in mean demineralization depth when compared with daily NaF rinsing alone.^ 101 ^ Finally, two different approaches to cleaning the plaque accumulation under orthodontic bands, removing the band and cleaning the revealed surface either through pumice prophylaxis or wiping with a cotton pellet, prevented any visually detectable demineralization on the smooth surfaces of first molars compared with groups where no band removal and cleaning occurred, in which all surfaces had detectable lesions.^ 102 ^ As these short-term studies did not have carious lesions as outcomes, no conclusion about the effectiveness of these methods for caries prevention in individuals undergoing orthodontic treatment was warranted. The longer term studies suggested that a variety of interventions in this population may well be effective, but the evidence is clearly incomplete.

The interventions aimed at individuals who were receiving, or had recently received, radiotherapy generally tested daily regimens involving fluoride or CHX, or both, against alternative fluoride regimens. Sample sizes in most of these studies were small, with intervention group numbers usually fewer than 20. In the only comparison against a placebo, daily use of 1 percent NaF gel reduced the incidence of new lesions 95 percent over a mean of 20 months.^ 103 ^ When sucrose restriction was added to the regimen, the reduction was 98 percent. Both reductions were statistically significant. Rinsing with a combination of NaF and calcium phosphate (CaP), first twice daily and then daily, together with NaF gel treatments reduced the incidence of new decay a nonsignificant 28 percent compared with the same regimen without the CaP over 12 months.^ 104 ^ A regimen that began with APF gel for 4 weeks and then switched to NaF gel sweetened with xylitol resulted in a nonsignificant 22 percent increase in caries incidence in a 12-month study.^ 105 ^ Daily brushing with SnF gel was no more effective than daily use of NaF gel for 3 months followed by twice daily NaF rinses in a 12-month study of coronal surfaces, but on root surfaces, the SnF regimen reduced the caries increment by a statistically significant 70 percent.^ 106 ^ Fluoride made available by means of an intraoral slow release device attached to molar facial surfaces resulted in a nonsignificant 67 percent decrease in caries incidence compared to daily application of an NaF gel over 6 months.^ 107 ^ In these latter two studies, which used NaF as comparison agents, comparison group incidence (0.06 and 0.03 DFS/mo, respectively) was much lower than in any of the other studies included in the review. Finally, a 6- to 10-month comparison of a combined CHX-NaF regimen (daily rinsing plus weekly topical applications for the first month) with daily NaF rinsing and APF topicals for the first month showed a significant 177 percent decrease in caries incidence (the experimental group DFS decreased).^ 108 ^ In a third experimental group in this study, a nonsignificant 94 percent reduction was achieved by the CHX-NaF daily rinses alone, without the introductory gel treatment. The evidence for the efficacy of fluorides with or without CHX in the prevention of carious lesions among individuals receiving head and neck radiotherapy is ranked as fair. The evidence for other interventions is judged to be incomplete.

### Harms

Only three studies contained any information regarding harms, in all instances commenting on side effects associated with the use of CHX. In one study,^ 87 ^ 4 of 59 subjects dropped out complaining of "bad taste" or "a burning feeling on mucosal surfaces." In two others, staining was at issue. "Mild staining on a small proportion of subjects" was noted in one or negligible,^ 73 ^ and "yellowish-brown staining of some dentitions…mostly very mild" in the other.^ 82 ^

### Limitations of the Evidence Base

The literature on the management of dental caries in individuals considered to be caries active or at risk for caries has several limitations. The principal shortcomings are the number of available studies for any given intervention, the variety of experimental protocols among any set of studies, the lack of studies including adult subjects and root surfaces, the meager number of studies examining effects on primary teeth, and several study design issues.

For any given management strategy, the number of available studies was small. Most preventive protocols were tested in general populations, with few investigations limiting their samples to individuals with elevated caries experience or with known risk factors for caries. The lack of a focus on such caries-active individuals is understandable because interest in "targeting" preventive procedures at the individual level has grown only within the past decade. Nevertheless, the number of available studies limited conclusions that can be drawn about the efficacy of specific preventive approaches and in some instances obviated them. For example, we found no studies describing the results associated with fluoride supplements.

Our ability to draw conclusions about any specific preventive approach was further limited by the variation in experimental protocols. For example, fluoride varnish was one of the few interventions for which we were able to rate the evidence at a level other than "incomplete." Yet in five fluoride varnish studies, three different concentrations of two different varnishes were evaluated using three different application frequencies. Comparison groups in these five studies received three different types of treatment, and all subjects received five different patterns of additional community and individual preventive procedures during the courses of the trials.

The literature focused almost exclusively on children, and in children, on permanent teeth. Only two studies of primary teeth were included in the literature and only one of adults. Efficacy of preventive approaches on root caries in caries-active individuals was examined only in one study of radiotherapy patients. The generalizability to adults of the outcomes in children is unknown, particularly in populations with relatively high rates of decay. Similarly, the extent of generalizability to primary teeth is unknown.

The variation in the methods for identification of caries-active subjects reflected the developmental nature of the literature on risk assessment methods for dental caries. Several approaches were advocated, all had some support from the literature on risk factors for dental caries, but none was validated. The two principal methods for selecting subjects were mutans streptococci levels and previous caries experience. When mS levels were used to identify subjects, the cutoff was generally 10^6^ CFU/ml, although both 10^5^ and 5 x 10^5^ cutoffs were also used. Criteria for cutoffs for previous caries experience were more variable, and depending on the age of the sample, included consideration of caries experience in both primary and permanent teeth. Presumably the cutoff was set in each study to capture individuals in the upper proportion of the distribution of disease (i.e., carious lesions and/or filled teeth and/or teeth missing as a result of caries). The mean cutoff for either admission to the study or for inclusion in subgroup analyses was the upper 35 percent of the study population or sample, but this value ranged widely, 7 to 87 percent, among the 18 studies reporting this information. For mS-based criteria, the mean cutoff was 33 percent (range 11 to 74 percent); and for previous caries activity, the mean cutoff was 38 percent (range 7 to 87 percent). One study^ 84 ^ used both mS (>10^6^) and caries experience (DMFS/dmfs>0) to form two separate post hoc analytical groups. The proportions of the entire sample population included were 15 and 36 percent, respectively, and the outcomes of the analysis were markedly different, a significant 33 percent reduction in 30-month caries incidence and a 9 percent increase, respectively. This observation heightens our general concern about the comparability of outcomes in subjects selected using differing criteria for caries activity.

The quality scores for the studies included in the review were similar to those included in the noncavitated lesion review, with a wider range from 25 to 80 and a similar mean of 55. Quality scores reflected limitations in fewer than one-half of the studies with respect to subject blinding, small sample sizes, high or unreported loss to followup, and insufficient information or selectivity about identification of caries-active subjects. More frequent problems occurred in terms of analytical designs (only three studies used intention-to-treat designs), examiner reliability (in 17 studies incomplete or no information was provided), and the rater's subjective assessment of internal validity. Finally, a majority of studies did not report compliance estimates for subjects in the study, which was not a component of the quality score. Although in a few instances compliance could be assumed to be 100 percent because only "full participants" were included in the final analyses, compliance was not ascertainable in the remainder.