# Introduction

## Primary Objectives and Scope of this Evidence Report

The National Institute of Dental and Craniofacial Research (NIDCR) is collaborating with the Agency for Healthcare Research and Quality (AHRQ) in supporting a series of systematic analyses of oral health topics at the beginning of the new century. NIDCR selected dental caries as the inaugural topic in the series partly because current approaches to diagnosis, treatment, and prevention of this most widespread of chronic diseases have become subjects of increased interest as the expression of the disease in the population has changed.

NIDCR has scheduled a National Institutes of Health (NIH) NIDCR Consensus Development Conference (CDC) on Diagnosis and Management of Dental Caries Through Life. The conference will address most aspects of the diagnosis and prevention of dental caries. The Evidence-based Practice Center (EPC) was asked to "anchor" the conference through the preparation and presentation of evidence-based reviews for selected aspects of conference topics. An objective of the CDC, and the principal objective of the evidence report, is to identify valid diagnostic methods for various lesions and effective professional preventive strategies for specific types of lesions and patients.

The treatment of dental caries has long claimed the majority of dentists' efforts, and until the last three decades, much of that effort was devoted to repairing teeth that had suffered irreversible loss of tissue and removing teeth deemed unsalvageable.^ 1 ^ With the advent of water fluoridation, fluoridated dentifrices, and both community-based and professional fluoride treatments, the nature of the disease has gradually changed for the majority of the population, who now experience what can be characterized as a more gradual and limited caries onset, with fewer lesions manifesting and progression of these lesions seemingly occurring more slowly.^ 2 ^ For a minority of individuals, however, caries incidence continues unabated, with the result that although caries is still ubiquitous, a relatively small proportion of the population now bears a large majority of the disease in terms of the number of lesions experienced.^ 3 ^ Thus, dentists now routinely encounter a distribution of disease among their patients that was uncommon two decades ago.

Concomitantly, as knowledge of the carious process is progressively refined, dentists are increasingly urged to view dental caries as a chronic infection, and more attention is being paid to the elimination of the infection as a key step in treatment.^ 4 ^ Also, nonsurgical treatment interventions are gaining in popularity as alternatives to mechanical replacement of damaged tooth tissue with artificial materials. Thus, at the same time that differences among patients in caries activity and perceived caries risk are raising new questions about the appropriate preventive and treatment strategies for individual patients, the range of possible strategies that can be applied to these patients is increasing.

This growing complexity in methods for caries management is matched by a similar increase in the complexity in methods for caries diagnosis. The diagnosis of carious lesions has been primarily a visual process, based principally on clinical inspection and review of radiographs. Tactile information obtained through use of the dental explorer or probe has also been used in the diagnostic process. Chiefly because these methods depend on subjective interpretation of subtle visual and tactile cues, variation among dentists' diagnoses had tended to be extensive.^ 5 ^ Some developing alternative diagnostic methods, such as fiberoptic transillumination (FOTI) and direct digital imaging, continue to rely on dentists' interpretation of visual cues, whereas other emerging methods, such as electrical conductance (EC) and computer analysis of digitized radiographic images, offer the first "objective" assessments, where visual and tactile cues are either supplemented or supplanted by quantitative measurements.

## Key Clinical Questions

The clinical questions in this report were developed in conjunction with the planning committee for the CDC. They reflect three aspects of the diagnosis and management of dental caries where the committee perceived either that current clinical practice might not reflect current knowledge regarding efficacy and effectiveness or that a review of current evidence might help stimulate new research.

The first question addresses methods used for identifying carious lesions. At issue is the validity of each diagnostic technique. Lesions must be identified in a variety of sites -- primary and permanent teeth, occlusal and smooth surfaces, and coronal and root surfaces. Several diagnostic techniques are available, and the ability of these different techniques to detect carious lesions on specific sites may not be completely appreciated.

The second question concerns the effectiveness of strategies to arrest or reverse the progress of carious lesions before tooth tissue is irreversibly lost. Early stages of dental decay involve demineralization of tooth tissues with minimal loss of the organic matrix. In some instances, dentists can promote remineralization of the matrix, thus effectively reversing the caries process.^ 6 ^ In other instances, the affected area can be covered with a protective material without any surgical removal of tooth tissue. The efficacy of these conservative, nonsurgical caries treatments is not well identified.

The third question addresses the effectiveness of preventive methods in those individuals who have experienced, are experiencing, or are expected to experience an elevated incidence of carious lesions. Dentists are now being urged to identify individuals with elevated caries activity,^ 7 ^ but this "risk assessment" strategy has not been complemented by the identification of the most effective interventions to mitigate the caries attack in these high-risk individuals.

## Technical Expert Advisory Group Involvement

Guidelines from AHRQ require identification of technical experts in diagnosis and management of dental caries. The Technical Expert Advisory Group (TEAG) (see Appendix B for its composition) was expected to contribute to (a) advancing AHRQ's broader goals of creating and maintaining "science partnerships" and "public-private partnerships" and (b) meeting the needs of a broad array of potential users of its products. Thus, it was both a resource and a sounding board throughout the project. The TEAG included seven members, three technical experts, two individuals representing the public health perspective of the population at large, and two potential users of the final evidence report or other materials.

To ensure scientifically robust work, the TEAG was called upon to provide reactions to work in progress and advice on substantive issues or possibly overlooked areas of research. TEAG members participated in conference calls and e-mail solicitations:

- At the beginning of the project to discuss the key clinical questions, initial drafts of causal pathways, and proposed inclusion and exclusion criteria for research articles.
- During the development of abstracting forms to provide comments concerning the forms, the content proposed for inclusion in the evidence tables, and the final versions of the key clinical questions and causal pathways.
- When the draft evidence tables were produced to discuss the content of the tables and the completeness of the search.

Because of their extensive knowledge of the caries literature and their active involvement in professional societies, TEAG members were also asked to participate in the peer review process by commenting on the draft report. In addition to the contribution of the TEAG, the preparation of the evidence report also benefited from the contributions of three consultants whose advice was sought informally during all phases of the project. Subject to their availability, the consultants also participated in the conference calls.

## Dental Caries: Background and Significance

Dental caries is a chronic infectious disease that results in the destruction of tooth tissue. It is caused by a complex interaction of oral microorganisms in dental plaque, diet, and a broad array of host factors ranging from societal and environmental factors to genetic and biochemical/immunologic host responses.^ 8 ^ Dental caries is also site specific as each tooth and each site have different susceptibilities because of their unique anatomical, physiologic, and environmental characteristics. The crown or coronal portion of a tooth is covered by a layer of enamel. The occlusal surfaces of posterior crowns have invaginations termed pits and fissures, whereas the facial, lingual, and proximal aspects of tooth crowns typically are smooth. In contrast, the tooth root consists of dentin covered by only a thin layer of cementum. These anatomical variations provide different environmental niches that permit very different forms of plaque to flourish.

Dental tissues are in a constant state of mineralization and demineralization because the acidogenic plaque adjacent to enamel surfaces. When this dynamic balance is disrupted, the caries process can proceed and can result in the destruction of tooth tissue. Initially there is a diffusion of acids into the enamel and subsurface demineralization begins to occur. Loss of subsurface enamel can result in a noncavitated lesion, or white spot lesion. If the balance of the equilibrium shifts to remineralization, the subsurface layer of enamel can be reformed by deposition of calcium and phosphate. However, when demineralization dominates, the subsurface lesion becomes so large that the surface layer of enamel collapses causing cavitation. Cavitated and noncavitated lesions can progress through the enamel to the dentoenamel junction (DEJ). Once in dentin, the lesion progresses by following the dentinal tubules and spreads laterally in a saucer-shape fashion. Root surfaces, which are composed of a thin layer of cementum over dentin, are much rougher than coronal (enamel) surfaces, facilitating plaque formation. Compared with coronal lesions, root lesions have less well-defined margins and exhibit a broad pattern of progression through the dentin.

### Prevalence of Carious Lesions

The Third National Health and Nutrition Examination Survey-Phase I (NHANES III), conducted from 1988 to 1991, provides the most recent estimates of the prevalence of carious lesions in the United States.^9,10^ This survey, which produced nationally representative estimates for the civilian noninstitutionalized U.S. population, found that the mean decayed and filled surfaces (dfs) of primary teeth score in children age 2 to 9 was 3.1. The score varied among racial-ethnic categories: non-Hispanic whites (2.5), non-Hispanic blacks (2.7), and Mexican-Americans (4.8). Overall, 83 percent of children age 2 to 4 years had experienced no lesions in the primary dentition, with this percentage dropping to 50 percent in children 5 to 9 years of age.

The overall mean decayed, missing, and filled surfaces (DMFS) of permanent teeth scores for children age 5 to 17 in various racial-ethnic categories are shown in Table 1, together with the D component scores and the D/DMF proportion, which represents the relative proportion of an individual's disease experience that has not received treatment. In this age group, overall DMFS was similar across race-ethnicity categories, but the proportion of DS in the DMFS varied substantially by race-ethnicity categories, which may be more of a reflection of access or utilization issues rather than disease patterns.

Table 1. Mean DS, DMFS, and % DS/DMFS per person by race-ethnicity in U.S. children and adolescents age 5 to 17, 1988-91

Race/Ethnicity | DS (SE) | DMFS (SE) | % DS/DMFS (SE) ^1^
Total | 0.4 (0.1) | 2.5 (0.2) | 19.7 (1.5)
Non-Hispanic Whites | 0.3 (0.0) | 2.4 (0.3) | 14.6 (2.2)
Non-Hispanic Blacks | 0.8 (0.1) | 2.5 (0.2) | 37.9 (3.1)
Mexican-Americans | 0.7 (0.1) | 2.7 (0.1) | 36.4 (2.8)

1 With at least one decayed or filled surface.

DS - decayed surfaces on permanent teeth.

DMFS - decayed, missing, and filled surfaces on permanent teeth.

%DS/DMFS - percent of DMF surfaces composed of decayed surfaces.

In children age 5 to 11, 74 percent had no carious lesions in the permanent dentition, whereas for children age 12 to 17, the proportion falls to 33 percent. Overall, carious lesions in children are not evenly distributed; 75 percent of overall caries experience in permanent teeth occurred in approximately 25 percent of the population.^ 3 ^ Thus, although the majority of children have moderate decay or less, carious lesions are a recurring problem for a substantial minority. Carious lesions are also not equally distributed across tooth surfaces in this population, as occlusal surfaces experience lesions five times more frequently than the mesial and distal (smooth) surfaces.

In adults 18 and older, evidence of past or present coronal carious lesions was found in 94 percent of the population. The mean DFS score for dentate adults (those with one or more teeth) was 22.2. Females exhibited a higher mean number of treated and untreated surfaces per person. Coronal DFS scores, shown in Table 2, varied by race-ethnicity, and the proportion of decayed surfaces in the DFS score varied as well.

Table 2. Mean DS, DFS, and %DS/DFS per person by race-ethnicity in U.S. dentate adults, ages 18 Years and older, 1988-91

Race/Ethnicity | DS (SE) | DFS (SE) | %DS/DFS (SE) ^1^
Total | 1.8 (0.0) | 22.2 (0.9) | 14.2 (0.8)
Non-Hispanic Whites | 1.5 (0.1) | 24.3 (1.5) | 10.6 (0.8)
Non-Hispanic Blacks | 3.4 (0.3) | 11.9 (3.4) | 35.4 (2.8)
Mexican-Americans | 2.8 (0.3) | 14.1 (2.8) | 31.0 (2.6)

1 With at least one decayed or filled surface.

DS - decayed surfaces on permanent teeth.

DFS - decayed, and filled surfaces on permanent teeth.

%DS/DFS - percent of DFS surfaces composed of decayed surfaces.

Carious root lesions were found in 23 percent of the dentate population overall and in more than 47 percent of individuals 65 or older. The average number of treated and untreated root surfaces ranged from a low in non-Hispanic whites of 1.1 to 1.4 in Mexican-Americans and 1.6 in non-Hispanic blacks.

### Burden of Illness from Dental Caries

Because treatment and/or prevention of carious lesions is one of several reasons for visiting a dentist, and because accurate information describing reasons for dental visits is not available, the extent to which carious lesions necessitate dental visits is not known. However, from the preceding section on the prevalence of carious lesions and filled tooth surfaces, it would seem that racial and ethnic minorities receive proportionally less treatment for carious lesions than do white non-Hispanics. This observation is supported from existing data on dental visits. The Surgeon General's report on oral health^ 11 ^ has assembled data from a number of Federal agencies that paint a clear picture of differences in the receipt of oral health care by race/ethnicity, income, and insurance status. In white, non-Hispanic adults, 64 percent reported a dental visit in 1993 compared with 47 percent of black, non-Hispanic adults and 46 percent of Hispanic adults. For individuals with incomes at or above poverty level, 64 percent reported a dental visit in the previous year compared with 36 percent for those with incomes below poverty level. In 1989, 70 percent of individuals 2 years and older with private dental insurance reported a dental visit within the preceding year compared with 51 percent for those without private dental insurance. Finally, those individuals who rate their oral health as very good or excellent are more likely to have visited a dentist in the preceding year (61 percent) than were those assessing their health as fair or poor (45 percent).

The economic cost of dental caries is also difficult to assess precisely. In 1998, Americans spent more than $53 billion on dental services.^ 11 ^ From an analysis of insurance claims, approximately 40 percent of charges are related to restorative dental services, which are usually, but not always, performed to repair teeth damaged by carious lesions.^ 12 ^ Thus, even without adding in the cost of more complex services necessary to restore function lost as a result of the sequalae of the dental caries process, expenditures related to caries were more than $20 billion.

Beyond the direct economic costs of dental treatment, there are the less directly calculable costs associated with the loss of working time, missed school, and reduced levels of social functioning. The National Health Interview Survey (NHIS) indicates that 2.9 million acute dental conditions occurred in the U.S. population during 1994. These dental conditions accounted for an estimated 3.9 million days of missed work in persons 18 years of age and over, 1.2 million days of missed school in youth 5 to 17 years of age, and 12.2 million days of restricted activity across all ages (e.g., nonperformance of usual family role activities).^ 13 ^ The NHIS methods may underestimate the actual amount of missed time from school and work and restricted activity days for dental conditions.^14,15^

Studies of how dental caries affects quality of life are much less empirically compelling, but experts agree on what the potential effects of dental caries are likely to be in the short and long term.^ 16 ^ In the short term, physical discomfort and pain are the most likely consequences of untreated lesions. Physical impacts can be felt directly as through the pain of toothaches, infections, and temporomandibular joint disorder resulting in part from a loss of posterior teeth and the failure to replace them when necessary. The possible eventual inability to eat -- both bite and chew -- because of tooth loss can lead to unnecessary dietary restrictions and nutritional deficiencies as well as complicate the dietary management of other chronic health conditions.

The psychological pain of self-consciousness and social isolation may also accompany the embarrassment of the unsightly deterioration of anterior teeth caused by dental caries. The same psychological distress can result from the embarrassment of missing anterior teeth, the communication dysfunction associated with not being able to be easily understood by others, and the isolation or withdrawal from social intercourse because of missing teeth. In the long term, left untreated, carious lesions may lead to the loss of such teeth, the replacement of which may be needed for functional, social, cosmetic, and physical and mental health reasons.

### Caries Diagnosis

The local result of the dental caries infection is a process of demineralization of tooth tissue (enamel, dentin, cementum). Acid produced by bacteria as a product of carbohydrate fermentation causes the demineralization. The diagnosis of dental caries at a particular site on a tooth is based on either direct or indirect detection of the demineralized tooth structure.

The principal methods dentists use to diagnose carious lesions -- visual and visual/tactile examinations and radiographic assessment -- have been employed with little change for decades. Refinement in techniques, rather than development of new technology, has characterized these methods over the years. Illumination has improved and magnification is more easily employed for visual examinations, whereas radiation doses have decreased for radiographic assessment as both equipment and film have been improved.

Visual inspection is based on a search for signs of demineralization, which include changes in color and in surface consistency and contour. Tactile inspection is usually accomplished with a fine-tipped dental explorer or probe that is passed over smooth surfaces of teeth as well as pits and fissures. On smooth surfaces, the surface texture is assessed for roughness as well as breaks in contour. In pits and fissures, the probe is usually pressed with differing levels of force into depressed areas to assess whether any penetration is possible and whether there is any resistance to withdrawal of the probe. Radiographic assessment is based on identification of demineralization of tooth tissue through differential exposure of film. Demineralized tooth tissue is less resistant to the passage of ionizing radiation and thus appears darker on film images.

More recently, new technologies have begun to appear that further refine radiographic diagnosis of carious lesions and offer alternatives to this technology. Digital radiographic techniques eliminate film by capturing radiographic images on phosphor storage plates or charge-coupled devices. The images can then be manipulated to enhance diagnostic features. Fiberoptic transillumination, passing a narrow beam of light through tooth tissue, has become an adjunctive diagnostic method now used for both anterior and posterior teeth, principally on proximal surfaces. Demineralized tooth tissue appears dark when transilluminated because of its decreased transmission of light. This method represents refinement of the traditional technique of transilluminating the anterior proximal surfaces using a mouth mirror and the operatory light. Measuring the resistance of tooth tissue to an electrical current passed through it is another approach to caries diagnosis, especially of occlusal fissure caries. First demonstrated in the 1950s, the technique has been progressively refined, with devices available commercially since the 1980s. The technique depends on the fact that when enamel becomes demineralized, it loses much of its resistance to electrical charges, hence its conductance increases.

The extent of variation in the diagnosis of dental caries is substantial among dental practitioners using the traditional techniques. Typically agreement among several dentists is poor to moderate, with kappa values ranging from 0.30 to 0.60 in several studies.^ 5 ^ The range of positive diagnoses (proportion of teeth diagnosed as carious) is typically wide for any given sample, often spanning 30 to 40 percentage points.^ 5 ^ The problem of calibrating dental practitioners to an objective standard for caries diagnosis results to a large extent from the absence of objective criteria for the diagnosis;^17,18^ consequently, dentists tend to develop widely different subjective patterns or "scripts" that they then use for identification of carious lesions.^ 19 ^ This variation in the diagnosis of carious lesions is a principal contributor to the still greater variation in the decision to restore teeth through irreversible surgical intervention^20,21^ and the concomitant variation in associated costs of those decisions.^ 22 ^

## Professionally Administered Methods of Caries Prevention

Caries prevention as accomplished in dental practice has traditionally been viewed as a combination of several procedures, including oral prophylaxis, topical application of fluoride, oral self-care instruction, sealants for fissured surfaces, and restoration of existing carious lesions. Although oral self-care instruction and oral prophylaxis methods have not changed appreciably over the years, application of topical fluoride has seen continuing modifications, both in delivery vehicles and in solutions and concentrations used. Dental sealant technology has similarly become refined, with changes in materials and in etching and polymerization techniques. In recent years, an additional intervention has become available: prescription antimicrobial mouthrinses. Also, the number of "over-the-counter" (OTC) products that dentists can specifically recommend for home use has increased, such as remineralization rinses, salivary substitutes for persons with decreased salivary flow, and candies and gums with nonfermentable sugars. Finally, simplified testing for mutans streptococci (mS), the putative pathogen for dental caries, has become commercially available.

As the incidence of carious lesions experienced by most children has decreased in the past three decades, available approaches to prevention in both children and adults have become more specific to individual clinical circumstances. The two circumstances on which this review is focused involve the management of noncavitated carious lesions and the prevention of carious lesions in caries-active individuals. Noncavitated carious lesions are areas where demineralization has started, but is not extensive. In theselesions, no tissue has been lost and no loss of contour or break in continuity of the enamel surface is detectable. Strategies for preventing these lesions from progressing to irreversible tissue loss, or cavitation, can include all of the traditional and more recently developed preventive techniques. The prevention of new carious lesions in caries-active individuals also can involve the full gamut of professionally applied preventive procedures.

### Variation in Methods to Control Noncavitated Lesions

Little is known about dentists' strategies to reduce or eliminate progression of noncavitated carious lesions and hence the necessity for surgical intervention. The previously cited literature on variation in dentists' decisions to initiate treatment includes some studies of dentists' treatment thresholds. These studies suggest there is variation in the extent of progression of a carious lesion that individual dentists are willing to tolerate before they intervene surgically. Unfortunately, these types of studies must be done using patient vignettes, and there is some suggestion that what dentists say they do with respect to intervention is often different than what they actually do in practice.^23-26^ These studies show that a sizable proportion of dentists routinely intervene when radiographic evidence of dental caries manifests itself in the enamel prior to cavitation. No recent studies are available to document circumstances surrounding application of nonsurgical means of control, although the continuing controversy about "sealing over caries"^ 27 ^ suggests that dentists vary in their willingness to use sealants as a method for the control of unidentified occlusal lesions.

### Variation in Methods to Control Caries in Caries-Active Individuals

Knowledge of dentists' practices in addressing caries control in caries-active individuals is exceedingly limited. Only recently have the concepts of "caries risk" and "medical management" emerged in the clinical dental literature.^4,7,28,29^ These discussions suggest that practitioners' preventive approaches may not be routinely based on a careful assessment of the magnitude of the caries challenge. Information from insurance claims suggests that topical fluoride applications tend to vary by practitioner, but not by patients within a practice, who all receive the same preventive care even though they have different rates for restoration receipt.^ 30 ^ Also, a survey of practitioners shows that commonly used clinical protocols are not congruent with current recommendations for low-risk individuals.^ 31 ^ Clearly, there is a potential for both over use and under use of prevention and control methods in a caries-active population; but studies that examine dentists' preventive treatment behaviors are rare, and none differentiate treatment by an individual's caries activity.

## Organization of this Report

The remainder of this report is organized in the following sections. Chapter 2 provides details about the literature search and review methods describes the causal pathway for key questions and approaches to establishing inclusion and exclusion criteria, conducting the systematic review, abstracting data from articles, maintaining quality control, assigning quality scores to individual articles, and similar details. Chapter 3 presents the results for the three key clinical questions -- diagnostic methods, management of noncavitated lesions, and management of caries-active individuals. Chapter 4 provides conclusions, and Chapter 5 offers recommendations concerning research on diagnosis and management of dental caries. References cited in the body of the report, the six evidence tables, and a list of all literature reviewed for the preparation of the tables follow. The appendixes contain acknowledgments (Appendix A), information on the TEAG (Appendix B) and the peer reviewers (Appendix C), data extraction forms (Appendix D), and acronyms and abbreviations used in this report (Appendix E).