# Appendix E. Acronyms and Abbreviations

AHRQ: Agency for Healthcare Research and Quality

AmF: amine fluoride

APF: acidulated phosphate fluoride

CaP: calcium phosphate

CDC: Consensus Development Conference

CFU: colony-forming unit

CHX: chlorhexidine

DEJ: dentoenamel junction

df: decayed and filled primary teeth

dfs: decayed and filled surfaces on primary teeth

DMF: decayed, missing, and filled permanent teeth

DMFS: decayed, missing, and filled surfaces on permanent teeth

EC: electrical conductance

EPC: Evidence-based Practice Center

FeAlF: ferric aluminum fluoride

FOTI: fiberoptic transillumination

MeSH: Medical Subject Headings

mS: mutans streptococci

NaF: sodium fluoride

NHANES: National Health and Nutrition Examination Survey

NHIS: National Health Interview Survey

NIDCR: National Institute of Dental and Craniofacial Research

NIH: National Institutes of Health

NNT: number needed to treat

OTC: over the counter

RCT: randomized controlled trial

ROC: receiver operating characteristic

RTI-UNC EPC: Research Triangle Institute-University of North Carolina at Chapel Hill Evidence-based Practice Center

SnF: stannous fluoride

TEAG: Technical Expert Advisory Group

TiF: titanium tetrafluoride