# Appendixes

Appendix A. Acknowledgments

Appendix B. Selection, Composition, and Role of the Technical Expert Advisory Group

Appendix C. Selection, Names, and Tasks of Peer Reviewers

Appendix D. Article Abstraction Forms

Appendix E. Acronyms and Abbreviations