# Evidence Tables

Evidence Table 1 - Epidemiology of Cancer Pain Summary

Author, year identifier ^1^ | Setting | Population | Aim of the study | Type of cancer | Incidence or prevalence of pain, etiology, characteristics (comments)
Daut 1982 87097307 | Country: USA Setting: hospital clinic (inpatient and outpatients) Specialty: oncology, urology, and gynecology | N=667 Age: 19-88 Symptoms: pain Sx duration: 9 months Source of data: questionnaire, charts | To evaluate the incidence of pain at the time of diagnosis and in progression of disease. Also evaluated were intensity, location and perceived cause, treatment and efficacy, interference with life. | Breast (289/667=43.3%) Prostate (48/667=7.2%) Colon/rectal (127/667=19.0%) Cervix (91/667=13.6%) Uterine (27/667=4.0%) Ovary (85/667=12.0%)
  | Met | Non-met
  Breast | 64% | 40%
  Prostate | 75% | 30%
  Colon/rectal | 47% | 40%
  Cervix | ND | 35%
  Uterine | 40% | 14%
  Ovary | 59% | 39%
  Total (pain due directly to tumor):
  | 33% | 6%
  6-7% pain due to other etiologies
Ahles 1984 84242554 | Country: USA Setting: clinic outpatients Specialty: oncology | N=208 Age: 17-86 Symptoms: pain Sx duration: 7 months Source of data: questionnaire, charts | To determine prevalence of pain and relation of pain to cancer, treatment of cancer, or other. The study also evaluated the incidence of pain according to the stage (local, regional, metastatic). | Breast (62/208=29.8%) Lung (26/208=12.5%) Lymphoma (22/208=10.6%) Colon (19/208=9.1%) Other (79/208=38.0%) | 33.5% pain due to cancer 6.7% cancer-related procedures 11.0% non-cancer-related pain commonly associated with metastatic disease.
Gilbert 1986 87097307 | Country: USA Setting: clinic inpatients Specialty: oncology | N=162 Age: >18 Symptoms: neurologic Sx duration: 3 months Source of data: questionnaire, charts | To determine the incidence and nature of pain and other major neurologic problems (e.g., disorientation) in cancer patients. | Non-Hodgkin's lymphoma (26/162=16.0%) Breast (17/162=10.5%) Hepatoma (15/162=9.2%) Small-cell lung (13/162=8.0%) Multiple myeloma (13/162=8.0%) Colon (10/162=6.1%) (All others <10) | 34/162 21% overall
Miser 1987a 87230445 | Country: USA Setting: hospital, clinic (in- and outpatients) Specialty: pediatric oncology | N=139 161 inpatient days, 195 outpatient clinic visits (in- and outpatients) Age: >7 yrs Symptoms: pain Sx duration: 6 months Source of data: questionnaires | To investigate the prevalence and nature of pain in children and young adults with malignancy. | Leukemia (44/139=31%) Soft tissue sarcoma (33/139=23.7%) Ewing's sarcoma (28/139=20.1%) Osteosarcoma (20/139=14.4%) Lymphoma (12/139=8.6%) Other (2/139=1.4%) | In 356 patient visits, pain present in 54% of total inpatient population and 26% of outpatient population. 46% pain due to tumor alone 14% pain due to both tumor and therapy 40% pain due to cancer Tx only Tumor-related pain was due to bone invasion 68%, cord compression 5%, and multiple causes 11%. Pain was associated with lower functional status (Karnofsky score).
Miser 1987b 87230446 | Country: USA Setting: hospital, clinic (in- and outpatients) Specialty: pediatric oncology | N=92 Age: children & young adults (age not stated) Symptoms: pain Sx duration: 26 months Source of data: questionnaires | To investigate the incidence of pain in children and young adults presenting with newly diagnosed malignancy. | Soft tissue sarcoma (23/92=25%) Ewing's sarcoma (21/92=22.8%) Osteosarcoma (14/92=15.2%) Leukemia (12/92=13%) Lymphoma (10/92=10.9%) Neuroblastoma (1/92=1.0%) Other (11) | Soft tissue sarcoma 52.2% Ewing's sarcoma 60.0% Osteosarcoma 78.3% Leukemia 100% Lymphoma 100% Neuroblastoma 100% On initial evaluation 72 of 92 patients were experiencing pain that had been present for median 74 days (3-821 days, range). 42 had experienced sleep disturbances due to pain. Pain was associated with lower functional status (Karnofsky score).
Greenwald 1987 88026644 | Country: USA Setting: hospital (outpatients) Specialty: anesthesiology and pain management | N=536 Age: 20-80 Symptoms: neurologic Sx duration: 18 months Source of data: Cancer Surveillance System registry, graphic rating scales, McGill Pain Questionnaire | To determine the prevalence and characteristics of pain in four types of primary cancer restricted to recently diagnosed patients (within 3 months of the survey). | Lung (260/536=48.5%) Prostate (201/536=37.5%) Uterine/cervix (50/536=9.3%) Pancreas (25/536=4.7%) | Lung 50.7% Prostate 38.3% Uterine/cervix 38.0% Pancreas 60.0% % of patients reporting moderate to very bad pain in past week by cancer site. % by stage are also reported.
Coyle 1990 90270702 | Country: USA Setting: pain service (outpatients) Specialty: neurology | N=90 (40 M, 50 F) Median age: 59 (23-82) Symptoms: pain Sx duration: 6 years (retrospective) Source of data: retrospective/patient charts | To retrospectively evaluate the prevalence of pain by intensity, type, analgesic consumption, and suicidal ideation in cancer patients during the 4 weeks preceding death. | Lung (23/90=25.6%) Colon (18/90=20.0%) Breast (18/90=20.0%) Head/neck (9/90=10.0%) Gynecologic (6/90=6.7%) (All others <5%) | For all sites: 100% had pain 80% mild to moderate 20% moderate to severe 67% more than one type of pain (40% somatic & neuropathic)
Portenoy 1990 90356275 | Country: USA Setting: pain service Specialty: neurology | N=63, 41 (64%) with breakthrough pain episodes (19 M, 22 F) Median age: 51 (15-81) Symptoms: breakthrough pain Sx duration:3 months Source of data: prospective survey | To evaluate prevalence and characteristics of breakthrough pain. | Genitourinary (11/41=26.8%) Head/neck (5/41=12.2%) GI (4/41=9.8%) Lung (3/41=7.3%) Sarcoma (3/41=7.3%) Other (13) | Patients with breakthrough pain, 1 type (32), 2 distinct types (8), & 3 types (1). Characteristics: (median 4 pains/day; range 1-3600) 22 (43%) had rapid onset (<3 min) Duration: (median 30 min; range 1-240) 21 (41%) both paroxysmal & brief 15 (29%) began or worsened at end of a fixed opioid dose interval Type of pain: somatic 17 (33%) visceral 10 (20%) neuropathic 14 (27%) mixed 10 (20%)
Hiraga 1991 92100649 | Country: Japan Setting: nationwide hospitals (inpatients) Specialty: all | N= 35,683 (31.6% of all hospitalized patients at the time of survey) Age: not reported Symptoms: pain Sx duration: not reported Source of data: nation-wide questionnaire by nurses | To determine the incidence* of pain in different stages of illness, analgesic methods, and rate of pain relief in cancer patients in Japan. *incidence was defined as the percentage of patients receiving pain medication. | Stomach (5882/35,683=16.4%) Liver/biliary/pancreas (4578/35,683=12.8%) Lung (4428/35,683=12.4%) Colon/rectal (3332/35,683=9.3%) Oral/pharynx/larynx (2966/35,683=8.3%) Ovary/cervix/corpus (2765/35,683=7.7%) Genitourinary (2746/35,683=7.7%) Lymphoma/leukemia (2686/35,683=7.5%) Breast (1925/35,683=5.4%) Other (9675) | 32.6%
Portenoy 1992 92386434 | Country: USA Setting: three physicians' outpatient practices Specialty: oncology, two specialists in lung cancer and one in colon cancer | N = 398 patients with lung or colon cancer Age: 57±10.4 (average for 91 patients who reported pain during the 2 previous weeks and consented to an interview) Symptoms: pain, mood (0-100 mm VAS for pain intensity, pain relief, and mood and 8-point categorical scale for pain intensity) Sx duration: 9 months Source of data: prospective survey with face-to-face interviews | To evaluate the prevalence and characteristics of pain in ambulatory patients with colon and lung cancer during active anti-tumor therapy. A prospective survey using face-to-face and telephone interviews by trained quality assurance analysts. | Lung (185/398=46.4%) Colon (213/398=55.6%) | "Persistent or frequent pain" during the previous 2 weeks was reported by: 57/145(39.3%) with lung cancer and 52/181(28.7%) with colon cancer. 91 of the above patients (47 lung, 44 colon) were interviewed in detail. There were no significant differences in pain with the exception of pain location between the two tumor types One-third of patients had more than one discrete pain. Median pain duration was 4 weeks (range, less than 1 week-468 weeks), and average pain intensity was moderate. Approximately 90% of patients experienced pain more than 25% of the time. Regarding pain treatment: 56/91(61.5%) were prescribed no medication 4/91(4.4%) were prescribed nonopioid medication 31/91(34.1%) were given opioids. Of patients reporting that pain in general was moderate or greater, 57.8% were prescribed no pain medications and 37.3% received opioids.
Brescia 1992 92092056 | Country: USA Setting: a 200-bed "specialty hospital for advanced cancer" Specialty: terminal care | N = 1103 patients admitted during the survey period, and 1017 patients who died within 6 months of the end of the survey Age: mean, 68; range, 24-94. 62% of patients were older than 65. Symptoms: pain intensity (none, mild, or severe) Severe pain was defined as recorded pain of moderate or greater intensity that occurred with regularity throughout the day. Mild pain was noted when the record stated that pain was relieved without the use of analgesics, by nonopioid agents, or by the "weak" opioids such as codeine. No pain was recorded when the record stated explicitly that the patient offered no complaint of pain or was comfortable. Sx duration: 12 months Source of data: prospective chart review at baseline (72 hrs after admission) and again "soon after the patient's death or discharge." | To develop a clinical data base for advanced cancer patients and to survey data to determine (1) pain severity at admission, (2) opioid use at admission, (3) change in opioid use during the hospital stay, and (4) survival in the hospital. Data were collected prospectively within 72 hours after admission and soon after death or discharge. | Primary sites: Lung 19% Breast 13% Colon 10% Colon-rectum 6% Other sites 33 to 55% Bone metastases: (pain-producing) in 38% Other sites of metastases: Lung 24% Liver 28% Brain 17% | 73% of patients had pain at admission. Severe pain was inversely related to age; patients younger than 55 were twice as likely to have severe pain as older patients. Frequency of severe pain by type of cancer: Cervix (68%, prostate 57%, colon-rectum 49% Severe pain was noted by nearly one-half (49%) of the patients with bone metastases. At baseline, 25% of patients were receiving morphine, 18% codeine, 6% hydromorphone, and 3% methadone or levorphanol. Most (71.7%) patients had a stable dosing pattern; only 4.2% required opioid dose increases of 10% or more per day.
Vuorinen 1993 94162760 | Country: Finland Setting: pain clinic (outpatients) Specialty: anesthesiology | N=378 (240 evaluable, 40% M, 60% F) Median age: 64 (27-89) Symptoms: pain Sx duration: 9 months Source of data: questionnaire | To investigate the prevalence and causes of pain at the early stages of cancer (0-6 months from diagnosis). | Genitourinary (73/240=31%) GI (38/240=16%) Breast (63/240=26%) Hematological (26/240=11%) Lung (14/240=6%) Skin (13/240=5%) Other (13/240=5 %) | 66/240 (28%) at time of questionnaire 42/240 (24%) as first sign of cancer Cause: 46% direct tumor growth 67% conditions secondary to cancer 18% unrelated to cancer
Portenoy 1994 94313536 | Country: USA Setting: hospital clinic (inpatients and outpatients) Specialty: neurology, pain | N=151 (111 inpatients, 40 outpatients) Median age: 55 (23-86) Symptoms: pain Sx duration: 18 months Source of data: questionnaires | To investigate the prevalence, characteristics, and impact of pain in ovarian cancer patients. | Ovarian cancer | 62% had pain before diagnosis 42% had pain during last 2 weeks Most patients had pain related interference with function.
Cleeland 1994 94134141 | Country: USA Setting: outpatients in 54 oncology clinics Specialty: medical research, neurology | N=1308 (376 M, 495 F) 871 with pain or taking analgesics during week prior to study Median age: 62 (19-90) Symptoms: pain Sx duration: 12 months Source of data: questionnaire | To assess adequacy of analgesic drug prescribing according to WHO guidelines, factors that influence whether analgesia was adequate, and the effects of inadequate analgesia on patients' perception of pain relief and function status. | Breast (270/871=60%)* GI (148/871=58%) Lung (124/871=63%) genitourinary (86/871=66%) Lymphoma (55/871=71%) Gyn (23/871=63%) *% of patients by site (see prior column) with substantial pain; pooled figure = 67% | Physicians commonly underestimated the severity of pain. 42% of patients with pain were not given adequate analgesic therapy according to WHO guidelines. Independent risk factors for inadequate pain management included pain not attributed to cancer, better performance status, age 70 or older, female sex, and minority status. Underrated pain impaired function.
Mercadante 1994 95158028 | Country: Italy Setting: palliative care service, outpatients) Specialty: pain management | N=60 (52 evaluable, 44 M, 8 F) Age: 64.2+/−2 (42-82) Symptoms: pain Sx duration: unclear, 51.3 days +/−9.4 days observation period Source of data: questionnaires | To obtain the prevalence, characteristics, and localization of pain in lung cancer and also to determine response to treatment by WHO analgesic ladder. | Lung | 46 of 52 (88.4%) experienced pain. Pain was localized in: Chest 26/52 Legs/lumbar 1/52 Abdomen/arms 8/52 Head 6/52 The type of pain was: Somatic 85.7% Visceral 42.8% Neuropathic 30.9% Incident 23.8%
Kelsen 1995 95190526 | Country: USA Setting: oncology and palliative care service, in- and outpatients Specialty: neurology & medicine | N=189 (130 evaluable, 79 M, 51 F, total screened 277) Patients were divided into two groups, those who underwent surgery (83/130) and those who received chemotherapy (47/130). Median age: 63 Symptoms: pain Sx duration: unclear Source of data: questionnaires | To evaluate the prevalence of pain and depression, their correlation and their effect on quality of life in patients with recently diagnosed adenocarcinoma of the pancreas. | Adenocarcinoma of the pancreas | At study entrance: 37% no pain 34% mild or minimal pain 29% moderate to severe pain. Of patients who reported pain at entry, its duration ranged from 1 to >5 months, 67% described a diffuse abdominal pain. Chemotherapy patients had more intense pain than preoperative patients. Patients with moderate or greater pain had more impairment of functional activity than patients with mild or no pain. Significant correlations between increasing pain and depression, and between pain/depressive symptoms and quality of life.
Larue 1995 95245216 | Country: France Setting: 20 cancer treatment services, in- and outpatients Specialty: not specified | N=605 (601 evaluable, 252 M, 347 F, ?2) Mean age: 57.8 +/−14SD Symptoms: pain Sx duration: unclear Source of data: questionnaires by patients and physicians | To describe the treatment of cancer pain in France and to evaluate the predictive factors for inadequate management. | Breast (211/605=34.8%) GI (108/605=17.9% Genitourinary (80/605=13.2%) Lung (77/605=12.7%) Head/neck (57/605=9.4%) Lymphoma (26/605=4.2%) Other (46/605=7.6%) | 57% (340/601) reported pain due to their disease. 69% (224/325) of those with pain rated their worst pain at a level that impaired their ability to function. 30% (84/279) were not receiving pain medication. 51% (137/200) of those receiving pain medication found relief was inadequate. Doctors' pain ratings were consistently less than patients'.
Stevens 1995 95372100 | Country: USA Setting: 16 ambulatory care services Specialty: nursing | N=95 (435 oncology patients screened) Mean age: 49.16 +/−13SD & 52.6 +/−12.4SD (with and without pain, respectively) Symptoms: postmastectomy pain Sx duration: unclear Source of data: medical records, questionnaires | To investigate prevalence, characteristics, and impact of postmastectomy pain. | Breast (postmastectomy) | 65% reported no pain 15% reported pain of somatic or visceral type associated with the tumor 20% postmastectomy pain All with pain reported interference with work or home activities. All with pain reported exacerbation on movement. Patients used weak, nonopioid analgesics (25%) or none (75%). 85% used nonpharmacologic pain control.
Vainio 1996 96280298 | Country: Switzerland (data from UK, Switzerland, Finland, USA and Australia) Setting: 7 hospices, in- and outpatients Specialty: multiple | N=1640 Age:>18 Symptoms: pain and other symptoms Sx duration: 3 months to 3 years Source of data: questionnaire by nurse or doctor | To estimate the prevalence of pain and eight other common symptoms in a large population of patients with advanced cancer from different palliative care centers. | Lung (343/1640=21% Breast (174/1640=11%) Colorectal (121/1640=7%) Head/neck (92/1640=6%) Stomach (86/1640=5%) Prostate (76/1640=5%) Gynecological (83/1640=5%) Lympho-hematological (60/1640=4%) Esophagus (36/1640=2%) Other, unknown (569/1640=35%) | The prevalence of moderate to severe pain was 51%, ranging from 43% (stomach) to 80% (gynecological). Wide intercenter differences (e.g., 10%-50% with severe pain).
Grond 1996 97020892 | Country: Germany Setting: pain service Specialty: anesthesiology; unclear if inpatient or outpatient | N=2266 (53% M, 47% F) Mean age: 59+/−13SD Symptoms: pain Sx duration: 9 years (1983-1992) Source of data: questionnaire by nurse or doctor | To evaluate the localization, etiologies, and pathophysiological mechanisms of cancer related pain syndromes. | GI (663/2266= 29%) Genitourinary (379/2266=17%) Head/neck (377/2266=17%) Breast (227/2266=10%) Lung (218/2266=10%) Lymphatic-hematopoetic (114/2266=5%) Skin, bone, connective (121/2266=5%) Others or multiple (167/2266=7%) | 30% 1 pain location 39% 2 pain location 31% 3 pain location Etiology: cancer 85% antineoplastic Tx 17% Type of pain: bone 35% soft tissue 45% visceral 33% neuropathic 34% Localization: lower back 36% abdominal 27% thorax 23% legs 21% head 17% pelvis 15%
Tasmuth 1996 97134848 | Country: Finland Setting: university hospital, surgical outpatient clinic Specialty: anesthesiology | N=93 (105 screened) Median age: 59 (29-85) and 57 (40-86) [two groups, mastectomy, resection] Symptoms: pain Sx duration: 1 year (1993-1994) Source of data: questionnaire by nurse or doctor | To assess pain, neurological symptoms, edema of the ipsilateral arm, depression, and anxiety in women treated with mastectomy or limited resection (plus axillary dissection for either), and the impact of these symptoms in daily life. | Breast (postmastectomy) | Incidence of pain before surgery: 36% (mastectomy) 23% (resection) After surgery: 26, 15, and 17% (1 month, 6 months, and 1 year postmastectomy) 28, 33, and 33% (postresection at same times)
Higginson 1997 97367049 | Country: UK, Ireland Setting: multidisciplinary palliative care centers (6 in England, 5 in London), in- and outpatients Specialty: palliative medicine and oncology (nursing with special training) | N=695 (55% M, 45% F [Irl], 54% M, 46% F [UK]) Median age: 67 (5-95) UK and 67 (32-90) Irl [two ethnic groups] Symptoms: pain Sx duration: not reported Source of data: questionnaire by nurse | To investigate the prevalence and intensity of pain in advanced cancer patients. | Lung/ENT (110/418=16.3% & 73/277=26%) GI (144/418=34% & 84/277=30%) Genitourinary (58/418=13.8% & 44/277=15.8%) Breast/bone (48/418=11.4% & 26/277=09.4%) Lymph/hematopoetic (13/418=3.1% & 10/277=3.6%) Other (45/418=10.8% & 40/277=14%)
  | UK | Ireland
  Lung/ENT | 69% | 74%
  GI | 68% | 68%
  Genitourinary | 66% | 84%
  Breast/bone | 71% | 85%
  Lymph/hemato | 62% | 90%
  Other | 62% | 63%
  Overall prevalence of pain at referral in the two settings was 68% and 74% (similar figures for home hospice patients as for hospitalized cancer patients).
Bernabei 1998 98296015 | Country: USA Setting: 1492 nursing homes Specialty: multiple | N=13,625 Age: >65 (65-74, 45% M) 65-84 (44% M) >85 (40% M) Symptoms: pain Sx duration: 1992-95 Source of data: Systematic Assessment of Geriatric drug use via Epidemiology database | To evaluate the adequacy of pain management in elderly and minority cancer patients admitted to nursing homes. | Not provided | 4003/13,625 (27.38%) reported daily pain. Age, gender, race, marital status, physical function, depression, and cognitive status were all independently associated with presence of pain. 26% of those in pain received no analgesic agent. Predictors for not receiving any analgesic agent despite daily pain were age >85, minority race, impaired cognition, and receiving multiple medications concurrently.
Ger 1998 98318902 | Country: Taiwan Setting: three outpatient oncology clinics Specialty: anesthesiology | N=296 (194 M, 66%, 102 F, 34%) 69% interviewed within 14 days from cancer diagnosis. Age: 56.4+/−16SD (10-80) Symptoms: pain Sx duration: 18 months Source of data: questionnaire | To evaluate the prevalence and severity of cancer pain in newly diagnosed cancer patients. | Lung (63/296=21%) Upper GI (58/296=20%) Colorectal (36/296=12%) Head/neck (29/296=10%) Other (76/296=36%) | 113/296 (38%) had pain Of those, 92% cancer related, 5% treatment related, 3% both cancer and treatment related. Ethnic minority status, lower-grade insurance status, excellent prior pain tolerance, impaired function status (ECOG scale), and distant spread of disease each separately predicted the presence of pain.

Abbreviations: Met -- metastatic. Non-met-nonmetastatic. GI-gastrointestinal. Sx-Symptoms. Tx -- therapy. WHO -- World Health Organization.

1 Medline or unique identifying number assigned by EPC.

Evidence Table 2 - NSAIDs: Randomized Controlled Trials in Cancer Pain

Author, year identifier | Treatment(s) studied, dose, route | Number of study arms | Study design (crossover, cohort, etc) | Method of randomization | Blinding | Total number enrolled (evaluable) | Mean age or range (% male) | Type(s) of cancer | Baseline pain severity | Type of pain ^1^ | Chronicity of pain (range or average) | Source of pain ^2^ | Exclusion criteria | Rescue medication (all arms) | Outcomes assessed | Outcome scales | Outcomes | Comments
Fuccella 1975 75129886 | Single-dose oral indoprofen (100 mg or 200 mg) vs. placebo. Study duration = 6 hrs. | 3 | Crossover | Random allocation list | Double-blind | 58 (36) | Median 55 (19-75) (58%) | Lung 33% Breast 19% Stomach 6% Liver metastases 6% Oral 6% Myeloma 3% Lumbar compression 19% Trigeminal neuralgia 6% Herpes zoster 3% | About 2.5 to 2.6 on 0 to 3 scale (information presented on graph only) | Not stated | Not stated | Cancer or neuropathic pain (lumbar radiculopathy, trigeminol neuralgia, herpes zoster) | Not stated | None | Pain intensity Pain relief Patient preference Time to full pain relief (if within 6 hrs post-drug) and number of patients in whom this occurred. | Descriptive 4-point (0-3) scores. Peak and summed both intensity difference (SPID) and total pain relief (TOTPAR). | Indoprofen superior to placebo for 6 hrs, in a dose-dependent fashion. | 10 of 36 patients had pain due to lumbar root compression from disc or spondylosis, trigeminal neuralgia, and herpes zoster.
Ventafridda 1975 75129887 | Single-dose oral indoprofen 100 mg or 200 mg; aspirin 600 mg or 1000 mg; or placebo. Study duration = 6 hrs. | 5 | Parallel | Not stated | Double-blind | 24 | 60 (34-71) (33%) | Lung 25% Breast 8% Uterus and ovary 16% Gastrointestinal 16% | About 3.5 on 5-point (0-4) scale | Not stated | Not stated | Cancer | Not stated | Not stated | Pain relief, side effects noted | 5-point (0-4) scales for intensity, relief, TOTPAR, SPID | Both doses of indoprofen and the higher dose of aspirin decreased pain intensity and provided pain relief. | It is unclear what the study did.
Martino 1978 79255834 | Single-dose oral indoprofen (200 mg) vs. naproxen (250 mg). No placebo group. Study duration = 8 hrs. | 2 | Crossover (each patient received both drugs an average of 29 hrs apart) | Not stated | Double-blind | 18 | 57.5 (33-82) (67%) | Lung 17% Uterus/cervix 11% Breast 17% Rectum 11% Larynx 17% Other 28% | 3.28 and 3.33 for indoprofen and naproxen, respectively, on 0-4 scale | Not stated | Not stated | Cancer | Not stated | Not stated | Pain intensity, pain relief, time of maximal pain relief. Adverse reactions noted. | 5-point (0-4) verbal scales | Both treatments equally effective with similar duration of pain relief and maximal pain relief within 2 hrs.
Sacchetti 1984 84207536 | Single-dose intravenous ketoprofen (100 mg or 400 mg) or lysine acetylsalicylate (1 gm). No placebo group. Study duration = 6 hrs. | 3 | Crossover (balanced incomplete block design in which each patient received two of three test treatments on two consecutive mornings) | Not stated | Double-blind | 36 | Median 61.5 (41-70) (53%) | Breast 31% Lung 14% Colon 8% Head / neck 6% Prostate 6% Bone Marrow 6% Other 8% Unknown 22% | 3.4 to 3.7 ± 0.10 on 0-4 pain severity scale. Severe (3) = 50% of subjects Very severe (4) = 50% of subjects | Not stated | Not stated | Bone metastasis | History of bleeding episodes, overt or suspected peptic ulcer, severe kidney or liver function impairment, concomitant treatments liable to interfere with the study drugs, terminal stage of disease, prior treatment with narcotics, age <18 or > 70 | Not stated | Severity of pain, pain relief, patient preference, side effects. | Pain severity: 5-point (0-4) verbal scale Pain relief: 10 cm VAS | All three treatments decreased pain intensity 50% by 2 hrs. Ketoprofen 400 mg was most effective, and longest acting.
Weingart 1985 85125751 | Single-dose oral ibuprofen (400 mg qid) or placebo, added to constant, 2 two-point scheduled opioid regimen. Study duration = 9 days, 3 days per arm. | 2 | Two-point crossover (crossed on day 4 to alternate treatment and day 7 to initial treatment) | Random number tables | Double-blind | 14 (10) | 55.3 (39-67) (50%) | Breast 20% Colon/rectum 20% Uterine/cervix 30% Lung 10% Bladder 10% Melanoma 10% | 44.4 ± 26.4 (range 5.6-96.5) on 0 to 100 VAS. Mean injectable morphine equivalent daily intake = 31 ± 17.6 mg (12-70 mg) | Not stated | Mean 55.3 months (range 4-240 months) | Bone metastases | Age < 16 or > 70, ibuprofen allergy, impaired hepatic, renal, hematological function (including coagulation), requirement for injectable opioids, active peptic ulcer disease, concurrent invasive pain therapies (cordotomy, hypophysectomy, radiation), TENS unit, potentially interfering medications. Concurrent chemotherapy allowed. | Not stated | Pain relief, nausea, depression, daytime drowsiness, nighttime sleeplessness. | VAS (0-100) | Ibuprofen was superior to placebo. Among 8 of 10 who had greater relief with ibuprofen than placebo, overall improvement in analgesia averaged 39% (range, 3%-76%) | All patients received oral opioids on an individualized basis, by their own physician. Compliance checked by tablet counts.
Epstein 1986 86312300 | Benzydamine hydrochloride rinse vs. placebo rinse, 15 ml for 30 seconds, qid Study duration = 3 weeks. | 2 | Parallel | Not stated | Double-blind, placebo control | 29 | 63.8 & 52.5 (36-80) (55%) | Oropharyngeal cancer: 24/29 with squamous cell carcinoma | Baseline pain 1.2 on VAS (VAS scale range or unit is not provided) | Oral mucositis due to radiation therapy | Not stated | External radiation: 4500 cGy in 15 fractions to 6000 cGy in 25 fractions | Age < 18, pregnancy, liver disease, hypersensitivity to benzydamine, inability or unwillingness to provide informal consent | Additional systemic analgesics (acetaminophen and codeine, 3 mg) or topical local anesthetics were administered "at the discretion of medical and/or dental staff when symptoms were present for > 24 hrs." | Signs and symptoms were recorded weekly by one observer on standardized forms. Symptoms recorded "with the aid of visual analog scales." | VAS (scale, range not provided) | Significantly lower pain ratings in benzydamine group than placebo. Fewer patients in benzydamine group required systemic analgesia, and had more discontinuance of topical viscous lidocaine. | Oral burning during rinse "probably" related to 10% alcohol content.
Turnbull 1986 88230041 | Single-dose oral naproxen (500 mg po bid) vs. aspirin 600 mg po q4h Study duration = 14 days, 7 days per arm. | 2 | Crossover | Not stated | "Blind" (unclear if single or double). Used "double-dummy" pills | 28 (23) | 65 (34-84) (54%) | Rectum/colon 34% Lung/bronchus 21% Other 45% | Not stated | Not stated | Not stated | Advanced malignant disease | Receiving highly protein-bound drugs, NSAIDs, or steroids within 6 weeks prior. | Not stated | Pain, severity | McGill Pain Questionnaire, 5-point (1-5) pain severity scale. (0-100 mm VAS = "linear analogue self-assessment", LASA) | Naproxen and aspirin "provided equal highly effective pain relief"
Levick 1988 89144615 | Naproxen sodium 2 capsules (275 mg each) every 8 hrs vs. naproxen 1 capsule (275 mg) plus identical placebo capsule every 8 hrs. Initial dose in both groups was 550 mg. Study duration = 3 days. | 2 | Parallel | Not stated | Double-blind | 145 (100) | 62 (19-81) (49%) | Not stated | > 40 mm on VAS (0-99 mm). Mean 58.8 (range 40-99) for all patients. | Not stated | Not stated | Bone metastases | Pregnant, lactating: other disease causing pain; NSAIDs; chemotherapy; radiotherapy; significant gastrointestinal, hepatic, renal diseases; hypersensitivity to aspirin, naproxen, codeine or any other NSAID, alcohol or drug abuse; peptic ulcer, anticoagulant at therapy in prior 4 weeks. | Other forms of pain management continued unchanged throughout the study ("electroanalgesia, acupuncture, alcohol etc.") However, no explicit description of rescue medication. | Pain intensity, by patients (for outpatients) and by physicians (inpatients), concomitant daily medications, adverse events | VAS (0-99) for pain intensity. PID (pain intensity difference from baseline) and SPID (sum of pain intensity differences) | Pain intensity scores decreased by one-third in both treatment groups. Global patient and physicians evaluation same for both. Patients with improvement reduction of pain intensity 6 hrs after the initial dose were considered responders, while those without improvement were considered nonresponders. Among responders, high-dose regimen more effective than the low-dose regimen. | Intergroup differences in adverse effects nonsignificant.
Staquet 1989 90094723 | Single-dose intramuscular ketorolac tromethamine 10, 30, 90 mg vs. placebo. Study duration = 6 hrs. | 4 | Parallel | Not stated | Double-blind | 126 (118) | Median age of 4 groups ranged from 57-69 (37%) | Not stated | Moderate to severe cancer pain | Not stated | "chronic" | Not stated | Pregnancy, nursing woman, alcoholics, drug addicts, intolerance to NSAIDs | Allowed, not specified | Pain intensity, pain relief, adverse events | Pain intensity with 4-point verbal scale, pain relief with 5-point verbal scale, global impression by patient and investigator; PID, SPID, TOTPAR | Ketorolac at each dose studied was superior to placebo | No difference in efficacy between 10, 30, and 80 mg doses of ketorolac. 10 of 15 observed with adverse events were after ketorolac.
Ventafridda 1990 90243070 | Oral naproxen 250 mg tid, diclofenac 100 mg bid, indomethacin 50 mg tid, ibuprofen 600 mg tid, suprofen 200 mg tid, pirprofen 400 mg tid, ASA 600 mg tid, sulindac 300 mg bid, paracetamol 500 mg tid. No placebo arm. Study duration = 2 weeks per arm, separated by 2-day drug-free period. | 9 | Within patient crossover; two drugs tested in each patient | Not stated | Double-blind, double-dummy | 65 (48 completed week 1, and 41 completed week 2) | 58 (40-65) (49%) | Not stated | Mean baseline values of 41 to 68 on a 100 mm VAS in the 9 drug groups tested | Not stated | Not stated | Cancer | Suspected hypersensitivity to NSAIDs, liver or renal dysfunction | Not stated | Pain relief, side effects | VAS 0-100 mm | "Naprosen, diclofenac, and indomethacin were highly effective in pain relief" and relatively well tolerated." However, while under treatment, mean path scores were <40/100 for all drugs tested and none appear different statistically. | Crossover design in which the second trial is susceptible to first trial effects, small numbers of patients, large proportions of dropouts with "insufficient analgesia" each week, and other uncontrolled confounders make this more like an observational study.
Ventafridda 1990 91151427 | Oral naproxen 550 mg bid vs. diclofenac 100 mg bid Study duration = 14 days. | 2 | Parallel | Not stated | Single-blind | 100 | 65 (49%) | Breast 12% Lung 12% Head/neck 5% GI 39% Male genitourinary 13% Female genitourinary 11% Others 8% | | Visceral N=61 Somatic N=62 (Some patients had more than 1 type); incident 13, static 76, incident & static 11, continuous 79, intermittent 21 | Not stated | Cancer | Neuropathic (deafferentation) pain, active or chronic GI diseases, coagulopathy | Next step of WHO ladder | Pain relief, side effects | Integrated score method (pain intensity and duration) weighted 5-category scale resulting in 0-240 points | Efficacy for both drugs was similar: both halved the integrated pain score during the 2 weeks, 55 patients were switched to second WHO step. (50 for ineffective analgesia, 9 for side effects, 6 for both). | 20 patients accrued from each of 5 centers.
Wool 1991 Cur Ther Res | Suppository of ketorolac 30 mg vs. diclofenac 100 mg suppositories. Study duration = 12 hrs. (single doses) | 2 | Parallel | Not stated | Single-blind | 60 | 70 (60%) | Intestine 18% Prostate 10% Kidney/bladder 12% Lung 18% Breast 12% Pancreas/liver 15% Other 15% | 2.5 on a 4-point (0 to 3) descriptive scale. ("Only patients reporting moderate or severe pain were eligible"). | Not stated | Not stated | Cancer | Severe acute gastrointestinal disease, severe uncontrolled renal, hepatic, endocrine, pulmonary, cardiac, neurologic, or cerebral impairment, salicylate or NSAID sensitivity, psychiatric diseases that could invalidate pain assessment | Second suppository, or (if breakthrough pain < 2 hrs) pentazocine | Pain severity, pain relief, physician and patient overall assessment, rescue analgesic requirement. | Pain severity and pain relief: (0 to 3) verbal rating scale | Both treatments were effective at reducing pain for 12 hrs. Ketoprofen produced statistically (but not clinically) better pain relief than diclofenac after hour 8. Physicians and patients were more likely to rate pain relief as excellent for ketorolac than for diclofenac. | Plastic treatment (chemo-, radio- or hormonal therapy) discontinued at least 1 week before entering study.
Gallucci 1992 93038986 | Oral nimesulide (200 mg q12 hr) vs. naproxen (500 mg q12 hr) Study duration = 14 days. | 2 | Parallel | Not stated | Double-blind | 68 (40) | 64.8 (32-82) (58.8%) | Head/neck 3/68 Gastrointestinal 27/68 Breast 8/68 Respiratory tract 11/68 Male genitourinary tract 10/68 Female genitourinary tract 4/68 Other 5/68 | Integrated pain intensity score was 40 and 50 of possible range (0-240) in the two groups at baseline, according to graph | Somatic 32/68, visceral 29/68, somatic and visceral 7/68. Static 35/68, incident 10/68, static and incident 22/68. | Not stated | Primary or metastatic cancer | Neurogenic or deafferentation pain, unconsciousness, severe hepatic or renal dysfunction, hypersensitivity to NSAIDs | Other NSAIDs or opioids were not used during the treatment period | Intensity of pain, occurrence of side effects | Pain severity and pain relief: (0 to 3) verbal rating scale | The integrated pain intensity score was reduced by 65% in the nimesulide and 70% in the naproxen group by 2 weeks. These were significantly lower than baseline but not different between groups | No significant differences between the two drugs in side effects. Pain scores are available only as a graph without standard errors. 22 and 18 patients in nimesulide and naproxen groups, respectively, required shifting to second step of WHO ladder.
Corli 1993 94102070 | Oral nimesulide (200 mg po bid), oral diclofenac (150 mg po bid), rectal nimesulide (400 mg qd), rectal diclofenac (200 mg qd). Study duration = 7 days. | 4 | Parallel | Not stated | Not stated | 64 | 66 (64%) | Lung 11/64 Breast 9/64 Colon/rectum 9/64 Stomach 8/64 Uterus/ovary 5/64 Prostate 4/64 Others 18/64 | Integrated intensity pain score of 30 to 35 (possible range 0-240), according to graph | Not stated | Not stated | Cancer, pain not previously treated | Previous treatment for cancer pain, impaired renal function, coagulopathy, history of gastropathy, NSAID intolerance | Not permitted | Integrated pain intensity score, sleep duration, adverse effects | Daily recording of intensity of pain times its intensity (0-240 range); sleep duration; adverse effects | No differences observed in efficacy between drugs and routes of administration when used as first step treatment of cancer pain; nimesulide was better tolerated by the GI tract | Pain score results available only as graphs; detailed table of adverse events provided.
Toscani 1993 94102071 | Oral nimesulide (200 mg bid) vs. naproxen (500 mg bid) Study duration = 2 weeks. | 2 | Parallel | Not stated | Double-blind | 68 (65) | 65 ±10 (59%) | Lung 11/68 GI 27/68 Breast 8/68 Male genitourinary 10/68 Female genitourinary 4/68 Head/neck 3/68 Others 5/68 | Integrated pain score of 40 to 50 (possible range 0-240), according to graph | Somatic 32/68 visceral 29/68 both 7/68. Resting 35, provoked 10, both 22. | Not stated | Primary cancer or metastases | Neuropathic pain, unconsciousness, severe hepatic or renal dysfunction, NSAID hypersensitivity | Not permitted | Integrated pain intensity score, side effects | Daily recording of intensity of pain times its intensity (0-3); side effect checklist | Analgesic efficacy and tolerability of the two drugs were both good and did not differ from each other | 4 and 6 patients in nimesulide and naproxen groups, respectively, dropped out due to GI side effect
Toscani 1994 94280461 | Oral ketorolac (10 mg q6h) vs. diclofenac (50 mg q8h) Study duration = 2 weeks. | 2 | Parallel | Not stated | Single-blind | 100 | 63 (39-75) (61%) | Lung 15%; Head and neck 15%; Colorectal 13%; Digestive tract 10%; Male genitourinary tract 9%; Breast 8%; Female genitourinary tract 7% | Unclear ("not yet treated accordingly to WHO guidelines"). 75 patients reported "much" or "very much" pain at baseline. Integrated pain score 40 (shown on graph). | Visceral 49, somatic 44, both 7. Static 53, incident 7, both 40. Continuous 74, intermittent 29. | Not stated | Cancer | Alcoholics, "dope addicts," psychiatric patients or "patients with severe mind alterations" concurrent or recent (<15 days prior) chemotherapy, patients already receiving opioids, NSAIDs, steroids | Progression to second WHO step (add weak opioids) | Integrated pain intensity score, side effects, hrs of sleep, hrs free of pain | Integrated pain score (pain intensity times duration possible range 0-240). | Integrated pain score declined to 10-20 range in both groups during study days 7-14 (by graph). 21 and 24 patients in ketorolac and declofenac groups, respectively, progressed to second WHO step by study day 14. | Detailed listing of side effects by drug and week. "Sleepiness" more common in diclofenac group.
Yalcin 1998 98196499 | Oral diflusinal (500 mg q12h) vs. dipyrone (500 mg q8h). Study duration = 7 days per arm separated by 2-day washout period. | 2 | Crossover | Not stated | Not blinded | 47 | 52 (18-69) (55.3%) | Breast 9/47 Lung 7/47 Colorectal 4/47 Stomach 6/47 Gall bladder 3/47 Head/neck 5/47 Sarcoma 2/47 Hypernephroma 2/47 Multiple myeloma 3/47 Pancreas 2/47 Various 4/47 | " VAS > 5". Baseline pain score 8.57+/−1.33 | Not stated, although anatomical sites of pain symptoms presented. | Not stated | Primary cancer (38%) or distant metastases (62%); of the latter, bone (12), lung (8), liver (4), lymph node (3), lung and bone (2). | Significant renal or liver impairment, GI malabsorption, hemorrhagic diathesis, intracranial metastasis, active peptic ulcer, history of long-term analgesic use. | Not stated | Pain, side effects were recorded | 10 point VAS (0-10 cm) | Dipyrone reduced VAS pain intensity than diflusinal (3.25+/−2.8 and vs. 4.65+/−3.1 respectively). No difference in side effects, which were "acceptable' with both diflunisal (17% incidence) and dipyrone (15%). | Data were also analyzed in three subgroups (metastatic, nonmetastatic, and bone metastatic). Dipyrone was less effective in all three groups than diflusinal but only statistically so in those with bone metastasis. No chemotherapy or radiotherapy was administered during the study.
Minotti 1998 98281411 | Single dose of ketorolac (10 mg or 30 mg intramuscular) or diclofenac (75 mg). Study duration = 6 hrs. | 3 | Parallel | Not stated | Double-blind | 180 | 59 ±11SD (73%) | Lung 59/180 Breast 21/180 GI 21/180 Bladder 9/180 Other 70/180 | Acute, moderate, or severe (60 ± 15 on 0-100 scale across the three treatment groups) | Nociceptive 128/180 Neuropathic 52/180 | At least 4 hrs (12 hrs if the patient was receiving long-acting analgesics) | "acute" cancer pain | Hypersensitivity to NSAIDs, history of active peptic ulcer or GI bleeding, concurrent analgesics, steroids, diphosphonates, calcitonin, and psychotropic drugs | Parenteral morphine | Pain intensity, pain relief, need for rescue medication within 1 hour after test drug administration. Spontaneously reported adverse reactions. | VAS for pain intensity 0-100 mm, 4-point (0-3) verbal scale for pain intensity; PID; summed PID; analog pain intensity difference (APID); summed APID; times to pain relief or study termination; global investigator and patient ratings. | No differences in any outcome between three treatment arms except true to first APID twice as long for diclofenac as for either dose of ketorolac. | 10 mg suggested as initial intramuscular ketorolac dose.

Abbreviations: q x hr= every x hrs.

1 Neuropathic, somatic, or visceral.

2 Cancer, sequel of treatment, or procedure related.

Evidence Table 3 - NSAID vs. Opioid (± NSAID): Randomized Controlled Trials in Cancer Pain

Author year, identifier | Treatment(s) studied, dose, route | Number of study arms | Study design (crossover, cohort, etc) | Method of Randomization | Blinding | Total number enrolled (evaluable) | Mean (±SD) age or range (% male) | Type(s) of cancer | Baseline pain severity | Type of pain ^1^ | Chronicity of pain (range or average) | Source of Pain ^2^ | Exclusion criteria | Rescue medication (all arms) | Outcomes assessed | Outcome scales | Outcomes | Comments
Moertel 1974 74251095 | Single oral doses of aspirin (650 mg) or combined with codeine (65 mg), oxycodone (9.76 mg), pentazocine (25 mg), caffeine (65 mg), pentobarbital (32 mg), promazine hydrochloride (25 mg), ethohepatazine (75 mg), vs. placebo alone. Study duration = 6 hrs after each dose, mean of 9 days to complete all testing with a minimum of 6 hrs between doses. | 10 | Each patient given a single dose of each study drug preparation or placebo in random sequence according to Latin-square method (10 square, each 10 x 10). | Not stated | Double-blind, placebo control | 100 | Not stated | Not stated | "Assumed to be related to intra-abdominal, retroperitoneal, pelvic or osseous malignant tumors"; mild to moderate. | Not stated | Not stated | Unresectable cancer | History of an allergic reaction to any of the study medications | Patients were not allowed any other analgesics, narcotics, sedatives, stimulants, antiemetics, antidepressants, tranquilizers, or alcoholic beverages during the study. | Patients were asked to record the time of administration, the time of onset of definite pain relief, and the time when pain returned. Patients recorded what percentage of pain was gone at the time of maximum pain relief. | No scale was used. The subjective maximum percentage of pain relief was reported by each patient, proportion of patients with > 50% pain relief also calculated. Relative efficacy of each drug preparation ranked by each patient. | Aspirin was superior to placebo. Aspirin plus codeine, pentazocine, or oxycodone were superior to aspirin alone. | Preliminary statistical analysis excluded drug sequence effects.
Martino 1976 77208209 | Three single-dose trials: Study duration = 6 hrs after each dose, next treatment given at unspecified time, "when pain made another treatment necessary." | 3 for each of the three trials | Parallel | Envelopes containing randomized treatment sequence; method of randomization not specified | Double-blind | 36, 12 subjects per 3-drug trial (each patient exposed to all 3 treatments within each trial). | 55.4±1.8 (63.8%) | Lung 8/36 Uterus 3/36 Lymphoma/leukemia 3/36 "Bone metastases" 4/36 Oropharyngeal 4/36 Breast 5/36 Rectum 4/36 Testicle 2/36 Other 3/36 | Severe to very severe. | Not stated | Not stated | Cancer/metastases | Not stated | No other treatment that could interfere with the results of the trials was given. No other exclusion criteria were stated. | Pain intensity and relief. Side effects. | 5-point descriptive scale for pain intensity: 0, no pain; 1, mild pain; 2, moderate pain; 3, severe pain; 4, very severe pain. Pain relief data not presented | Indoprofen (600 mg) was significantly more active than aspirin (600 mg); both were more effective than placebo. | It is unclear whether this is one or three studies.
  a) | Oral indoprofen (200 mg) vs. aspirin (600 mg) vs. placebo
  b) | Oral indoprofen (100 mg) vs. aspirin (1000 mg) vs. placebo
  c) | Intramuscular pentazocine (15 mg) vs. 30 mg vs. 60 mg.
Stambaugh 1980 80204844 | Two trials: | 3 for each study | Parallel | Randomized in six possible orders of drug administration in two Latin-square designs | Double-blind | 40 (37) single-dose study 170 repeated-dose study | 64 (54%) single-dose study and ∼59 (35.2%) repeated-dose study | Breast 61/170 GI 24/170 Lung 18/170 Gynecological 9/170 Hematopoietic 12/170 Other 46/170 [data from repeated-dose study] | Moderate to extremely severe for single-dose study, mild to severe for repeated-dose study. Mean baseline pain intensity score in single-dose study = 3 on a 5-point (0-4) scale and 2.07 in repeated-dose study | Not stated | Not stated | Cancer / metastases | Not stated for single-dose study. For repeated-dose study, patients on chemotherapy with unstable hematological status were excluded as were those "taking narcotic drugs in doses greater than usual recommended dose." | In single-dose study conventional analgesics given for inadequate pain relief after 2 hrs. Not specified in multidose study. | For single-dose study: pain intensity, pain relief, and derived variables SPID and TOTPAR (sum of pain intensity difference and sum pain relief, respectively). Not specifically stated for repeat dose study. Adverse reactions. | Pain intensity on a 5-point descriptive scale: none, mild, moderate, severe, or extremely severe, and pain relief on a 3-point scale (a little, some, a lot). | Pain intensity decline after all 3 pentazocine doses not statistically distinguishable but that of highest pentazocine dose "around that of 100 mg indoprofen by mouth." Single-dose study: no significant difference in any of the derived variables (SPID, TOTPAR, etc.) between zomepirac and oxycodone + APC. Repeat dose study oxycodone +APC was superior to both doses of zomepirac in pain relief and acceptability. | Oxycodone + APC=Percocet. Contains aspirin 224 mg, phenacetin 162 mg, caffeine 32 mg, oxycodone HCL 4.5 mg, oxycodone terephthalate 0.38 mg.
  a) | Single-dose study: zomepirac 100 mg vs. oxycodone + APC (Percodan ®) vs. placebo. Duration = 3 days (one study drug or placebo per day).
  b) | Repeated-dose study: zomepirac 50 mg vs. zomepirac 100 mg vs. oxycodone + APC (Percodan ®) every 4 hrs for 1 week
Stambaugh 1980 Cur Ther Res | Single-dose Tylox ® (acetaminophen 500 mg, oxycodone HCl 4.5 mg, oxycodone terephthalate 0.38 mg) po or Percodan ® (aspirin 224 mg, phenacetin 160 mg, caffeine 32 mg, oxycodone terephthalate 0.38 mg) or placebo Study duration = 6 hrs | 3 | 3-way crossover | Not stated, but study implemented via preassigned test drug sequences for each subject. | Double-blind, placebo control | 31 | 63 (44-82) (48%) | Not stated (39% had bone metastases). "None was terminal; all had adequate renal and hepatic function." | 2.6 to 2.8 on a 5-point (0-4) descriptive scale | Not stated | Not stated | Cancer | Addicted or not responsive to narcotics; receiving any agent that might confound assessment of analgesia; test preparation "contraindicated for any reason" | "Alternate analgesic therapy" if pain not relieved in 2 hrs. | Pain intensity, pain relief, global evaluation, adverse reactions | Pain: 5-point (0-4) descriptive scale. TOTPAR, SPID, peak pain intensity difference and peak pain relief. Global evaluation: 1 (poor) to 5 (excellent) | Tylox ® and Percodan ® were equally effective and significantly more effective than placebo. Few, minor adverse reactions. | 18 investigators in repeated-dose study.
Stambaugh 1981 82143186 | Single-dose oral zomepirac sodium 100 mg vs. oxycodone + APC (percodan ®) vs. placebo. Study duration = 6 hrs per drug administration. Usually (86%) 3 test drugs given on consecutive days. | 3 | Crossover | Not stated, but study implemented via preassigned test drug sequences for each subject. | Double-blind, placebo control | 40 (37) | 63 (36-87) (50%) | "Advanced malignancy either primary or metastatic to head and neck, thorax, abdomen, lower back, pelvis and extremities" | "Moderate to extremely severe chronic pain" | Not stated | "Chronic" | Cancer/ metastases | Not stated | "Conventional analgesic medication" if study medication did not provide sufficient pain relief within 2 hrs. | Pain relief, pain intensity, global evaluation, side effects. | 5-point (0-4) descriptive scales for pain relief and pain intensity. Curvilinear visual analog scale for pain intensity. Summed pain intensity, pain relief, peak pain intensity difference, peak pain relief. | All assessments demonstrated that zomepirac provided greater analgesia than oxycodone with APC, but no difference was significant. Zomepirac was consistently, significantly superior to placebo at all time points, while oxycodone with APC was superior to placebo between 1 and 3 hrs only. | 32 White, 5 Black subjects.
Stambaugh 1982a Cur Ther Res | Single-dose oral butorphanol (4 mg), acetaminophen (650 mg), combined butorphanol / acetaminophen (4 mg/650 mg) or placebo. Study duration = 6 hrs | 4 | Crossover | Not stated, but study implemented via preassigned test drug sequences for each subject. | Double-blind, placebo control | 29 (20) | 65.2 (45-86) (Not stated) | "Diverse" primary sites of cancer. Bone most common metastatic site in patients reporting pain in back and extremities. | 2.29 to 2.49 on a 0 to 4 descriptive scale | "Chronic" | Not stated | Metastatic cancer | Drug tolerance or addiction; hypersensitivity or contraindications to use of study drug | "An alternate analgesic" | Pain intensity, pain relief, global evaluation, side effects. | 5-point descriptive scales for pain intensity (0-4), and pain relief (0-4), and global evaluation (1-5). Summed pain intensity, pain relief, peak pain intensity difference, peak pain relief. | Butorphanol alone and acetaminophen alone each provided slightly and insignificantly better pain relief than placebo. Combination of butorphanol and acetaminophen was significantly better than placebo or butorphanol alone for 6 hrs of observation. | Sedation in 20% of patients given butorphanol alone or with acetaminophen.
Stambaugh 1982b Cur Ther Res | Single-dose oral zomepirac (100 mg or 200 mg) or intramuscular morphine (4 mg or 8 mg) Study duration = 6 hrs after each test drug; at least 1 day between test drugs. | 4 | Crossover | Latin square | Double-blind | 45 (40) | Not stated | Not stated | 2.75 to 2.80 on a 0 to 4 descriptive scale | Not stated | Not stated | Cancer | Compromised hepatic or renal function; history of ulcers; analgesic sensitivity; age < 18 years | Not stated, but "subjects could withdraw from the study at any time." | Pain relief, pain intensity, global evaluation, side effects. | 5-point descriptive scales for pain intensity (0-4), pain relief (0-4), global evaluation (1-5). Summed pain intensity, pain relief, peak pain intensity difference, peak pain relief. | 100 mg and 200 mg doses of zomepirac were equivalent. Zomepirac was more effective than morphine 4 mg and equivalent to morphine 8 mg. | Equivalent results for all 3 levels of baseline pain (moderate, moderate-severe, and extremely severe). Similar adverse effect profile except that lethargy more common after morphine.
Stambaugh 1983 84129666 | Single-dose intramuscular meperidine (50 mg) or hydroxyzine (100 mg) or meperidine (50 mg) with hydroxyzine (100 mg) or saline placebo. Study duration = 6 hrs after each test drug; one drug tested each day for 4 days. | 4 | Crossover | Not stated | Double-blind, placebo control | 30 | 58 (45-80) (Not stated) | Not stated | 3.4 to 3.7 (scale not stated) | Not stated | "Chronic" | Cancer | Severe hepatic, renal or cardiac disease; decompensated diabetes; advanced pulmonary disease; chronic barbiturates or other known enzyme inducers; monoamine oxidase inhibitor therapy | Not stated | Pain intensity, pain relief, global acceptability, side effects. | Pain intensity: curvilinear VAS (scale not stated) Pain relief: not stated but graphs show 0-4 Acceptability: verbal scale from poor to excellent | Meperidine and hydroxyzine equally effective during first 2 hrs. Hydroxyzine provided pain relief for 6 hrs but effectiveness of meperidine began to wane after 2 hrs. Hydroxyzine significantly more effective than placebo over the 6 hrs studied. Meperidine more effective than placebo only for first 3 to 5 hrs. Combination meperidine and hydroxyzine produced additive analgesia only during the first 2 hrs. | "Addition of meperidine to hydroxyzine does not justify the added toxicity of the narcotic." Pharmacokinetic studies suggested threshold serum levels of 0.10 mg/ml and 60 ng/ml for analgesia from meperidine and hydroxyzine, respectively.
Ferrer-Brechner 1984 84277729 | Methadone 2.5 mg or 5 mg qd placebo or ibuprofen (600 mg) for 4 days | 4 | Crossover | Not stated | Double-blind | 30 (28) | 31-74 | 83% stage IV and 63% had > 3 sites of metastasis | "Moderate to severe" | Not stated | Not stated | Cancer | Intolerance to methadone or NSAID | Not stated | Pain intensity, pain relief, side effects. | Visual analog mood scale 16 cm, multiple pain ratings: severity, descriptive | Addition of ibuprofen increase analgesia after a single dose, without increasing side effects or changing mood levels | 1-day crossover periods weaken the validity of the results
Tonachella 1985 Cur Ther Res | Twice-daily intramuscular doses of diclofenac sodium (75 mg) vs. pentazocine (30 mg) Study duration = 8 days, test drugs given in two successive 3-day periods, preceded and separated by 1-day placebo washouts. | 2 | Crossover | Not stated | Double-blind, placebo control | 20 (16) | 60.1(±9) (90%) | Not stated | "Moderate to severe" | Bone pain prevalence 20% and 50% in pentazocine-diclofenac and diclofenac-pentazocine treatment sequence groups, respectively. | Not stated | Metastatic or nonmetastatic cancer/ | Not stated | Not stated | Pain intensity (with duration), pain relief by patient, and global evaluation of analgesic efficacy (by physician). | Integrated pain score based on intensity and duration: 1=pain absent, 12=continuous and severe pain. Pain relief and global analgesic efficacy assessed according to a 4-point scale. | Each drug significantly reduced pain intensity baseline (p<0.01). There was a significantly greater reduction of pain in the diclofenac periods compared with pentazocine periods (p < 0.047). | Recommend reclassification of injectable NSAIDs such as diclofenac and indomethacin from "mild" to "potent" analgesics since their efficacy "is similar to or better than that of weak narcotics"
Stambaugh 1987a 88059744 | Single oral doses of ciramadol (30 mg or 90 mg) vs. codeine (60 mg) vs. placebo. Study duration = 6 hrs after each study medication, no more than one test per day. Total duration not specified. | 4 | Crossover | Not stated | Double-blind | 43 (40) | 62 (19-84) (44%) | Not stated | Moderate to severe | Not stated | 0-24 months (mean, 2 months) | "Attributable to primary or metastatic malignancy" | Significant hepatic, renal, or cardiac disease, active peptic ulcer. "Tranquilizers, analgesic, or anti-inflammatory agents" withheld for 6 hrs after, and 4 hrs before, medication. | | Pain relief, pain intensity, global evaluation, side effects | 6-point pain relief scale, 100 mm VAS pain intensity scale, 4-point global evaluation | Ciramadol 30 mg and codeine 60 mg provide equally superior analgesic efficacy to placebo; ciramadol 90 mg was superior to both other active treatments. | Ciramadol is an opioid agonistis-antagonist
Stambaugh 1988b 89063812 | Oral ibuprofen (60 mg qid) vs. placebo in addition to stable as-needed doses of oxycodone (52 mg) / acetaminophen (325 mg) Study duration = 7 days. | 2 | Parallel | Not stated | Double-blind | 64 (30) | 18 - 80 | Not stated | 2 moderate, 13 severe in ibuprofen group; 6 moderate, 9 severe in placebo group | Bone pain due to metastatic cancer | "Chronic" | Bone metastases | Recent or concurrent gastric disease, drug allergies to oxycodone, acetaminophen, or NSAIDs, or medically unstable | "Alternate parenteral analgesic," but patients dropped from the study if > 1 dose required in 24 hrs. | Pain relief, side effects, oxycodone acetaminophen intake, subjects and investigator global evaluations, adverse effects. | Global rating 1-5: 1 (excellent), 5 (poor). | Ibuprofen reduced the need for oxycodone / acetaminophen. 5 days required for maximal dose-reduction effect. | 88% of patients were White, 12% Black. Outcome scales poorly described. Two and 3 black patients in ibuprofen and placebo groups, respectively. "Because of delayed [dose-sparing ibuprofen] effect, it would appear that repeat dose studies of NSAIDs are necessary to yield more complete efficacy information that cannot be obtained from single dose data…and provide [more useful] toxicity information."
Sunshine 1988 89214773 | Single-dose oral ketoprofen (75 mg or 225 mg) vs. intramuscular morphine (5 mg or 10 mg) Study duration = 6 hrs after each test. Each drug given as need. Total or average duration of enrollment not specified. | 4 | Parallel | Not stated | Double-blind (each patient received three capsules and an injection) | 123 (all) | Not stated | Not stated | Moderate to severe (2 to 3 respectively on a 0-3 scale | Not stated | Not stated | Cancer | " Allergic sensitivities to any of the study medications; any complicating illness; history of drug abuse" (criteria refer globally to 5 single-dose studies reported in 1 paper, of which 1 study examined "chronic cancer pain"). | Not stated | Pain relief, pain intensity, global evaluation, side effects. | Pain intensity = 0-3, pain relief = 0-4 (0 = none, 1 = a little, 2 = some, 3 = a lot, 4 = complete). Derived measures: PID, SPID, or TOTPAR | No significant differences were observed between morphine (either dose) and ketoprofen (either dose). Pooled ketoprofen results superior to pooled morphine results. | Study was terminated due to poor patient enrollment. Authors state that these results "do not permit a reliable estimate of relative potency, but suggest that ketoprofen is superior to morphine at the doses studied." Four other single-dose studies in postpartum and postoperative pain reported in same paper.
Stambaugh 1988a 89214771 | Single oral dose of ketoprofen (100 mg or 300 mg) vs. aspirin + codeine (650 mg+ 60 mg) vs. placebo. Study duration = 6 hrs after each dose. Each test drug dose given as needed for cancer pain, but no sooner than 4 hrs after last prior NSAID, analgesic, sedative, or psychoactive agent. Total or average duration of enrollment not specified. | 4 | Parallel | Not stated | Double-blind, placebo control | 160 (not provided) | 61.7 (±10.1) (57%) | Not stated | Moderate to severe (2 to 3 respectively), for all patients, mean values in treatment groups 2.3-2.4 (no SD reported for baseline pain intensity) | Not stated | Not stated | "Primary or metastatic cancer" | Pregnant, breast feeding; hypersensitivity to salicylates; NSAIDs or opiates; serious cardiac, liver, or renal impairment; history of alcohol or drug abuse; receiving radiotherapy at the pain site | "Remedication" presumably but not explicitly with another dose of test drug. Those remedicating within first hour of receiving test drug were replaced; those doing so afterward were assigned their baseline pain intensity score and "no relief" for remaining evaluations. | Pain relief, pain intensity, onset of pain relief, time to peak relief, time to remedication, global evaluations of the drug (by patients) and patient response (by observer), adverse events. | Pain intensity = 0-3, pain relief = 0-4, reduction of baseline pain (0=0%, 1=25%, 2=50%, 3=75%,4=100%). Measures of analgesia derived from pain scores = PID, SPID, peak PID, TOTPAR, time to remedication, 3-point patient response (poor, fair, good) category. | No significant differences were observed among active treatments for any of the derived parameters. Proportion of patients requiring rescue analgenics greatest for both ketoprofen groups, but aspirin + codeine group not significantly different from placebo. | Ketoprofen as effective as aspirin plus codeine.
Puglisi 1989 Cur Ther Res | Pirprofen (600 mg rectal capsule) vs. pentazocine (65.78 mg, suppository) vs. placebo rectal capsule. Study duration = 2 hrs. | 3 | Parallel | Not stated | Double-blind, placebo control | 45 (40) | 61.2 (±8.1) (34-79) (73.3%) | Not stated | >40 mm (VAS 0-100 mm) | Localization of pain: Chest 24/45 Lower limbs 8/45 Breast 3/45 Upper limbs 7/45 Spinal column 3/45 | 5.3±4.2 days | "Bone metastases and infiltration or compression of the nervous structures" | Pain associated with cancer therapy (surgery, chemotherapy, radiation); chronic pain existing before the diagnosis of cancer; peptic ulcer; ulcerative colitis or other relevant gastroenteropathies; severe hepatic, renal, cardiac, respiratory failure; hypertension; hypersensitivity to NSAIDs; NSAID administration during previous 3 days. | "A second administration of the same drug" was offered "if pain did not decrease satisfactorily within 2 hrs," and pain intensity then assessed for another 2-hour period. | Pain relief, side effects, treatment efficacy by investigator, patient satisfaction | VAS (0-100 mm) pain intensity | Investigator and patient global evaluations favored the two active treatments. No difference was observed between the two active treatments, but both decreased pain intensity significantly more than placebo.
Minotti 1989 89144649 | Oral diclofenac (50 mg), nefopam (60 mg), or aspirin + codeine (640 mg + 60 mg), all given qid Study duration = 10 days. | 3 | Parallel | Not stated | Double-blind, double-dummy | 99 (only 26 of 99 completed all 10 days) | 60±10 (all 3 groups pooled) (63%) | Lung 33% Breast 20% Gastrointestinal 14% Metastases in 85%, half of these to bone. | Moderate to severe (>40 mm on a 100 mm VAS) on 2 occasions. Pooled for 3 groups intensity was 60±10. | Not stated | Not stated | Not stated | Abnormal liver or renal function; history of peptic ulcer or gastrointestinal bleeding; impaired cerebral function; totally bedridden; concurrent chemo- or radiotherapy; concurrent treatment with antidepressants, anti-inflammatory agents, "or other drugs able to influence analgesia." | "Failures in diclofenac or nefopam groups treated" under open conditions with aspirin + codeine if they "had not responded to therapy within 2 days." | Pain relief, side effects, investigator's global rating, pre- and poststudy blood count, platelet count, serum creatinine, duration of patient's participation in study. | VAS (0-100 mm) for pain intensity, 4-point (1-4) descriptive scale for global efficacy. | Mean time in the study was 4.65 out of intended 10 days, due to inefficacy and side effects. Nefopam-treated patients left study earlier. 3 regimens have similar efficacy, but diclofenac may have a slightly better safety profile. | Only 26% of patients completed treatment.
Carlson 1990 90318896 | Oral ketorolac tromethamine (10 mg) vs. acetaminophen plus codeine (600 mg + 60 mg) vs. placebo. Six hrs later, placebo group then re-randomized to receive one of the other two drugs. Study duration = 7 days. | 3 | Parallel | Not stated | Double-blind | 75 (70 for efficacy, 74 for safety) | 62 (30-88) (75%) | "19 types" (no specifics): most common were genitourinary, lung, breast, gastrointestinal | Moderate to severe | Not stated | At least 1 week | Bone metastases 60% Direct tumor infiltration 21% Postsurgical 13% Post-chemo/radiotherapy 5% | Mild pain; <18 years old; opioid intake within 4-6 hrs of study initiation; concomitant treatment with potentially confounding medications (e.g., benzodiazepines); known coagulopathy; pregnant or nursing; medical condition that might interfere with absorption or metabolism of study medication. | Not permitted (once randomized to first two arms). | Pain intensity, adverse events, patient global evaluation of medication. | 4-point pain intensity scale (0-3), SPID, TOTPAR. | Both active treatments were superior to placebo and equally effective in singe-dose phase of trial. Acetaminophen plus codeine provided slightly superior pain relief than ketorolac, and was associated with fewer side effects in multidose phase. | Trial carried out across 9 institutions.
Estape 1990 91032539 | Oral ketorolac (10 mg) vs. pentazocine (50 mg), both given every 6 hrs. Study duration = 7 days. | 2 | Parallel | Not stated | Double-blind | 40 (40) | 52 (34-71) (50%) | Not stated | Moderate to extreme pain; mean pain score at baseline: ∼3.2 on a 0 to 4 scale (from graph) | Not stated | Not stated | 60% had bone metastases | Impaired brain, liver, kidney, heart, or lung function; abnormal endocrine function; gastric or duodenal ulcer; history of asthma, allergy to NSAIDs; hypersensitivity to pentazocine; addiction to alcohol or other drugs; pregnant or nursing. | Acetaminophen (paracetamol, 500-1000 mg) available but not within the first 2 hrs of the initial dose of the study medication. | Pain intensity, pain relief, global ratings by patients and investigators, adverse reactions. | 5-point scales for pain severity and pain relief (0-4). | No differences between the two groups with respect to pain severity, pain relief rescue medication. More patients withdrew from the pentazocine group than from the other group, mainly due to nausea and/or vomiting.
Bjorkman 1993 93170354 | Diclofenac (50 mg) or placebo rectal suppository tid added to intravenous morphine via patient-controlled analgesia. Study duration = 5 days, after stabilization of PCA morphine dose for at least 2 days. Two days per study arm, separated by single-blind placebo washout day. | 2 | Crossover | Not stated | Double-blind | 16 (15) | 63.0±11.3 (44-78) (50%) | Pulmonary (various) 75% Mesothelioma 12%. | Severe, patients already on morphine preenrollment. Average VAS score (0-100 scale) was 36.5±7.3 during PCA morphine run-in period | Mostly somatic | Not stated, but prestudy mean duration of morphine therapy was 7 days (range 1-318). | "Bone metastases or skeletal involvement" in 11 of 16 patients. | Uncooperative; unstable or progressive cancer pain; asthma; intolerance to morphine or NSAIDs; active ulcer disease; anticoagulant therapy | Not stated | Pain relief, morphine consumption, side effects | VAS 0-100 mm | Mean response to addition of diclofenac appeared greater (41.4%) in 4 patients without bone metastasis than in 11 patients with bone metastasis (18.6%). Diclofenac lowered daily morphine requirement by 10%, while also decreasing pain intensity by 26%. The former effect reached statistical significance (p > 0.01) while the latter did not (p = 0.09 vs. placebo).
Staquet 1993 Cur Ther Res | Single oral dose of piroxicam (40 mg), codeine (60 mg), or piroxicam with codeine (20 mg + 30 mg). Study duration = 6 hrs after each dose. | 3 | Parallel | Not stated | Double-blind | 90 (88) | 64±10 for all groups pooled (66%) | Lung 24% Breast 19% Head/neck 13% Unknown primary 13% Prostate 10% Other 22% | 60% "moderate" 40% "severe" | Not stated | Not stated | Cancer: 31 of 88 patients had bone metastases | Age < 18 or > 80; pregnant or nursing; aspirin allergy; addiction to alcohol or other drugs; unable or unwilling to cooperate. | "Rescue analgesics," otherwise unspecified. | Pain intensity, pain relief, patient and observer global evaluation, side effects | 5-point (0-4) scales for pain intensity and pain relief; 4-point (0-3) scales for global evaluation, SPID. | All three treatments equally effective, with peak effectiveness 3 hrs after administration. | Placebo control not allowed by hospital's ethical committee. Patient sample heterogeneous and study power low (0.36).
Rodriguez 1994 94361852 | Oral dipyrone (1 or 2 gm every 8 hrs) or morphine (10 mg every 4 hrs). Study duration = 7 days. | 3 | Parallel | Not stated | Double-blind, double-dummy (patients in dipyrone groups received 3 placebo doses per day to preserve blinding) | 179 (121) | 60±10 for all groups pooled (69%) | Lung 28/121 Breast 10/121 Bowel 11/121 Mouth 10/121 Larynx 7/121 Bladder 7/121 Endometrium 7/121 & others | Mean 83 on 0-100 VAS | "Visceral and somatic pain present in most patients" | Not stated | Cancer | Age < 18; other causes of pain; gastric disorders; inadequate mental status for analgesic efficacy evaluation; concurrent adjuvant, radio- or chemotherapy; brain or liver metastases; hypersensitivity to study medications; severe underlying disease; pregnancy. | Acetaminophen (paracetamol 300 mg) plus codeine 15 mg | Pain intensity and relief, side effects | VAS (0-100 mm) | Dipyrone 2 gm q8h is comparable to morphine 10 mg q4h. A lesser effect was found for dipyrone 1gm q8h. Dipyrone appears to be better tolerated.
Chary 1994 95052963 | Controlled-release codeine (Codeine contin, 100 mg, 200 mg, or 300 mg) every 12 hrs vs. acetaminophen plus codeine (600 mg +/ 60 mg) every 6 hrs. Study duration = 4 days. | 4 | Parallel | Not stated | Double-blind, double-dummy | 24 | 65.1±13.5 (63%) | Lung 6/24 Breast 5/24 Colorectal 6/24 Prostate 4/24 Others 3/24 | Moderate to severe. Mean 59.7±14.5 on 0-100 VAS | Not stated | Not stated | Not stated | Not stated | Not stated | Pain intensity, pain relief, side effects. | 10 cm VAS, 5-point ordinal scales for pain intensity and pain relief. 3-point scale for "the extent to which medication bothered them" and 4-point scale for each of 9 specific adverse events. SPID, TOTPAR. | 200 mg and 300 mg doses of controlled-release codeine were most efficacious. By interpolation, 150 mg dose of controlled-release codeine q12h approximately equivalent, in terms of efficacy and side effects, to acetaminophen plus codeine (600 mg + 60 mg), q4-6 hour.
Dellemijn 1994 95092369 | Oral naproxen (500 mg tid) vs. controlled-release morphine (MS Contin, 30 mg bid). Study duration = 14 days, 7 days per arm. | 2 | Crossover | Not stated | Double-blind, double-dummy (placebo tablets given to maintain dual dosing schedules) | 20 (16) | 42-81 (50%) | Breast 7/20 Rectal 3/20 Lung 3/20 Others 7/20 | 82 on an VAS scale of 0-100 points | Neuropathic pain only | Less than 4 weeks in duration | Tumor involvement of nerve root or lumbar or brachial plexus | Intolerance to NSAIDs or morphine; history of peptic ulcer; use of corticosteroids or anticoagulants; diabetes mellitus; active or recent hormone, chemo-, or radiotherapy. | Acetaminophen (paracetamol) 500 mg up to 8 times per day for pain. Also given domperidone 60 mg suppositories up to 4 times per day for nausea, and sachets of psyllium seeds for constipation. | Pain intensity relief; and of rescue medications; side effects; overall evaluation; use of acetaminophen, domperidone and psyllium; preference between drugs. | VAS 0-100 mm for pain intensity, 6-point (0-5) scale for pain relief, 4-point severity scale for side effects. | Pain reduction and rescue acetaminophen intake after 1 week of naproxen, but not controlled-release morphine, significantly less than baseline. One patient developed renal failure on naproxen. | Well-characterized neuropathic pain. Data support the concept of a nociceptive component in malignant nerve pain responding to both NSAIDs and opioids, favoring their coadministration.
Bosek 1994 95161866 | Intravenous ketorolac 5 mg/ml vs. morphine 1mg/ml, both given as 1 ml bolus on demand using patient-controlled analgesia devices. Study duration = 48 hrs, following initial control of pain in Post Anesthesia Care Unit (PACU). | 2 | Parallel | Not stated | Double-blind | 92 (70) | 60±15 for both groups pooled (ketorolac group 8 years older than morphine group) (69%) | Abdominal or soft tissue operations | Not stated | Acute postoperative pain | Not applicable | Postoperative pain in cancer patients | History of peptic ulcer disease; bleeding problems; impaired kidney function; intolerance to study medications; already receiving narcotics or NSAIDs. | Intramuscular morphine (0.1 mg/kg) offered q6h | Pain relief, side effects, amounts of study medication and supplemental morphine used. | VAS (0-100 mm) for pain and sedation | Comparable pain scores between both groups. Ketorolac supplemented with morphine associated with lower incidence of nausea, vomiting, and pruritus than morphine alone. | "Some patients received up to 100 mg loading dose" of ketorolac in PACU, but "no adverse reactions were observed."
Minotti 1998 98179049 | Oral diclofenac (50 mg, qid) vs. diclofenac with codeine (50 + 40 mg, qid) vs. diclofenac (50 mg qid) with imipramine (10 mg, for age > 65 or 25 mg, for age < 65, tid) Study duration = 7 days. | 3 | Parallel | Not stated | Double-blind | 184 (180) | 61±10 for all 3 groups pooled (65%) | Nonreported | Moderate to severe pain (at least 40 mm on a 100 mm VAS) | Nociceptive somatic 116/184, nociceptive visceral 23/184, neuropathic 45/184 | At least 10 days | Moderate or severe pain due to cancer | History of active peptic ulcer disease; concurrent analgesics, corticosteroids, or psychotropic drugs; cardiovascular diseases, chemotherapy, or radiotherapy within prior 20 days; impaired renal or hepatic function or depressed platelet count; epilepsy; glaucoma; prostatic hypertrophy. | Not stated. However, patients failing to achieve 50% pain reduction or VAS pain intensity < 40 on 0-100 scale by day 4 were termed "nonresponders," dropped from the trial, and given "more appropriate analgesic therapy." | Pain intensity and relief, depression severity, investigator global evaluation of efficacy and tolerability. | Pain intensity VAS (0-100 mm). 4-point global evaluation scale (1 = satisfactory, 2 = moderate, 3 = good, 4 = excellent) Hamilton depression rating scale | Short-term administration of imipramine or codeine provided equivalent analgesia to diclofenac alone. Depression severity not different between treatment groups "at the end"; unclear if poststudy values differed from prestudy. | Suggested that the WHO second analgesic step is less optimal than adding a "strong" opioid when pain is no longer relieved with NSAIDs. However, relatively low dose of codeine was used in this study, which also lacked sensitivity because all 3 groups improved.

Abbreviations: q x hr=every x hrs. qid=four times per day. tid=three times per day.

1 Neuropathic, somatic, or visceral.

2 Cancer, sequel of treatment, or procedure related.

Evidence Table 4 - Opioid vs. Opioid: Randomized Controlled Trials in Cancer Pain

Author, year, identifier | Treatment(s) studied, dose, route | Number of study arms | Study design (crossover, cohort, etc) | Method of Randomization | Blinding | Total number enrolled (evaluable) | Mean (±SD) age or range (% male) | Type(s) of cancer | Baseline pain severity | Type of pain ^1^ | Chronicity of pain (range or average) | Source of Pain ^2^ | Exclusion criteria | Rescue medication (all arms) | Outcomes assessed | Outcome scales | Outcomes | Comments
Twycross 1976 77185960 | Oral morphine vs. oral diamorphine "equivalent." Study duration = 2 weeks, 1 week for dosage stabilization and 2 days testing of each drug in the second week. Two-day tests separated by 1 day. | 2 | Crossover | Not stated | Not stated | 699 (89) ^3^ | 66.5 median (44.7%) | Not stated | Not stated | Not stated | Not stated | Cancer | Not stated | Both arms were receiving cocaine 10 mg elixir and a phenothiazine (chlorpromazine) | Pain intensity, sleep, appetite, nausea, and mood | VAS (0-100 mm) | Only patients with unchanged doses for prior-5 days were compared (n=89). "No over-all clinical difference between diamorphine and morphine." | No statistical methods are applied. Provides concise historical overview of cancer pain trials.
Staquet 1980 80156120 | Ciramadol (opioid agonist-antagonist, 20 mg or 60 mg) vs. placebo orally | 3 | Parallel | Not stated | Double-blind | 15 (15) | 29-70 | Not stated | Moderate to severe pain for the last 3 days (rating on a 4-point scale) | Not stated | Not stated | Cancer | Large doses of narcotics; insufficient mental clarity; GI, renal, or hepatic disease. | Not stated | Pain intensity | 4-point verbal scale | Ciramadol produced significantly more pain relief than placebo in a dose-dependent fashion. No side effects were reported.
Ventafridda 1983 83256803 | Buprenorphine 0.2-0.4 mg sublingual q6-8h vs. pentazocine 50-100 mg orally q6-8h Study duration = 2 weeks, 1 week per drug. | 2 | Crossover (two 7-day periods but no washout period) | Not stated | Not stated | 86 (60) | 35-79 (70%) | Lung 15 Rectum 11 Breast 9 Others 25 | 7.2 ± 0.5 (buprenorphine group) 8.1 ± 0.4 (pentazocine group) | Not stated | Not stated | "Neoplastic origin" | Serious renal/hepatic insufficiency; serious respiratory insufficiency; chronic treatment with analgesic agonists in high doses; persistent mental confusion; increased intracranial pressure; pregnancy | Removed from trial | Pain intensity, side effects, hrs of sleep/standing/sitting/lying | VAS, daily integrated score (possible range 0-240) | Buprenorphine superior to pentazocine after 7 days of treatment: mean integrated pain score 32 and 51.3, respectively (p<0.01)
Ventafridda 1986 87059284 | Oral morphine vs. oral methadone. Study duration = 14 days. | 2 | Parallel | Not stated | Not stated | 66 (54) | 59.5 (morphine group) (57%) | Head/neck 13 Lung 14 Breast 10 Colon 6 Others 11 | Pain requiring strong opioids after NSAID and weak opioid trials | Not stated | Not stated | "Advanced cancer pain" | Not stated | Not stated | Pain intensity, side effects, daily dosage, performance status | 5-category verbal pain score integrated across the number of hrs per day (range 0-240) | No significant differences in efficacy and side effects of the two treatments. | The mean daily methadone dosage remained constant (18 mg) over the study period of 14 days, whereas average morphine dosage increased by 64% over mean initial dosage (73 mg mean initial dosage).
Pasqualucci 1987 87288547 | Single doses of epidural buprenorphine (0.3 mg) vs. epidural morphine (3 mg), studied for 18 hrs after a single dose | 2 | Parallel | Not stated | Not stated | 12 | 45-78 (75%) | Lung 8 Others 4 | "Severe continuous, nonincident pain (5 cm out of 10 cm VAS pain scale) that did not respond to NSAID" | Not stated | Not stated | "Continuous, nonincident pain" | Not stated | NA | Pain intensity | VAS numerical rating scale, simple descriptive scale | Similar analgesic efficacy for both drugs (no actual data reported); both decreased pain intensity from starting values | Statistically but not clinically significant respiratory effects seen only in the buprenorphine group.
Stambaugh 1987b 87274551 | Intramuscular dezocine (10 mg) vs. butorphanol (2 mg) vs. placebo (single and repeated doses). Study duration = one dose, then 7 days. | 3 | Parallel | Numeric randomization schedule using a Latin-square design | Double-blind | 60 | 60 (36-84) (40%) | Not stated | Moderate 26/60 Severe or "very severe"34/60 | Visceral 12/60 Bone 43/60 Others 5/60 | 1.9 months (range 1-24 months) | Not stated | Clinically significant cardiac, hepatic, or renal diseases; active radiotherapy to pain site; potential opioid tolerance; hypersensitivity to butorphanol (structurally similar to dezocine) | Either a standard analgesic or an additional dose of the same study medication | Pain intensity, global evaluation of efficacy, side effect | 4-point verbal global efficacy evaluation; (0-100 mm) analog pain intensity scores; 3-point pain relief scale | Single dose: peak analgesia for dezocine and butorphanol was similar. Multiple doses: dezocine was superior to butorphanol in terms of duration of benefit. Dezocine has less toxicity than butorphanol after both single and multiple doses. | Experimental design to compare single dose and multiple doses proposed as a more generalizable one. Psychotomimetic reactions in 9 of 20 subjects who received 2 mg butorphanol.
Hanks 1987 88021688 | Controlled-release morphine (MS Contin) q12h vs. oral morphine solution q4h. Study duration = 4 days, 2 days per arm, after at least 7 days stabilization on oral morphine solution. | 2 | Crossover | Not stated | Double-blind, double-dummy | 27 (18) | 70 (53-82) (39%) | Breast 6 Colon 2 Others 9 | "Pain requiring opioids" (but see comments) | Not stated | Not stated | Not stated | Fluctuating opioid requirement in week prior to study; "too ill or confused" | Not stated | Pain intensity, side effects, sleep, appetite | 10 cm VAS for pain and side effects, 5-point global pain scale recorded by nurse and patient | No difference in terms of efficacy, adverse effects between regimens, or nurse or patient preference for either morphine formulation. 17 of 18 patients chose to continue the controlled-release opioid after conclusion of the study. | Initial pain intensity seemed high in both study arms (80-85/100), despite prestudy "steady state" maintenance. 50% dropout rate.
Bruera 1988 88317010 | Patient-controlled subcutaneous hydromorphone vs. continuous subcutaneous infusion. Study duration = 6 days, 3 days per arm. | 2 | Crossover (3-day period) | Not stated | Open | 25 | No ages specified (83%) | Gastrointestinal 7 Breast 5 Hematologic 4 Others 6 | "Need for parenteral narcotics" | Visceral 11 Somatic 7 Neuropathic 4 | Not stated | Advanced cancer | Brain metastases, confusional syndromes, history of alcoholism or drug dependence | "Extra doses" as needed, each equivalent to 2 hrs of hydromorphone infusion | Pain intensity, side effects, number of hrs of sleep, medication usage, total daily drug dosage, and breakthrough dose requirement | 100 mm VAS for pain and side effects | Both methods had similar effectiveness and side effects in short-term hospital use. More rescue doses given during continuous than patient-controlled infusions. | One patient developed sepsis while on self-injection, one patient developed bowel obstruction while on continuous infusion, one patient developed organic brain syndrome and died while on continuous infusion.
Thirlwell 1989 89248820 | Controlled-release morphine (MS Contin) q12h vs. oral morphine solution q4h. Study duration = 10 days, 5 days per arm. | 2 | Crossover | Not stated | Double-blind, double-dummy | 28 (23) | 58 (±12) (57%) | Lung 7 Colon 3 Bladder 3 Others 10 | "Requires opioids" | Not stated | Not stated | Not stated | Hepatic or renal impairment, severe nausea or vomiting, uncontrolled pain requiring frequent parenteral morphine, chemotherapy or radiotherapy scheduled within 7 days | Open-label of morphine solution at unspecified strength | Pain intensity, side effects, rescue dose requirement, plasma morphine levels | McGill Present Pain Intensity (PPI) scale; 4-point side effects scale | No significant differences between controlled-release or morphine solution in pain scores or side effects. | No between-group differences in peak or minimum plasma morphine concentrations, although nearly 3 times longer to each maximum concentration after one dose of controlled-release morphine than morphine solution.
Portenoy 1989 89248821 | One controlled-release (MS Contin) tablet 100 mg vs. three 30 mg controlled-release (MS Contin) tablets q12h x 3 days, after 1-day stabilization period on immediate-release oral morphine (20 mg q4h) | 2 | Parallel | Not stated | Double-blind | 51 (49) | 53 (57%) | "Wide variety of tumor types, …most metastatic" | "Inadequate control of pain on an oral opioid regimen generally used for moderate pain" | Not stated | Not stated | Not stated | All children or adults with severely compromised renal, pulmonary, hepatic, or gastrointestinal function. | 15 mg immediate-release oral morphine q2h prn | Pain intensity, side effects, number of rescue doses | 5-point categorical scale for pain intensity and side effects | Comparable analgesic efficacy and side effects for one 100 mg or three 30 mg controlled-release tablets. | Pain intensity declined and total daily morphine dose increased after transition from immediate- to controlled-release morphine at start of study.
Goughnour 1989 89248823 | Controlled-release morphine (MS Contin, q12h) vs. oral morphine solution q4hr. Study duration = 20 days, 10 days per arm. | 2 | Crossover | Not stated | Double-blind, double-dummy | 29 (17) | 63 (± 17) (71%) | Not stated | Chronic severe pain | Not stated | "Chronic" | Cancer in 14/17 patients | Widely fluctuating pain severity, prior pain control measures unsuccessful, intractable nausea or vomiting, scheduled to receive chemo- or radiotherapy | Oral morphine solution, each dose equal to one-sixth of the prestudy daily total analgesic dose | Pain intensity, supplemental morphine dose, side effects | 10 cm VAS pain intensity score, supplemental morphine requirement, 0-6 verbal severity scale for side effects | Controlled-release morphine q12h as effective as oral morphine solution q4h for pain control | Initial phase of study found no differences in efficacy between single doses of morphine solution and controlled-release tablets.
Grochow 1989 89385650 | Intravenous morphine vs. intravenous methadone, both given via patient-controlled analgesia device. One-eighth of the total opioid requirement given by patient-controlled analgesia every 15 min. Study duration = 5-6 days per arm. | 2 | Parallel | Not stated | Double-blind | 23 (18) | 53 (21-74) (50%) | Mixed: breast, cervix, lung, colorectal, others | Intractable cancer pain | Not stated, although site(s) of pain enumerated for each patient | Not stated | Cancer | Abnormal renal, hepatic, or pulmonary function; brain metastases; recent cancer treatments; altered mental status or suicidal ideation | None | Pain intensity, pain relief, side effects; opioid self-administration (doses, frequency) | McGill Present Pain Intensity index (0-4) | Pain intensity and relief were similar for both groups. Parenteral methadone does not offer a clinically significant increase in the duration of analgesia. | Mean self-dosing interval for both morphine and methadone was 3.9 hrs
Ferrell 1989 89331294 | Short-acting analgesics vs. controlled-release morphine (MS Contin) (no dosage information) | 2 concurrently randomized plus a third historical control group (equal numbers in all three groups) | Parallel | Not stated | Not stated | | | | | | | | Not stated | Not stated | Quality of life, including pain intensity and pain distress, on a 28-item "city of Kape Medoral Center Quality of Life Instrument" | Present Pain Intensity Scale of the McGill Pain Questionnaire; Karnofsky Performance Status Scale, City of Hope Quality of Life Survey | "Improved pain management with controlled-release morphine" by ANOVA on mean pain intensity, and pain distress and related items in 40 patients across four visits. Insufficient data on pain intensity outcome for meta-analysis (no standard errors). | The main purpose of this study was to apply the concept of quality of life as an outcome measure in a clinical analgesic trial.
Ventafridda 1989 89381485 | Controlled-release morphine (MS Contin) tablets vs. oral morphine solution (dosing not stated). Study duration = 14 days. | 2 | Parallel | Not stated | Not stated | | | | | | | | Not stated | Not stated | Pain intensity, drug dosage, side effects | Daily integrated pain score (5-point, possible range 0-240) | No significant difference between the two regimens in terms of efficacy or adverse effects, but there were fewer side effects with controlled-release morphine. | This report also described a concurrent open trial of controlled-release morphine in 113 patients.
Hoskin 1989 90087279 | Studied whether a loading dose is required when oral aqueous morphine is changed to controlled-release morphine tablets (MST Continus). Study duration--12 hrs after active or placebo "loading dose." | 2 | Parallel | Randomization code kept in pharmacy | Double-blind | 20 (19) | 67 (51-84) (Not stated) | Mixed: breast (5), lung (5), prostate (2), colorectal (2), others (5) | "Advanced cancer…require morphine" | Not stated | Most patients with <2 weeks on aqueous morphine | Cancer | Prognosis of < 4 weeks, total morphine dose > 800 mg daily, serum hemoglobin < 9g/L. | None | Pain intensity; side effects by patients and nurses, who also judged whether loading dose was active or placebo; serum morphine levels | VAS | Loading dose is not necessary when changing from aqueous to controlled-release tablets | Pharmacokinetic data showed no effect of a loading dose; 6 of 8 patients given placebo loading dose were thought by their nurses to have had morphine, and 6 of 10 given morphine were thought to have had placebo.
Kalso 1990 90263355 | Morphine vs. oxycodone intravenously via patient-controlled analgesia, then in oral formulations. Study duration = 8 days, 2 days in each arm for dosage titration via intravenous patient-controlled and then oral therapy. | 2 | Crossover | Not stated | Double-blind | 20 | 52 (22-75) (45%) | Metastatic cancer from breast (5), pancreas (4), colorectal (3), prostate (1), others (7) | "Severe cancer pain" | Nerve, visceral, bone, soft tissue | Not stated | Cancer | Not communicative, uncooperative, unable to tolerate oral medication | None | Pain severity, side effects (by questionnaire), quality of sleep | 0-10 VAS for pain, recommendation to other patients; Beck Depression Inventory, Symbol/Digit test; work recognition test; Williams Delayed small test. | Morphine and oxycodone effectively relieved cancer pain with both IV and oral administration. Average VAS of 7.6 before opioid titration decreased to 1.1 with opioids. Morphine caused more nausea and hallucination. | At the end of study, 5 patients preferred morphine, 5 preferred oxycodone, 10 had no preference
Gourlay 1991 92107537 | Intermittent bolus doses of morphine vs. continuous infusion, both administered epidurally. Study duration = 140 (range 28-378) days for bolus doses, 164 (range 6-537) days for continuous infusion. | 2 | Parallel | Not stated | Not blinded | 29 (28) | Age not stated (70%) | Not stated | "Optimized oral therapy with opioids and other adjuvant drugs could no longer provide effective analgesia without unacceptable side effects" | Not stated | Not stated | Not stated | Diabetes, severe respiratory disease, anticoagulant therapy | Not stated | Pain score, pain relief, side effects, patient recommendations, depression, neuropsychological function | VAS | No significant difference between regimens for pain control or side effects: both options "provided very good pain relief." No within- or between-group differences in depression or neuropsychological testing. | 10 patients (6 in infusion, 4 in bolus group) progressed to intrathecal drug delivery because of dosage escalation.
Moulin 1991 91124974 | Continuous subcutaneous vs. intravenous infusion of hydromorphone. Study duration = 4 days; 48 hrs per arm, after dose titration and optimization. | 2 | Crossover | Not stated | Double-blind, double-dummy (two infusion pumps) | 20 (15) | 61.9 (±11.8) (50%) | Breast 5 Lung 5 Gastrointestinal 4 Uringenital 2 Others 4 | "Poorly controlled" | Bone metastases 8 Soft tissue infiltration 8 Brachial plexopathy 2 Subacute bowel obstruction 2 | Not stated | Cancer | Brain metastases, metabolic encephalopathy | Morphine subcutaneous every 3 hrs at 50% of the equianalgesic dose of a 3 hr hydromorphone infusion | Pain intensity, pain relief, mood, sedation | 10 cm VAS | No clinical or statistical differences between the two routes. | Steady-state plasma hydromorphone concentrations were greater during intravenous than subcutaneous infusion
Hill 1992 93026543 | Alfentanil vs. morphine by pharmacokinetically based patient-controlled intravenous infusion system. Study duration = 4-14 days. | 2 | Parallel | Not stated | Single (patient) blind | 28 | 34.4 (±8.5) (67% alfentanil) 30.7 (±9.5) (63% morphine) | Various leukemias, mostly chronic myelogenous leukemia, treated with bone marrow transplant | "Typically severe" | Mucositis pain | 1-3 weeks of mucositis pain | Following bone marrow transplant | Not stated | Not applicable (study employed patient-controlled analgesia) | Daily pain intensity rating, VAS for side effects | 10 cm VAS | Alfentanil and morphine have similar efficacy in control of prolonged pain in BMT patients, but the utility of alfentanil in long-term pain management may be limited by relatively rapid development of tolerance | Primarily a pharmacokinetic study
Wilkinson 1992 93099680 | Rectal vs. oral administration sustained-release morphine. Study duration = 4 days, 2 days per arm. | 2 | Crossover | Not stated | Open | 11 (10) | median=70 (40-83) (60%) | Lung 3 Prostate 3 Breast 2 Myeloma 1 Adenoma, unknown 1 | Not stated | Not stated | Not stated | Not stated | Colorectal cancer or proctitis, creatinine clearance < 60ml/min, albumin < 30g/l, prothrombin ratio > 1.5 times normal | Oral acetaminophen (paracetamol) and/or oral meperidine, doses not specified (pethidine) | Pain intensity, side effects, patient preference; pharmacokinetic data | 10 cm VAS for pain intensity and side effects | No significant difference was noted between oral and rectal route with respect to pain or side effects. More patients preferred the oral route over the rectal route (8:1, plus 1 undecided) | Primarily a pharmaco-kinetics study: plasma levels of morphine and metabolites reached maximal levels more quickly after rectal dosing. Though plasma morphine levels were equivalent after oral and rectal dosing, the ratio of metabolites to morphine was lower for the rectal route.
Boureau 1992 93132421 | Controlled-release morphine suspension vs. controlled-released morphine tablets, each given q12h Study duration = 14 days, 7 days per arm. | 2 | Multicenter, crossover | 4-patient block randomization | Double-blind, double-dummy | 52 (44) | 61.6 (±11) (65%) | Ear, nose, throat 22/52 Breast 6/52 Gastrointestinal 10/52 Prostate 4/52 Uterus 3/52 Others 7/52 | Pain relieved by CRM at a daily dose of less than 400 mg/24hr | Nociceptive ("i.e., tissue lesion-related") | 11.2±14.8 months | Cancer | Neuropathic lesions, contraindication to opioids, recent radiation or chemotherapy, difficulty swallowing, inability to respond to questions, progression of underlying disease, antidepressant in prior 3 weeks, risk of poor compliance, NSAIDs or corticosteroids within prior week | Immediate-release morphine solution | Pain intensity, adverse effects, impact on activity, rescue medication, length and quality of sleep | 100 mm VAS for pain severity assessed tid, self-reported 5-point verbal rating scale, need for rescue doses of immediate-release morphine | No statistically significant differences in efficacy, adverse effects, or duration of action between the two groups. | "Results… especially relevant for patients with cancer pain who have difficulty swallowing."
Deschamps 1992 93132420 | Immediate-release morphine sulfate solution (q4h) vs. controlled-release morphine (q12h). Study duration = 14 days, 7 days per arm. | 2 | Crossover | Randomization table (by pharmaceutical company) | Double-blind, double-dummy | 20 (12) | 57 (40-72) (65%) | All metastatic; Lung 10/20 Breast 2/20 Gynecologic 2/20 Prostate 2/20 Others 4/20 | Site of pain tabulated for each individual patient "sufficient severity to warrant the use of opioids" | Somatic, visceral | Not reported | Cancer | Active anticancer therapy, receiving nondrug pain control (radiation, nerve block), unable to take oral medications, intolerant of morphine, or regularly requiring parenteral analgesics | Supplemental morphine sulfate solution. | Pain intensity, morphine consumption for breakthrough pain (percentage of daily dose of test drug), side effects (0-3 scale), patient preference | Present Pain Intensity scale (0-5) of the McGill Pain Questionnaire, plus 0-10 VAS for pain. Side effect index considered both intensity and duration of each side effect. | Differences in pain scores, side effects, and supplemental morphine requirement between the two groups were not significant. | No clear patient preference for either formulation.
Walsh 1992 98358029 | Oral morphine sulfate sustained-release tablets (q2h) vs. oral immediate-release morphine sulfate solution (q4h). Study duration = 6 days, 1 day to convert from prior regimen and stabilize on immediate-release morphine, 2 days for first arm, 3 days for second arm. | 2 | Crossover | Random number table (by pharmacist) | Double-blind, double-dummy | 33 (27) | 60.72 (±1.9) (44.4%) | Genitourinary 8/27 Breast 7/27 Lung 5/27 Colorectal 2/27 Other 5/27 | Not reported | Not reported | "Chronic" (no specifics) | Cancer | Consumed two or more parenteral morphine doses in the 24 hrs prior to baseline for breakthrough pain, unstable fluctuating pain, unable to take oral medication | Individualized: acetaminophen, immediate-release oral morphine, or "stat" morphine sulfate, intramuscular or subcutaneous | Pain intensity, anxiety, sedation, depression, nausea, constipation, confusion, patient preference. | 0-100 VAS for pain, side effects and depression | There was no significant difference with respect to pain, breakthrough pain frequency, depression, or side effects between the two formulations.
Finn 1993 93253444 | Oral morphine sulfate sustained-release tablets (q2h) vs. oral immediate-release morphine sulfate solution (q4h). Study duration = 6 days, 1 day to convert from prior regimen and stabilize on immediate-release morphine, 2 days for first arm, 3 days for second arm. | 2 | Crossover | Randomization schedule provided to responsible pharmacist at each of the 3 study sites | Double-blind, double-dummy | 37 (34) | 60 (±2) (26.5%) | Breast 9/37 Lung 7/37 Colorectal 4/37 Skin 4/37 Renal 3/37 Pancreas 2/37 Sarcoma 2/37 Cervix: all 2/37 Adrenal 1/37 Prostate 1/37 Scrotal 1/37 Unknown: all 1/37 | 24.5 ± 2.7 for both groups during baseline day (Day 1) | Not reported | "Chronic" (no specifics) | Cancer | Not reported | Individualized: acetaminophen, immediate-release oral morphine, or "stat" morphine sulfate, intramuscular or subcutaneous | Intensity of pain, incidence of sedation, nausea, anxiety, depression, breakthrough pain episodes. | VAS (by patient) for pain, depression, and side effects | The two treatments did not differ with respect to pain control, side effects, or frequency of breakthrough pain episodes. Prestudy nonopioid dosing regimens were continued.
Panich 1993 95096729 | Oral morphine slow-release tablet (MST, 10 or 30 mg q12h) vs. oral morphine sulfate solution (MSS, 5-10 mg q4h titrated upward to 7-day, table dosage. Study duration = 7 days per arm. | 2 | Crossover | Not stated | Blind (blinded single pair assessment by pair clinic nurse) | 73 (49) | 53 (±10.3) 43% | Neck 44.9% Face 16.3% Lower abdomen 10.2% Buttock 8.2% Leg 8.2% Back 6.1% Perineum 4.1% Breast 2% | 5.9 ± 1.3 on 0-10 self-report VAS, or 2.4 ± 0.5 on 0-3 nurse rating scale, (same for both groups) | Soft tissue 51.1% Soft tissue & nerve 22.4% Bone & soft tissue 26.5% | Not reported | Cancer | Unconsciousness or inability to speak. | "Paracetamol (acetaminophens) or narcotic injection as required" | Self-report of pain intensity, duration of sleep, nurse-assessed pain intensity | 0-10 VAS (by patient), 4-point ordinal pain scale by nurse (0-3) | Nurse-rated pain control was better for morphine but they also judged it less tolerated. The two treatments had equally significant benefit for pain and sleep duration. | MST was 15 times as costly as equianalgesic dose of MSS.
Wilder-Smith 1994 94242672 | Oral tramadol (50 mg starting dose) vs. oral morphine (16 mg starting dose) every 4 hrs, with upward titration based on breakthrough medication requirement. Each drug dose formulated as 20 drops of identical solution. Study duration = 8 days, 4 per arm | 2 | Crossover | Not stated | Double-blind | 25 (20) | 52 (26-74), 57 (31-75) for tramadol/morphine and morphine/tramadol groups, respectively. (55%) | Breast 8/20 Lung 6/20 Non-Hodgkin's lymphoma 2/20 Prostate, colon, stomach, melanoma each 1/20 | | Neural 15 Visceral 20 Osseous 20 (more than one type possible per patient) | > 3 months | Cancer | Inability to swallow; pulmonary, renal, or hepatic compromise; concomitant pain treatment; radiotherapy or chemotherapy | 20 drops of study drug | Intensity of pain, sedation, nausea, unspecified adverse effects | 5-point verbal scale (VRS) | Pain intensity was similar on the 4th day of study between morphine and tramadol There was a significantly lower incidence of side effects in the tramadol group, and constipation and nausea were less.
Cherny 1994 94247657 | Single intraventricular injections of morphine (8 and 16 mg) or heroin (4 or 8 mg), single oral doses, heroin (20 or 40 mg), "and/or single doses of another study drug" | 6 | Combined retrospective analysis of three unpublished and one partially reported twin crossover, two-dosage analgesic trials conducted in 1978-1982. | Not stated | No | 168 (all) patients who "together received 474 assessable drug administrations" | Median 52 (20-79) (47.6%) | Lung 26/168 Breast 25/168 Unknown primary 10/168 Sarcoma 8/168 Prostate 8/168 Bladder 8/168 Esophagus 8/168 Other 75/168 | "Relatively few" had severe or excruciating pain | Markers of drug administrations: Nociceptive pain component: 425 Nociceptive pain only: 205 Nociceptive & neuropathic pain: 220 Neuropathic pain only: 49 | Not reported | Cancer | Not reported | Not applicable: single-dose acute studies | Pain intensity and pain relief | TOTPAR summary score = "percentage of maximal possible pain relief represented in the area under the curve describing changes in the VAS pain relief vs. time." | TOTPAR score of patients with any neuropathic pain was significantly lower than that of patients with nociceptive pain only. TOTPAR greatest (28.0) for definite nociceptive pain alone, significantly less for possible/probable (22.9) or definitive (20.6) neuropathic pain alone. | Covariate analysis identified factors predictive of opioid responsiveness related to prior opioid therapy, Blood Urea Nitrogen BUN/creatinine ratio, and pain mechanism, with purely nociceptive pain the most responsive.
Hays 1994 94363641 | Immediate-release hydromorphone q4h vs. controlled-release hydromorphone q12h. Study duration = 14 days, 7 days per arm | 2 | Crossover, after 3-day stabilization on immediate-release hydromorphone. | Not stated | Double-blind, double-dummy | 48 (44) | 57.1(±13.6) (42%) | Breast 20% Colorectal 14% Lung 13% Urologic 8.8% Prostate 6.6% Leukemia 4.4% Other 33.2% | Not reported | Bone or soft tissue 45% Visceral 16% Mixed neuropathic 34% Neuropathic 2% Unknown 2% | Not reported | Cancer | Hypersensitivity to opioids, intolerance to hydromorphone, medical or surgical condition interfering with GI absorption, concurrent use of opioids, intractable nausea or vomiting | Immediate-release hydromorphone (10% of the total daily hydromorphone dose) | Pain intensity, nausea, sedation, and spontaneously reported or investigator-recorded adverse events | VAS (0-100) for pain, nausea and sedation, ordinal 6-point Present Pain Intensity scale of McGill Pain Questionnaire | VAS and ordinal pain intensity scores, rescue analgesic consumption, sedation, and nausea did not differ between dosage groups, nor in the proportions of patients and investigators expressing treatment preference.
DeConno 1995 95222298 | Oral vs. rectal (microenema) morphine, 10 mg. Study duration = 4 days, 2 days per arm. | 2 | Crossover | Not stated | Double-blind, double-dummy | 34 (all) | 57.12 (±8.8) (23%) | Lung 38.2% Breast 26.5% Prostate 8.8% Head/neck 2.9% Other types 23.6% | Not reported | Somatic 55.9% Visceral 5.9% Neuropathic 2.9% Mixed neuropathic 26.5% Somatic+visceral 8.9% | Not reported, though all patients had advanced or metastatic cancer and were treated as first-time outpatients. | Cancer | Pain intensity <30 mm on 0-100 VAS, previous opioids, active radiation or chemotherapy | Not reported | Raw and percentage differences from starting values of pain intensity for 3 hrs after a single dose. Pain, nausea and sedation, number of vomiting episodes | VAS | The onset of pain relief was more rapid and its duration was prolonged after morphine administration. There was no difference in sedation, nausea or number of vomiting episodes between anal and rectal routes.
Bruera 1995 95271279 | Controlled-release morphine suppository (MS-CRS every 12 hrs) vs. subcutaneous morphine every 4 hrs. Study duration = 8 days (crossover on day 5) | 2 | Crossover | Not stated | Double-blind, double-dummy | 30 (23) | 64.0 (±2) (56%) | Lung 7/23 Prostate 4/23 Head/neck 4/23 Other 8/23 | Not reported | Bone or soft tissue pain 32% Visceral pain 49% Neuropathic and non-neuropathic 14% Neuropathic 5% | Not reported | Cancer | Hypersensitivity to opioids, intolerance to codeine or acetaminophen, concurrent use of opioids, intractable nausea/vomiting | Subcutaneous morphine (10% of total daily dose) | Pain intensity, nausea and sedation, other adverse events. | 0-100 VAS, 6-point ordinal scale (the Present Pain Intensity scale of the McGill Pain Questionnaire). | There was a small but significant difference in favor of MS-CRS in overall ordinal pain intensity scores, but there were no significant differences in overall VAS pain scores, sedation, nausea, or consumption of rescue analgesics. | 17 of 23 patients who completed the study requested to continue long-term, open-label treatment with MS-CRS.
Mignault 1995 96045260 | Oral controlled-release morphine, (MS Contin) q8h vs. q12h. Study duration = 5 days per arm. | 2 | Crossover | Not stated | Double-blind | 27 (19) | 57.2 (±7.5) (Not stated) | Not reported | "Moderate or severe" | Not reported | Not reported | Cancer | Concurrent chemotherapy or radiotherapy | Oral morphine solution | Pain intensity, pain relief, rescue analgesic intake, side effects, and global pain control. | 0-10 VAS for pain intensity and relief, 4-point global rating scale (1-4), 4-point side effects scale (0-3). | Treatment schedules were not significantly different with respect to pain intensity, pain relief, and global efficacy scores. The requirement for supplemental medication did not differ between the two schedules.
Dhaliwal 1995 96135506 | Oral controlled-release codeine (q12hr) vs. placebo, 7 days per arm. | 2 | Crossover | Not stated | Double-blind | 35 (30) | 64.4 (±9.8) (56%) | Not reported | Not reported | Bone pain 60%, soft tissue pain 33%, neuropathic pain 33%, visceral pain 17%, steady pain 53%, incident pain 37%, lancinating pain 10% | Not reported, but prior opioid use averaged 15.4 ± 23.5 months | Cancer | Hypersensitivity to opioids, intolerance to codeine or acetaminophen, concurrent use of other opioids, intractable nausea or vomiting, drug or alcohol abuse | Oral tablets of 300 mg acetaminophen plus 30 mg codeine, 1-2 tablets every 4 hrs as needed. | Pain intensity, adverse experiences, rescue analgesic use, functioning, patient and investigator preference. | VAS, pain disability index | Controlled-release codeine treatment resulted in significantly lower overall VAS pain intensity, categorical pain intensity, pain scores, and consumption of rescue analgesic than placebo. Nausea and somnolence were more likely with active treatment than with placebo.
Bruera 1996 96208853 | Oral immediate-release hydromorphone vs. oral slow-release hydromorphone. Study duration = 10 days (crossover on day 6). | 2 | Crossover | Not stated | Double-blind, double-dummy | 95(75) | 62 (±12) (48%) | Lung 15/75 Prostate 17/75 Breast 14/75 Colorectal 9/75 Genitourinary 20/75 | No baseline scores provided | Not reported | Not reported | Cancer | Recent anticancer therapy (except hormones), physical or mental inability to answer questions and comply with protocol, opioid hypersensitivity, impaired renal or hepatic function, impaired ventilatory function (dyspnea at rest), current use of an investigational drug, pregnancy or lactation | Immediate-release hydromorphone tablets | Pain intensity, global assessment, adverse effects | VAS and ordinal scale (0 none, 3 severe) for pain, 5-point verbal rating scale of global evaluation, VAS for adverse effects | Pain intensity, number of rescue doses of hydromorphone and total daily dose, global drug rating, and final blinded choice between immediate- and slow-release dosage forms by both patients and investigators did not differ, nor did side effects. | 73 of 75 (97%) patients chose to enter an open-label follow-up study of slow-release hydromorphone after completion of the double-blind phase.
Kalso 1996 97109660 | Continuous infusion plus patient-controlled morphine by the epidural route vs. the subcutaneous route, 48 hrs per arm | 2 | Crossover | Not stated | Double-blind | 10 | 22-75 (40%) | Colon/anus 2/10 Breast 3/10 Pancreas 1/10 Kidney 1/10 Other 3/10 | Estimated (from figure) 35 at rest, 70 with movement on 0-100 VAS | Neuropathic 7/10 Visceral 1/10 Neuropathic visceral 1/10 Neuropathic & bone 1/10 | Not reported | Cancer | Not reported | As needed, individualized bolus doses of morphine via patient-controlled analgesia | Pain intensity at rest and with movement, adverse effects | VAS (0-100) for all outcomes | Both epidural and subcutaneous administration were significantly more effective and produced fewer side effects than baseline oral morphine, but did not differ from each other in effectiveness or acceptability. | Morphine consumption and plasma levels of morphine and 3-glucuronides were significantly higher during subcutaneous than epidural administration.
Ahmedzai 1997 97328940 | Transdermal fentanyl every 3 days vs. oral controlled-release morphine (MST, q12h), for 15 days per arm | 2 | Crossover | Not stated | Open label | 202 (trial completed by 50 of 101 in fentanyl/morphine group, 60 of 101 in morphine/fentanyl group) | 61.5 (18-89) (55%) | Not reported | No baseline scores provided | Not reported | Not reported | Cancer | Life expectancy < 1 month or unable to complete assessments | Immediate-release morphine IRM tablets | Quality-of-Life Assessment | Quality-of-life assessments using WHO scale and EORTC QLQ-C30 questionnaire, and pain and mood using Memorial Pain Assessment Card. Data on VAS pain scores assessed as area under the curve. | No significant between-group differences or change from baseline on WHO and EORTC scales or pain relief measures. More patients preferred the fentanyl patch. Fentanyl was associated with less constipation and daytime drowsiness but shorter and more disturbed sleep. | Carryover, phase, and drug effects assessed using Mann-Whitney U test.
Broomhead 1997 97405392 | Controlled-release morphine capsules (Kadian/Kapanol q12hr or q24hr) or controlled-release tablets (MS Contin, q12hr) or placebo. Study duration = 7 days. | 4 | Parallel | Not stated | Double-blind, double-dummy | 169 (152) | 61 (56%) | Primary or metastatic sites in lung, bone, breast, liver, colon, prostate, and kidney accounted for 75% of cancer sites | No baseline scores provided | Not reported | Not reported | Cancer | Concurrent chemotherapy or radiotherapy, changing hormone therapy, ECOG performance status>3, clinically significant laboratory abnormalities, impaired bowel mobility, intractable vomiting or respiratory depression, inability to swallow capsules, hypersensitivity to opioids, other contraindications to morphine treatment, previous Kadian or Kapanol, pregnancy, lactation, or risk of pregnancy. | Immediate-release morphine tablets (one-eighth the total daily dose) | Primary measures of efficacy: elapsed time to remedication, total amount of rescue medication. Secondary measures of efficacy: daily VAS of pain intensity in prior for last 24 hrs, quality of sleep, pain intensity on the final day, and patient and investigator global assessment. | 0-100 VAS for pain intensity and 4-point verbal rating scales of pain control, pain intensity, sleep quality, global assessments. | Patients in all three study arms experienced similar results for efficacy, safety, and adverse effects. Patients rated treatment "good" or "very good" more often for Kadian/Kapanol q24h (89%) than for Kadian/Kapanol q12h (76%) or MSC q12h (68%). | Primary outcome measures selected as adequately differentiating between active and placebo treatment. Patients rated treatment "good" or "very good"
Heiskanen 1997 98074866 | Controlled-release oxycodone vs. controlled-release morphine, 3-6 days per arm. | 2 | Crossover | Computer-generated randomization | Double-blind, after open-label titration for up to 21 days | 45 (27) | 39-76 (59%) | Breast 2/27 Rectum 5/27 Esophagus 1/27 Unknown 2/27 Lung 4/27 Pancreas 4/27 Prostate 6/27 Kidney 1/27 Pleura 1/27 Ovary 1/27 | No baseline scores provided | Not reported | 2 weeks - 10 years, 8 months | Cancer | Radiation therapy or other cancer treatment that would affect the amount of pain | One-sixth to one-eighth of respective controlled-release medication given as oral solution. NSAIDs continued in 18 of 27 who used them prestudy. | Pain intensity, acceptability of therapy, escape analgesic use | Verbal and visual analog (0-100) scales of pain intensity, Modified Specific Drug Effect Questionnaires completed by patient and investigator. | When both periods of study were combined, patients in the oxycodone group required more escape medication doses and experienced greater pain intensity than those in the morphine group. Adverse effects were similar in both groups but vomiting was more frequent with oxycodone and constipation more common with morphine. | Dose ratio of oxycodone to morphine set at 2:3 apriori to utilize available tablet strengths. Daily telephone contact between patients and investigator. Pharmacokinetics results reported separately.
O'Brien 1997 98179695 | Once-daily controlled-release morphine capsules (MXL 60 mg) vs. 12-hr controlled-release morphine tablets (MST continuous, 30 mg twice daily) "at least 5 days" per arm. | 2 | Crossover | Not stated | Double-blind, double-dummy | 85 (69 completed both treatment periods) | 64.3 (Not stated) | Breast 14/85 Lung 14/85 Prostate 10/85 Colon/rectum 9/85 Ovary 3/85 Spine 3/85 Other 32/85 | No baseline pain scores provided | Not reported | | Cancer | MAO inhibitor therapy, sensitivity to opioids, clinically significant respiratory depression, severe obstructive airway disease, renal or hepatic impairment, unstable analgesic maintenance requirement. | "Normal release" morphine tablets (Sevredol) | Pain intensity (0-10 Likert VAS, the "BS-11"), time and dose of escape medication, number of pain-related nocturnal awakenings, adverse events (3-point scale) | BS-11 | Both treatments equally well-tolerated and effective. No difference between preparations in terms of patient preference. | Thirteen of 16 withdrawals not related to study and not different between groups.
  Over 5 years: | 9
  1-5 years: | 44
  3-12 months: | 24
  1-3 months: | 8
Farrar 1998 98213107 | Oral transmucosal fentanyl citrate (OTFC) (200 mcg to as high as 1600 mcg) vs. placebo for 10 breakthrough pain episodes. | 2 | Parallel | Not stated | Double-blind, placebo-controlled | 92 (72) | 53 (±11) (45.8%) | Breast 18/72 Lung 14/72 Colon/rectal 11/72 Uterine 6/72 Solid tumor 14/72 Hematologic 1/72 Other 8/72 | "Relatively stable" pain that required at least 60 mg/day morphine or 50 mcg/hr transdermal fentanyl. No other information is provided on baseline pain intensity. | Somatic 38/72 Visceral 22/72 Neuropathic 11/72 Unknown 1/72 | Not reported | Cancer (breakthrough pain) | History of psychiatric disease, drug abuse, or oral, hepatic, renal, or cognitive disease | OTFC or (unspecified) "previous nonstudy breakthrough medication" | Pain intensity (0-10), VAS pain relief (4-point) global performance evaluation (4-point); patient decision to take additional breakthrough pain medicine (yes/no) | VAS 0-4 and 0-10 scales | OTFC produced significantly greater changes in pain intensity and better pain relief than placebo at all time points (15-60 min). Placebo group required rescue medication significantly more often than OTFC group. | No consistent relationship between prestudy rescue medication dose and OTFC dose required. Novel trial methodology applicable to other breakthrough medication studies. High (66%) incidence of placebo response.
Wong 1997 97355997 | Transdermal fentanyl patch applied to torso every 3 days vs. Controlled-release oral morphine (MST) q12h, for 14 days. | 2 | Parallel, after stabilization phase with immediate-release morphine | Not stated | Open label | 47 (40, i.e., 20 per group) | 58.2 (±10.4)(MST) 60.7 (±12.8)(TDF) (72.5%) | Head/neck 9/40 Liver 6/40 Cervix 5/40 Pancreas 4/40 Lung 3/40 Kidney 3/40 Bladder 3/40 Other 7/40 | Baseline VAS (0-10 cm): 3.95±0.05 (MST) and 3.85±0.08 (TDF) | Somatic 18 (MST) or 18 (TDF) of 47 Visceral 7 (MST) or 8 (TDF) of 47 Deafferentation 6 (MST) or 7 (TDF) of 47 | Group 1 148 ± 156 days (14-545) Group 2 126 ± 133 days (10-485) | Directly related to Cancer or treatment 40/47 Additional reasons 14/47 | Narcotic abuse, allergy to opioids, CO2 retention, bilirubin or creatinine > 2 mg/dl, active skin disease precluding TDF use | Morphine hydrochloride immediate-release tablets | Pain intensity, pain frequency, degree of pain improvement, profile of mood state as affected by pain, quality of sleep, activity status, daily rescue dose of immediate-release morphine, patient satisfaction, treatment preference, side effects | 0-4 scale for all variables | There were no significant differences between study groups in analgesic efficacy or adverse effects. | Both TDF and MST "could be safe to offer effective analgesia."
Babul 1998 98259851 | Morphine sulfate controlled-release suppositories (MSC-R) q12h vs. Morphine sulfate controlled-release oral tablets (MSC-T) q12h, for 7 days each. | 2 | Crossover | Not stated | Double-blind, double-dummy | 27 (22) | 55.1 (±2.1) (59%) | Breast 10/22 Lung 7/22 Esophagus 2/22 Pharynx 1/22 Appendix 1/22 Bone 1/22 | Not stated, though day 1 (of 7) pain intensity 27.2 (MSC-R) and 21.8 (MSC-T) on 0-100 VAS. | Bone or soft tissue 64% Visceral 18% Mixed neuropathic & nonneuropathic 9% Neuropathic 9% (according to Edmonton Staging System) | Not reported | Not reported | Hypersensitivity to opioid analgesics, intolerance to morphine, significant anorectal disease, concurrent use of other opioids | MSC-T | Pain intensity, rescue analgesic requirement, sedation, nausea (on 0-100 VAS) | VAS and PPI (McGill Pain Questionnaire) | There were no significant differences between MSC-R and MSC-T in overall scores for VAS pain intensity, ordinal pain intensity, and sedation. Mean nausea score was slightly (13±3 vs. 10±3) but significantly greater in the MSC-T group. | Equianalgesia observed for the two routes.
Mercadante 1998 98155409 | Dextropropoxyphene (120-240 mg/d) vs. controlled-release morphine (MS Contin, 10mg bid). Patients followed during the first 10 days on opioid therapy and during the last 4 weeks of life. | 2 | Parallel | Not stated | Not blinded | 32 | 68 (47-87) (50%) | Lung 7 Breast 6 Urogenital 6 Gastrointestinal 5 Liver/pancreas 5 Others 3 | No longer responsive to nonopioid drugs, pain>4 on 0-10 VAS | Neuropathic in 4 of 16 in dextropropoxyphene group, 5 of 16 in morphine group | Not stated | Not stated | Not stated | Switch to subcutaneous morphine | Days on each treatment before switching (and reason for switch), pain intensity, performance status, mean doses of opioids. | 10 cm VAS for pain intensity, 4-point (0-3) side effects scale and aggregate opioid-related symptom distress scale. | "Dextropropoxyphene therapy caused fewer side effects and provided similar pain scores than the lowest doses of commercially available slow-release morphine. Stresses the role of "weak" opioids during the induction of opioid therapy in opioid-naïve cancer patients with pain. | NSAIDs continued if not contraindicated (chiefly ketoprofen).

NA = Not applicable

1 Neuropathic, somatic, or visceral.

2 Cancer, sequel of treatment, or procedure related.

3 Patients included from only one study center.

Evidence Table 5 - Opioid Adjuvants: Randomized Controlled Trials in Cancer Pain

Author, year, identifier | Treatment(s) studied, dose, route | Number of study arms | Study design (crossover, cohort, etc) | Method of Randomization | Blinding | Total number enrolled (evaluable) | Mean (±SD) age or range (% male) | Type(s) of cancer | Baseline pain severity | Type of pain ^1^ | Chronicity of pain (range or average) | Source of Pain ^2^ | Exclusion criteria | Rescue medication (all arms) | Outcomes assessed | Outcome scales | Outcomes | Comments
Bruera 1985 85254557 | Methylprednisolone po 32 mg/2qd (MP) vs. placebo. Study duration = 14 days. | 2 | Crossover | Not stated | Double-blind | 40 (31) | 54 (±12) (45%) | Colon 22.5% Breast 20% Lung 15% Soft tissue 10% Kidney 7.5% Prostate 7.5% Head/neck 5% Melanoma 5% Pancreas 5% Ovary 2.5% | Baseline pain score = 57.7 ±15 (VAS 0-100 mm), Baseline analgesic consumption = 3.6±15 capsules | Not stated | Not stated | Cancer | Patients with infection, history of peptic ulcer, insulin-dependent diabetes mellitus, severe psychiatric disturbances, neurological deficits, altered levels of consciousness, inability to take oral medication. | Capsules of naproxen 98 mg in combination with 400mg dipyrone. | Pain intensity, analgesic consumption, depression, anxiety, appetite and food consumption, performance status, activity | VAS (0-100 mm) for pain, number of capsules for analgesic consumption. | There was a significant difference in pain scores between placebo and methylprednisolone with respect to pain. | Two patients developed cushingoid facies and one patient showed significant retention of fluids in the MP group.
Bruera 1987 87078087 | Methylphenydate vs. placebo in cancer patients receiving narcotics | 2 | Crossover | Not stated | Double-blind | 32 (28) | 53 (±11) (60%) | Breast 10/32 Lung 3/32 Myeloma 3/32 Prostate 3/32 Gynecological 3/32 Kidney 2/32 Head/neck 2/32 Melanoma 2/32 Sarcoma 2/32 Pancreas 1/32 Leukemia 1/32 | Not stated | Not stated | Not stated | Cancer | Although not stated as exclusion criteria, history of major contraindication for amphetamines, neurological deficits or altered level of consciousness, or lack of ability to take oral medication. | Patients were regularly receiving morphine, hydromorphone, levorphanol, and oxycodone. For increased pain they were receiving extra doses. | Pain intensity, hrs of sleep, activity, nausea, depression, anxiety, drowsiness, sensation of well-being, performance status (Karnofsky scale), side effects, and patient preference. | VAS (0-100 mm) | The intensity of pain and intake of extra doses of analgesics were significantly lower in the methylphenydate group compared with placebo. Both patients and investigators demonstrated preference for methylphenydate as a more useful drug.
Kaiko 1987 88095975 | 10 mg oral cocaine, 10 mg intramuscular morphine, morphine + cocaine, and placebo | 4 | Crossover | Not stated | Double-blind | 34 total, 20 chronic (11 chronic) | 53 (34-67) (45%) | Not stated | Severe 45% moderate 55% (categorized by patients) | Not stated | Not stated | Not stated (the pain is described as "chronic malignant") | Not stated | Patients were receiving a routinely administered analgesic (e.g., hydromorphone, oxycodone, morphine, or meperidine, most commonly in both groups) prior to and between treatments | Pain intensity and relief, global mood, side effects | VAS and categorical scale for pain intensity and relief, questionnaire for global mood | There were no differences between cocaine and placebo or between morphine and the combination of morphine plus cocaine. Side effects were morphine-like and occurred in 59% after combination, 43% after morphine, 34% after cocaine, and 25% after placebo. | Although the authors state that the study is randomized double-blind crossover, the use of different routes requires a double-dummy design to be successfully blinded. Patient population is postoperative and has chronic pain. Table includes only chronic patients
Ellemann 1989 92216257 | Xylocaine 5 mg/kg in 200 ml saline IV vs. placebo IV | 2 | Crossover | Not stated | Double-blind | 10 (10) | 50 (30-67) (40%) | Breast 30% Ovarian 20% Testicular 30% Myeloma 10% Uterine 10% | Not stated | Neuropathic with allodynia | 1.3 years median (0.2-7 years) | Cancer, with chemo- or radiation therapy | Prospective primary neoplastic disease or metastatic involvement of the peripheral or central nervous system; clinical and/or biochemical signs of cardiac, renal, or hepatic disorders. | Patients were receiving additional analgesics during the study (details not stated) | Pain intensity, analgesic consumption | VAS (0-100 mm) | Neither lidocaine nor placebo reduced pain or analgesic consumption. | One patient had complete and one had partial pain relief with lidocaine, and three experienced partial pain relief with placebo. These effects were all transient.
Bruera 1992 92270272 | Methylphenydate vs. placebo in cancer patients receiving continuous subcutaneous infusion of opioids | 2 | Crossover | Not stated | Double-blind | 20 (19) | 55 (±12) (60%) | Lung 10/20 GI 5/20 Breast 3/20 Prostate 1/20 Ovarian 1/20 | Not stated | Not stated | All patients were receiving continuous SC infusion of opioids for at least 5 days | Cancer | Brain metastases, present or past history of neurological or psychiatric disease, sepsis, and sodium, calcium, or renal function abnormalities. | Not stated. However patients in both groups were receiving morphine (11), hydromorphone (8), or diamorphine (1) throughout the study | Pain, drowsiness, confusion, depression, activity, also tapping speed, arithmetic test, memory for digits, visual memory. | VAS (0-100 mm) | Methylphenidate resulted in a significant improvement in the tests for cognitive function and in the VAS for drowsiness and confusion. No change was observed in the VAS for pain, nausea, and activity. | Significantly more investigators and patients chose methylphenidate over placebo when blinded. The study does not provide actual raw data for VAS pain for each assessment. Only average percentage changes from baseline are provided.
Yajnik 1992 92388770 | Phenytoin vs. Buprenorphine vs. Phenytoin + Buprenorphine | 3 | Parallel | Not stated | Double-blind | 75 (75) | Not stated (57.33%) | GI 25/75 Oral 14/75 Breast 17/75 Penile 6/75 Prostate 5/75 Bladder 5/75 Ovary 2/75 Thyroid 1/75 | Moderate to severe pain (6-10 cm in VAS) | Not stated | Not stated | Cancer | Not stated | Not stated | Pain intensity, adverse effects | VAS (0-100 mm) | Buprenorphine +phenytoin provided better pain relief than buprenorphine alone. | There are no statistical comparisons reported in the study results or abstract.
De Conno 1994 94223136 | One daily injection of octreotide 200 ng vs. placebo " subcutaneously in the right deltoid muscle" for breakthrough pain | 2 | Crossover (two parallel groups; each received three single daily doses of octreotide or water, followed by three single daily doses of the alternative solution) | Not stated | Single-blind | 9 (9) | Not stated | Lung + bone metastases 33.3% Lung + pancreatic 11.1% Pancreatic 44.4% Uterine 11.1% | Not stated | Bone 3 Somatic 6 | "More than 2 weeks" | Cancer (somatic and visceral) | Deafferentation pain, inability to self-evaluate pain, or receiving specific oncologic treatment | Diclofenac 75 mg intramuscular | Pain intensity, nausea, vomiting, drowsiness | VAS (0-100 mm) | Somatostatin was not superior to placebo in alleviating pain. | The number of patients enrolled is marginal.
Wilwerding 1995 95291643 | Methylphenidate vs. placebo in patients receiving opioid as primary pain treatment | 2 | Crossover | Not stated | Double-blind | 43 (34) | Median 65 (43-78) (52.94% M) | GI 5%, 32%* Liver, gallbladder, pancreas 10%, 14% Lung 29%, 18% Breast 19%, 14% Genitourinary/gynecological 19%, 14% Unknown 14%, 0% Other 5%, 9% * % in two groups | Score <40% on VAS | Neuropathic 38% Other 62% | Not stated | Cancer | Inability to ingest, drug or alcohol abuse, allergy to methylphenidate, hypertension, seizure disorder, glaucoma, symptomatic cardiac disease, severe renal or hepatic insufficiency, malabsorption syndrome, brain metastases, psychostimulants, pregnancy. | Patients were receiving a variety of opioids as primary treatment for their pain | Pain, appetite, anxiety/agitation, drowsiness, and well-being/mood | VAS (0-100 mm) | The data did not demonstrate any statistically significant benefit for methylphenydate.
Eisenach 1995 96058975 | Clonidine continuous epidural infusion 10 mcg/h vs. placebo as an adjuvant to morphine | 2 | Parallel | Not stated | Double-blind | Not stated (85) | 57 (±12), 56 (±12) 71%, 51% (in two groups) | Only partially listed | Not stated | Primary pain neuropathic=36 nonneuropathic=49 Secondary pain neuropathic=24 nonneuropathic=46 Tertiary pain neuropathic=12 nonneuropathic=25 | Not stated | Cancer | Atrioventricular block > 1^st^ degree, serum creatinine > 3.5 mg/dl, inability to understand and provide pain assessments, known hypersensitivity to clonidine or morphine. | IV PCA morphine | Pain intensity, blood pressure, heart rate, oral temperature, sedation, nausea, and occurrence of any adverse effect | VAS (0-100 mm) | Successful analgesia was more common with epidural clonidine (45%) than with placebo (21%). This was particularly prominent in those with neuropathic pain (56% vs. 5%). | Clonidine but not placebo decreased blood pressure and heart rate. Hypotension was considered a serious complication in two patients receiving clonidine and one patient receiving placebo.
Roca 1996 97170164 | Morphine plus placebo vs. morphine plus 90 mg/24h nimodipine | 2 | Crossover | Not stated | Double-blind | 42 (32) | 55.59 (±9.8) (27-70) 65.62% | Colon 4/32 Mesothelioma 4/32 Lung 3/32 Bladder 2/32 Prostate 2/32 Esophagus 2/32 Gastric 2/32 Lymphoma 2/32 Unknown 2/32 Tonsils 1/32 Larynx 1/32 Ovary 1/32 Cervix 1/32 Endometry 1/32 Other 4/32 | Not stated | Mixed pain 16/32 Somatic 3/32 Bone 6/32 Visceral 7/32 | Not stated | Cancer | Existing pathologies requiring concomitant drug therapy, liver or kidney failure, a known sensitivity to nimodipine, pregnancy or lactation, surgery or surgical complications. | Not stated | Pain intensity, pain relief, mood, sleep quality | VAS (0-100 mm), verbal pain rating scale with validated descriptors in Spanish | No differences in pain relief between nimodipine and placebo were found.
Bernstein 1998 98318906 | Full analgesic dose* plus placebo vs. one-half analgesic dose plus 50 mg of proglumide. *The patient's usual opioid analgesic dose, individualized for route and dose | 2 | Crossover | Not stated | Double-blind | 60 (43) | Not stated | Not stated | Not stated | Not stated | Not stated | Metastatic cancer | Patients with known intolerance to opioids. | Not stated | Nine descriptors of pain, intensity, unpleasantness, emotional reaction to pain | VAS scale and Tursky verbal rating scale | No differences in pain perception were detected between study arms. No side effects related to proglumide. | This study found that proglumide (cholocystokinin antagonist) when used as an adjuvant to opioid analgesia may reduce the dose of opioid to half. However, it did not give sufficient evidence of any benefit for its clinical use.
Santillan 1998 98359644 | Nimodipine vs. placebo as adjuvant to morphine | 2 | Parallel | Not stated | Double-blind | 54 (30) | 62.7 (±1.9), 63.4 (±1.9) (71.4, 76.1%) | Prostate 4/30 Bladder 3/30 Lung 4/30 Rectum/colon 2/30 Pancreas 4/30 Kidney 3/30 Breast 1/30 Stomach 1/30 Bones 2/30 Other 6/30 | Not stated | Not stated | 42 to 420 days prior to the study | Cancer | History of drug or alcohol abuse; pregnancy; increased intracranial pressure; COPD; severe cardiac, hepatic, or renal insufficiency; consumption of calcium-channel blockers; hypersensitivity to dihydropyridines | Patients were receiving many opioid, nonopioid, or other coanalgesics throughout the study | Pain relief, consumption of analgesics | VAS (0-100 mm) patient completed | Nimodipine controlled escalation of morphine dose in significantly more patients. The daily consumption of morphine was significantly reduced in the nimodipine group compared with the placebo group. | Plasma determinations of M3G, M6, and morphine performed in this study were useful to exclude the possibility of a kinetic effect of nimodipine on morphine.

SC = subcutaneous

1 Neuropathic, somatic, or visceral.

2 Cancer, sequel of treatment, or procedure related.

Evidence Table 6 - Miscellaneous Interventions: Randomized Controlled Trials in Cancer Pain

Author, year, identifier | Treatment(s) studied, dose, route | Number of study arms | Study design (crossover, cohort, etc) | Randomization | Blinding | Total number (evaluable) | Mean age or range (% male) | Type(s) of cancer | Baseline pain severity | Type of pain ^1^ | Chronicity of pain (range or average) | Source of Pain ^2^ | Exclusion criteria | Rescue medication (all arms) | Outcomes assessed | Outcome scales | Outcomes | Comments
Staquet 1978 78126043 | Nitrogen analog of tetrahydrocannabinol (NIB) vs. codeine vs. placebo plus NIB vs. secobarbital vs. placebo. (two trials) | 3 (in each) | Parallel | Not stated | Double-blind | 30(26), 15 | Not stated | Not stated | Continuous moderate to severe pain for at least 3 days prior to the study | Not stated | Not stated | Cancer | Patients receiving large doses of narcotics; insufficient mental clarity; GI, renal, or hepatic disease. | Not stated | Pain intensity | 4-point rating scale | NIB and codeine were equally effective and significantly more effective than placebo. NIB was significantly more effective than secobarbital and placebo. | In the text, side effects are described as "minimal," but the authors suggest that NIB is not clinically useful due to toxicity.
Oyama 1980 80098591 | B-endorphin intrathecal vs. placebo (saline) | 2 | Crossover (not in all patients) | Not stated | Single-blind | 14 (3) | 47.5 (71.42%) | Not stated | Not stated | Not stated | Not stated | Cancer | Not stated | Pentazocine, aminopyrine, meperidine, indomethacin | Pain intensity | VAS (0-100 mm) | No comparisons between the placebo and endorphin effect. Results are descriptive. | Only duration of pain relief for 3 patients is reported in a figure following b-endorphin and placebo.
Young 1980 81071447 | Laminectomy plus radiotherapy vs. radiotherapy | 2 | Parallel | Table of random numbers | Not blinded | 29 (all) | 53.8, 63.8 (Not stated) | Breast 20.7% Lung 17.2% Prostate 13.8% Melanoma 10.3% Sarcoma 13.8% Lymphoma 20.7% Thyroid 3.4% | Not stated | Not stated | Not stated | Cancer metastases | Patients with more than one demonstrable lesion who had previous radiotherapy to the area or spinal epidural metastasis or whose general medical status was too poor to permit surgery. | Not stated | Pain relief, motor performance, sphincter function. | Pain relief was measured by consumption of opioid analgesics before and after treatment. | No significant difference was found in the effectiveness of the two treatment methods in regard to pain relief, improved ambulation, or improved sphincter function.
Scheef 1987 88190000 | Flupirtine (opioid agonist-antagonist) oral vs. pentazocine oral | 2 | Parallel | Not stated | Double-blind | 52 (51) | 56.9 (+/-12.5) and 53.7(+/-14.8) (39.21%) | Not stated | Severe to very severe on a 4-point scale | Not stated | Not stated | Cancer | Not stated | Not stated (patients were not receiving other medication) | Pain intensity | 4-point verbal scale | Differences in pain relief and adverse effects were not significantly different between the two study drugs | Poor study
Li 1994 94374211 | Combinations of epidural morphine, chinese herbs, and ear acupuncture or placebo. Comparison of all possible (8) combinations to each other. | 8 | Orthogonal experiment | Not stated | Double-blind | 16 (all) | 48.64 (+/-11.35) (100%) | Liver cancer | 22.5+/-18.7, 24.4+/-17.5, 20.6+/-6.8 baseline pain scores (VAS) in three treatment groups. | Postoperative pain | 4.5 months (0.5-10 months) | Treatment sequela | Not stated | 50-100 mg meperidine when VAS>50 | Pain intensity, meperidine consumption, Leukin-Enkephaline levels in plasma, adverse effects (abdominal distension, urinary retention, constipation) | VAS (0-100 mm) | Any combination that included epidural morphine, herbs, or ear acupuncture produced better pain relief. EP morphine and herbs produced significantly better pain relief. Herbs and acupuncture reduced bowel distention and urinary retention. | The orthogonal design demands a substantial number of patients to reach clinically useful conclusions, which is not the case here.
Kalso 1995 96303779 | Oral amitriptyline (25 mg sustained-release tablets in weekly escalating doses to 100 mg or highest tolerated dose) vs. placebo | 2 | Crossover (2-week washout between agents) | Not stated | Double-blind | 20 (15) | Median 56 (39-72) all female | Breast cancer, postmastectomy | "At least moderate" or worst in severity [baseline VAS=5 (1.7-7.1)] in ipsilateral arm, 3.3 (1.4-6.2) in breast scar] (no other data are provided) | Neuropathic | Median time after breast surgery 45 months (median 15-79 range) | Postmastectomy | Relapse or metastasis of breast cancer, or clinically overt cardiac, renal, or hepatic disease. | Not stated | Pain intensity, pain relief, number of disturbed activities, effect on daily life, disturbed sleep. | 10 cm VAS for pain intensity, verbal rating scale (8-point for pain intensity, 5-point for pain relief). Finnish McGill Pain Questionnaire, pain effect on daily life on a 5-point rating scale, 10 cm VAS for side effects, 4-point depression scale applied to 2 questions. | Amitriptyline significantly relieved neuropathic pain both in the ipsilateral arm and in the breast scar area; 8 patients (good responders) had >50% decrease in pain intensity, 7 (poor responders) had <50% effect. The poor responders reported more side effects.
Ellison 1997 97398217 | 0.075% capsaicin cream, four times daily vs. placebo cream | 2 | Crossover | Not stated | Double-blind | 103 (99) | 63.3 or 63.9 (two crossover arms) (28%) | Not stated | Moderate or greater in a scale of none, mild, moderate, severe, very severe | Neuropathic | 3-12 months (55-56%) or >12 months (44-45%) | Treatment (e.g., postmastectomy, postthoracotomy, postamputation) | 1. Concurrent radiotherapy to the painful area 2. Neurotoxic chemotherapy in preceding 6 weeks 3. Cutaneous problems (e.g., skin breakdown) 4. Change in analgesic regimen 10 days prior to study 5. Recurrent malignancy in painful area 6. Life expectancy <6 m 7. Alcohol or drug abuse 8. Topical local anesthetic, corticosteroids or other agents in the week before entry 9. Pregnancy or lactation 10. Inability or unwillingness to provide informed consent | Not stated | Pain intensity, pain relief, functional deficits related to pain, cream-related toxicities | VAS scale, Likert scale | Capsaicin cream gave significantly more relief after the first 8 weeks than placebo. | During the first 8 weeks capsaicin produced significantly more skin burning, redness, and coughing. These toxicities declined over time. However, treatment was stopped for patient refusal or toxicity at the same rate in both capsaicin and placebo groups. Postmastectomy pain showed greater benefit than other sources of pain.
Polati 1998 98162436 | Neurolytic celiac plexus block vs. diclofenac plus anesthetic celiac plexus block | 2 | Parallel | Not stated | Not blinded | 24 | 58 | Pancreatic | Mean pain score of 7 on 0-10 VAS | All visceral | Mean 5 months (range 2-7) | Cancer | Not stated | Diclofenac, opioids | Drug consumption | Arner and Arner pain classification; Scott-Huskisson VAS | Neurolytic celiac plexus block reduced analgesic drug needs and drug-related adverse effects | NSAID not the primary modality compared
Pud 1998 98243129 | Amantadine 200 mg IV infusion vs. placebo infusion | 2 | Crossover | Not stated | Double-blind | 15 (13) | 57 (±13.5) (33.3%) | Lung, breast, ovary, testis, stomach, prostate | 54+/-6 (placebo) 46+/-6 (amantadine) | "Pure" neuropathic | 24.5 months (range 3 - 60) | Postsurgical; postmastectomy, postthoracotomy | Mixed neuropathic and nonneuropathic pain. | Scheduled and rescue analgesics not specifically stated | Immediately before and after infusions: spontaneous and evoked (mechanical and thermal stimuli induced) pain [mechanical allodynia, mechanical hyperalgesia, "wind up" like pain, cold allodynia]. Daily 0-10 numerical pain scale averaged over 48 hrs before and after each infusion. | VAS scale | Spontaneous pain was significantly reduced by amantadine compared to placebo. In four patients with "wind up" pain, this was significantly reduced following amantadine compared with placebo. | Other types of evoked pain (e.g., mechanical hyperalgesia and allodynia or cold allodynia) were not present in a sufficient number of patients to permit statistical comparisons. Quantitative sensory testing in 13 patients showed no significant changes in heat or cold sensations or pain thresholds. The only side effect noted was dryness of mouth.
Ramesh 1998 99019892 | Liquid ayurvedic formulation (Misrakasneham) vs. conventional laxative (Sofsena) for prophylaxis against opioid-induced constipation in cancer patients. Three progressive doses of each agent were available, with escalation every 3 days and an interval of 2 days between steps. Total study duration: 14 days. | 2 | Parallel | Randomization performed by drawing lots (sampling with replacement) | Open trial | 50 (36) | 15 years or older (64%) | Lung 32% Tongue 12% Breast 12% Esophagus 6% Oropharynx 10% Tonsil 2% Liver 6% Multiple myeloma 2% Ovary 2% Cervix 8% Cheek 4% Penis 2% Acute myelogenous leukemia 2% | Not stated | Not stated | Not stated, although regimen was begun at the time patients began oral morphine | Cancer | Not stated | Not stated | Bowel movements | Not stated | 85% (N=17) of patients in the Ayurvedic preparation group and 69% (N=11) in the Sofsena group had satisfactory bowel movements; 15% (N=3) and 31% (N=5) of the respective groups did not have satisfactory bowel movements. This difference was not statistically significant. | The morphine doses administered to each group appear to be similar.

1 Neuropathic, somatic, or visceral.

2 Cancer, sequel of treatment, or procedure related.

Evidence Table 7 - Biphosphonates: Randomized Controlled Trials in Cancer Pain

Author, year, identifier | Treatment(s) studied, dose, route | Number of study arms | Study design (crossover, cohort, etc) | Method of randomization | Blinding | Total number enrolled (evaluable) | Mean age or range (% male) | Type(s) of cancer | Baseline Pain severity | Type of pain ^1^ | Chronicity of pain (range or average) | Source of pain ^2^ | Exclusion criteria | Rescue medication (all arms) | Outcomes assessed | Outcome scales | Outcomes | Comments
Aminohydroxypropylidene biphosphonate
van Holten-Verzantvoort 1987 88037750 | Aminohydroxypropylidene biphosphonate (APD) 300 mg/day orally vs. no treatment. Specific antitumor Tx was at the discretion of the clinician. | 2 | Parallel | Not stated | Not blinded | 122 (122, interim analysis) | 61 (all female) | Breast | Not stated | Bone pain | Not stated | Cancer/ bone metastases | Hypercalcemia, life expectancy < 6 months, creatinine clearance <30ml/min, peptic ulcer, malabsorption, pregnancy. | No specific information is provided | Bone pain, serum calcium, pathological fractures | Incidence of bone pain severe enough to require radiotherapy or surgery | There was a significant reduction in pathological fractures and bone pain in the APD group. | This report is an interim analysis after 13 months.
Cleton 1989 89346402 | Aminohydroxypropylidene biphosphonate (APD) 150 mg/ q2/day orally vs. no treatment. Variable antitumor treatment was at the discretion of the clinician. Median duration of follow-up = 13 months. | 2 | Parallel | Not stated | Not stated | 131 | Not stated (all female) | Breast | Not stated | Bone pain | Not stated | Cancer/bone metastases | GI ulcers, malabsorption, pregnancy, Rx to the only evaluable lesion, creatinine clearance<10 ml/min, hypercalcemia, other malignancy, expected poor compliance. | Not stated | Pain events | Number of events of bone pain requiring bone Rx or surgery | The difference between pain events in the control and clodronate group was significant (11 in the APD and 33 in the control, p<0.003) | There is no quantitative measurement of pain.
Clodronate
Siris 1980 80078029 | Dichloromethylene biphosphonate 1600 mg q2/day vs. placebo. Duration 8 weeks (until crossover). Antitumor Tx was either melphalan or cyclophosphamide. | 2 | Crossover | Computer-generated random number table. | Double-blind | 13 (10) | 59 (30-83) (10%) | Multiple myeloma | Severe bone pain was a symptom in 9/10 patients | Bone pain | Not stated | Cancer/ bone metastases | Inclusion criteria: hypercalcemia or sustained hypercalciuria | No specific information is provided | Intensity of bone pain reported by patients | Patient report; no specific quantitative or qualitative tool for the assessment of pain is reported | Five patients reported lessening of skeletal pain. No other information is provided. | Very little information on pain and very small sample size.
Elomaa 1983 83113852 | Disodium dichloromethylene biphosphonate 1600 mg/day orally vs. placebo. Duration 3 to 9 months. Various antitumor Tx were administered. | 2 | Parallel | Not stated | Not stated | 34 (Not stated) | 51 (34-69) (all female) | Breast | Not stated | Bone pain | Not stated | Cancer/ bone metastases | Not stated | No specific information is provided | Intensity of bone pain | Daily consumption of analgesics | Daily consumption of analgesic drugs was reduced in 15 of 17 patients in the active treatment group and in 3 of the 17 in the placebo group. Radiotherapy for pain was given in 3 patients in the active group and 10 in the placebo group.
Adami 1989 89346401 | Clodronate 300 mg IV qd for 2 weeks vs. placebo. Study duration = 4 weeks. | 2 | Parallel | Not stated | Single-blind | Not stated | Not stated (100%) | Prostate | Not stated (10-20 on VAS 0-20 cm from figure) | Bone pain | Not stated | Cancer/ bone metastases | Not stated | All patients received ketoprofen | Pain intensity, analgesic consumption | VAS (0-20 cm) | The difference as regards both pain and analgesic consumption between placebo and clodronate was very significant (P<0.001 for both variables) | This paper reports on the results of more than one protocol. An open-label, multicenter study; a single-blind, placebo-controlled study; and a comparative oral vs. IM clodronate study are all reported without details or raw data provided.
Martoni 1991 91149007 | Dichloromethylene biphosphonate 300 mg/d IV for 7 days, 100 mg/d IM for 3 weeks, and finally 100 mg IM every 2 days for 2 months vs. matching placebo. Both groups received standard antitumor Tx. | 2 | Parallel | Not stated; postrandomization stratification for type of bone metastases and antitumor treatment (hormone vs. chemotherapy) took place. | Double-blind | 38 (33) | 58 (39-78) (all female) | Breast | Not stated | Bone pain | Not stated | Cancer/ bone metastases | Not stated | Patients were receiving opioids; no other information is provided | Bone pain, consumption of analgesics, biochemical markers of bone mineralization | VAS (0-10 cm) for pain, number of daily administrations of morphine or shift from morphine to minor analgesics and the reverse. | During the first 7 days there was a reduction of pain in both groups (no difference between the two groups). A significantly more frequent reduction in analgesic consumption was observed in the active treatment group compared with the placebo group.
Ernst 1992 92166465 | Dichloromethylene biphosphonate 600 mg IV vs. placebo (4hr infusion). Study duration = 2 weeks. | 2 | Crossover | Random block assignment | Double-blind | 24 (21) | 59 (36-82) (37.5%) | Breast 13/24 Lung 5/24 Prostate 4/24 Other 2/24 | Prior to study 88% of patients were receiving a mean number of 6 analgesic doses daily (and 12% were receiving continuous parenteral sc narcotics | Bone pain | Not stated | Cancer/ bone metastases | Previous history of congestive heart failure, impaired renal function, benign focal bone disease. | Patients were receiving opioids orally or parenterally | Pain intensity, consumption of analgesics, physical activity, biochemical markers, side effects | VAS (0-100 mm) for pain, nausea, anxiety, depression, drowsiness, and appetite | A significant decrease in pain scores and an increase in physical activity were observed with biphosphonate (p<0.01). No significant difference in analgesic consumption or clinical and laboratory markers of toxicity. | Well-designed crossover study with presentation of quantitative information throughout and data on patient and physician preference for treatment.
Elomaa 1992 92324804 | Estramustine phosphate 280 mg bid with placebo or estramustine (same dose) with clodronate orally 3.2 g for the first month and 1.6 g thereafter for a further 5 months. | 2 | Parallel | Not stated | Double-blind | 75 (all) | 71 (60-83) (100%) | Prostate | Not stated | Bone pain | Not stated | Cancer/ bone metastases | Radiation therapy 2 months before | Not specifically stated | Presence or absence of pain (by patient and by doctor), use or no use of analgesics | No scales used | Pain relief was more distinct in the clodronate group, where one-third of patients were totally free of bone pain. The use of analgesics stopped in 38% of patients in the clodronate group and in 18% of the placebo group.
Lahtinen 1992 93023374 | Clodronate 2.4 g orally for 24 months vs. placebo. Patients in both groups received standard melphalan-prednizolone. | 2 | Parallel | Not stated | Double-blind | 336 (all) | % of three age groups provided (49.5%) | Multiple myeloma | Not stated | Bone pain | Newly diagnosed patients | Cancer/ bone metastases | Previous treatment with biphosphonates | Opioid and nonopioid analgesics | Pain intensity | Pain was evaluated as 0=no pain, 1=slight, 2=severe, and 3=incapacitating; consumption of analgesics = mean daily number of tablets/capsules | The percentage of patients feeling no pain increased more in the clodronate group (from 24 to 54%, p<0.001) than in placebo group (from 29 to 44%, p<0.01). Side effects were similar in both groups.
Paterson 1993 93115782 | Clodronate 1600 mg/d vs. placebo. | 2 | Parallel | Prerandomized numbering system whereby patients allocated a number in the order in which they presented. | Double-blind | 173 (all) | 60 (all female) | Breast | Not stated | Bone pain | Not stated | Cancer/ bone metastases | Patients with breast cancer and metastatic skeletal disease assessable according to International Union Against Cancer/ National Cancer Institute (United States) criteria were eligible for trial entry. No exclusion criteria are stated. | Radiotherapy and medication for bone pain were allowed. Specific medication used not stated. | Incidence of the requirements for palliative radiotherapy for bone pain, hypercalcemia and pathologic fractures, and bone deformities. | Pain was assessed indirectly by the incidence of requests for radiotherapy. | Requirements for radiotherapy were not significantly different between the clodronate and placebo groups, although there was a trend in favor of clodronate-treated patients.
Clemens 1993 93229572 | Chemotherapy plus Clodronate vs. chemotherapy alone. Chemotherapy =melphalan 15 mg/m2 i.v. plus prednisolone 60 mg/m2, Clodronate= 1600 mg/d po. | 2 | Parallel | Number assignment. Patients were stratified prior to randomization for stage and osteolytic lesions | Open-label | 38 (26) | 28-76 (42.3%) | Multiple myeloma | Not stated | Bone pain | Not stated | Cancer/osteolysis | Presence of a serious concurrent illness and participation in a clinical therapy study, especially with biphosphonate, within the preceding 4 weeks | Not stated | Pain, performance status, side effects, and toxicity every 4 weeks | Side effects, toxicity, pain, and performance status were assessed using the WHO scoring system: 0=no impairment, 1=mild impairment, 2=moderate impairment, 3=severe impairment 4=not tolerable impairment | Pain improved in the clodronate group, whereas there was no lasting change under chemotherapy alone. No toxicity of clodronate was observed. | This report is an interim report before the end of the trial.
Kylmala 1993 93249770 | Clodronate orally 3.2 g for the first month and 1.6 g thereafter for a further 5 months vs. Estramustine phosphate 280 mg bid Study duration = 6 months. | 2 | Parallel | Not stated | Open-label | 99 (Not stated) | 71 (47-90) (100%) | Prostate | Not stated | Bone pain | Not stated | Cancer/ bone metastases | Radiation therapy 2 months before | Not stated | Pain score, reduction of analgesics, biochemical markers, bone scans | VAS (0-100 mm) | Pain relief appearing within 1 month and reduction of the use of analgesics were more accentuated in the E+C group than in the E group (nonsignificant finding). | This is an open-label study with no appropriate control group. Much information on pain outcome is not provided. A figure on percent reduction of analgesics is presented but there is no information on the type of analgesics or the unit used to combine data.
O'Rourke 1995 95222321 | Oral clodronate 400 mg, 1600 mg or 3200 mg once daily for 4 weeks or matching placebo. | 4 | Parallel | Randomization method not stated but patients were stratified according to initial fasting urinary calcium. | Double-blind | 84 (80) | 57 (28-80) (14%) | Breast 69/84 Prostate 6/84 Lung 3/84 Kidney 2/84 Other 4/84 | Not stated | Bone pain | Not stated | Tumor-induced osteolysis | Urinary calcium excretion <0.175 mmol/mmol Calcium creatinine, chemotherapy, hormone treatment or biphosphonates within 3 months before randomization, life expectancy <1 month, renal failure, primary hyperparathyroidism, Paget's disease of bone. | 73% of patients were on analgesic medication; no other information is available. | Urinary excretion of calcium was the primary outcome in this study. Pain intensity weekly, analgesic intake, and adverse effects were secondary outcomes. | VAS (0-100 mm) | There were no significant differences between groups in pain scores (means 3.4±0.8 mm for pl, 2.7±0.7 mm for 400 mg, 2.7±0.6 for 1600 mg, and 3.5±0.8 for 3200 mg). Also no differences were observed in analgesic consumption after 4 weeks of treatment.
Robertson 1995 95395501 | Oral clodronate 1600 mg/d or matching placebo. | 2 | Parallel | Randomization method is not stated but it was post-stratification for tumor type. | Double-blind | 55 (33) | 60 (±4.6) (cl) 65 (±3.8) (pl) (Not stated) | Breast (48%, 53%) Lung (7%, 7%) Prostate (7%, 7%) Myeloma/lymphoma (7%, 7%) Other (26%, 25%) clodronate, placebo respectively. | Median and range (VAS score) cl = 3.2 (1.6-7.5) pl = 4.8 (2.1-6.9) | Bone pain | Not stated | Cancer/ metastases | Life expectancy<2 months, inability to take oral medication, significant renal dysfunction, previous or current treatment with biphosphonates. | Opiate, NSAID, nonopiate. Patients were receiving analgesics throughout the study but no other specific information is provided. | Bone pain, general well-being, analgesic use, and compliance with therapy. | VAS (10 cm) for pain and general well being. | Visual analog pain score (median [interquartile range]) decreased from the pretreatment value in the clodronate group (−0.9 [−2.6 to −0.4]) but increased in the placebo group (+0.4 [−1.0 to +4.0]) (p=0.03 between groups). Analgesic use increased in both. | The authors attribute the increased rate of withdrawal from the study (cl 37%, pl 46%) to lack of reduction in analgesic requirements and difficulty in swallowing the capsules.
Ernst 1997 97348667 | Clodronate 600 mg or 1500 mg IV vs. placebo saline. | 2 | Crossover | Random block assignment | Double-blind | 60 (46) | 63 (37-85) (Not stated) | Breast 37% Prostate 28% Unknown 8% Multiple myeloma 7% Renal cell 5% Lung 5% Other 10% | Not stated (the mean po equivalent morphine dose was 451 mg) | Bone pain | Not stated | Cancer/ bone metastases | History of congestive heart failure, renal insufficiency, or benign focal bone disease. | Daily number of breakthrough doses 3.1 (no other information is provided) | General pain, pain at rest, pain with movement, level of activity, nausea, depression, anxiety, drowsiness, appetite, and general well-being. Daily morphine equivalent dose (DMED) scores | VAS (0-150 mm) | During the first period there were no significant differences between active treatment and placebo in any pain (despite a reduction from baseline). The DMED scores were significantly lower in the active treatment compared with placebo. | There is discrepancy between two pain outcome measures (intensity and consumption of analgesics). The preference of both doctors and patients when blinded is clodronate.
Kylmala 1997 97466816 | Clodronate 300 mg IV qd for 5 days followed by 1.6 gr /day orally for 12 months vs. placebo. Both groups received estramustine. | 2 | Parallel | Not stated | Double-blind | 57 (55) | 74 (100%) | All patients had painful bone metastases from prostate cancer | Not stated | Bone pain | Six or 5 months was the median duration of the cancer (but not the pain) | Cancer/ bone metastases | Not stated | Additional analgesics were prescribed and consumption was recorded | Pain intensity, performance status, and response to treatment (with biochemical markers), side effects. | VAS categorical verbal scale (0-4 by doctor), VAS (0-100 mm) by patient. Consumption of analgesics in a 4-step grading scale (0=no analgesics, 1=nonnarcotic <3 times/day, 2=nonnarcotic>3 times/day, 3=narcotic) | There was not a statistically significant difference between the distribution of patients to groups according to the intensity of pain (reported either by doctor or patient) or according to the use of analgesics at any time.
McCloskey 1998 98147943 | Clodronate 1600 mg daily vs. placebo in addition to chemotherapy. | 2 | Parallel | Not stated | Double-blind | 614 (536) | 62.5 median (1.33, 1.43 male-to-female ratio in clodronate and placebo groups respectively) | Multiple myeloma | Not stated | Bone pain | Not stated, although the primary disease was recently diagnosed (prior to the study) | Cancer/ increased osteoclastic activity | Previous cytotoxic treatment other than the minimum dose of radiotherapy required to relieve localized pain | Systemic chemotherapy | Incidence of pathological fracture in vertebral and extravertebral sites, hypercalcemia, performance status, bone pain intensity, and survival. | Bone pain was noted as present or absent by the physician and was evaluated at spine, rib cage, and upper and lower limbs using a 5-point scale (1=none, 2=slight, 3=moderate, 4=severe, and 5=incapacitating). Pain was present with score of 3 or more. | The frequencies of back pain and poor performance status were significantly lower at 24 months in clodronate than in placebo-treated patients. | Pain is not the primary outcome of this study but it is a measured outcome.
Strang 1997 98155699 | Clodronate 300 mg IV for 3 days followed by 3200 po for 4 weeks vs. placebo IV for 4 days followed by placebo tablets for 4 weeks. | 2 | Parallel | Not stated | Double-blind | 55 (46) | 72.5 (Not stated) | All patients had painful bone metastases from prostate cancer | 47 median (range 5-97) baseline VAS (0-100 mm) | Bone pain | Not stated | Cancer/ bone metastases | Significantly impaired renal function, biphosphonates (within 30 days prior to the study), palliative radiotherapy (within 3 months prior to the study) | Not stated. Although analgesic consumption was recorded, no reference to the type of analgesics or the consumption is made in the paper | Pain intensity, analgesic consumption | VAS (0-100 mm) | Changes in the mean pain intensity and in pain intensity during best and during worst period were not significantly different between clodronate and placebo. | The lack of significant differences is attributed by the authors to the premature ending of the study due to difficulties in recruiting patients.
Etidronate
Smith 1989 89068935 | Sodium etidronate 7.5/kg IV for 3 days followed by 200 mg po bid, SE IV (same IV dose) followed by placebo bid, Placebo IV followed by SE (same po dose), and Placebo IV followed by Placebo po (Duration=1 month). | 4 | Parallel | Randomization code (no other information provided) | Double-blind | 57 (51) | Not stated (100%) | Prostate | Not stated | Bone pain | Not stated | Cancer/ bone metastases | Patients' serum creatinine>2.5 mg | Patients were receiving analgesics, no other information is provided | Bone pain | Numerical and visual analog scales by patient and investigator (no other information is provided). Analgesic requirement was recorded daily. | No difference was seen in the symptomatic response rate or analgesic requirement between patients treated with sodium etidronate and placebo. No serious adverse events were recorded in any patient. | This report provides very little information in either the methods or results section.
Belch 1991 91303191 | Etidronate disodium 5 mg/kg/d or placebo. Standard melphalan plus prednisone in both arms. Duration until death or refusal to take medication. | 2 | Parallel | Randomly numbered medication bottles and balanced stratification (variables not mentioned) | Double-blind | 173 (166) | Age groups provided (62.65%) | Multiple myeloma | Newly diagnosed patients | Bone pain | Newly diagnosed patients | Cancer/ osteolysis | Serious concurrent illness and chronic renal failure with a creatinine level greater than 3.0 mg/dL (265 mmol/L) | Not stated | Bone pain (every 8 weeks), height, vertebral height and deformity, hypercalcemia, development of pathologic fractures | Scale for pain not described | There were no significant differences between etidronate and placebo with respect to bone pain.
Pamidronate
van Holten-Verzantvoort 1991 91274037 | Pamidronate 150 mg orally bid vs. no treatment. | 2 | Parallel | Not stated | Not stated | 167 (144) | 61 (38-84) (all female) | Breast | Not stated | Bone pain | Not stated | Cancer/ bone metastases | Hypercalcemia, life expectancy<6 months, creatinine clearance<30ml/min, peptic ulcer, malabsorption, pregnancy | Not stated | Bone pain, mobility impairment, gastrointestinal toxicity, fatigue | Each outcome was assessed using a questionnaire consisting of a number of items per outcome. For bone pain three items were scored using a scale of 0 to 3 0=none, 1=mild, 2=moderate, 3=severe | Bone pain was significantly higher in the control group (p=0.007) reflecting an early reduction of bone pain in the pamidronate group the first 3 months. In both groups bone pain increased over time although more rapidly in the control group. | This report is an interim analysis of a multicenter trial.
van Holten-Verzantvoort 1993 93187683 | High-dose (HD) pamidronate 600 mg/d High-dose/low-dose (HD/LD) pamidronate 600 mg/d and 300 mg/d Low-dose (LD) pamidronate 300 mg/d with respective control groups (all study medications administered po). | 6 | Parallel | Not stated | Open-label | 205 (161) | 56.7 (all female) | Breast | Not stated | Bone pain | Not stated | Cancer/ bone metastases | Hypercalcemia, upper GI disease, malabsorption, pregnancy, life expectancy < 6 months, creatinine clearance < 30mL/min. | Not stated | Bone pain, hypercalcemia, clinically relevant fractures, changes in systemic treatment, radiotherapy, or surgery. | Pain intensity was not quantified. An assessment of pain events requiring radiotherapy or surgery was performed. | A significant reduction in the rate pain events per patient in the pamidronate group (all three groups together) is reported. A 30% decrease of pain events in the pamidronate groups vs. the control group is also reported. | A reduction of the original 600 mg/d dose of pamidronate due to toxicity resulted in changes of the protocol at the mid-study. Also, pain was not measured using a scale. Only pain events requiring Tx were recorded.
Glover 1994 95042148 | Pamidronate IV 30 mg/2 week X1 vs. 60 mg/4 week X1 vs. 60 mg/2 week X1 vs. 90 mg/4 week X1 Study duration=12 months. | 4 | Parallel | Not stated | Open-label | 61 (51) | 52 (33-89) (all female) | Breast | A bone pain score of 4 or more at baseline was required for inclusion | Bone pain | Not stated | Cancer/ bone metastases | Previous exposure to pamidronate, other biphosphonate, calcitonin, mithramycin within 90 days before study, other investigative drugs within 30 days, radiation 2 weeks before, history of hypercalcemia, pathologic fracture, epidural spinal cord compression. | Morphine or derivatives, or combinations, NSAIDs (naproxen, piroxicam). | Pain score, narcotic score and secondary outcomes (narcotic score, urinary calcium/creatinine, hydroxyproline/ creatinine, serum osteocalcin, bone alkaline phosphatase, radiologic response). | Pain (0-3) and frequency of pain (0-3) were quantified as a product of intensity and frequency. | There were no statistically significant differences among the four treatment groups; however, patients who received 90 mg/4weeks had a significantly lower narcotic score than patients in the other three groups. | Narcotic score (analgesic consumed* X frequency) did not parallel pain scores, because there was little evidence of any effect for any of the treatment groups. *analgesic score 0=none, 1=mild analgesic, 2=mild narcotic, 3=strong narcotic.
Conte 1994 95178399 | Chemotherapy vs. chemotherapy plus pamidronate 45 mg IV /3 weeks. Study duration = until death. | 2 | Parallel | Not stated | Open-label | 295 (283) | Not stated | Breast | Not stated | Bone pain | Not stated | Cancer/bone metastases | Not stated | Not stated | Reduction of bone pain, progression of bone metastasis. | 6-point self-assessment scale (none, mild, moderate, severe, very severe, unbearable). No. of patients with "some" or "marked" improvement. | Patients reporting "some" improvement were 83 (65%) & 80 (60%) in the pamidronate and control groups respectively. Patients with marked improvement were 54 (44%) and 38 (30%) in the pamidronate and control groups (p=0.025). | No quantitative data are included in the report.
Hortobagyi 1996 97081204 | Pamidronate 90 mg IV once monthly for 12 months vs. placebo. | 2 | Parallel | Site-specific, computer-generated randomization list. Stratification in two strata took place before randomization. | Double-blind | 382 (380) | 57 (±12),56 (±12) (all female) | Breast 100% | 17%, 14% (0) 40%, 39% (1-3) 43%, 47% (4-9) The ranges in parentheses represent a pain score, which is pain intensity multiplied by frequency (0=no pain, 9=constant pain) | Bone pain | Not stated | Cancer/ bone metastases | Skeletal complication, surgery, cord compression, Ca>12 mg/dl creatinine>2.5/dl, ascites or total bilirubin>2.5/dl NYHA rank III or IV, biphosphonate Tx 60 days prior, radiation or corticosteroid Tx for bone pain, calcitonin or plicamycin 2 weeks prior. | The analgesics patients were receiving throughout the study are not reported. | Assessments at 3, 4, 6, 9, 10, and 12 months of pain, and analgesic use, determinations of ECOG performance status, scoring on the Spitzer quality of life index, and physical examination. | The methods for bone pain and analgesic consumption assessment are not stated. Instead a published report is cited in which these methods are described. | There was significantly less increase in bone pain (p=0.046) and deterioration of performance status (p=0.027) in the pamidronate group than in the placebo group. | Also reported is a very significant difference in median time to occurrence of first skeletal complication (greater in the pamidronate group than in the placebo group).
Coleman 1997 98026760 | Pamidronate 120 mg IV vs. placebo IV bolus. | 2 | Parallel | Not stated | Double-blind | 51 (46) | Not stated | Breast 52/86 Prostate 17/86 Others 17/86 Population of both studies=86 | Not stated | Bone pain | Not stated | Cancer | Biphosphonates or other drugs known to affect bone metabolism in the previous 3 months. | Analgesics were given as necessary (but no other information is provided) | Pain intensity, analgesic consumption, and WHO score. These parameters were combined to produce the overall pain score (PPA). Also quality of life was assessed using the Rotterdam Symptom Checklist. Also biochemical markers of bone metabolism. | Scales not provided. | Five of 21 patients (24%) achieved a symptomatic response (>=20% reduction in PPA) to pamidronate compared with 1 of 25 patients (4%) with a response to placebo. A significant reduction of PPA was observed with pamidronate but not placebo. | This paper reports on two studies, one uncontrolled, open label and one randomized, placebo controlled. Data from the first study are not included in this table. Some data reported in the paper refer to the total population of both studies.
Vinholes 1997 98157475 | Pamidronate 120 mg IV vs. placebo (saline). | 2 | Parallel | Not stated (envelopes were used; no stratification was performed) | Double-blind | 52 (48) | 54 median (33.3%) | Breast 31/48 Prostate 10/48 Others 7/48 | 2.8 and 2.7 median pain intensity in respective groups (pam and plac) at baseline. A categorical scale was used (0-5, 2=moderate, 3=severe) | Bone pain | Not stated | Cancer/ bone metastases | Not stated | Not stated | Pain intensity, performance status, analgesic score, quality of life, biochemical markers of bone resorption. | Categorical scales for pain intensity (0=none - 5=intolerable), analgesic use scale (0-8), performance status (0-4). | The pain score improved with pamidronate and was unaffected with placebo; 4 weeks after the first infusion there was a significant difference in the pain score in favor of the pamidronate group. | By chance the overall quality of life was significantly worse in the active group at baseline compared with placebo, suggesting failure in the randomization or insufficient sample size.
Cascinu 1998 98200996 | Pamidronate 45, 60, 90 mg IV infusions q 3 weeks for 12 weeks. | 3 | Dosage comparison parallel | Not stated | Not blinded | 70 (64) | 61 (41-67) (Not stated) | Breast 56/70 Lung 6/70 Rectal 4/70 Kidney 4/70 | Not stated | Bone pain | Not stated | Cancer/ bone metastases | Hypercalcemia, asymptomatic bone metastases, brain metastases, prior treatment with biphosphonates, chemotherapy, or hormone therapy. | Patients were receiving diclofenac and morphine throughout the study. | Pain intensity, patient mobility, consumption of analgesics. | Questionnaire with items scored using a 4-point scale (0 to 3). | The highest pamidronate dose reduced pain intensity significantly more than baseline at three time points (6, 9, 12 weeks), the intermediate at two (9, 12 weeks), and the lower dose at one (12 weeks). Reduction of analgesic consumption for all three doses. | There is no control group, and the consumption of analgesics is not compared using a statistical approach.
Salmon calcitonin
Hindley 1982 83077452 | Salmon calcitonin 200IU SC every 6 hrs for 48 hrs vs. matching placebo. Study duration = 1 month or until death. | 2 | Parallel | Not stated | Double-blind | 32 (25) | Not stated | Various types not grouped | Baseline VAS > 5 | 16/25 bone pain | Not stated | Cancer/ bone metastases in some of the patients | Pain VAS score < 5, prognosis of less than 1 month, active therapy within the last 3 weeks. | All patients received narcotics and/or anti-inflammatory drugs. | Pain intensity, response to therapy. | VAS (0-20) by patient and 4-point verbal scale by investigator. An attempt was made to reduce analgesic medication in a step-wise manner. | There was no significant difference in the verbal rating and VAS scores between the two groups. No significant difference in the numbers of patients who increased their analgesic level by more than one step.
Roth 1986 87015715 | Salmon calcitonin 100IU SC daily vs. placebo. Study duration = 28 days. | 2 | Parallel | Not stated | Double-blind | 40 (38) | 52 and 53.5 (all female) | Breast | Baseline pain data not provided | Bone pain | Not stated | Cancer/ bone metastases | Not stated | Analgesic medication is not specified. | Bone pain (by patient), pain duration, functional capacity, analgesic consumption, assessment of the efficacy of treatment by the investigator. | VAS (0-10 cm) for pain intensity, pain duration scale 0=no pain, 1=1-6h daily, 2=7-12h daily, 3=13-18h daily, 4=19-24h daily. A similar descriptive scale for functional capacity. Investigator efficacy scale: less, moderately useful, extremely useful. | Pain intensity, analgesic consumption, and duration of pain were significantly less in the calcitonin group. The assessment by the investigator showed that the treatment with calcitonin was extremely useful.
Blomqvist 1988 88240810 | Salmon calcitonin 100MRCU/day injections vs. saline placebo. Study duration = 3 months. | 2 | Parallel | Not stated | Double-blind | 50 (49) | Not stated (all female) | Breast | Pretreatment pain VAS 6 and 6.1 in the two groups respectively; pain duration score 1.2 and 1.3 respectively | Bone pain | Not stated | Cancer/ bone metastases | Not stated | Analgesic medication is not specified. | Bone pain, pain duration, use of analgesic drugs and general performance. | VAS (0-10 cm) for pain intensity, pain duration scale 0=no pain, 1=1-6h daily, 2=7-12h daily, 3=13-18h daily, 4=19-24h daily. A similar descriptive scale for general performance. | Mean performance score and bone pain measured by VAS or pain duration score did not change during treatment, nor were there any differences between the two groups. No differences in analgesic medication consumption (no data reported).
Samarium-EDTMP
Resche 1997 98051358 | 153Samarium-EDTMP 0.5 or 1 mCi/kg or placebo. Study duration = 16 weeks. | 2 | Parallel | Not stated | Single-blind; patients knew they received active treatment | 114 (56) | 63.5 median (65.78%) | Prostate 67/114 Breast 36/114 Lung 2/114 Other 9/114 | Pain at one or more sites was a requirement for inclusion. No baseline pain levels are provided; 71% and 59% were receiving opioids at start | Bone pain | Not stated | Cancer/ bone metastases | Granulocyte < 2000 /microL, pl < 15000 /microL, creatinine <2.0 mg/dL, previous Tx with maximum tolerated radiation, systemic radio- or chemotherapy within 6 weeks, biphosphonate Tx within 6 months, or irradiation or hormonal Tx within 8 weeks of dosing. | A number of patients were receiving opioids; no other information is provided. | Level of pain, sleep characteristics, and analgesic were recorded daily by patient. Global assessment by physician at weekly intervals. | VAS (0-10 cm) for pain, descriptive scale for sleep. | Mean changes from baseline in the Area Under the Pain Curve (AUPC) were significant in the larger dose group at weeks 3 and 4. No changes were significant compared with baseline in the lower dose group. The difference was significant between groups at week 4. | Females with breast cancer among other subgroups have the most noticeable improvement.
Serafini 1998 98211795 | 153Samarium-EDTMP 0.5 or 1 mCi/kg or placebo. | 3 | Parallel | Not stated | Double-blind (for 4 weeks of the 16 weeks) | 118 (30) | 63.5 (24-83) (78%) | Prostate 80/118 Breast 21/118 Lung 6/118 Other 13/118 | Not stated | Bone pain | 35.5 to 42.9 months (median duration of disease, not necessarily pain) | Cancer/ bone metastases | Radiotherapy or chemotherapy targeting metastases (6 weeks), hormonal Tx (8 weeks), strontium-89 (9 months), biphosphonate (6 months), other experimental drug (6 weeks), bone fractures, cord compression, allergy to phosphonates, inability to complete diaries. | NSAIDs/acetamin-ophen +/− codeine or oxycodone for mild to moderate pain, long-acting morphine sulfate with morphine sulfate tablets or liquid morphine for severe pain. | Pain intensity in 13 body sites, average oral daily morphine equivalent dose, global assessment by physician (PGA) (worse, no change, marked relief). | VAS (0-10 cm), calculated and averaged areas under curve for pain intensity (AUPC). | During the first 4 weeks patients who received 1 mCi/kg Sm had significant reductions of pain in both patient-rated and physician-rated evaluations. The 0.5 mCi/kg dose produced pain relief significantly different to placebo only during the first week. | Well-designed study

Tx = Therapy; SC = subcutaneous

1 Neuropathic, somatic, or visceral.

2 Cancer, sequel of treatment, or procedure related.

Evidence Table 8 - Chemo- or Radiotherapy: Randomized Controlled Trials in Cancer Pain

Author, year, identifier | Treatment(s) studied, dose, route | Number of study arms | Study design (crossover, cohort, etc) | Method of randomization | Blinding | Total number enrolled (evaluable) | Mean age or range (% male) | Type(s) of cancer | Baseline pain severity | Type of pain ^1^ | Chronicity of pain (range or average) | Source of pain ^2^ | Exclusion criteria | Rescue medication (all arms) | Outcomes assessed | Outcome scales | Outcomes | Comments
Radionuclide Therapy
Lewington 1991 92000881 | Strontium-89 vs. stable strontium. Study duration = 5 weeks. | 2 | Crossover | Random number tables and coded vials. | Double-blind, placebo-controlled -- the inactive strontium was considered placebo. | 32 (26) | 64-79 (100%) | Prostate | Not stated | Bone pain | Not stated | Cancer/ bone metastases | Currently receiving local external beam radiotherapy, patients >80 yrs and those unable to complete the forms as well as patients with Karnofsky index < 5 | Not stated | Pain | Not stated, a reference of the methodology for pain assessment is provided. | Complete pain relief was reported only following strontium-89. | Statistical comparisons or results with respect to pain are not provided.
Quilty 1994 94316817 | External beam radiotherapy vs. strontium-89. Study duration = 12 weeks. | 2 | Parallel | Not stated | Not stated | 305 (284) | 69 (40-83) (100%) | Prostate | Baseline pain evaluation not provided | Not stated | Not stated | Cancer/ bone metastases | Patients with immediate risk of spinal cord compression or pathological fracture or who were taking calcium supplements. | Patients were receiving analgesics; no other information available | Pain site, type, and severity. Analgesic intake was recorded at each visit. | A questionnaire was used. Type was defined as "on pressure/movement," "intermittent," or "constant"; and severity was rated (mild, moderate, severe, or intractable). Changes vs. baseline values of analgesic intake and pain at original sites were recorded at each visit. | Pain relief at index pain sites and reduction of analgesics were similar in both strontium-89 and external radiotherapy (NS). Significantly more patients (p<0.05) in the strontium-89 group were free of newly painful sites compared with external RadTx. | While pain relief and comparison of analgesic intake were similar, strontium was shown to significantly delay progression of new pain sites.
Chemotherapy
Schmidt 1979 79132757 | Cyclophosphamide vs. DTIC vs. procarbazine. Study duration = 12 weeks. | 3 | Parallel | Not stated | Not blinded | 165 (129) | ~68 (100%) | Prostate (stage D) | Not stated | Not stated | Not stated | Cancer | Not stated | Not stated | Subjective response to pain | Not stated | Percentage responses with respect to pain are presented for the three groups. No significant differences were observed between the treatments. | The criteria for subjective response are not stated in the paper.
Coates 1987 88065744 | Continuous chemotherapy (doxorubicin+cyclophospha-mide or CMF +prednisone) vs. Intermittent chemotherapy. Study duration = unclear. | 2 | 2 x 2 factorial design | Randomized by telephone and stratified for institution, performance score, and previous adjuvant chemotherapy. | Not blinded | 308 (305) | Not stated (0.3%male) | Breast | Baseline pain not stated | Not stated | Not stated | Cancer/ metastases | Previous cytotoxic therapy for metastatic disease or extensive radiotherapy, history of other neoplasms, diabetes mellitus, cardiac failure, metastatic disease confined to the central nervous system. | Not stated | Pain as a domain of quality-of-life assessment | VAS scale (range not provided, probably 0-20 cm from figure) | It is stated that all end-points within quality-of-life assessments (by both physicians and patients) favored continuous therapy. Observations on pain are not specifically stated. | Analysis was based in 76% of patients.
Fossa 1990 91159052 | Estramustine vs. mitomycin. Study duration = until death. (first posttreatment assessment 6 weeks). | 2 | Parallel | Not stated | Not blinded | 162 (72 question-naires returned) | Not stated (100%) | Prostate | Pain at baseline (quite a bit, very much) 36/72 50% | Bone pain | Not stated | Cancer/ bone metastases | Not stated | Patients were receiving analgesics | Analgesic intake | The pain level was scored as follows: 0=no analgesics, nonnarcotic analgesics irregularly=1, nonnarcotic analgesics regularly=2, narcotic analgesics irregularly=3, narcotic analgesics regularly=4 | Treatment in most patients did not reduce pain. | No data or statistics are provided.
Labianca 1991 92075588 | Folinic acid + 5-Fluorouracil (5-FU) vs. equidose 5-FU. Study duration = 4 weeks. | 2 | Parallel | Randomization at central trial office, power analysis performed | Not blinded | 182 | 59 mean (54.39% male) | Colon 131/182 Rectum 51/182 | VAS at baseline: FA+5-FU=1.2 (0-9.5 range) 5-FU=1.1 (0-8 range) VAS (0-10 cm) | Not stated | Not stated | Cancer | ECG with signs of ischemia or rhythm alterations, second tumors, brain metastasis, no geographic accessibility and informed consent. | Not stated | Pain | VAS (0-10 cm) and degree: absent (0), medium (0.5-5), intense (5.5-10). | There was a significant increase of pain in both groups compared with baseline. No difference between groups was found.
Fraser 1993 93160019 | CMF vs. weekly low dose epirubicin IV/week. Study duration = until death. | 2 | Parallel | Stratification for sites of primary or metastatic disease and menopause. | Not blinded | 40 | 52, 63 (100% female) | Breast | Not stated | Not stated | Not stated | Cancer/ metastases | Postmenopausal women with locally advanced disease suitable for a trial of tamoxifen, those with a significant medical condition or known previous or current cardiovascular disease, and those who had received nonadjuvant chemotherapy. | Not stated | Pain as a domain in a quality-of-life instrument. Other quality-of-life assessments. | Nottingham Health Profile (NHP), no other information stated | A significantly better score in CMF than epirubicin was observed with respect to NHP pain score at 2 months (p<0.05). | Very little information is provided on precise methodology of the quality-of-life instrument used and pain score.
Sullivan 1995 96117533 | 5-FU + leucovorin (25 mg/day vs. 5-FU + placebo. Study duration = 3 months. | 2 | Parallel | Randomized by telephone using a computer-generated list. | Double-blind | 218 (210) | 66%>60 (61%) | Colorectal | At the start of treatment half of patients experienced disease-related pain. | Abdominal pain | Not stated | Cancer/ metastases | Prior radiation or chemotherapy, brain metastases, or a history of another malignancy. | Not stated | Pain and quality of life. | Pain was graded on a subjective scale of 0 (none) to 3 (severe). For quality of life, Karnofsky Performance Status and functional living index-cancer were used. | Improvement of abdominal pain was 43% and 33% in groups and of other pain 42% and 22% in 5-FU+LV and 5-FU+PL respectively at 120 days. No significant differences between groups with respect to pain.
Tannock 1996 96243733 | Mitoxantrone 12 mg/m2 + prednisone vs. prednisone alone (10 mg/day q2). Study duration = until death. | 2 | Parallel | Not stated | Not stated | 161 | 68 (100%) | Prostate cancer (metastatic adenocarcinoma -hormone resistant) | All but two patients had pain: Present Pain Intensity at start: 0 =2/161 1=53/161 2=67/161 3=30/161 4=9/161 | Bone pain | Not stated | Cancer/metastases | Prior malignancy, except nonmelanotic skin cancer, prior chemotherapy or treatment of cancer with glucocorticoids, radiotherapy in the last month or strontium-89 in the last 2 months, contraindications to use of prednisone such as active peptic ulcer. | Patients were receiving opioid and nonopioid analgesics | Pain relief (primary response criterion). Analgesic consumption score 1=nonopioid medication, 2=opioid medication. Secondary response criterion | Present Pain Intensity scale of the McGill Pain Questionnaire (0=no pain, 1=mild pain, 2=discomforting pain, 3=distressing pain, 4=horrible pain, 5=excruciating pain). A positive response was considered a 2-point reduction on two evaluations (3 weeks apart) | The primary criterion was met in 23/80 patients on mitoxantrone + prednisone and 10/81 on prednisone, which was significantly different. The response duration was also significantly longer in the combination treatment group (43 weeks vs. 18 weeks, p<0.0001) | The secondary response criterion was satisfied in 7 patients.
Radiotherapy
Tong 1982 82233408 | 4050 rad/3 weeks vs. 2000 rad/1 week and 3000 rad/2weeks vs. 1500 rad/1 week vs. 2000 rad/1 week vs. 2500 rad/week. Study duration = until death. Two groups were randomized, one with multiple metastases (M) and one with single metastases (S) | 2 and 4 | Parallel | Stratified for institution, primary site, metastatic site, and internal fixation (present or absent) | Not blinded | 1016 (759) | Not stated | Lung, prostate, breast, other. No other information provided. | Not stated | Not stated | Not stated | Cancer | Not stated | Not stated | Severity, frequency, type of analgesic, frequency of administration of analgesic. Pain score = pain severity X pain frequency, Narcotic score = medication type X medication frequency. | 4-point scale for pain (none, mild, moderate, severe), frequency (no pain, occasional, intermittent, constant), type of narcotic (none, analgesic [NSAID], mild narcotic, strong narcotic), frequency of administration (none, less than daily, once per day, more than once daily). | There were no significant differences between treatment groups in both single and multiple sites of pain. | Three basic responses were examined: minimal relief (pain score dropping below the initial score); partial relief (pain score dropping below four); and complete relief (pain score dropping to zero).
Madsen 1983 84111122 | 4 Gy in 6 fractions over 3 weeks with 2 fractions/week vs. 10 Gy in 2 fractions with an interval of 1 week. Study duration = 20 weeks. | 2 | Parallel | Not stated | Not blinded | 57 | ~65 (Not stated) | Breast=20/57 Prostate=11/57 Lung=6/57 Intestine=6/57 Uterus=4/57 Bladder=2/57 Myeloma=2/57 Lymphoma=1/57 Unknown=2/57 Kidney=3/57 | Baseline pain: (no pain/pain) 7/57, no analgesics/analgesics=6/57 | Bone pain | Not stated | Cancer/ bone metastases | Patients unable to determine subjectively the amount of pain and consent; less than 2 months between prior hormonal treatment and study start. | Patients were receiving analgesics; no other information provided | Pain intensity and consumption of analgesics. | VAS categorical scale where descriptors appeared below the line = no pain, slight, moderate, severe, unendurable pain. Scoring system for narcotic and nonnarcotic analgesics. | The results obtained between the two treatments were not significantly different.
Price 1986 87042093 | Single fraction 8Gy vs. 30 Gy in 10 daily fractions. Study duration = 28 months. | 2 | Parallel | Randomized by telephone using a code | Not blinded | 288 | 61.5 mean (Not stated) | Breast=107/288 Lung=58/288 Prostate=24/288 Kidney=8/288 Myeloma=23/288 Others=68/288 | Baseline pain in single and multiple fraction groups respectively: Severe = 73 & 48% mild/moderate = 33 & 29% | Not stated | Not stated | Cancer/ metastases | Prognosis < 6 weeks, incapability to complete the pain chart, inability to consent, pathological fracture of long bone, previous radiotherapy in the same site, change in systemic therapy 6 weeks prior to initiation of study. | Patients were receiving analgesics; no other information provided | Pain intensity, frequency of analgesic intake | 4-point categorical scale for pain: none, mild, moderate, severe, and 4-point scale for analgesic strength (none, nonnarcotic, mild narcotic, strong narcotic). Complete response was defined as a complete loss of pain. | No significant differences in speed of onset of pain relief or duration of response were seen between the two treatment groups. The incidence of complete response was not different between groups. Analgesics or baseline pain did not influence response.
Okawa 1988 89072185 | I = 5/week at 2 Gy/day total 30 Gy/15 fractions II = 2/week at 4.5 Gy/day total 22.5 Gy/10 fractions III = 3/week 2 Gy/day total 20 Gy/10 fractions. Study duration = not stated. | 3 | Parallel | Table of random numbers regardless of age, sex, and site. | Not blinded | 80 | ~58 mean (55%male) | Various | All patients had pain to some degree. Baseline data provided in a table | Bone pain | Not stated | Cancer/ bone metastases | Not stated | Not stated | Pain at baseline and degrees of improvement following radiation therapy. | 0=no pain, 1=mild pain (no drug), 2=moderate pain (drug needed po), 3=severe pain (pentazocin needed i.m.), 4=unendurable pain (narcotic drug needed). Improvement: excellent, good, fair, no change. A response of fair or higher was considered positive. | The response rate was 76%, 75%, and 78% in groups I, II, and III respectively. These rates were not significantly different between the groups.
Hoskin 1992 92187922 | Single fraction 4 Gy vs. single fraction 8 Gy RadTx. Study duration = 12 weeks. | 2 | Parallel | Randomization by telephone call to a central trials office | Not stated | 270 | Not stated | Breast=124/270 Lung=50/270 Prostate=35/270 Kidney=8/270 Myeloma=12/270 Other=41/270 | Pain scores at admission: no pain = 9/270, 3.33%. All other patients had variable degree of pain (mild, moderate, severe). Also, analgesics were administered to 81.1% of patients. | Bone pain | Not stated | Cancer/ bone metastases | Estimated prognosis of <6 weeks, pathological fracture, and inability to complete the pain form. | Patients were receiving analgesics (opioids, NSAIDs). | Pain | A 4-point categorical scale was used (0-3), 0=none, 1=mild, 2=moderate, 3=severe. Assessments were made at 2, 4, 8 and 12 weeks. Response was defined as an improvement of pain score in at least one category. | The response rates were 69% for 8 Gy and 44% for 4 Gy (p<0.001). There was no significant difference with respect to complete response rates (from some to none) or duration of response in the two arms. | Compliance with the pain chart was 72% at 4 weeks.
Medical Research Council 1992 92313868 | Two fractions radiotherapy (18 Gy, 8.5GyX2) [F2] vs. one fraction radiotherapy (10 Gy) [F1]. Study duration = until death. | 2 | Parallel | Randomized over the phone using a minimization procedure, stratifying for histological type and admitting radiotherapist | Not blinded | F1:118 F2:117 | 45 to 75+ (79%) | Lung (advanced) | Chest pain on admission: none = 41%, some = 59%, (some = mild, moderate, or severe) | Chest pain | Not stated | Cancer | Not stated | Not stated | Pain. Other symptoms were evaluated as well | A scale of 0-3: 0=none, 1=mild, 2=moderate, 3=severe. Palliation of a symptom was defined as disappearance of the symptom or improvement in one or more categories. | There was high proportion of palliation of pain in both groups. There were no differences between the two groups in any of the symptoms evaluated. | Patient proportions with palliation or disappearance of pain are provided.
Porter 1993 93239545 | Local field radiotherapy + Strontium-89 10.8 mCi vs. local field RadTx + placebo. Study duration = until death. | 2 | Parallel | Not stated | Double-blind | 126 | 71.25 yrs (100%) | Prostate/ metastases | 11.3±0.8 (active); 10.0±0.68 (placebo). Patients receiving strong opioids: 56.3% active and 43.9% placebo. | Bone pain | Not stated | Cancer/ bone metastases | Extensive soft tissue involvement; unwilling to give appropriate written informed consent. | Patients were receiving analgesics (opioids or NSAIDs) | Pain severity and frequency at index site, analgesic consumption by potency of agent and dosing. Also progression of pain by mapping at subsequent visits new pain sites and quality of life. Biochemical markers. | Pain score = severity: (0-4 scale, none, mild, moderate, severe, intractable) multiplied by frequency (0-4 scale: none, occasional, intermittent, frequent, constant). Analgesic intake = potency (0-4 scale) multiplied by frequency (0-4 scale). | Relief of pain at index sites was not significantly different between groups. A significantly greater proportion of patients had stopped taking analgesics in the active group (p<0.05). Also significantly more painful sites in placebo than active (p<0.002). | In the three pain variables assessed (pain, analgesic intake, and pain progression) two were significantly different in favor of active treatment.
Macbeth 1996 96409389 | 17 Gy (2 fractions 1 week apart) vs. 39 Gy (13 fractions, 5 days/week). Study duration = 3 months. | 2 | Parallel | Patients were randomized by telephone, stratification for consultant, performance status, histological type, and sex. | Not stated | 509 | <=54 to >=75 (79%) | Lung (inoperable non-small-cell) | Chest pain 152/254 (2 fractions group) and 137/253 (13 fractions group) | Not stated | Not stated | Cancer | Previous or concomitant malignant disease except basal cell carcinoma or in situ carcinoma of the cervix. | Not stated | Chest pain and 12 other symptoms | Rotterdam Symptom Checklist (RSCL), all symptoms scored as: not at all, little, moderately, or very much. Also an Anxiety and Depression Scale was applied. | Palliation of chest pain at 2 and 3 months following randomization did not differ between the two groups.
Teshima 1996 97073536 | Radiation (20 Gy) alone vs. radiation (RadTx)+ methylprednizolone (500 mg IV) (RT+MP). Study duration = 14 days. | 2 | Parallel | Peto's balanced randomized list | Not stated (probably not) | 38 | ~65 (55.3%) | Lung=8/38 Liver=7/38 Breast=10/38 Stomach=2/38 Prostate=2/38 Others=7/38 Unknown=2/38 | RTOG pain score, 0-9 range, (mean±SD): 5.59±1.77 RT 6.15+/2.5 RT+MP | Not stated | Not stated | Cancer/ bone metastases | Patients with severe inflammation or myelopathy caused by disease progression. | Not stated | Pain intensity | RTOG pain scale. | There was no significant difference between the two RT and RT + MP in pain scores. | A description of the RTOG pain scale and the actual pain data at different time points during and at the end of the study are not provided.
Niewald 1996 97138004 | Rapid course radiotherapy 20 Gy in 1 week (daily dose 4 Gy) vs. 30 Gy in 3 weeks (daily dose 2 Gy). Study duration = 12 months. | 2 | Parallel | Modified replacement randomization | Not stated (probably not) | 100 | 59.6 (Not stated) | Breast=43% Lung=24% Prostate=14% | Severe pain=64/100 Moderate=10/100 Slight=26/100 | Bone pain | Not stated | Cancer/ bone metastases | Patients with involvement of large parts of the vertebral column or the pelvis, or patients who had undergone surgery before radiotherapy in the later target volume. | Patients were receiving analgesics; no other information available. | Pain | Pain and mobility were assessed using a subjective scale (none, slight, moderate, severe). | There were no significant differences with respect to pain between the two groups. The proportion of patients with at least partial pain relief was 68% in group I and 83% in group II.
Rees 1997 97281585 | 17 Gy (mid-point dose 2 fractions 1 week apart) vs. 22.5 Gy in five daily fractions. Study duration = 24 weeks. | 2 | Parallel | Numbered sealed envelopes designed to balance at 200. (Derived from power analysis for 20% absolute difference, 80% power). | Not stated | 216 (187) returned questionnaire | 70 mean (77.3%) | Lung | Not stated | Not stated | Not stated | Cancer/ bone metastases | Previous radiotherapy or chemotherapy. | Not stated | Pain and other symptoms. | Yes or no, and if yes then mild, moderate, or severe. Also for other symptoms. | 88% of evaluable patients reported improvement of chest pain but there was no significant difference in the response rate between the two groups.
Nielsen 1998 98345210 | 8 Gy single dose vs. 20 Gy fractionated in four daily fractions. Study duration = 20 weeks. | 2 | Parallel. | Not stated | Open-label | 241 (239) | 67 median (30-87) (48.11%male) | Breast 34% Prostate 34% Lung 13% Other 14% | Not stated (patients suffered one bone metastasis localized in a single region) | Bone pain | Not stated | Cancer/ bone metastases | Previous radiotherapy to the region concerned, pathological fractures except compression fractures of the vertebral spinal column and suspicion of spinal cord compression. | Patients were receiving morphine. No other information is provided. | Pain and quality of life, intake of analgesics (type and dose of drug -- all doses were converted to morphine equivalents). | VAS (0-100 mm) and 5-point categorical scale (none, mild, moderate, severe, and excruciating) | Independent of the pain evaluation method there was no significant difference in pain relief between the two groups at any time of the follow-up period. Pain relief defined as >=50% reduction in VAS or by an improvement of one category on the 5-point scale. | Data are provided at 4 time points of the follow-up period.
Bailey 1998 98408959 | Continuous Hyperfractionated accelerated radiotherapy (CHART) vs. conventional radiotherapy (NSCLC). Study duration variable (short term = 3 months, long term = 1 and 2 years). | 2 | Parallel | Not stated; there was a 2/3 randomization in favor of CHART | Not stated | 356 (variable until completion of observation period) | Not stated | Small cell carcinoma (lung) | Not stated | Bone pain | Not stated | Cancer/ bone metastases | Not stated | Not stated | Pain as one of 30 symptoms. | RSCL and Hospital Anxiety and Depression Scale. In the first scale all symptoms were scored on a 4-point scale (not at all, a little, moderately, very much). The AUC was calculated for each symptom and each patient. | Short-term analysis (3 months) demonstrated nonsignificant differences between the two groups with respect to pain. (Mann Whitney U comparison of AUCs for pain, n=178). There is no reference on pain for the long-term survivors. | The numbers of long-term survivors in each group permitted identification of differences of 25% and 40% (1 and 2 years respectively) according to post-hoc power analysis. The randomization was unequal from the beginning of the study.
Jeremic 1998 98418606 | Single dose radiotherapy 4Gy vs. 6 Gy vs. 8 Gy. Study duration = 8 weeks. | 3 | Parallel | Not stated | Not stated | 327 (all) | 60 median (30-71) (37% male) | Breast=138/327 Prostate=54/327 Lung=62/327 Myeloma=17/327 Kidney=15/327 Rectum=24/327 Other=17/327 | Pain score at inclusion (all patients): None=17/327 Mild=44/327 Moderate=196/327 Severe=70/327 Analgesic requirement per group is also provided. | Bone pain | Not stated | Cancer/ bone metastasis in a single site (other metastases at later times were not considered) | Life expectancy < 8 weeks, existing pathological bone fracture or metastatic spinal cord compression or metastatic bone lesion located in superficial bones (ribs, clavicle, scapula, sternum) due to unavailability of orthovoltage x-ray machine). | Nonnarcotics, mild narcotics, and strong narcotics were administered. | Pain intensity and analgesic consumption, toxicity | 4-point categorical scale and three types of overall responses: complete response (CR)=complete disappearance of pain, partial response (PR)=improvement of pain by at least one category, and no response (NR)=no change in pain. | Overall response of groups II and III was significantly better than group I (CR +PR) at 8 weeks. Time to first occurrence of pain relief was significantly faster in group III compared with the other two groups. No significant differences in toxicity. | Data on responses at various time points up until 8 weeks are provided.
Hormonal Therapy
Rizzo 1990 90214984 | Leuprorelin acetate depot 3.75 mg vs. 7.5 mg vs. 15 mg vs. 30 mg SC once every three weeks. Study duration = not stated. | 4 | Parallel | Not stated | Not blinded, open-label | 47 (43) | 69 median (100%) | Prostate | Not stated | Bone pain | Not stated | Cancer/ bone metastases | Not stated | Not stated | Pain was classified according to its severity and frequency, type of analgesia used, and frequency used. | No scale is provided | In 8 of 16 patients (50%) there was complete disappearance in the subjective response of pain. No statistics or Tx group specific results are reported. | Very poor report.
Boccardo 1990 91243718 | Zoladex vs. Zoladex + Flutamide. Study duration = lifelong (this study is an interim report). | 2 | Parallel | Randomization at central trial office | Not blinded | 304 | 81 median (100%) | Prostate | Bone pain at baseline: Zoladex=38.2% Zoladex+Flutamide=33.5% | Bone pain | Not stated | Cancer/ bone metastases | Previous treatment with hormonal therapy and/or chemotherapy, performance status >3 according to Union Internationale Contre le Cancer (UICC) score, life expectancy < 3 months, inability to adhere to protocol due to distance or disease. | Not stated | Pain | Bone pain was evaluated using a 4-grade UICC score. | More prompt relief of bone pain was observed in the combined treatment group. | This report provides no numerical, graphic, or other form of the results or statistics; it is an interim report.
da Silva 1993 94085467 | Orchiectomy vs. LH-RH analog (goserelin 3.6 mg s.c.) and flutamide (250 mg tid). Study duration = 12 months. | 2 | Parallel | Not stated | Not blinded | 327 76 at start 48 at 6 months 29 at 12 months | Not stated | Prostate | At baseline 68% experienced pain (score 1-4) | Not stated | Not stated | Cancer/ metastases | Not stated | Patients were receiving analgesics; no other information available | Pain and other symptoms. | Pain was scored as follows: no analgesics, nonnarcotic analgesics used irregularly, nonnarcotic analgesics used regularly, narcotic analgesics used irregularly, and narcotic analgesics used regularly. | No comparisons were made between the two treatment groups with respect to pain/no pain outcome. Doctors' and patients' assessments were compared with respect to quality of life and were found different but without any statistics.

RadTx -- radiotherapy. CMF = cyclophosphamide

1 Neuropathic, somatic, or visceral.

2 Cancer, sequel of treatment, or procedure-related.

Evidence Table 9 - Educational-Behavioral-Psychosocial Interventions: Randomized Controlled Trials in Cancer Pain

Author, year, identifier | Treatment(s) studied, dose, route | Number of study arms | Study design (crossover, cohort, etc.) | Method of randomization | Blinding | Total number enrolled (evaluable) | Mean (±SD) age or range (% male) | Type(s) of cancer | Baseline pain severity | Type of pain ^1^ | Chronicity of pain (range or average) | Source of pain ^2^ | Exclusion criteria | Rescue medication (all arms) | Outcomes assessed | Outcome scales | Outcomes | Comments
Kane 1985 85185758 | Comprehensive hospice care vs. traditional medical care. Duration = 2 years or until death. | 2 | Parallel | Not stated | None | 247 | 64 (97%) | Lung, colorectal, prostate, ear, nose, throat, brain, bladder, and stomach | Not stated | Not stated | Not stated | Cancer | Not stated | Not specified (got among others acetaminophen + morphine equivalents) | Pain, depression, and anxiety | Ware General Well Being Scale, California Pain Assessment Profile, McGill Pain Questionnaire, Center for Epidemiologic Studies - Depression Scale. | No significant differences between groups in either the proportion of patients with pain at any time or the intensity of pain. | Interviewed at fixed schedule
McCorkle 1989 89354196 | Oncology home care nursing vs. regular home care nursing vs. office care group without home care. Duration = 6 months. | 3 | Parallel | Not stated | None | 166 (55) | 18-89 (63%) | Lung | Not specified (not even necessarily had to have had pain) | Not stated | Not stated | Cancer | Standard home nursing care within 6 months of entry to the study; enrolled in either oncology regular home care nursing before enrollment in the study. | Not stated | Pain intensity, distress, social dependency, health perceptions. | Symptom Distress Scale, McGill Pain Questionnaire, Inventory of Current Concerns, Profile of Mood States, Enforced Social Dependency Scales, (adjective list) | The three groups did not differ with respect to pain, mood disturbance, and concerns. Both home care nursing groups had less distress and greater independence for 6 weeks longer than the office care group, but reported worse health perception over time than the office care group. The latter group had improved perception of health over time.
Arathuzik 1994 94332824 | Relaxation and visualization vs. relaxation and visualization and cognitive coping skills training vs. control. Duration = 75-120 minutes. | 3 | Parallel with pre- and posttesting | Not stated | None | 24 (Not stated) | 31-80 (all female) | Breast | VAS (0-10): 4.5, 4.875, and 4.375 in 3 groups, respectively. | Metastatic bone pain in 2/3 | Not stated | Cancer/ bone metastases in 67% | Brain metastasis, terminal stage of disease. | Analgesics administered parenterally (no other information) | Pain intensity, pain distress, pain control, mood state, ability to control pain. | Johnson Pain Intensity - Distress scales, Rosenstiel pain control scale, Profile of Mood State | Both treatment groups perceived more ability to decrease pain than controls, but no between-group differences were found in pain intensity or distress or mood. | General Health Rating Index, Medical Record Review Instrument. "Cognitive-behavioral interventions could be useful clinical nursing interventions for selected cancer patients."
Kravitz 1996 97063270 | Graphical display of cancer patients' pain vs. no display (control). Periodic pain assessments were made in both groups. Duration = 5 days. | 2 | Parallel | Not stated | None | 78 (72) | 51.1 (56.4%) | Not stated | Mean current pain (VAS) = 2.03 (intervention) and 2.96 (control); mean worst pain in previous 24 hr = 5.68 (intervention) and 6.51 (control). (No standard deviation reported.) | Not specified | Not stated | Cancer pain | Not stated | Opioids (unspecified) | Current pain and worst pain during the last 24 hrs, hrs of sleep, symptoms (nausea, vomiting, constipation, loss of appetite, drowsiness and depression); quality of life (0-10 scale), opioid analgesia score. | VAS (0-10), 5-point verbal scale. VAS scale for symptoms and descriptive scale for quality of life. | No evident beneficial effect of the intervention on pain control, sleep, cancer-related symptoms, or analgesic dosing. | All patients had periodic pain assessment by staff. Confidence intervals were broad.
Elliot 1997 97281966 | Community educational intervention provided by community leaders, physicians, and nurses on pain vs. control (no intervention). Duration = 15 months. | 2 | Parallel with pre- and posttesting | Not stated | None | 438 patients (320, 82%) 167 physicians (124, 86%) 177 nurses (150, 86%) | 67 (±14) (49%) | Not stated | 2.9±2.0 (VAS 0-10) | Not specified | Not stated | Cancer-related | Not stated | Not stated | Pain intensity, consumption and prescribing of analgesics | VAS (0-10 cm) for 4 questions in Brief Pain Inventory (pain now, worst pain in the last 7 days, least pain in the last 7 days, average pain in the last 7 days). Pain Management Index. | Pain intensity score and prevalence of pain were slightly reduced in the communities subjected to the educational intervention, compared with control communities. None of the observed differences were significant. | The study concerns educational intervention at the community level rather than the patient level.
Trowbridge 1997 97457514 | Clinical Practice Intervention (review of patient charts that included pain rating scales) vs. control (no review of pain summaries). Duration = 4 weeks. | 2 | Parallel | Not stated | None | 510 patients (320) 22 oncologists | 65.7 median (43% & 54% in treatment and control group, respectively) | Recurrent metastatic disease, leukemias, stage III/IV lymphomas, and myeloproliferative diseases | Not stated | Not specified | Not stated | Cancer related | Nodal metastases from breast or colorectal cancer, unable to understand or read informed consent and survey instruments, refusal to participate, first clinic visit. | Not stated | Pain intensity and analgesic medication prescribed, combined in Pain Management Index (PMI). | PMI: pain medication level on a scale from 0 to 3, and pain level on a scale from 0 to 3. Negative PMI indicates insufficient treatment. | A significant difference in the physicians' patterns of prescribing analgesics was found (0.0162). A significant decrease in the incidence of pain described as "more than life's usual aches and pains" was found for the intervention group. (p=0.05) | Thirteen oncologists and 23 clinics participated; unclear how these 13 physicians were randomized to yield 10 with pain summary sheets and 12 without. Raw data are not provided in tables or figures or even in descriptive form.
de Wit 1997 98074868 | Pain education program by nurses vs. control (no education). Duration = 8 weeks post-discharge. | 2 (2 subgroups in each, according to whether district home nursing offered) | Parallel with pre- and posttesting | Not stated; prerandomization stratification for gender, age, and metastatic sites. | None | 383 (313) | 55.5 (±12.4) (37.4%) | Breast=30% Lip,oral,pharynx=5.8% Gastrointestinal=12.1% Lungs,thorax=10.9% Bone, connective skin=13.7% Genitourinary=23.6% | Mean Pain Rating scale of the McGill Pain Questionnaire (range, 0-50) at baseline = 18.2 (maximum range, 0-48) | Not specified | 14.2±33.4 months (1-324 months) | Tumor involvement=64.9% Cancer treatment=11.5% Tumor involvement and cancer treatment=6.7% Related to disease or debility=12.5% Unknown=5.5% | "Inclusion and exclusion criteria were" pain related to cancer, cancer therapy, or illness; pain duration of at least 1 month; life expectancy of at least 3 months; able to read and speak Dutch; accessible by telephone; not residing in nursing home or retirement home. | Analgesics=88.2%, coanalgesics=55.6,% TENS=00.3%, other=3.3% | Pain experience, Present Pain Intensity and Average Pain Intensity | Dutch language version of the McGill Pain Questionnaire | Pain education program produced a significant increase in pain-related knowledge and a significant decrease in pain intensity (the latter mainly in the group without district nursing) | Very well-designed study and comprehensive presentation. Pain education program had information about pain and pain management; self-recording of pain in diary; help-seeking behavior with regard to pain and pain management.

1 Neuropathic, somatic, or visceral.

2 Cancer, sequel of treatment, or procedure-related.

Evidence Table 10 - Hypnosis: Randomized Controlled Trials in Cancer Pain

Author, year, identifier | Treatment(s) studied, dose, route | Number of study arms | Study design (crossover, cohort, etc) | Method of randomization | Blinding | Total number enrolled (evaluable) | Mean (±SD) age or range (% male) | Type(s) of cancer | Baseline Pain severity | Type of pain ^1^ | Chronicity of pain (range or average) | Source of pain ^2^ | Exclusion criteria | Rescue medication (all arms) | Outcomes assessed | Outcome scales | Outcomes | Comments
Zeltzer 1982 83059117 | Hypnosis vs. nonhypnotic behavioral techniques for pain relief during bone marrow aspiration (27) and lumbar puncture (22) | 2 | Parallel | Not stated | Not blinded | 45 (33) | 10.5 (6-17) (51.51%) | Leukemia 28/33 NH Lymphoma 3/33 Neural tumors 2/33 | Not stated | Procedural (bone marrow aspiration or lumbar puncture) | Acute pain | Procedure related | Twelve of those eligible had "no need for intervention" regarding pain and anxiety | NA | Pain intensity and anxiety | 5-point scale (1=no pain, 5 maximum) patient rated | Preintervention pain was similar in both groups (4.51±0.68 for bone aspiration and 3.7±1.12 for lumbar puncture) Hypnosis was more effective in reducing both pain and anxiety in both procedures. | No differences were observed between adolescents and pre-adolescents with respect to their responses to both interventions.
Wall 1989 89148152 | Hypnosis vs. cognitive strategies | 2 | Parallel | Prerandomization stratification in two age groups (5-11 and 12-18). | Blinding in the sense that procedures were named as "cognitive" or "hypnosis" | 42 (20) | 5-18 (Not stated) | Not stated | Not stated | Procedural (lumbar puncture, bone marrow aspiration) | Acute pain | Procedure related | Not stated | Not stated | Anxiety, procedural anxiety and procedural pain | VAS (1-100 mm), McGill Pain Questionnaire if >12yrs, BPI, State-Trait Anxiety Inventory, Preset Pain Index + Pain Ranking Index. | Hypnosis and active cognitive treatment both decreased pain by self-report. | Because data were collected at second procedure, may patients have had less pain because they had less fear (but of note - no decreased anxiety during intervention)? Study also does not comment on pain medication given preprocedure and their effect.
Syrjala 1992 92270268 | Hypnosis training (HYP) vs. cognitive-behavioral (CB)* vs. therapist contact (TC) vs. treatment "as usual" (TAU) for cancer pain in bone marrow transplant patients [*see text for items of cognitive-behavioral training] | 4 | Parallel | Not stated | Not blinded | 67 (45) | 19-49 (58%) | Hematological malignancies or lymphoma | Not stated | Oral mucositis pain post-marrow transplant | Not stated | Sequel of treatment | Not stated | NA | Pain intensity, opioid use, nausea, and emesis | VAS (0-100 mm) and opioid use (morphine equivalent) for pain, 0-3 scale for emesis (by nurse), Sickness Impact Profile and Brief Symptom Inventory | Oral pain was significantly less in the hypnosis group compared with the other groups. Oral pain was lower in women than in men. regardless of treatment. Differences in emesis, nausea, and opioid use were not significant. | Well-designed study with fairly sufficient observation period (3 weeks) following marrow transplantation.
Sloman 1995 96099376 | Progressive muscle relaxation (tape) vs. guided imagery (live) vs. no treatment (control) | 3 | Parallel | Not stated | Not blinded | 67 (60) | 64 (71.6%) | Abdominal structures 28% Pelvic and UT 21% Breast, lung, thoracic 18% Brain/spinal cord 15% Musculoskeletal 15% Hematological 12% | Not stated | Not stated | Not stated | Not stated | Prior use of relaxation or meditation techniques or prior involvement in pain control study | Morphine plus NSAIDs | Pain sensation, pain affect, present pain intensity, overall pain intensity, morphine intake (mg/wk), nonopioid prn analgesia | SF-MPQ and VAS scale | Six hypotheses of reduction of pain or opioid consumption were tested. In four of them the live group and the tape group (3) produced a significant reduction of pain qualities. There was no difference in pain affect and opioid requirements.
Syrjala 1995 96187377 | Cognitive-behavioral and imagery relaxation vs. therapist support vs. relaxation + imagery vs. treatment as usual | 4 | Parallel | Randomization method not stated, patients were stratified for non and total body irradiation and gender | Not blinded, but patients were not told the content of treatment prior to randomization | 94 (all) | 36.3 (±9.4) (18-56) (55%) | Leukemia, myelodysplastic syndromes, or lymphoma | Pain was rated (but complex data form); VAS pain scores adjusted for mucositis and SCL-90-R | Oral mucositis pain | Duration maximum from 10 days prior to BMT to end of study; 5 weeks for oral mucositis pain | Sequel of treatment | Pain problems at the time of consenting; actively practicing imagery. (67 patients dropped out) | Continuous IV opioids plus boluses from PCA | Pain intensity, nausea, opioid use. | VAS (1-100 mm) for pain, VAS for nausea, oral mucositis index, symptom checklist 90-Revised 0-4 scale for patient satisfaction from the program in relieving pain. | Relaxation with imagery and cognitive with relaxation and imagery package produced better pain relief than the other two groups | Well-designed study as the previous one.

1 Neuropathic, somatic, or visceral.

2 Cancer, sequel of treatment, or procedure related.

NA = not applicable

Evidence Table 11 - Neurolytic Celiac Plexus Block: Randomized Controlled Trials in Cancer Pain

Author, year, identifier | Treatment(s) studied, dose, route | Number of study arms | Study design (crossover, cohort, etc) | Method of randomization | Blinding | Total number enrolled (evaluable) | Mean age or range (% male) | Type(s) of cancer | Baseline pain severity | Type of pain^1^ | Chronicity of pain (range or average) | Source of pain^2^ | Exclusion criteria | Rescue medication (all arms) | Outcomes assessed | Outcome scales | Outcomes | Comments | Side effects assessed | Quantitative/qualitative assessment of side effects | Statistical comparisons on side effects | Time of assessment(s) of side effects | Treatment-response or Dose-response relationship for side effects
Ischia 1992 92197865 | Three posterior celiac plexus block techniques, transaortic, retrocrural, and chemical splanchnicectomy. Follow-up until death. | 3 | Parallel | Not stated | Not blinded | 61 (20 per CPB group, 21 in splanchnicectomy group) | 39-73 | Pancreatic (positive needle aspiration diagnosis prior to entry) | >6 on VAS scale for 18/20 in two CPB groups and 17/21 in the third group | Visceral (continuous, sometimes intermittent) | Mean ∼ 4.7 months (range 1 - 11) in all three groups combined | Cancer | Not stated | NSAIDs, opioids or NSAIDs + opioids | Qualitative and quantitative pain assessment, performance status, side effects. Pain assessed during the 5 days after the block and in the long term until death. | Arner and Arner pain classification; VAS; Karnofsky and Burchenal index. | There were no statistically significant differences among the three techniques. Of the total patient population 32/61 (52%) had residual pain (17 had pain at a different site or different type compared with the original pain). 29/61 had immediate pain relief and the incidence of recurrence of pain in this group increased as a function of time of survival. The mean time interval between onset of pain and performance of the block was 4.7 months. | Comparison of outcomes between the 3 techniques shows no difference. Success rate [complete abolition of celiac pain] in all patients together is high, both immediately (70-80%) after block and until death (60-75%), with no operative mortality. In patients with either complete or partial pain relief, those with a good response to NSAIDs prior to block had better immediate results from the block compared with those with poor response to NSAIDs. Overall (until death) celiac block provides complete pain relief in 10-24% and when combined with other treatments, in 80-90%. | 1. Orthostatic hypotension 2. Diarrhea 3. Dysesthesia 4. Transient interscapular back pain 5. Hiccoughing 6. Hematuria | Incidence of block-related side effects in each group. | Chi-square between celiac block techniques. | The first 5 postblock days, plus regular assessment by phone or office visits twice weekly for a month, then once a week until death. | The incidence of side effects across groups was: orthostatic hypotension 10%-52%, transient diarrhea 5%-65%, transient dysesthesia 5%-14%, transient interscapular back pain 15%-19%.
Mercadante 1993 93205431 | Celiac plexus block vs. NSAID-opioid sequence according to WHO method (weak opioid= dextropropoxyphene, strong opioid = morphine). Follow-up until death. | 2 | Parallel | Not stated | Not blinded | 20 initially (10 in each group, declining to 3 in WHO and 4 in CPB group) | 62.7 (unknown if mean or median) 55% male | Pancreatic | Baseline VAS Group A: 6.59±0.76 Group B: 5.5±0.4 Group A: NSAID+opioid Group B: CPB plus NSAID+opioid | "severe" Group A: 10 abdominal, 5 back, 1 shoulder Group B: 9 abdominal, 1 back | Not stated, but Group A: 191 days from diagnosis Group B: 206 days from diagnosis | Cancer | Not stated | Continued administration of oral or subcutaneous opioids titrated to VAS <4 cm. | Pain intensity, opioid consumption. | VAS (0-10 cm) for pain, integrated VAS and consumption: (1+M/10)xVAS, where 1 indicates administration of NSAID at fixed times and full dosage, M indicates the opioid dosage in oral morphine equivalents. | There was no difference between the two groups in pain relief or survival (median duration of study 51 days). Integrated VAS x consumption scores were lower until the 4th week in the group that received the block. Opioid consumption was lower in the CPB than WHO groups at all weeks until death, and lower than baseline values in weeks 1 and 2 post CPB. | Both celiac plexus block treatment and NSAID + opioid achieved equal pain relief. Opioid consumption and opioid-related side effects gradually increased in control group and decreased in CPB group. There was no difference in nausea and constipation between the two groups. Study suggests celiac block reduces opioid-related side effects. The integrated score (VAS x daily dosage) supports the above conclusion. | 1. Drowsiness 2. Tiredness 3. Hypotension 4. Back pain 5. Diarrhea 6. Constipation 7. Nausea | No objective assessment criteria reported. Adverse events related to the block seemed fewer than those attributed to WHO-based therapy, but were not defined objectively. One case of prolonged diarrhea, two cases of orthostatic hypotension (still present at 48 hrs after the block), and one case of back pain at the site of injection reported in the CPB group. | Not reported | Not specified: "side effects were recorded during the course of treatment." | Side effects are attributed to one or the other treatment as follows: Due to opioids:
  Incidence | Grp A | Grp B
  1. Drowsiness | 2 | 0
  2. Tiredness | 3 | 1
  3. Constipation | 6 | 5
  4. Nausea | 1 | 1
  Due to the block: | (Grp B only)
  1. Hypotension | 2
  2. Back pain | 1
  3. Diarrhea | 1
Lillemoe 1993 93256637 | Intraoperative chemical splanchnicectomy with 50% alcohol vs. saline placebo in patients with unresectable pancreatic cancer. Duration of study: until death. | 2 | Parallel | Not stated | Double-blind | 139 (137) from 371 screened | 64 (57% in saline group, 60% in alcohol group) | Pancreatic, inoperable | Baseline pain 2.1±0.3 alcohol 2.0±0.3 placebo Baseline mood and disability were also assessed using VAS | Not stated | Not stated | Cancer (potentially painful postoperative complications such as cholangitis, biliary anastomotic leak equivalent in alcohol and saline group noted but without intergroup differences) | Inclusion criteria: patients with suspected pancreatic carcinoma to undergo surgical exploration for resection or palliation. Only patients with unresectable pancreatic carcinoma (histologically proven) were randomized. | Not stated explicitly, although opioids available "if required" | Pain intensity, mood, degree of disablility, survival time. Assessments were performed preoperatively, and at 2, 4, and 6 months and before death. | VAS (0-10 cm) scores for pain intensity, mood, and degree that pain interfered with activity. | Mean pain scores were significantly lower in the alcohol group at 2-, 4-, 6-month follow-up and at the final assessment (p<0.05). Poststratification analysis in patients given alcohol showed significantly less pain between than after placebo whether or not preoperative pain had been present. | Statistical comparisons between the two groups were performed at each time point (pairwise) and likely uncorrected for multiple comparisons. One of the comparisons in VAS for pain is marginally significant. Kaplan-Meier analysis used to compare survival in alcohol or placebo groups. | Not reported in detail, although stated to be the same in alcohol or placebo groups. | Not reported | Not reported | Postoperative: 14 days in both groups | Not reported
Kawamata 1996 96377487 | Celiac plexus block (CPB)* vs. NSAID-morphine for pain related to pancreatic cancer. Duration of study: until death. *percutaneous posterior approach with X-ray guidance | 2 | Parallel | Not stated | Not blinded | 21 (10 CPB, 11 NSAID-morphine) | 67.5 (43% male) | Pancreatic | Baseline pain 5.5 CPB 4.9 NSAID + morphine Data from figure Baseline performance status and quality of life (multiscale and uniscale) also recorded | Not stated | Time from referral (does not reflect duration of cancer pain before treatment) 77±39d CPB 63±27days NSAID + morph. | Cancer | Not stated | po morphine dosage was increased when VAS was >3. The range of morphine dose at the initiation of the study was 20-60 mg/day. SC morphine was administered when patients were unable to swallow. | Pain intensity, morphine consumption, performance status, quality of life (multiscale, uniscale), and side effects. Pain and morphine consumption (mg/d) recorded weekly and performance status and quality of life recorded every 2 weeks. | VAS for pain intensity, daily dose of oral morphine equivalent (calculated from total consumption each week), multiple factor questionnaire for QOL (each of 10 factors is graded) and single VAS scale for QOL (very dissatisfied to very satisfied) descriptive scale (0-4) for performance status, 4-point scale for each side effect. | Significant differences between NSAID+morphine and CPB groups in VAS scores for the first 4 weeks postCPB and in morphine consumption for weeks 4-7 (inclusive) following CPB. The uniscale assessment of QOL was significantly lower in the morphine group on the 8th and 10th week compared with baseline, but not compared with CPB. | Authors suggest CPB does not directly improve QOL in patients with pancreatic cancer pain, but may prevent deterioration in QOL by its long-lasting analgesic effect, reduction of morphine consumption, and limitation of side effects. Number of patients per group is small and statistical analysis of outcomes with repeated measurements does not account for multiple comparisons. Differences in loss of appetite and nausea in favor of the CPB group at 6th and 8th, and 8th week respectively. | 1. Loss of appetite 2. Nausea 3. Tiredness 4. Insomnia 5. Constipation 6. Urinary retention 7. Back pain 8. Diarrhea | Assessment of side effects used 4-point scales (1=no symptom, 2=moderate, 3=severe but tolerable, 4=severe and intolerable). | Chi-square test between the two groups. | Baseline plus once every 2 weeks for 10 weeks (total of 6). Side effect assessments made by each patient. | No differences in side effects attributed to CPB or NSAID+ morphine. An insignificant trend towards an increase in opioid-related side effects (nausea, constipation) occurred in the morphine group during the interval of accelerating morphine consumption (4-7 weeks).
Polati 1998 98162436 | Neurolytic (alcohol) celiac plexus block (group 1) vs. diclofenac + local anesthetic celiac plexus block (group 2) | 2 | Parallel | Not stated | Not blinded | 24 (12 per group) | 58 (Not stated) | Pancreatic (positive needle aspiration cytology) | Mean pain score of 7.5 (range 6-10) in Group 1, 7 (range 6-9) in Group 2 | Visceral (including chronic episodic + colicky) | Mean 4.8 months (range 2-7) | Cancer | Not stated | Diclofenac, opioids available to all patients according to WHO method. | Drug consumption, presence of "complete pain relief" | VAS | Neurolytic celiac plexus block reduced analgesic drug consumption (significantly for diclofenac but significantly only through one-half of survival time for opioids) and drug-related adverse effects. | Pain relief data provided only in dichotomous form (absent or present). | 1. Hypotension 2. Diarrhea 3. Constipation 4. Nausea 5. Vomiting 6. Gastric ulcer 7. Local abscess | Dichotomous incidence data provided for each group. | Fisher's exact test (for categorical variables) but no specific P-value provided. | Not reported | The incidence of CPB-related complications was not significantly different between neurolytic or local anesthetic groups. Constipation and nausea were significantly lower in the CPB group.

QOL = quality of life.

Evidence Table 12 - Rhizotomy: Nonrandomized Controlled Trials in Cancer Pain

Author, year, identifier | Treatment(s) studied, dose, route | Study design | Total number enrolled (evaluable) | Mean age or range (% male) | Type(s) of cancer | Baseline pain severity | Type of pain ^1^ | Chronicity of pain (range or average) | Source of pain ^2^ | Exclusion criteria | Rescue medication (all arms) | Outcomes assessed | Outcome scales | Outcomes | Side effects assessed | Quantitative/ qualitative assessment of side effects | Statistical comparisons performed (studies with > one treatments or doses) | Time of assessment(s) of side effects (following treatment) | Dose-response relationship for side effect
Papo 1974 75052840 | Chemical rhizotomy with intrathecal phenol. Follow-up period not specified, but seems to be at least 3 weeks (see "Outcome scales"). | Case series Retrospective | 270 | Not stated | Gynecologic, rectal, abdominal; tumors of lungs, pleura, and mediastinum; primary and secondary bone tumors; kidney and bladder cancer. Incidence not presented. | Not stated | Not stated | Not stated | Cancer / metastases | Not stated | Not stated | "Pain result" | Result was "good" if the patient is "pain-free until death"; "fair" if pain relief "is sufficient to allow a significant decrease in the amount and kind of medication required to keep the patient comfortable for a prolonged period or if pain is completely relieved for over 3 weeks." | 40% (108 of 270 patients) had "good" results. In most of the cases the mean duration (2-4 months) was enough to relieve the patients until their death. In 25% treatment failed, i.e., pain symptoms remained unchanged after the fading of the anesthetic action of intrathecal phenol. No statistical analysis was performed. | Lower and upper limb weakness, urinary retention, urinary incontinence. | Lower limb weakness: 9 (mild and/or transient), 11 (severe). Upper limb weakness: 4 (mild and/or transient), 1 (severe). Urinary retention: 8 (transient), 5 (permanent) Urinary incontinence: 2 (transient). The actual total number of patients screened for side effects is not reported, although it is suggested that the incidence of bladder side effects refers only to the 39 patients "treated for saddle pain." | NA | Not stated | NA
Arbit 1989 90088006 | Modified open thoracic rhizotomy. Follow-up until death (6 to 45 weeks, median 22 weeks after procedure). | Retrospective study | 14 | 39-73 (9/13 male) | Lung or chest wall | Not stated, but required "extensive attempts at pain control with various analgesics including high-dose opioids" despite prior operation, irradiation, and chemotherapy in 9 patients. | Somatic, visceral | Not stated | Cancer / metastases | PaCO2 >50 mmHg or PaO2 <50 mmHg or a FEV1<1L. Unacceptable anesthetic risk. Individual patients selected according to source and location of pain, clinical examination, and radiologic findings. | Extensive use of opioids before the procedure. | Pain relief | 3-point scale (none, partial, excellent) | 9 (64%) had excellent pain relief, 4 (29%) had partial ("good") relief and 1 (7%) had no relief ("poor result"). | Minor postoperative nosocomial infection in 3 patients | None | NA | There are no specific time points of assessment of the outcome. | NA
Quinn 1988 89047024 | CT-guided nerve root block and ablation. Follow-up appears to have been for at least 4 weeks after procedure (see "Outcome scales"). | Retrospective study | Twenty patients with cancer had 27 nerve root ablations; 19 of these patients had diagnostic nerve blocks prior to nerve root ablations; 33 other patients in this series had nerve root blocks for nonmalignant disease. | Not stated | Not stated | Not stated | Not stated | Not stated | Cancer / metastases | Patients were excluded if the resultant neurologic motor deficit was unacceptable and if the life expectancy was not limited. | Not stated | Pain relief | In 15 cases the VAS was used, but these results are not reported. Clinical success was defined as significant pain relief for 4 weeks or for the remainder of the patient's life. | 17 of the 27 ablation procedures (63%) were successful on the basis of the criteria used. The thoracic ablations were successful in 9 out of 10 cases (90%). There were no complications. | No complications | None | NA | Not stated | NA

1 Neuropathic, somatic, or visceral.

2 Cancer, sequel of treatment, or procedure related.

NA = not applicable

Evidence Table 13 - Cordotomy: Nonrandomized Controlled Trials in Cancer Pain

Author, year, identifier | Treatment(s) studied, dose, route | Study design | Total number enrolled (evaluable) | Mean age or range (% male) | Type(s) of cancer | Baseline pain severity | Type of pain ^1^ | Chronicity of pain (range or average) | Source of pain ^2^ | Exclusion criteria | Rescue medication (all arms) | Outcomes assessed | Outcome scales | Outcomes | Side effects assessed | Quantitative/ qualitative assessment of side effects | Statistical comparisons performed (studies with > one treatments or doses) | Time of assessment(s) of side effects (following treatment) | Dose-response relationship for side effect
Rothbard 1972 72236751 | High and low cervical percutaneous radiofrequency cordotomy: Follow-up interval not stated, but all patients relieved of pain for at least 6 months. | Case series | 10 | 37-67 | Cervix 100% | "intractable" | Not stated | Not stated | Cancer | Not stated | Not stated | Not stated | Not stated | "All 10 patients were free of pain after the procedure and all forms of analgesics, previously necessary, were discontinued. The pain-free interval lasted from 6 to 29 months." | Not stated | Not stated | NA | Not stated | NA
Meglio 1981 82088062 | Percutaneous cervical cordotomy. Follow-up 11-38 weeks (16 patients surviving at the time of article submission for publication) 50% of patients had already received or were receiving palliative radiotherapy. | Case series | 52 | 56 (22-79) 28 male (52.8%) | Lung 17/52 Abdominal 7/52 Other 8/52 Pain location also reported: Cervicothoracic 11/52, thoracic 10/52 and lumbosacral 31/52 | Not stated (50% of patients had received or were receiving radiotherapy for pain) | Not stated but unilateral | 1-36 months (mean=9.1) | Primary or metastatic cancer | Not stated (pulmonary function in 6 lung cancer patients was studied and PaO2 was more than 65 mm Hg; also Rx therapy was discontinued at least 15 days before cordotomy) | Not stated | Pain relief (immediately after the operation and at 1, 2, 3, 4, 5, 10, and 15 weeks). Complications, mortality, occurrence of other pain syndromes, pain distribution. | Complete pain relief (from patient report) immediately after the operation and at 1, 2, 3, 4, 5, 10, and 15 weeks. Incidence of complications, mortality, the occurrence of other pain syndromes; pain distribution or cancer location or both. | 48/52 patients (92.3%) reported complete pain relief immediately after the operation. In 9 patients (9/43=21%) pain recurred 1 to 20 days after the operation. Highest incidence of path recurrence within first 2 weeks after operation. No recurrence later than 3 weeks after operation. | Respiratory dysfunction, paresis, bladder dysfunction, hypotension, and asthenia recorded in relation to the localization of the pain (cervico-thoracic, thoracic, lumbosacral). New contralateral pain syndromes occurred in 20/52 (38.4%) of patients 3 to 30 days after the operation. | Incidence: Respiratory dysfunction: 3/44 (6.8%) Paresis: 4/44 (9%) Bladder dysfunction: 2/44 (4.5%) Hypotension: 1/44 (2.2%) Asthenia: 1/44 (2.2%). Respiratory insufficiency, hypotension, and weakness occurred only in patients with lung cancer; 5/52 (9%) of patients died due to the procedure. | NA | Not stated | NA
Cowie 1982 83019163 | Anterolateral cervical cordotomy for intractable pain. Follow-up until death. | Case series | 56 (43 cancer patients) | 54 (17-72) (25/31 male) | Colorectal 10/43 Breast 8/43 Lung 6/43 Cervix 5/43 Ovary 4/43 Bladder 2/43 Thyroid 2/43 Uterus 1/43 Larynx 1/43 Pancreas 1/43 Sarcomas 3/43 | Not stated | Not stated | Not stated | Vertebral metastases | Not stated | Not stated | Pain relief | 4-point grading system: I=no pain, no analgesia required; II=infrequent and/or mild pain, weak nonnarcotic analgesics effective; III=frequent and/or moderate pain, strong nonnarcotic analgesics required for relief; IV=constant severe pain, narcotic analgesics required for relief | "Of the 43 patients who underwent surgery for malignant pain 95% of survivors had effective relief on discharge form the hospital, the success rate falling to 73% at 6 months, and 55% at 1 year of follow-up." | Urinary retention, ataxia, hemiparesis, respiratory failure, dysaesthesia | Incidence: Urinary retension: 6/56 (11%) Ataxia: 1/56 (~2%) Hemiparesis: 2/56 (3.6%) Respiratory failure: 2/56 (3.6%) Dysesthesia: 4/56 (7.1%) Mortality: 2/56 (3.6%), both patients with respiratory failure. Complication rates from both cancer and noncancer patients. Data are reported on incidence of complications after unilateral (44) and bilateral (9) cordotomy. | NA | Not stated | NA
Ischia 1984a 84271886 | Unilateral percutaneous cervical cordotomy for neoplastic vertebral pain | Case series | 69 | Not stated (65%) | Prostate 23.2% Breast 18.8% Lungs 15.9% | 43.5% treated with radiotherapy and 59.4% with opioid (po, parenteral or spinal) for 10 days to three months. In 68.1% pain was >6.0 and unilateral. In 31.9% pain was >6.0 (continuous or incident) with spontaneous or provoked contralateral pain | Bone pain | 10 days to 3 months prior to cordotomy | Cancer / metastases | Not stated | Residual pain contralateral to the lesion or pain ipsilateral to the lesion was treated with opioids. | Pain relief | Descriptive scale: none, moderate, severe. 0-10 VAS for initial pain. | Immediate results: 1) 62/69 (89.9%) complete analgesia (deep pin prick) 2) 7/69 (10.1%) hypoalgesia. Mortality in the first 7 days was 2/69 (2.9%). In 46 patients suffering from unilateral pain results in the contralateral side were no pain in 37 (80.4%), partial abolition of pain in 3 (6.52%), no abolition of pain in 6 (13.04%). In 21 patients with bilateral pain results in the contralateral side were no pain in 18 (85.7%), partial abolition of pain in 1 (4.76%), no abolition of pain in 2 (9.52%). | Two types of side effects are reported:1) loss of ability to walk and 2) urinary retention. | The ability to walk could not be evaluated in 19 preoperatively bedridden patients (27.5%) and 7 others (10.1%) who were bedridden after the operation. Urinary retention could not be evaluated in 11 patients (15.9%) as they were already catheterized. | NA | Not stated | NA
Ischia 1984b 84163936 | Bilateral percutaneous cervical cordotomy | Case series | 36 | Not stated | Mediastinal, pulmonary, abdominal and bladder neoplasms. | Not stated | Not stated | Not stated | Cancer / metastases | Not stated | Not stated | Analgesia, mortality, adverse sequelae. | Descriptive (no scales) | Deep pin-prick analgesia from T10, T4, or T1 to S5: 35/36 (97.5%), hypoalgesia T4-S5 1/36 (2.8%). Immediate effect on same side as lesion: Claude-Bernard-Horner syndrome 36/36 (100%). | Motor function, bladder function, hypotension, other (sleep apnea) | Motor weakness: 13 patients (36.1%) Paresis, 1 patient (2.8%) Total paralysis, 0 patients (0%) Ability to walk: Nonassessable, 21 patients (72.4%) Intact, 6 patients (20.7%), Lost, 2 patients (6.9%) Bladder Nonassessable, 12 patients (33.3%), Permanent urinary dysfunction, 12 patients (33.3%) Urinary incontinence, 2 patients (5.55%). Hypotension, 13 patients (36.1%) Sleep apnea (Ondine's syndrome), 0 patients. | NA | Immediately after cordotomy. | NA
Gildenberg 1984 84113768 | Midline open myelotomy (N=20), alone or with unilateral cordotomy. Follow-up until death. | Case series | 20 (4 with combined myelotomy and cordotomy) | Not stated | Pelvic malignancy | Not stated | Primary tumor and bone pain | Not stated | Cancer / vertebral and other bone metastases | Not stated | Not stated | Pain relief | Descriptive. (excellent = "virtually no pain remained"; good = "significant improvement and no longer required narcotics stronger than codeine, but still had some remaining pain"; fair = improved "but not enough to increase activity or decrease medication"; poor = "no change in pain") | 6/14 patients had excellent and 4/14 good pain relief after myelotomy. The combination of myelotomy and cordotomy produced good pain relief in 2 of 4 patients. | Motor weakness | 2/4 patients with combined myelotomy and cordotomy had ipsilateral leg weakness | NA | Not stated | NA
Nagaro 1994 95199762 | Percutaneous cervical cordotomy (PCC) and subarachnoid phenol block using fluoroscopy (SAPB-F) | Case series | 10 and 13 (for each procedure) | 58.3 (PCC) 58.1 (SAPB-F) | PCC patients Lung (10/10) SAPB-F Lung (9/13) Breast (1/13) Colon (1/13) Renal (1/13) Mesothelioma (1/13) | 8.5±0.9 (PCC) 7.5±1.9 (SAPB-F) | PCC: somatic (6/10), neuropathic (4/10). SAPB-F: somatic (12/13), neuropathic (1/13). | Not stated | Cancer / metastases | Inclusion criteria: good or moderate general and respiratory condition, PaO2 >70 mmHg without dyspnea. | Opioids (morphine, buprenorphine, pentazocine) and NSAIDs (indomethacin). In the PCC group 6/10 patients received epidural morphine (dose range 2-20 mg/daily), 3/10 patients received i.m. morphine, and 1/10 po morphine. In the SAPB-F group 4 patients received epidural morphine or buprenorphine and the remaining 9 received oral, i.m., or rectal morphine or pentazocine. | Pain intensity, before and 1 week after the block, performance status, morphine consumption, complications. | VAS for pain, 5-point WHO scale for performance status (0=able to carry out daily activities, 4=completely disabled) | Pain score decreased from 8.5±0.9 to 3.0±2.7 1 week after PCC. Pain Score (PS) was <3 in 80% of patients. Four patients required no analgesics, 2 had no change in analgesic dose. In 4 patients evaluation was difficult due to change of route and type of analgesics. After SAPB-F there was a decrease in pain score from 7.5±1.9 to 2.7±2.6. PS was <3 in 3/10 patients (76.9%). | For PCC: general fatigue, hemiparesis, In SAPB-F patients, side effects, complications, and changes in performance status were not explicitly described. | For PCC: General fatigue 6/10 (60%) Hemiparesis 2/10 (20%) | NA | One week after the block was performed and "intermittently thereafter" | NA
Fenstermaker 1994 95199762 | Percutaneous radiofrequency anterior cervical cordotomy | Case series | 6 | Not stated | Kidney (1) Breast (1) Ovarian (1) Lung (1) Bone (2) | Not stated | Not stated | Not stated. However, "3 patients had undergone previous lateral cervical cordotomies on the opposite side" | Cancer | Not stated | Not stated; however, 4 of 6 patients were intolerant to morphine. | "Result" of the procedure (fair, good, excellent without definition); complications | Not stated | Not stated | Bladder dysfunction | Permanent bladder dysfunction (1), transient bladder dysfunction (1), none (4) | NA | Not stated | NA

1 Neuropathic, somatic, or visceral.

2 Cancer, sequel of treatment, or procedure related.

NA = not applicable

Evidence Table 14 -- Adverse Events Reported During Oral Opioid Therapy of Cancer Pain: Data from Nonrandomized Studies

Author, year Identifier | Opioid | Trial design | Study size | Duration mean (range) | Dosage mean (range) | Naus | Vom | Const | Sed | Dry | Derm | D/C
Sykes 1998 ^1^ 99123675 | "Strong" | Cohort | 492 (498) ^1^ | NR | NR | NR | NR | 57% ^1^ | NR | NR | NR | NR
De Conno 1991 ^2, 2a^ 92043926 | Buprenor-phine | Cohort 5 arms | 245 (944) | 4 weeks | 0.5-0.6 mg/d (NR) ^2^ | 16% | 9% | 27% | 31% | 36% | 10% ^2^ | NR
Campora 1991 ^3^ 92043927 | Buprenor-phine | Cohort 4 arms | 132 (260) | 3 d | 0.6 mg/d (0.4-0.8) | 8% ^3^ | 23% ^3^ | NR | NR | NR | NR | NR
De Conno 1996 ^4^ 97028332 | Methadone | Case series | 196 | Up to 90 d | 14-24 mg/d ^4^ | 25% | 24% | 37% ^4^ | 54% | 29% | NR | 7% ^4^
Schug 1992 ^5^ 92325528 | Morphine | Cohort | 550 | 35 d (NR) | 82 mg/d (5-1900) | NR | 7% | 11% | 2% | NR | 4% ^5^ | NR
Ventafridda 1987 ^6^ 87224371 | Morphine | Case series | 390 | 120 d maximum | 134 mg/d (NR) | 13% | 9% | 73% | 48% ^6^ | 49% | 12% ^6^ | NR
Payne 1998 ^7^ 98211797 | Morphine SR | Cohort 2 arms | 295 | 2 weeks minimum | 195 mg/d (15-3000) | No adverse events = 36% No adverse events or were not bothersome = 46%
Campora 1991 ^3^ 92043927 | Morphine | Cohort 4 arms | 71 (260) | 3 d | 90 mg/d (60-180) | 18% ^3^ | 28% ^3^ | NR | NR | NR | NR | NR
Warfield 1991 ^8^ 92100664 | Morphine SR & IR | Cohort | 260 | NR | 80-150 mg/d (60-500+) | NR ^8^ | 17% ^8^ | NR | NR ^8^ | NR | NR | NR
Vijayaram 1990 ^9^ 91003862 | Morphine | Cohort | 223 | 10 d ^9^ | Initial: 120 mg/d Peak: 380 mg/d | 48% | | 11% ^9^ | NR | NR | 9% ^9^ | 2% ^9^
De Conno 1991 ^2, 2b^ 92043926 | Oxy-codone | Cohort 5 arms | 321 (944) ^2^ | 4 weeks | 17-20 mg/d (NR) ^2^ | 7% | 6% | 24% | 31% | 34% | 11% ^2^ | NR
Campora 1991 ^3^ 92043927 | Oxy-codone | Cohort 4 arms | 20 (260) | 3 d | 60 mg/d (40-120) | 10% ^3^ | 40% ^3^ | NR | NR | NR | NR | NR
De Conno 1991 ^2, 2c^ 92043926 | Dextropro-poxyphene | Cohort 5 arms | 107 (944) | 4 weeks | 192-246 mg/d (NR) ^2^ | 12% | 5% | 26% | 27% | 36% | 8% ^2^ | NR
De Conno 1991 ^2, 2d^ 92043926 | Penta-zocine | Cohort 5 arms | 139 (944) | 4 weeks | 150-181 mg/d (NR) ^2^ | 16% | 10% | 27% | 23% | 32% | 9% ^2^ | NR
De Conno 1991 ^2, 2e^ 92043926 | Codeine | Cohort 5 arms | 132 (944) | 4 weeks | 191-207 mg/d (NR) ^2^ | 15% | 9% | 25% | 29% | 38% | 8% ^2^ | NR
Campora 1991 ^3^ 92043927 | Codeine | Cohort 4 arms | 37 (260) | 3 d | 180 mg/d (120-300) | 16% ^3^ | 30% ^3^ | NR | NR | NR | NR | NR
Sykes 1998 ^1^ 99123675 | "Weak" | Cohort | 38 (498) ^1^ | NR | NR | NR | NR | 37% ^1^ | NR | NR | NR | NR

Const = constipation; d = days; D/C = discontinued drug due to adverse events; Derm = dermatologic adverse events; Dry = dry mouth; Naus = nausea; NR = not reported; Resp = respiratory depression; Sed = sedation; SR = sustained release; Vom = vomiting.

1Study on laxative use with various opioids. 498 total subjects; laxative use reported separately for when subjects on "strong," "weak," or no opioids. Specific opioids not reported. Constipation values refer to percentage of subjects using laxatives; 44% of subjects not taking opioids (n=110) used laxatives. In a subsample of 298 subjects, increased opioid dosage was associated with increased number of dosages of laxatives, but not with change in stool frequency.

2 944 total subjects, 5 drugs studied. Dosages are range of mean dosages in weeks 1 - 4. Dermatologic adverse events = pruritus.

2a Other: trembling 12%, vertigo 12%, agitation 15%, sweating 27%.

2b Other: trembling 12%, vertigo 9%, agitation 20%, sweating 21%.

2c Other: trembling 15%, vertigo 12%, agitation 19%, sweating 18%.

2d Other: trembling 21%, vertigo 15%, agitation 23%, sweating 21%.

2e Other: trembling 8%, vertigo 11%, agitation 13%, sweating 10%.

3 260 total subjects. Nausea = moderate to severe; vomiting = 2 or more episodes. Of note, percentage of subjects with vomiting always higher than those with nausea. Although not reported, presumably nausea and vomiting were mutually exclusive symptoms.

4 Adverse event data reported as exacerbation of symptoms from baseline (generally on other analgesics). Data on amelioration from baseline also reported. Range of mean daily doses of methadone reported. Percentage of subjects complaining of constipation generally stable through day 60 at 32% - 37%; at day 90, 78% of subjects had constipation (n = 43). 5% of subjects discontinued methadone due to sedation, 2% due to constipation. Other: respiratory depression 0%, coma 0%, hallucinations 0%, confusion 39%, subjective dyspnea (with no objective abnormalities) 25%.

5 Adverse event rate reported as percentage of patient-days with symptoms. Dermatologic adverse events = pruritus. Other: urinary retention 5%, sweating 2%.

6 Adverse event rate reported as percentage of patient-days with symptoms. Sedation = drowsiness. Dermatologic adverse events = pruritus. Other: sweating 27%. Dose-response data: From 30 mg/d - 120 mg/d, nausea = 25%, vomiting = 10%; From 121 mg/d - 270 mg/d, nausea = 19%, vomiting = 11%; At > 270 mg/d, nausea = 6%, vomiting = 9%.

7 Data on individual adverse events not reported.

8 Nausea, drowsiness, and confusion scored on a 5-point scale from 0 - 4. Mean scores were: nausea 0.16, drowsiness 0.62, confusion 0.27. Vomiting reported as occurring a mean of 0.17 times per patient-day.

9 Study from India. Data reported for up to 480 days; however, cumulative adverse events rate reported only at day 10. Low level of constipation explained by authors as due to typical high-fiber Indian diet. Dermatologic adverse events = pruritus. 3 discontinuations due to severe vomiting.

Evidence Table 15 -- Adverse Events Reported During Parenteral Opioid Therapy of Cancer Pain: Data from Nonrandomized Studies

Author, year Identifier | Drug, Route | Trial design | Study size | Duration mean (range) | Dosage mean (range) | Naus | Vom | Const | Sed | Derm | Resp | D/C
Meuret 1996 ^1^ 96214075 | Morphine, SC or IV, PCA | Cohort | 143 | 27 d (1-143) | 188 mg/d median (15-1008) | 15% | NR | 29% | 17% ^1^ | 9% ^1^ | NR | NR
Ferris 1990 ^2^ 90331094 | Morphine or Hydro-morphone, SC | Case series | 135 | 23 d (6-103) | M:(0.4-185 mg/hr) H:(0.4-140 mg/hr) | 4% ^2^ | 1% ^2^ | 8% ^2^ | 12% ^2^ | 7% | 0% ^2^ | NR
Bruera 1988 ^3^ 88253150 | Morphine or Hydro-morphone, SC | Cohort | 108 | 31 d (2-156) | M:305 mg/d (80-3000) H:310 mg/d (40-4024) | NR | NR | NR | 6% ^3^ | 7% ^3^ | 2% | 4% ^3^
Stuart 1986 ^4^ 87133016 | Morphine IV (continuous) | Case series | 79 (84) ^4^ | 7 d median (1-162) | 4.5 mg/h (0.5-300) | 0% | 0% | 70% | 51% ^4^ | NR | 18% | NR
Gagnon 1999 ^5^ 99349916 | Oxycodone SC ^5^ | Cohort | 63 | 11 d (1-49) | 149 mg/d (4.5-660) | NR | NR | NR | 2% | 3% ^5^ | NR | 3% ^5^
Moulin 1992 ^6^ 92183030 | Morphine or Hydro-morphone, SC | Case series | 60 | 62 d (NR) | 24 mg/hr ^6^ | 3% | | NR | 0% | NR | 2% | NR
Bruera 1987 ^7^ 87215722 | Morphine or Hydro-morphone SC | Cohort | 56 M=34 H=22 | 26 d (NR) | 126 mg/d (NR) | 0% | 0% | 0% | 5% | 5% | 2% | 0%

Const = constipation; d = days; D/C = discontinued drug due to adverse events; Derm = dermatologic adverse events; H = hydromorphone; IV = intravenous; M = morphine; Naus = nausea; PCA = patient-controlled analgesia; Resp = respiratory depression; SC = subcutaneous; Sed = sedation; Vom = vomiting.

1 Adverse events data reported for both groups combined. Sedation = "fatigue"; Derm = "local inflammation."

2 Adverse events data reported for both groups combined. Morphine (n=85), hydromorphone (n=30), or both in succession (n=20); adverse events data reported for all groups combined. Derm = "local problems." Adverse events classified as "secondary to infusion", "secondary to disease", or cause "not clear." Event rate "secondary to infusion" presented in this table. Total adverse events were: nausea 33%, vomiting 24%, constipation 13%, sedation 39%, respiratory depression 1%. Other: myoclonus 9% (total 13%), confusion 7% (50%), hallucinations 6% (16%), severe sedation 4% (4%), dizziness 2% (3%), mental cloudiness 2% (2%), Seizures 1% (3%), dry mouth 0% (2%), sweating 0% (20%). Laxatives were used by 79% of subjects; antiemetics were used by 59% of subjects.

3 Adverse events data reported for both groups combined. Morphine (n=62), hydromorphone (n=46); adverse events data reported for all groups combined. Sed = severe sedation. Derm = "chemical irritation" 6%, bleeding 1%. Other: local infection 2%. Discontinuations due to "chemical irritation" or "local toxicity."

4 84 infusions in 79 subjects. Sed = mild sedation or drowsiness. Other: mental clouding 32%, diaphoresis 20%, dry mouth 20%, hallucinations 15%, dizziness 3%.

5 Injectable oxycodone not available in the United States. 2 cases of local toxicity with higher concentration solution (>50 mg/ml). 1 subject discontinued due to sedation, 1 due to local toxicity with ecchymosis. Other: local infection 0%.

6 Adverse events data reported for both groups combined. Mean dosage reported as hydromorphone equivalent, conversion equation not reported. Other: confusion and myoclonus 10%, local infection 8%.

7 Adverse events data reported for both groups combined. Other: confusion 9%, local infection 4% (both subjects had neutropenia), bleeding 2%.

Evidence Table 16 -- Adverse Events Reported During Transdermal Fentanyl Therapy of Cancer Pain: Data from Nonrandomized Studies

Author, year Identifier | Trial design | Study size | Duration mean (range) | Dosage mean (range) | Naus | Vom | Const | Sed | Dry | Derm | Resp | hTN | D/C
Payne 1998 ^1^ 98211797 | Cohort (2 arms) | 209 | Minimum of 2 weeks | 84 mcg/hr (25-400) | No adverse events = 50% No adverse events or were not bothersome = 68%
Zech 1995 ^2^ 95329767 | Cohort [pilot] {main} | 70 [20] {50} | -- [7 d] {65 d (2-534 d)} | Various | NR ^2^ | NR ^2^ | NR ^2^ | NR ^2^ | NR ^2^ | -- [25%] ^2^ {18%} ^2^ | -- [0%] {6%} | -- [0%] {NR} | -- [NR] {2% ^2^ }
Sloan 1998 ^3^ 98408314 | Cohort | 53 | 58 d (up to 84 d) | 169 mcg/hr (NR) | 13% | 8% | 0% ^3^ | 4% | NR | NR | 0% | 0% | 13-17% ^3^
Donner 1998 ^4^ 98225278 | Cohort | 51 | 158 d (15-855 d) | 168 mcg/hr (25-1000) | 38% | 18% | 41% | 77% | 53% | 28% | 0% | NR | NR
Grond 1997 ^5^ 97213265 | Cohort | 50 | 66 d (3-535 d) | 200 mcg/hr (25-800) | 8% | 5% | 10% | 58% | 34% | 2% | 2% | NR | 2% ^5^
Korte 1996 ^6^ 97004059 | Cohort | 39 | up to 28 d | 140 mcg/hr (NR) | 69% ^6^ | NR | NR ^6^ | NR | NR | 10% | 3% | 3% ^6^ | 3% ^6^
Donner 1996 ^7^ 96377478 | Cohort | 38 ^7^ | 15 d | Initial: 1.4 mg/d (0.6-6.0) Final: 2.4 mg/d (0.6-12.0) | NR | NR | 35% ^7^ | NR | NR | 42% ^7^ | 0% | NR | NR
Hammack 1996 ^8^ 97054128 | Cohort | 30 ^8^ | NR | 75 mcg/hr median (25-200) | 43% ^8^ | NR | 66% ^8^ | 3% ^8^ | NR | 20% ^8^ | 7% ^8^ | NR | 13% ^8^

Const = constipation; d = days; D/C = discontinued drug due to adverse events; Derm = dermatologic adverse events; Dry = dry mouth; hTN = hypotension; mcg/hr = micrograms per hour; Naus = nausea; NR = not reported; Resp = respiratory depression; Sed = sedation; Vom = vomiting.

1 Data on individual adverse events not reported.

2 Data reported separately for pilot and main studies. In pilot: improvement seen in nausea, vomiting, constipation, sedation, and anorexia compared with prestudy on other (weak or strong) opioids; primary complaints were constipation, mouth dryness, and sweating. In main: improvement seen in nausea, vomiting, and constipation; no change in sedation, pruritus, sweating, and dizziness.

3 42% of patients on laxative. 2 of 9 discontinuations were due to adverse events believed to be unrelated to fentanyl. Specific reasons for discontinuation not reported.

4 Maximum percentage of adverse events from days 15, 30, 45. Other: 18% diarrhea; 30% dyspnea; 41% dizzy; 54% sweating; on laxative 35%.

5 Also diarrhea 4%; dyspnea 17%; sweating 28%; vertigo 5%. Single discontinuation due to respiratory depression.

6 Also vertigo 3%. 56% of subjects treated with regimens that placed them at risk for nausea; antiemetic treatment given on 26% of evaluated days. Laxatives required continually or intermittently in 87% of patients. Single episode of hypotension associated with opioid overdose and hot shower. Single discontinuation due to vertigo.

7 Less complete study results also published in Anti-Cancer Drugs, 1995. Study included 98 subjects; 60 excluded due to unstable pain, protocol violations, or tumor progression. Constipation reported as percent of days present; severe constipation occurred 8% of days. Laxatives used 38% of days. Dermatologic adverse events were mild.

8 35 subjects enrolled; no data available for 5. At dose of 25 - 50 mcg/hr, also: moderate to severe confusion and hallucinations 17%; moderate to severe dizziness 25%; moderate to severe impaired thinking 10%; moderate to severe sweating 26%. Percentages of moderate to severe symptoms of nausea, constipation, and sedation were for either 25 - 50 mcg dosages reported here. Skin reactions were mild and at 25 - 50 mcg/hr dosages. Four discontinuations were due to either constipation, hallucinations, sedation, or impaired thinking.

Evidence Table 17 -- Adverse Events Reported During Spinal Opioid Therapy of Cancer Pain: Data from Nonrandomized Studies Enrolling 100 or More Patients

Author, year Identifier | Route | Trial design | Study size | Duration mean (range) | Dosage mean (range) | Naus/Vom | Const | Derm | Resp | Meng | Cath | D/C
Du Pen 1990 ^1^ 91052525 | Epidural | Cohort | 339 ^1^ | 92 d (4-1460) | NR | NR | NR | NR | NR | 4% | 9% ^1^ | 6% ^1^
Plummer 1991 ^2^ 91270942 | Epidural / intrathecal | Case series | 284 ^2^ | 147 d (6-961) | 21 mg/d ^2^ (0.5-130) | NR | NR | NR | NR | 0.3% | 8% ^2^ | 0.3% ^2^
Liew 1989 ^3^ 89260900 | Epidural | Cohort | 252 | NR | 19.5 mg/d ^3^ (NR) | 40% | 18% | 38% ^3^ | 1% | 0% | NR | NR
Nitescu 1995 ^4^ 95306964 | Intrathecal | Cohort | 200 | 33 d, median (1-575) | NR | NR | NR | NR | NR | 0.5% | NR | 1% ^4^
Samuelsson 1995 ^5^ 95248158 | Epidural | Cohort | 146 | 92 d (2-2040) | 69 mg/d (2-540) | NR | NR | NR | 0% | 0% | 1% ^5^ | 10% ^5^
Zenz 1985 ^6^ 85186375 | Epidural | Cohort | 139 | 72 d (1-700) | Morphine: 15.6 mg/d (2-290) Buprenorphine: 0.9 mg/d (0.15-7.2) | 15% | NR | 1% ^7^ | 0% | 2% | 9% ^7^ | NR ^7^
Madrid 1988 ^7^ 88187426 | Intrathecal | Case series | 100 | Maximum >= 7 months | ^8^ | 9% | 34% | 13% ^8^ | 1% | 0% | 0% | NR
Cheng 1993 ^8^ 94322423 | Intrathecal | Case series | 100 | Up to 12 months | 1.4 mg/d (NR) | 40% | 17% | 36%^9^ | 0% | 1% | 0% | NR

Cath = other catheter-related infection; Const = constipation; d = days; D/C = discontinued catheter and/or drug due to adverse events; Derm = dermatologic adverse events; Meng = meningitis; Naus/Vom = nausea and/or vomiting; NR = not reported; Resp = respiratory depression;

1 Opioid +/- bupivacaine, bolus or infusion. 350 subjects evaluated, 339 had cancer. 7% had superficial catheter-related infections. 2% had deep catheter track infection. All cases of deep catheter infections and meningitis resulted in catheter removal.

2 Morphine, bolus, or infusion. 313 subjects evaluated; 284 had cancer. Mean dosage reported is mean of subjects' maximal daily dose. Superficial or deep catheter track infections reported only for all 313 subjects. Catheter removed in one subject with meningitis. Other: pain with bolus injection 12% (of all 313 subjects).

3 Morphine. Mean dosage reported is mean of subjects' maximal daily dose. Skin inflammation 38%, pruritus 35%; Other: urinary retention 73%; injection pain 56%; headache 3%.

4 Opioid +/- bupivicaine, bolus or infusion. Catheter removal due to occlusion 1, dislodgement 1. Other: paraplegia or paresthesia due to damage to intraspinal tumor, nerve root, or spinal cord 2.5%; post-dural-puncture headache 16%; bolus injection pain 4%; continuous injection pain 0%; catheter obstruction 1%; insertion site skin breakdown 2%.

5 Morphine, bolus, or infusion. Catheter track infection 2%; superficial infection NR. Catheter removed in 14 subjects due to catheter problems 5, confusion 3, injection pain 2, infection 2, hyperesthesia 1, nausea 1. Opiate changed from morphine to buprenorphine or methadone in 18 subjects due to: nausea 6, confusion/hallucinations 6, sedation 3, rash 2, pruritus 1, no data 1. Other: bolus injection pain 10%.

6 Morphine or buprenorphine, bolus. Only dermatologic event was severe pruritus. No catheter track infections reported. Incomplete data reported on discontinuation. Other: catheter obstruction 4%; urinary retention 4%

7 Morphine, bolus. Average dose ranged from 0.5 - 2 mg given every 6 to 24 hrs. Only dermatologic event was pruritus. No infections were reported. Other: urinary retention 28%; headache 13%; catheter occlusion 8%; meningismus 6%; cerebrospinal fluid leak 4%, hypotension 0%.

8 Morphine, bolus. Only dermatologic event was pruritus. Other: urinary retention 29%; headache 18%; catheter obstruction 5%; catheter dislodgement 2%; sedation 1%; catheter leak 1%; cauda equina syndrome 1%; anterior spinal artery syndrome 1%.

Evidence Table 18 -- Adverse Effects Reported During NSAID Therapy of Cancer Pain: Data from Nonrandomized and Other Studies

Author, year Identifier | NSAID | Trial design | Study size | Duration mean (range) | Dosage mean (range) | Dyspepsia | GI bleed | GI perforation | D/C
Levick 1988 89144615 | Naproxen, oral | RCT | 145 | 3 d | 275 mg vs 550 mg q8h ^1^ | Low dose 7% High dose 16% | NR | NR | 5% ^1^
Yalçin 1997 ^2^ 97285173 | Ketorolac, Dipyrone, oral | Cohort (2 arms) | 50 | 2 d | K: 40 mg/d Dp: 1500 mg/d | "No significant adverse effect was observed."
Gottlieb 1990 ^3^ 90270698 | Naproxen, IV | Cohort ^2^ | 40 | 1 dose | 275 mg | "There were no side effects from the infusion."
Myers 1994 ^4^ 94286452 | Ketorolac, SC | Cohort | 36 | 21 d (3-115) | 60 mg/d (30-120) | NR | 11% ^4^ | 3% ^4^ | 11% ^4^
Mercadante 1999 ^5^ 99283640 | Diclofenac, Naproxen, Ketorolac, oral | Cohort | 32 D: 18 N: 5 K: 9 | 14 d | D/C: 200-300 mg/d N: 0.5-1 g/d K: 30-60 mg/d | "No relevant adverse effects attributable to NSAIDs were observed."
Cohn 1988 ^6^ 88206235 | Piroxicam, oral | Cohort | 30 | 6 months (2-16.5) | 87 mg/d (60-120) | 13% ^6^ | 7% | 3% | 20% ^6^
Hughes 1997 ^7^ 97348664 | Ketorolac, SC | Case series ^6^ | 25 | 20 d (3-185) | 60 mg/d (60-90) | NR | 8% ^7^ | NR | NR

D = diclofenac; d = days; D/C = discontinued drug due to adverse effects; Dp = Dipyrone; GI = gastrointestinal; IV = intravenous; K = ketorolac; NR = not reported; RCT = randomized controlled trial; N = naproxen; NSAID = nonsteroidal anti-inflammatory drug; SC = subcutaneous.

1 Study was randomized controlled trial comparing the efficacy and safety of two dosages of naproxen sodium. All subjects received a 550 mg loading dose followed by 275 mg or 550 mg every 8 hrs. Only 139 subjects received more than just the loading dose. Other unspecified adverse events: low dose 10%; high dose 6%. Discontinuations: immediately after loading dose (550 mg) 1% of all subjects; on low dose 0%; on high dose 4% gastrointestinal problems, 1% rash, 1% "dizziness, shaking, weak knees."

2 Dipyrone not available in the United States. No detailed adverse event data provided.

3 Letter. No detailed adverse event data provided.

4 Subjects also given misoprostol. 4 gastrointestinal bleeds: 2 had upper gastrointestinal cancer, 1 bled when high-dose dexamethasone was introduced, 1 had radiation proctitis; all were over 65 years old. 1 colonic perforation after recent high-dose steroids. 4 discontinuations due to 3 bleeds, 1 perforation.

5 No detailed adverse event data provided.

6 Subjects also given doxepin 93 mg/day average (range, 25-225 mg/day). Dyspepsia occurred while on sucralfate; all improved with increased dose of sucralfate. Other: platelet count depression 3%; no agranulocytosis, aplastic anemia, worsened renal or hepatic function, dermatological, allergic, or ophthalmic symptoms. Six discontinuations due to: gastric perforation 1, gastrointestinal bleed 2, dizziness 1, tinnitus 1, diarrhea 1.

7 Letter. Subjects also given misoprostol or omeprazole. Two gastrointestinal bleeds: 1 melena, 1 local rectal bleed.

Evidence Table 19 -- Adverse Effects Reported During Cancer Pain Treatment According to WHO Guidelines: Data from Nonrandomized Studies

Author, year Identifier | Trial design | Study size | Duration mean (range) | Naus | Vom | Const | Sed | Dry | Dyspep | Bleed | Derm
Mercadante 1999 ^1^ 99238092 | Cohort | 2500 ^1^ | 64 d (1-821) | 2% (cause of change in step) | | NR | 15% (step change) | NR | NR | NR | NR
Zech 1995 ^2^ 96124026 | Cohort | 2118 ^2^ | 66 d (1-1613) | 13% ^2^ | 6% ^2^ | 14% ^2^ | 14% ^2^ | NR | 3% ^2^ | NR | 2% ^2^
Ventafridda 1987 ^3^ 87102521 | Case series | 1229 | 8 weeks ^3^ | I: 10% II: 19% III: 23% | | I: 13% II: 28% III: 36% | I: 26% II: 28% III: 46% | I: 35% II: 36% III: 51% | I: 14% II: 18% III: 16% | I: 6% II: 4% III: 6% | I: 7% II: 8% III: 8%
Grond 1991 ^4^ 92363643 | Case series | 1070 | 52 d | N: 16% ^4^ O: 22% | N: 11% ^4^ O: 15% | N: 20% ^4^ O: 21% | N: 22% ^4^ O: 14% | NR | N: 8% ^4^ O: 5% | NR | N: 4% ^4^ O: 5%
Ventafridda 1990 ^5^ No Identifier | Cohort | 371 | 4 weeks | 12% | 6% | NR | 16% | 8% | 4% | 1% | NR
Takeda 1990 ^6^ No Identifier | Cohort | 205 | NR (1-450) | I: NR II: NR III: 20% | | I: NR II: NR III: 3% | I: NR II: NR III: 17% | NR | I: 6% II: NR% III: NR% | I: 0% II: NR% III: NR% | NR
Siguan 1992 ^7^ No Identifier | Cohort | 105 | NR | I: 8% II: NR III: NR | | I: NR II: NR III: 8% | NR | NR | I: 5% II: NR III: NR | NR | NR

I = Step 1; II = Step 2; III = Step 3; Bleed = bleeding; Const = constipation; d = days; Derm = dermatological symptom; Dry = dry mouth; Dyspep = dyspnea; Naus = nausea; N = NSAID; NR = not reported; O = other nonopioid analgesic; Sed = sedation; Vom = vomiting.

1 1703 subjects were evaluated during Step 1 (nonopioid analgesics), 1853 during Step 2 (weak opioids), 890 during Step 3 (strong opioids). Subjects spent an average of 18 days (range 3-95 days) during Step 1, 27 days (2-343) during Step 2, 19 days (1-459) during Step 3. Laxatives used prophylactically in at-risk patients before opioids given, and H2 blocker or prostaglandins used before NSAIDs. Adverse events reported only as cause of change in step. 1% changed steps for other reasons.

2 605 subjects were evaluated during Step 1, 1223 during Step 2, 1322 during Step 3, 323 were evaluated while not receiving analgesics. Subjects spent an average of 26 days in Step 1, 36 days in Step 2, 52 days in Step 3, and 28 days without analgesics. 8% changed steps due to adverse events. Adverse events reported as percent of patient-days. Derm = pruritus. Other: sweating 4% of patient-days, anorexia 4%, urinary disorders 2%, diarrhea 1%.

3 Adverse events noted at 8 weeks. Derm = pruritus. Other: Step 1: agitation 22%, sweating 8%, pruritus 7%; Step 2: agitation 18%, sweating 18%, pruritus 8%; Step 3: agitation 26%, sweating 29%, pruritus 8%.

4 NSAIDs 40% of days; other nonopioids 45%; no nonopioid analgesics 4%; weak opioids 32%; strong opioids 51%; spinal opioids 2%; no opioids 15%. Derm = pruritus. Sed = neuropsychological conditions (e.g., "confusion, unconsciousness, paralysis, etc.") Not all symptoms due to adverse events. Symptoms reported as percent of patient-days. Other: anaphylaxis, agranulocytosis, respiratory depression 0%; on NSAID: gastric perforation 0.6%, renal insufficiency 0.5%, urinary symptoms 13%, sweating 8%, diarrhea 4%; on other nonopioid analgesics: urinary symptoms 10%, sweating 7%, diarrhea 5%.

5 At end of 1 month: 28% of subjects at Step 2, 41% at Step 3. Highest frequency reported in paper presented here. Other: restlessness 4%; tremor 2%, sweating 3%, vertigo 2%

6 102 subjects were evaluated during Step 1, 76 during Step 2, 162 during Step 3. Subjects spent 1-250 days in Step 1, 1-200 days in Step 2, and 3-450 days in Step 3. Const = severe constipation. No adverse events reported in Step 2. Other: Step 1: 1% gastric hemorrhage (on aspirin), 1% allergic reaction; Step 3: unsteadiness 7%, confusion 7%.

7 Final regimen: 69 subjects in Step 1, 12 in Step 2, 24 in Step 3. Constipation occurred on morphine. "Noncompliant due to side effect" in Step 1 1%.

Evidence Table 20 -- Opioid Relative Potency Assays: Randomized Controlled Trials in Cancer Pain (Part A)

Author, year, identifier | Treatment(s) studied, dose, route | Number of study arms | Study design (crossover, cohort, etc) | Randomization | Blinding | Total number enrolled (evaluable) | Mean age or range (% male) | Type(s) of cancer | Baseline pain severity | Type of pain ^1^ | Chronicity of pain (range or average) | Source of pain ^2^ | Exclusion criteria | Rescue medication (all arms) | Outcomes assessed | Outcome scales | Outcomes | Comments
Houde 1960 Clinical Pharmacology and Therapeutics [prior to Medline] | Morphine 10 mg IM vs. placebo; morphine 10 mg IM vs. aspirin 600 mg po vs. morphine and aspirin combination (10 mg IM and 600 mg po, respectively). Study duration, 6 hrs. Two studies. | 2 and 3 | Crossover. Drugs were administered in a random order to each patient. | Not stated | Double-blind. To maintain double-blind conditions, both capsules and an injection were included in each drug administration. | 67 (67) Morphine vs. placebo; 28 (28) morphine vs. aspirin vs. morphine - aspirin combination | Not reported | "Advanced cancer" | Not stated | Not stated | Not stated | Cancer | Patients were included if they were well-oriented and cooperative and could report pain due to their disease and if they were without medical contraindications to the type of drugs that were tested. | Not stated | Pain intensity, pain relief, total pain relief. | Observations were made for 6 hrs after administration of the test drug, or until pain returned to the premedication level and an additional analgesic is required. Pain intensity was assessed as "no pain," "slight pain," "moderate pain," or "severe pain." Pain relief was defined as the difference between pain intensity score at each assessment minus pain intensity score at initial assessment. Thus, a drop from an initial score of severe pain to a score of slight pain represents a pain relief score of 3. Total pain relief was calculated as the sum of pain relief scores multiplied by the hrs this score was reported (range 0-18). | Comparison of morphine and placebo: morphine 10 mg IM produced considerably more relief than placebo for at least 5 hrs. Peak pain relief was noted at the first hour. Pain relief scores after morphine and saline were 1.5 and 0.9, respectively. The percentage of patients reporting at least 50% pain relief after these drugs were 63 and 41, respectively. Placebo was therefore about one-third less effective than morphine by either index of effect. Comparison of morphine, aspirin and the combination of morphine and aspirin: The (analgesic) effects of morphine and aspirin differed significantly; no information is provided on the comparison of morphine, aspirin and morphine-aspirin combination. | Sixteen patients in the aspirin-morphine study received two rounds of medication and so they represent replicate data.
Beaver 1966a 67015217 | Intramuscular pentazocine (20, 40, or 80 mg) vs. intramuscular morphine (8 or 16 mg). Study duration 6 hrs. | 2 | Crossover. Each patient received two test series comparing 8 and 16 mg of morphine sulfate (standard treatment) with two doses of pentazocine (the test drug). Each patient received all test medications randomly on separate days and was included only if he/she completed all 4 doses of the crossover comparison or "round." | Use of numerical codes for each sequence | Double-blind | 38(38) | 48 16-68 47.9% | "Wide variety of malignant tumors; most suffered from widespread disease with chronic pain due to skeletal metastases, or invasion of viscera, soft tissues, nerves, or nerve roots." | The study medications were administered by a nurse observer only when the patient complained of moderate to severe pain, and only if at least 3 hrs had elapsed since the last analgesic medication. | Not stated | Not stated | Cancer/metastases | Patients were included if they were able to communicate meaningful information about their pain. | Not applicable. A routine analgesic was administered 5 hrs after test drug administration or if pain returned to the premedication level. | Pain intensity and relief were assessed 1/2, 1, 2, 3, 4, and 5 hrs after drug administration. Also spontaneously reported side effects were recorded. | Pain intensity using a Categorical scale: 0=none, 1=slight, 2=moderate, 3=severe. Pain relief using a categorical scale: 0=none, 1=slight, 2=moderate, 3=lots, 4=complete. No leading questions for side effects | In the two series, a total of 58 crossover comparisons were carried out in 38 patients. The configurations of the time-effect curves for the mean upper and lower doses of morphine and pentazocine did not differ substantially, and comparable curves were obtained in terms of the hourly estimates of change in pain intensity. However, the effects of both doses of pentazocine were less than those of morphine. The relative potency of pentazocine to morphine is 0.17 in terms of total pain relief or 0.30 in terms of peak pain relief. | During the first series it became apparent that patients who had previously received opioids experienced acute and distressing opioid withdrawal reactions. For this reason, patients were tested by administration of increasing doses of pentazocine up to 60 mg in a non-double-blind fashion prior to entering the second series of test drug administration. Note also that data from some patients (from different series of test drug administration) were used more than once.
Beaver 1966b 66154982 | Intramuscular methotrimeprazine (7.5 or 15 mg) vs. intramuscular morphine (8 or 16 mg). Study duration 6 hrs. | 2 | Crossover. Each patient received both doses of the two drugs. Each patient received all test medications randomly on separate days and was included only if he/she completed all 4 doses of the crossover comparison or "round." | Use of numerical codes for each sequence. | Double-blind | 40(40) | 51 19-87 42.5% | "Widespread disease and pain attributable to skeletal metastases or invasion of viscera, soft tissues, nerves, or nerve roots." | The study medications were administered by a nurse observer only when the patient complained of moderate to severe pain, and only if at least 3 hrs had elapsed since the last analgesic medication. | Not stated | Not stated | Cancer/skeletal metastases | Patients were included if they were able to communicate meaningful information about their pain. | An additional analgesic was administered when pain returned to premedication level. | Pain intensity and relief were assessed hourly for 6 hrs. Spontaneously reported side effects were recorded. | Pain intensity using a categorical scale: 0=none, 1=slight, 2=moderate, 3=severe. Pain relief using a categorical scale: 0=none, 1=slight, 2=moderate, 3=lots, 4=complete. No leading questions for side effects. | A total of 67 crossover comparisons were carried out in 40 patients. The configurations of the time-effect curves for the upper and lower doses of morphine and methotrimeprazine did not differ substantially. Comparable curves were obtained in terms of the hourly estimates of change in pain intensity. The relative potency of methotrimeprazine to morphine is 0.53 in terms of total pain relief or 0.48 in terms of pain intensity. | A significantly larger number of patients reported or were observed to have side effects after methotrimeprazine. Sedation was the predominant side effect after methotrimeprazine, occurring after 39% of doses and after only 12% of the doses of morphine. Pain on injection (13% of doses) and dry mouth and nasal stuffiness (5% of doses) were other prominent side effects after methotrimeprazine. Nausea and vomiting (13% of doses) were more prominent after morphine.
Beaver 1969 69239166 | Intramuscular profadol (25 or 50 mg) vs. intramuscular morphine (8 or 16 mg). Study duration 6 hrs. | 2 | Crossover. Each patient received both doses of the two drugs. Each patient received all test medications randomly on separate days and was included only if he/she completed all 4 doses of the crossover comparison or "round." | Treatments were given to patients in an order determined by a series of randomly chosen Latin squares. | Double-blind | 28 (23) | 45 20 to 65 43.8% | "Wide variety of malignant tumors." | The study medications were administered by a nurse observer only when the patient complained of moderate to severe pain, and only if at least 3 hrs had elapsed since the last analgesic medication. | Not stated | Not stated | Cancer | Patients were included if they were able to communicate meaningful information about their pain. | In all cases, the patients were given an analgesic other than profadol or morphine during nonstudy hrs and as was possible, concomitant administration of psychoactive drugs such as sedatives and tranquilizers was avoided. | Pain intensity and relief were assessed hourly for 6 hrs. Spontaneously reported side effects were recorded. | Pain intensity using a categorical scale: 0=none, 1=slight, 2=moderate, 3=severe Pain relief using a categorical scale: 0=none, 1=slight, 2=moderate, 3=lots, 4=complete. No leading questions for side effects. | Drug slopes were significant for both measures of total effect but for neither measure of peak effect. In total effect, profadol was approximately one-fourth as potent as morphine. The configurations of the time-effect curves for morphine and profadol were not significantly different. Adverse effects observed after profadol were qualitatively similar to those after morphine. | Except for pain at the injection site, which was more frequent after profadol than morphine, the occurrence of adverse effects was dissimilar for the two drugs. However, in a study of this size, the difference would have to be marked in order to be identifiable.
Beaver 1977 77141298 | Oral vs. intramuscular oxymorphone and intramuscular oxymorphone (1, 2, 4 mg), morphine (8 or 16 mg), and placebo (2 studies). Study duration 6 hrs. (Two studies) | 2 | Crossover. Each patient received a high and a low dose of both the "standard" and the "test" drug, chosen at equilog intervals, and in addition a placebo treatment in the morphine-oxymorphone study. Unless a patient completed all doses of the crossover comparison or "round," the data were excluded from the relative potency assays. | Treatments were assigned to patients in an order by a series of randomly chosen Latin squares. | Double-blind | 34 (26) oxymorphone-morphine study 33(28) oxymorphone study | 54 32 to 75 52.2% oxymorphone-morphine study 48 19 to 69 46.4% oxymorphone study | "Wide variety of malignant tumors in both studies." | The study medications were administered by a nurse observer only when the patient complained of moderate to severe pain, and only if at least 3 hrs had elapsed since the last analgesic medication. | Not stated | Not stated | Cancer | Patients were included if they were able to communicate meaningful information about their pain. | In all cases, the patients were given an analgesic other than the "test" and "standard" medications during nonstudy hrs and as was possible, concomitant administration of psychoactive drugs such as sedatives and tranquilizers was avoided. | Pain intensity and relief were assessed hourly for 6 hrs. Spontaneously reported side effects were recorded. | Pain intensity using a categorical scale: 0=none, 1=slight, 2=moderate, 3=severe Pain relief using a categorical scale: 0=none, 1=slight, 2=moderate, 3=lots, 4=complete. No leading questions for side effects | Significant parallel slopes were obtained for all indices of analgesic effect (peak and total intensity and relief, and ridit transformations). The effects of morphine and oxymorphone were significantly higher than the placebo for all measures of effect. In total effect oxymorphone is 8.7 times (6-12.2, 95% CI) as potent as morphine, while in the peak effect it is 13 times (7.8-70, 95% CI). The side effects observed were qualitatively similar regardless of the type of opioid analgesics. In the oxymorphone IM vs. oral study significant common slopes were obtained for all indices of analgesic effect except peak change in pain intensity (raw score and ridit). In total effect, oral oxymorphone is one-sixth (0.16) as potent as injectable oxymorphone (0.09 - 0.31, 95% CI); while in peak effect, oral oxymorphone is only one-fourteenth (0.07) as potent as injectable oxymorphone (0.006 to 0.16, 95% CI). | Note that in the morphine-oxymorphone study medication was administered on the same day approximately 20 percent of the time.
Beaver 1978a 79029266 | Oral vs. intramuscular codeine and oral vs. intramuscular oxycodone. Study duration 6 hrs. (Two studies) | 2 | Crossover. Each patient received a high and a low dose of both the "standard" and the "test" drug, chosen at equilog intervals. Unless a patient completed all doses of the crossover comparison or "round," the data were excluded from the relative potency assays. | Treatments were assigned to patients in an order by a series of randomly chosen Latin squares. | Double-blind. To maintain double-blind conditions, both capsules and an injection, one of which was a dummy, were administered each time a patient was given a study medication. | 43(37) oral vs. intramuscular codeine 17(13) oral vs. intramuscular oxycodone | 53 19 to 82 43.2% oral vs. intramuscular codeine 48 23 to 68 38.4% oral vs. intramuscular oxycodone | "Wide variety of malignant tumors in both studies." | The study medications were administered by a nurse observer only when the patient complained of moderate to severe pain, and only if at least 3 hrs had elapsed since the last analgesic medication. | Not stated | Not stated | Cancer | Patients were included if they were able to communicate meaningful information about their pain. | In all cases, the patients were given an analgesic other than the "test" and "standard" medications during nonstudy hrs and as was possible, concomitant administration of psychoactive drugs such as sedatives and tranquilizers was avoided. | Pain intensity and relief were assessed hourly for 6 hrs. Spontaneously reported side effects were recorded. | Pain intensity using a categorical scale: 0=none, 1=slight, 2=moderate, 3=severe Pain relief using a categorical scale: 0=none, 1=slight, 2=moderate, 3=lots, 4=complete. No leading questions for side effects | Highly significant parallel drug slopes were obtained for all indices of analgesic effect. The estimates of relative potency of oral to intramuscular codeine range from 0.57 to 0.64 for measures of total analgesic effect. Side effects did not occur with sufficient frequency to allow meaningful analysis. In the second study, in total effect, oral oxycodone is one-half as potent as intramuscular oxycodone (0.19-1.30, 95% CI). The side effects after both oral and intramuscular oxycodone are dose-related and qualitatively similar to those noted in the codeine study. | The authors suggest that the high oral to parenteral relative potency ratios of codeine and oxycodone relative to morphine and its congeners are not because of more efficient absorption after oral administration, but rather because methylation at position 3 in codeine and oxycodone protects these drugs from rapid first pass metabolism.
Beaver 1978b 790299237 | Intramuscular oxycodone (7.5, 15, and 30 mg) vs. intramuscular morphine (8, 16 and 32 mg) and intramuscular codeine (90 and 180 mg) vs. intramuscular oxycodone (15 and 30 mg) vs. intramuscular morphine (16 mg). Study duration 6 hrs. (Two studies) | 2 | Crossover | Not stated | Double-blind | 34 (28) oxycodone vs. morphine study 30 (26) codeine vs. oxycodone vs. morphine study | 46 (23-68) (50%) oxycodone vs. morphine study 45 (23-80) (53.8%) codeine vs. oxycodone vs. morphine study | Not stated | Not stated | Not stated | Not stated | Cancer | Not stated | Not stated | Pain intensity and relief were assessed hourly for 6 hrs. Spontaneously reported side effects were recorded. | Pain intensity using a categorical scale: 0=none, 1=slight, 2=moderate, 3=severe. Pain relief using a categorical scale: 0=none, 1=slight, 2=moderate, 3=lots, 4=complete. No leading questions for side effects | Significant parallel slopes were obtained for all indices of analgesic effect suggesting a valid assay. The estimates for relative potency of oxycodone to morphine range from 0.68 to 0.78 for measures of total analgesic effect and from 0.82 to 0.98 for measures of peak analgesic effect. The low frequency of side effects for oxycodone and morphine precluded meaningful comparisons. The relative potency of oxycodone and codeine ranged from 8.44 to 11 for measures of total analgesic effect, and 12.15 to 12.83 for measures of peak effect. Side effects were qualitatively similar to those noted in the oxycodone morphine comparison, but likewise occurred with insufficient frequency to allow a meaningful comparison between treatments. | The subjects and study design section of this report appears to be incomplete compared with previous reports of the same group of investigators. For example, the methodology for pain assessment is not reported.

1 Neuropathic, somatic, or visceral.

2 Cancer, sequel of treatment, or procedure related.