# Glossary

Ablative surgery: surgical procedure performed at peripheral or central neural structures to relieve pain by permanent disruption of nerve pathways.

Acupuncture: the piercing of specific sites of the body surface with needles to produce pain relief.

Addiction (psychological dependence): pattern of compulsive drug use characterized by a continued craving for a drug and the need to use the drug for effects other than pain relief.

Adjuvant analgesic drug: a drug that has independent or additive analgesic properties. Adjuvants are used to provide analgesia for specific types of pain, eg. neuropathic pain, to augment the efficacy of other agents such as opioids.

Allodynia: pain produced by a stimulant that is not normally painful, such as after nerve injury.

Analgesia: a deadening or absence of pain without loss of consciousness.

Analgesic: a medication that reduces or eliminates pain.

Anxiolysis: sedation or hypnosis used to reduce anxiety, agitation, or tension.

Anxiolytic: medication used to reduce anxiety, agitation, or tension.

Behavioral technique: a coping strategy in which patients are taught to monitor and evaluate their own behavior and to modify their reactions to pain.

Biofeedback: a process in which a person learns to reliably influence physiologic responses of two kinds: those that are not ordinarily under voluntary control and those that ordinarily are easily regulated but for which regulation has broken down because of trauma or disease.

Biphosphonates: a class of medication that decreases the turnover of bone.

Breakthrough pain: intermittent exacerbations of pain that can occur spontaneously or in relation to specific activity despite ongoing analgesic therapy.

Cognitive reappraisal: a coping strategy in which patients are taught to monitor and evaluate negative thoughts and replace them with more positive thoughts and images.

Confidence interval (CI): an interval (range of values) within which the population parameter (the "true" value) is expected to lie with a given degree of certainty (e.g., 95%).

Conscious sedation: "light sedation" during which the patient retains airway reflexes and responses to verbal stimuli.

Continuous variable: any characteristic that can be measured on a continuous scale (e.g., blood pressure, height, pain intensity score).

Continuous variable: Correlation association or interdependence between two variables (characteristics).

Counterstimulation: application of moderate to intense sensory stimulation, such as cold, heat, rubbing, pressure, or electrical current, so as to decrease perception of pain at the same or a distant site.

Cryotherapy: the therapeutic use of cold to reduce discomfort; limit progression of tissue edema; or break a cycle of muscle spasm.

Deafferentation pain: pain due to loss of sensory input into the central nervous system, as occurs with avulsion of the brachial plexus or other types of lesions of peripheral nerves.

Dichotomous variable: observations that occur in one of two possible states, often labeled 0 and 1. Commonly occurring examples include "dead/alive" and "improved/not improved."

Distraction: the cognitive strategy of focusing attention on stimuli other than pain or negative emotions that accompany pain.

Dysesthesia: an unpleasant abnormal sensation, whether spontaneous or evoked.

Effect size: refers to the size (or the distance from null value indicating no treatment effect) of the summary measure (or point estimate) of the treatment effect and the values included in the corresponding 95% confidence interval.

Epidural: situated within the spinal canal, on or outside the dura mater (tough membrane surrounding the spinal cord); synonyms are "extradural" and "peridural."

Equianalgesic: having equal pain-killing effect; morphine sulfate, 10 mg intramuscularly is widely used for opioid analgesic comparisons.

Evidence-based medicine: conscientious, explicit, and judicious use of current best evidence in making decisions about the care of individual patients.

External validity: degree to which the results of a study can be applied to situations other than those under consideration of the study, such as for routine clinical practice.

Fixed or random effects model: statistical methods used to produce weighted summary estimates of an effect of interventions across many studies. The fixed effects model assumes that all studies are studying the same true effect and that variability is due to random error only. The random effects model assumes that the true effect differs among studies and therefore must be represented by a distribution of values instead of a single value.

Heterogeneity: diveristy, such as may exist between studies. In that context, heterogeneity may be due to identifiable factors or statistical factors or both, especially the component that cannot be explained by random error. If there is significant heterogeneity, this suggests that the trials are not estimating a single common treatment effect.

Hyperalgesia: exaggeration (to an abnormal degree) of the intensity of a normally painful stimulus.

Hyperpathia: a painful syndrome characterized by increased reaction to a stimulus, especially a repetitive stimulus, as well as an increased threshold.

Hypnosis: a state of heightened awareness and focused concentration that can be used to manipulate the perception of pain.

Iatrogenic: induced by a medical treatment or other procedure, e.g., surgery.

Imagery: a cognitive-behavioral strategy that uses mental images as an aid to relaxation.

Incident pain: see "movement-related pain."

Internal validity: degree to which the inferences drawn from a study are warranted when account is taken of its design, conduct, and reporting (e.g., blinding, randomization, dropouts).

Intrathecal: the space enclosed by the arachnoid meninges and containing cerebrospinal fluid and the spinal cord.

Lancinating: characterized by piercing or stabbing sensations.

Local nerve block: infiltration of a local anesthetic around a peripheral nerve so as to produce anesthesia in the area supplied by the nerve.

Meta-analysis: synthesis and quantitative summary of the results from several studies identified in a systematic review.

Mixed opioid agonist-antagonist: a compound that has an affinity for two or more types of opioid receptors and blocks opioid effects on one receptor type while producing opioid effects on a second receptor type.

Movement-related pain: a type of breakthrough pain related to specific activity, such as eating, defecation, socializing, or walking. Also referred to as incident pain.

Mucositis: inflammation of a mucous membrane. Oral mucositis is a common complication of chemotherapy and radiation therapy.

Music therapy: a form of distraction that uses music as an aid to relaxation.

Myofascial pain: a group of painful muscle disorders characterized by the presence of hypersensitive points, called trigger points, within one or more muscles and/or the investing connective tissue together with a syndrome of pain, muscle spasm, tenderness, stiffness, limitation of motion, weakness, and occasionally autonomic dysfunction.

Neuraxial: within the spinal canal. Term used to indicate administration of drugs to the intrathecal or epidural space.

Neurolytic block: the injection of a chemical agent to cause destruction and consequent prolonged interruption of peripheral somatic or sympathetic nerves, or in some cases, the neuraxis.

Neuropathic pain: pain that results from a disturbance of function or a pathologic process in a nerve; in one nerve, mononeuropathy; in several nerves, mononeuropathy multiplex; if diffuse, polyneuropathy.

Nociception: the neural process by which tissue injury or nerve dysfunction is detected, transmitted through the nervous system, and in conscious individuals perceived in pain.

Nociceptive pain: pain produced by activation of nociceptors as a result of heat, mechanical pressure, or the release of chemical mediators of inflammation or as a result of tissue injury.

Nonsteroidal anti-inflammatory drug (NSAID): aspirin-like drug that reduces inflammation (and hence pain) arising from injured tissue.

Opiate receptor: opiate-binding sites found throughout primary afferents and the neuraxis.

Opioid: any synthetic narcotic that has morphine-like activities. Also denotes non-morphine-like molecules such as naturally occurring peptides (e.g., enkephalins), that exert morphine-like effects by interacting with opioid receptors.

Opioid agonist: any morphine-like compound that produces bodily effects, including pain relief, sedation, constipation, and respiratory depression.

Opioid partial agonist: a compound that has an affinity for and stimulates physiologic activity at the same cell receptors as opioid agonists but that even at maximal doses produces only a partial (i.e., submaximal) bodily response.

Pain: an unpleasant sensory and emotional experience associated with actual or potential tissue damage or described in terms of such damage.

Pain intensity difference (PID): outcome measure in analgesic trials. The difference between pain intensity at a given time and at baseline (start time of an observation period).

Pain relief: reduction in pain intensity.

Palliative therapy: a procedure such as chemotherapy, radiation therapy, or surgery that is performed to relieve or ease pain.

Pancoast tumor: tumor originating from the superior sulcus of the lung that invades all or a portion of the brachial plexus.

Patient-controlled analgesia (PCA): self-administration of analgesics by a patient instructed in doing so; usually refers to self-dosing with intravenous opioid (e.g., morphine) administered by means of a programmable pump.

Physical dependence: adaptation of the body to the presence of a drug, such as an opioid or benzodiatepine, such that sudden drug discontinuation or exposure to an antagonist will precipitate an abstinence syndrome.

Physical modalities: therapeutic interventions that use physical methods, such as heat, cold, massage, or exercise, to relieve pain.

Progressive muscle relaxation: a cognitive-behavioral strategy in which muscles are alternately tensed and relaxed in a systematic fashion.

Pseudo-addiction: pattern of drug-seeking behavior of pain patients receiving inadequate pain medication; can be mistaken for addiction.

Psychological dependence: see addiction.

Psychosocial intervention: a therapeutic intervention that uses cognitive, cognitive-behavioral, behavioral, and supportive interventions to relieve pain. These include patient education, interventions aimed at aiding relaxation, psychotherapy, and structured or peer support.

Random effects model: see "fixed effects model."

Relative risk: one of several ways to quantitatively describe the strength of association between a suspected cause and its presumed effect. The relative risk is a ratio of two risks -- the risk of the outcome in those exposed to the suspected cause compared with the risk of the outcome in those not exposed.

Relaxation.: a state of relative freedom from both anxiety and skeletal muscle tension.

Risk ratio: see relative risk.

Self-statement: involves instructing patients to substitute positive thoughts such as "I can withstand this experience" for such negative ones as "I can't stand this" or "How much longer will this go on?"

Sensitivity analysis: any test of the stability of the conclusions of an evaluation over a range of probability estimates, value judgments, and assumptions.

Somatic pain: pain that arises from the surface of the body (e.g., skin).

SPID: sum of pain intensity differences following administration of a different analgesic to two or more groups of patients, or a single patient studied at different times.

Suffering: a state of severe distress associated with events that threaten the wholeness of the person.

Systematic review: the process of systematically locating, appraising, and synthesizing evidence from scientific studies in order to obtain a reliable answer to a specific question posed a priori.

Tolerance: a common physiologic result of chronic use of drugs such as opiods or benzodiatepines; connotes the requirement for doses progressively higher across time to maintain the same analgesic effect.

Variable: some characteristic that differs from subject to subject or from time to time.

Visceral pain: pain that arises from injury of or psychophysiology involving internal organs (viscera) or their innervation.

Visual analog scale (VAS): typically, a 10-centimeter horizontal line on which the left side represents no pain and the right side represents the worst imaginable pain. Variants according to orientation (i.e., vertical), size, and design (e.g., cross-hatched) are common.

WHO analgesic ladder (or staircase): a method for management of cancer pain that focuses on selecting analgesics on the basis of pain intensity. There are three steps, from mild pain -- suggesting use of a nonopioid analgesics and the possibility of an adjuvant analgesic -- to severe pain, suggesting an opioid with the possibility of nonopioid and adjuvant analgesics.