# Abbreviations and Acronyms

AHRQ: Agency for Healthcare Research and Quality

APD: Aminohydroxypropylidene biphosphonate

BMT: Bone marrow transplant

CT scan: Computer-aided tomography scan

FDA: Food and Drug Administration

GI: Gastrointestinal

IM: Intramuscular

IRH: Immediate-release hydromorphone

IV: Intravenous

NCPB: Neurolytic celiac plexis block

NSAID: Nonsteroidal anti-inflammatory drug

PCA: Patient-controlled analgesia

PCC: Percutaneous cervical cordotomy

PID: Pain intensity difference (from baseline)

RCT: Randomized controlled trial

SRH: Slow-release hydromorphone

TENS: Transcutaneous electrical nerve stimulation

TOTPAR: Total pain relief

VAS: Visual analog scale

WHO: World Health Organization