# Meta-analysis of Randomized Controlled Trials

Three meta-analyses were performed to quantify the magnitude of the treatment effect. Potential meta-analyses were identified by noting the number of studies in the evidence tables available to address each of the study subquestions. When two or more studies were found, the studies were further scrutinized to determine whether the studies are combinable. Details about the conduct of meta-analysis are provided in Chapter 2, Methodology.

## Comparisons of Controlled-release Morphine Versus Aqueous Morphine Administered Orally

This meta-analysis compared the efficacy of controlled-release morphine versus oral morphine solution. None of the studies included in this meta-analysis identified a statistically significant difference with respect to the analgesic outcome. The difference between the mean pain intensity of the two treatment arms was analyzed.

Studies used in the meta-analysis: (see Evidence Table 4)

Comparisons of Controlled-release Morphine Versus Aqueous Morphine Administered Orally

Primary author, year, unique identifier | Pain intensity difference controlled-release morphine (mean ± SE) | Pain intensity difference immediate-release morphine
Panisch, 1993 95096729 | 32 ± 2.8 | 28 ± 2.7
Finn, 1993 93253444 | 24.82 ± 2.64 | 19.69 ± 2.23
Walsh, 1992 98358029 | 19.8 ± 2.32 | 20.0 ± 2.42
Deschamps, 1992 93132420 | 13 ± 0.1 | 14 ± 0.5
Goughnour, 1989 89248823 | 13.6 ± 3.96 | 15.7 ± 3.82
Thirlwell, 1989 89248820 | 13.75 ± 3.4 | 14.25 ± 5.87
Hanks, 1987 88021688 | 7.1 ± 8.7 | 3.7 ± 5.5
Ventafridda, 1989 89381485 | Difference between two arms = 1.27 ± 3.85

### Results

The difference of the average pain intensity (4 to 14 days), measured on a continuous VAS scale (0-100 mm), between the two study arms -- controlled-release morphine and morphine solution -- were combined using a random effects model. No difference was found between controlled-release morphine and morphine sulphate solution, 1.2 mm (95% CI, -1.6 mm to 4.0 mm).

### Conclusions

Eight studies comparing controlled-release morphine with oral morphine solution did not report any significant difference between the two treatments with respect to efficacy (reduction of pain intensity or increased pain relief). A population of 344 patients with a wide range of cancer types as well as pain types was enrolled, from which 271 were evaluated (78.7%). Certain limitations of the applicability of the results arise from factors such as the baseline pain intensity in the population studied in individual studies. This information was not provided in all studies.

## Comparison of Oral Versus Rectally Administered Controlled-release Morphine

This meta-analysis compared the analgesic efficacy between controlled-release morphine formulations administered through the oral (tablets) and rectal routes (suppositories).

Studies comparing oral and rectally administered controlled-release morphine (see Evidence Table 4).

Comparison of Oral Versus Rectally Administered Controlled-release Morphine

Author/year unique identifier | Study size (evaluable) | Comparison
Babul, 1998 98259851 | 27 (22) | Morphine suppositories versus morphine tablets
DeConno, 1995 95222298 | 34 (34) | Oral versus rectal (enema) morphine
Wilkinson, 1992 93099680 | 11 (10) | Rectal versus oral morphine

One study was excluded due to different formulation (enema) used through given via the rectal route (DeConno et al., 1995). The difference between the two study arms of the average pain intensity from baseline, measured on a continuous VAS scale (0-100 mm) or transformed from the original pain scale, was the outcome pooled across studies.

Outcomes of studies included in the meta-analysis:

Comparison of Oral Versus Rectally Administered Controlled-release Morphine

Author, year/unique identifier | Pain intensity difference between rectal and oral administration of controlled-release morphine (mean ± SE in mm) [VAS scale, 0-100mm]
Babul, 1998 98259851 | 3 ± 5.66
Wilkinson, 1992 93099680 | 1.9 ± 4.16

### Result

No difference in pain intensity was found between oral and rectal routes for controlled-release morphine, 2.3 mm (95% CI, -4.3 mm to 8.9 mm). These results suggest that efficacy of controlled-release morphine is similar between the rectal and oral route, offering only the obvious benefit of one used as an alternative to the other.

## Comparison of NSAIDs with NSAIDs Plus Opioids

This meta-analysis compared NSAIDs with combinations of NSAIDs and weak opioids or opioids. This is a very diverse group of reports with respect to design characteristics, agents used, route of administration, and subpopulations of cancer patients in terms of type of pain (i.e., bone versus somatic pain). Meta-analysis of the difference in mean pain intensity between orally and rectally administered controlled-release morphine and immediate-release morphine (solution) was possible with only three studies (Dellemijn, 1994; Minotti, 1998; Rodriguez, 1994).

The treatment arms included in these studies were diclofenac, naproxen, and dipyrone (NSAIDs arm) combined with codeine, MS Contin, and morphine (NSAIDs combined with a weak opioid, or opioid). The evaluated outcome was pain intensity difference between baseline and the last day of study (7^th^ day).

Outcomes of studies included in the meta-analysis (see Evidence Table 3):

Comparison of NSAIDs with NSAIDs Plus Opioids

Author, year/unique identifier | Pain intensity difference of the last day of study^*^ between NSAIDs and NSAIDs + weak opioids or opioids (mean ± SE in mm, n) [VAS scale, 0-100mm]
Minotti, 1998 98179049 | 5.9 ± 3.1
Dellemijn, 1994 95092369 | 10.5 ± 13.5
Rodriguez, 1994 94361852 | -3.3 ± 6.2

* The difference in pain intensity between the baseline pain and pain on the last day of study.

### Results

No difference was found between NSAIDs and NSAIDs combined with weak opioids or opioids, 3.8 mm (95% CI, -4.7 mm to 12.4 mm).