# Bibliography

Abram SE. Cancer pain. Kluwer Academic Publishers. 1989.
Abram SE and Hopwood M Can meta-analysis rescue knowledge from a sea of unintelligible data? Regional Anesthesia 1996 21(6):514 6 8956386
Adami S and Mian M. Clodronate therapy of metastatic bone disease in patients with prostatic carcinoma. Recent Results in Cancer Research. 1989;116:67-72. [pmid: 2527401].
Agra Y, Sacristan A, Gonzalez M, Ferrari M, Portugues A, and Calvo MJ Efficacy of senna versus lactulose in terminal cancer patients treated with opioids Journal of Pain & Symptom Management Jan 1998 15(1):1 7
Ahles TA, Ruckdeschel JC, and Blanchard EB Cancer-related pain--I. Prevalence in an outpatient setting as a function of stage of disease and type of cancer Journal of Psychosomatic Research 1984 28(2):115 9 6610747
Ahmedzai S Recent clinical trials of pain control: impact on quality of life European Journal of Cancer 1995 31A(Suppl 6):S2 S7 8534526
Ahmedzai S and Brooks D Transdermal fentanyl versus sustained-release oral morphine in cancer pain: preference, efficacy, and quality of life Journal of Pain & Symptom Management May 1997 13(5):254 61 9185430
Cancer facts and figures - 1997. Atlanta: American Cancer Society. 1998.
Special Section: Childhood Cancer. In Cancer facts & figures 2000. Atlanta: American Cancer Society. 2000.
Principles of analgesic use in the treatment of acute pain and cancer pain. 4th ed. Glenview IL: American Pain Society. 1999.
Practice guidelines for cancer pain management. A report by the American Society of Anesthesiologists Task Force on Pain Management, Cancer Pain Section Anesthesiology May 1996 84(5):1243 57 8624021
Drug topics red book. New York: Topics Publishing. 1999.
Flecainide in cancer nerve pain [letter; comment] Lancet 01 Jun 1991 337(8753):
Antila H and Kirvela O Neurolytic thoracic paravertebral block in cancer pain. A clinical report Acta Anaesthesiol Scand May 1998 42(5):581 5 9605376
Arathuzik D Effects of cognitive-behavioral strategies on pain in cancer patients Cancer Nursing Jun 1994 17(3):207 14 8055491
Arbit E, Galicich JH, Burt M, and Mallya K Modified open thoracic rhizotomy for treatment of intractable chest wall pain of malignant etiology Ann Thorac Surg Dec 1989 48(6):820 3
Arner S and Arner B Differential effects of epidural morphine in the treatment of cancer-related pain Acta Anaesthesiol Scand Jan 1985 29(1):32 6
Aronoff GM. Evaluation and treatment of chronic pain. 3rd ed. Baltimore: Williams & Wilkins. 1999.
Ashburn MA and Rice LJ (eds). The management of pain. New York: Churchill Livingstone. 1998.
Ashburn MA and Staats PS Management of chronic pain [Review] [39 refs] Lancet 29 May 1999 353(9167):1865 9
Ashby MA, Fleming BG, Brooksbank M, Rounsefell B, Runciman WB, Jackson K, Muirden N, and Smith M Description of a mechanistic approach to pain management in advanced cancer. Preliminary report Pain 1992 51(2):153 62 1283009
Babul N, Provencher L, Laberge F, Harsanyi Z, and Moulin D Comparative efficacy and safety of controlled-release morphine suppositories and tablets in cancer pain Journal of Clinical Pharmacology Jan 1998 38(1):74 81
Bailar JC The practice of meta-analysis Journal of Clinical Epidemiology Jan 1995 48(1):149 57 7853040
Bailey AJ, Parmar MK, and Stephens RJ Patient-reported short-term and long-term physical and psychologic symptoms: results of the continuous hyperfractionated accelerated [correction of acclerated] radiotherapy (CHART) randomized trial in non-small-cell lung cancer Journal of Clinical Oncology Sep 1998 16(9):3082 93
Bailey EJ Sociocultural factors and health care-seeking behavior among black Americans Journal of the National Medical Association 1987 79(4):389 92 3586036
Ballantyne JC, Carr DB, Berkey CS, Chalmers TC, and Mosteller F Comparative efficacy of epidural, subarachnoid, and intracerebroventricular opioids in patients with pain due to cancer Regional Anesthesia 1996 21(6):542 56 8956391
Ballantyne JC, Carr DB, deFerranti SD, Suarez T, Lau J, Chalmers TC, Angelillo IF, and Mosteller F. The comparative effects of postoperative analgesic therapies on pulmonary outcome: cumulative meta-analyses of randomized controlled trials. Anesth Analg. 1998;86:598-612. [pmid: 9495424].
Basbaum AI. Insights into the development of opioid tolerance. Pain. 1995;61:349-52. [pmid: 7478677].
Baszanger I. Inventing pain medicine: from the laboratory to the clinic. New Brunswick: Rutgers University Press. 1998.
Beaver WT, Wallenstein SL, Houde RW, and Rogers A A comparison of the analgesic effects of pentazocine and morphine in patients with cancer Clin Pharmacol & Thera 1966a 7(6):740 51
Beaver WT, Wallenstein SL, Houde RW, and Rogers A A comparison of the analgesic effects of methotrimeprazine and morphine in patients with cancer Clin Pharmacol & Thera 1966b 7(4):436 46
Beaver WT, Wallenstein SL, Houde RW, and Rogers A A comparison of the analgesic effects of profadol and morphine in patients with cancer Clin Pharmacol Ther May 1969 10(3):314 9 4894155
Beaver WT, Wallenstein SL, Houde RW, and Rogers A Comparisons of the analgesic effects of oral and intramuscular oxymorphone and of intramuscular oxymorphone and morphine in patients with cancer J Clin Pharmacol Apr 1977 17(4):186 98
Beaver WT, Wallenstein SL, Rogers A, and Houde RW Analgesic studies of codeine and oxycodone in patients with cancer. I. Comparisons of oral with intramuscular codeine and of oral with intramuscular oxycodone J Pharmacol Exp Ther 1978a 207(1):92 100
Beaver WT, Wallenstein SL, Rogers A, and Houde RW Analgesic studies of codeine and oxycodone in patients with cancer. II. Comparisons of intramuscular oxycodone with intramuscular morphine and codeine J Pharmacol Exp Ther Oct 1978b 207(1):101 8
Beck SL The therapeutic use of music for cancer-related pain Oncology Nursing Forum Nov 1991 18(8):1327 37 1762973
Begg C, Cho M, Eastwood S, Horton R, Moher D, Olkin I, Pitkin R, Rennie D, Schulz KF, Simel D, and Stroup DF Improving the quality of reporting of randomized controlled trials. The CONSORT statement JAMA 28 Aug 1996 276(8):637 9
Bennett G, Serafini M, Burchiel K, Buchser E, Classen A, Deer T, Du Pen S, Ferrante FM, Hassenbusch SJ, Lou L, Maeyaert J, Penn R, Portenoy RK, Rauck R, Willis KD, Yaksh T Evidence-based review of the literature on intrathecal delivery of pain medication [review] J Pain Symptom Manage Aug 2000 20(2):S12 36
Belch AR, Bergsagel DE, Wilson K, O'Reilly S, Wilson J, Sutton D, Pater, Johnston D, and Zee B Effect of daily etidronate on the osteolysis of multiple myeloma Journal of Clinical Oncology Aug 1991 9(8):1397 402
Berde CB and Glick R. The placebo response: powerful and still puzzling. IASP Newsletter. July/August 1994:3-4.
Bergman B, Sullivan M, and Sorenson S Quality of life during chemotherapy for small cell lung cancer. I. An evaluation with generic health measures Acta Oncologica 1991 30(8):947 57 1663774
Berlin JA and Rennie D Measuring the quality of trials: the quality of quality scales. [editorial; comment] JAMA 15 Sep 1999 282(11):1083 5
Bernabei R, Gambassi G, Lapane K, Landi F, Gatsonis C, Dunlop R, Lipsitz L, Steel K, and Mor V Management of pain in elderly patients with cancer. SAGE Study Group. Systematic Assessment of Geriatric Drug Use via Epidemiology JAMA 17 Jun 1998 279(23):1877 82
Bernstein ZP, Yucht S, Battista E, Lema M, and Spaulding MB Proglumide as a morphine adjunct in cancer pain management Journal of Pain & Symptom Management May 1998 15(5):314 20 9654837
Besson JM The neurobiology of pain Lancet 1999 353(9164):1610 5 10334274
Bjorkman R, Ullman A, and Hedner J Morphine-sparing effect of diclofenac in cancer pain European Journal of Clinical Pharmacology 1993 44(1):1 5 8436146
Blackwell N, Bangham L, Hughes M, Melzack D, and Trotman I Subcutaneous ketorolac--a new development in pain control Palliative Medicine 1993 7(1):63 5 8287202
Blendon RJ, Aiken LH, Freeman HE, and Corey CR Access to medical care for black and white Americans. A matter of continuing concern JAMA 1989 261(2):278 81 2909026
Blomqvist C, Elomaa I, Porkka L, Karonen SL, and Lamberg-Allardt C Evaluation of salmon calcitonin treatment in bone metastases from breast cancer--a controlled trial Bone 1988 9(1):45 51 3288258
Boccardo F, Decensi A, Guarneri D, Rubagotti A, Oneto F, Martorana G, Giuliani L, Delli Ponti U, Petracco S, and Cortellini P Zoladex with or without flutamide in the treatment of locally advanced or metastatic prostate cancer: interim analysis of an ongoing PONCAP study. Italian Prostatic Cancer Project (PONCAP) European Urology 1990 18(Suppl 3):48 53
Bonica JJ. Treatment of cancer pain: current status and future need. In: Fields ML, Dubner R, Cerrero F, Jones LE (eds). Proceedings of the Fourth, World Congress on pain. Advances in pain research and therapy. New York: Raven Press; Ltd. 1985;Vol. 9.
Booth A, Djulbegovic B, Guthrie B, Perleth M, Sackett D, Endersly S, Jenkins D, Taylor D, Dent T, and Enkin M. What proportion of healthcare is evidence based? Resource Guide. www.shef.ac.uk/~scharr/ir/percent.html. Jan 2000.
Bosek V and Miguel R Comparison of morphine and ketorolac for intravenous patient-controlled analgesia in postoperative cancer patients Clinical Journal of Pain Dec 1994 10(4):314 8
Boureau F, Saudubray F, d'Arnoux C, Vedrenne J, Esteve M, Roquefeuil B, Siou DK, Brunet R, Ranchere JY, and Roussel P A comparative study of controlled-release morphine (CRM) suspension and CRM tablets in chronic cancer pain Journal of Pain & Symptom Management Oct 1992 7(7):393 9
Breitbart W, Chandler S, Eagel B, Ellison N, Enck RE, Lefkowitz M, and Payne R Expert consensus: An alternative algorithm for dosing transdermal fentanyl in managing cancer-related pain Oncology, 2000 14(5):695 705 10853461
Brescia FJ, Portenoy RK, Ryan M, Krasnoff L, Gray G Pain, opioid use, and survival in hospitalized patients with advanced cancer Journal of Clinical Oncology Jan 1992 10(1):149 55
Broomhead A, Kerr R, Tester W, O'Meara P, Maccarrone C, Bowles R, and Hodsman P Comparison of a once-a-day sustained-release morphine formulation with standard oral morphine treatment for cancer pain Journal of Pain & Symptom Management Aug 1997 14(2):63 73
Brown DL A retrospective analysis of neurolytic celiac plexus block for nonpancreatic intra-abdominal cancer pain Regional Anesthesia Mar 1989 14(2):63 5 2487665
Brown DL. Regional anesthesia and analgesia. Philadelphia: W.B. Saunders Company. 1996.
Brown DL, Bulley CK, and Quiel EL Neurolytic celiac plexus block for pancreatic cancer pain Anesth Analg Sep 1987 66(9):869 73
Bruera E, Roca E, Cedaro L, Carraro S, and Chacon R Action of oral methylprednisolone in terminal cancer patients: a prospective randomized double-blind study Cancer Treatment Reports Jul 1985 69(7-8):751 4
Bruera E, Chadwick S, Brenneis C, Hanson J, and MacDonald RN Methylphenidate associated with narcotics for the treatment of cancer pain Cancer Treatment Reports Jan 1987a 71(1):67 70
Bruera E, Brenneis C, Michaud M, Chadwick S, and MacDonald RN Continuous sc infusion of narcotics using a portable disposable device in patients with advanced cancer Cancer Treatment Reports Jun 1987b 71(6):635 7
Bruera E, Brenneis C, Michaud M, Macmillan K, Hanson J, and MacDonald RN Patient-controlled subcutaneous hydromorphone versus continuous subcutaneous infusion for the treatment of cancer pain Journal of the National Cancer Institute 21 Sep 1988a 80(14):1152 4
Bruera E, Brenneis C, Michaud M, Bacovsky R, Chadwick S, Emeno A, and MacDonald N Use of the subcutaneous route for the administration of narcotics in patients with cancer pain Cancer Jul 1988b 62(2):407 11
Bruera E, Miller MJ, Macmillan K, and Kuehn N Neuropsychological effects of methylphenidate in patients receiving a continuous infusion of narcotics for cancer pain Pain Feb 1992 48(2):163 6
Bruera E, MacEachern T, Ripamonti C, and Hanson J Subcutaneous morphine for dyspnea in cancer patients Annals of Internal Medicine 01 Nov 1993 119(9):906 7
Bruera E, Fainsinger R, Spachynski K, Babul N, Harsanyi Z, and Darke AC Clinical efficacy and safety of a novel controlled-release morphine suppository and subcutaneous morphine in cancer pain: a randomized evaluation Journal of Clinical Oncology Jun 1995 13(6):1520 7
Bruera E, Sloan P, Mount B, Scott J, and Suarez-Almazor M A randomized, double-blind, double-dummy, crossover trial comparing the safety and efficacy of oral sustained-release hydromorphone with immediate-release hydromorphone in patients with cancer pain. Canadian Palliative Care Clinical Trials Group Journal of Clinical Oncology May 1996 14(5):1713 7 8622092
Bunker JP, Hinkley D, and McDermott WV Surgical innovation and its evaluation Science 26 May 1978 200(4344):937 41
Burki F New French studies of clodronate in cancer-induced osteolysis Bone 1991 12(Suppl 1):
Calvillo ER and Flaskerud JH. Evaluation of the pain response by African-American, Mexican-American, and Anglo-American women and their nurses. Journal of Advanced Nursing. 1993;18:451-9. [pmid: 8450141].
Campora E, Merlini L, Pace M, Bruzzone M, Luzzani M, Gottlieb A, and Rosso R The incidence of narcotic-induced emesis Journal of Pain & Symptom Management Oct 1991 6(7):428 30
Caraceni A, Portenoy RK An international survey of cancer pain characterisitics and syndromes. IASP Task Force on Cancer Pain. International Association for the Study of Pain Pain Sep 1999 82(3):263 74
Caratozzolo M, Lirici MM, Consalvo M, Marzano F, Fumarola E, and Angelini L Ultrasound-guided alcoholization of celiac plexus for pain control in oncology Surg Endosc Mar 1997 11(3):239 44
Carlson RW, Borrison RA, Sher HB, Eisenberg PD, Mowry PA, and Wolin EM A multiinstitutional evaluation of the analgesic efficacy and safety of ketorolac tromethamine, acetaminophen plus codeine, and placebo in cancer pain Pharmacotherapy 1990 10(3):211 6 2196536
Carr DB and Cousins MJ. Spinal route of analgesia and opioids and future options. In: Cousins MJ and Bridenbaugh PO. Eds. Normal Blockade in Clinical Anesthesia and Management of Pain, 3^rd^ ed. Philadelphia: Lipponcott-Raven. 1998:915-84.
Carr DB and Goudas LC Acute pain Lancet 1999 353(9169):2051 8 10376632
Carr DB, Wiffen P, Fairman F, and LeMaitre M. The Cochrane Collaboration and its Pain, Palliative and Supportive Care Review Group. In Pain 1999 - An updated review: Refresher course syllabus. Seattle: IASP Press. 1999:399-410.
Carroll D, Tramer M, McQuay H, Nye B, and Moore A. Randomization is important in studies with pain outcomes: Systematic review of transcutaneous electrical nerve stimulation in acute postoperative pain. British Journal of Anaesthesia. 1996;77:798-803. [pmid: 9014639].
Cascinu S, Graziano F, Alessandroni P, Ligi M, Del Ferro E, Rossi D, Ficarelli R, and Catalano G Different doses of pamidronate in patients with painful osteolytic bone metastases Supportive Care in Cancer Mar 1998 6(2):139 43
Cassel C and Foley KM. Principles for care of patients at the end of life: an emerging consensus among the specialties of medicine. New York: Milbank Memorial Fund. 1999.
Cervero P and Laird JMA Visceral pain Lancet 1999 353(9170):2145 8 10382712
Chalmers I and Altman DG (eds). Systematic reviews. London: BMJ Publishing Group. 1995.
Chary S, Goughnour BR, Moulin DE, Thorpe WR, Harsanyi Z, and Darke AC The dose-response relationship of controlled-release codeine (Codeine Contin) in chronic cancer pain Journal of Pain & Symptom Management Aug 1994 9(6):363 71
Cheng KI, Tang CS, Chu KS, Yip NS, Yu KL, and Tseng CK Retrospective investigation of intermittent bolus intrathecal morphine for cancer pain patients Kao-Hsiung i Hsueh Ko Hsueh Tsa Chih [Kaohsiung Journal of Medical Sciences] Nov 1993 9(11):632 42
Cherny NI, Thaler HT, Friedlander-Klar H, Lapin J, Foley KM, Houde R, and Portenoy RK Opioid responsiveness of cancer pain syndromes caused by neuropathic or nociceptive mechanisms: a combined analysis of controlled, single-dose studies Neurology May 1994 44(5):857 61 7514771
Cherny NI, Chang V, and Frager G et al. Opioid pharmacotherapy in the management of cancer pain: a survey of strategies used by pain physicians for the selection of analgesic drugs and routes of administration. Cancer. 1995;76:1288-93.
Cherny NI and Portenoy RK. Cancer pain: principles of assessment and syndromes. In Wall PD and Melzack R. (eds). Textbook of Pain. 4^th^ ed. Edinburgh: Churchill Livingstone. 1999a:1017-64.
Cherny NI and Portenoy RK. Practical issues in the management of cancer pain. In Wall PD and Melzack R. (eds). Textbook of Pain. 4^th^ ed. Edinburgh: Churchill Livingstone. 1999b:1497-522.
Chochinov HM, Tataryn D, Clinch JJ, and Dudgeon D Will to live in the terminally ill Lancet 04 Sep 1999 354(9181):816 9
Cleeland CS. Pain assessment in cancer. In Oshiba D (ed). Effect of cancer on quality of life. Boston: CRC Press. 1991:293-306.
Cleeland CS, Gonin R, Hatfield AK, Edmonson JH, Blum RH, Stewart JA, and Pandya KJ Pain and its treatment in outpatients with metastatic cancer N Engl J Med 03 Mar 1994 330(9):592 6
Cleeland CS, Gonin R, Baez L, Loehrer P, and Pandya KJ Pain and treatment of pain in minority patients with cancer Annals of Internal Medicine 1997 127(9):813 6 9382402
Clemens MR, Fessele K, and Heim ME Multiple myeloma: effect of daily dichloromethylene bisphosphonate on skeletal complications Annals of Hematology Mar 1993 66(3):141 6
Cleton FJ, van Holten-Verzantvoort AT, and Bijvoet OL. Effect of long-term bisphosphonate treatment on morbidity due to bone metastases in breast cancer patients. Recent Results in Cancer Research. 1989;116:73-8. [pmid: 2669067].
Coates A, Gebski V, Bishop JF, Jeal PN, Woods RL, Snyder R, Tattersall MH, Byrne M, Harvey V, and Gill G Improving the quality of life during chemotherapy for advanced breast cancer. A comparison of intermittent and continuous treatment strategies N Engl J Med 10 Dec 1987 317(24):1490 5
Cohen MJM and Campbell JN (eds). Pain treatment centers at the crossroads: a practical and conceptual reappraisal. Seattle: IASP Press. 1996;Vol. 7.
Cohn ML, Machado AF, Bier R, and Cohn M Piroxicam and doxepin--an alternative to narcotic analgesics in managing advanced cancer pain Western Journal of Medicine Mar 1988 148(3):303 6
Colditz GA, Miller JN, and Mosteller F. How study design affects outcomes in comparisons of therapy. I: Medical. Statistics in Medicine. 1989a;8:441-54.
Colditz GA, Miller JN, and Mosteller F. How study design affects outcomes in comparisons of therapy. II: Surgical. Statistics in Medicine. 1989b;8:455-66.
Coleman RE, Purohit OP, Vinholes JJ, and Zekri J High dose pamidronate: clinical and biochemical effects in metastatic bone disease Cancer 15 Oct 1997 80(8 Suppl):1686 90
Conte PF, Giannessi PG, Latreille J, Mauriac L, Koliren L, Calabresi F, and Ford JM Delayed progression of bone metastases with pamidronate therapy in breast cancer patients: a randomized, multicenter phase III trial Annals of Oncology 1994 5(Suppl 7):S41 S44 7873461
Cooper-Patrick L, Gallo JJ, Gonzales MD, Vu HT, Powe NR, Nelson C, and Ford DE Race, gender, and partnership in the patient-physician relationship JAMA 1999 282(6):583 9 10450723
Corli O, Cozzolino A, and Scaricabarozzi I Nimesulide and diclofenac in the control of cancer-related pain. Comparison between oral and rectal administration Drugs 1993 46(Suppl 1):152 5
Cousins M and Bridenbaugh P (eds). Neural blockade in clinical anesthesia and management of pain. 3rd ed. Philadelphia: Lippincott-Raven. 1998.
Cowie RA and Hitchcock ER The late results of antero-lateral cordotomy for pain relief Acta Neurochir (Wien). 1982 64(1-2):39 50 6181657
Coyle N, Adelhardt J, Foley KM, and Portenoy RK Character of terminal illness in the advanced cancer patient: pain and other symptoms during the last four weeks of life [see comments] Journal of Pain & Symptom Management Apr 1990 5(2):83 93
Crombie IK, Croft PR, Linton SJ, LeResche L, and von Korff M. eds. Epidemiology of Pain. Seattle: IASP Press. 1999.
Crothers TD Criminal morphomania. JAMA 100 Years Ago JAMA 1999 282(6):
da Silva FC Quality of life in prostatic carcinoma European Urology 1993 24(Suppl 2):113 7 8262115
Daut RL and Cleeland CS The prevalence and severity of pain in cancer Cancer 01 Nov 1982 50(9):1913 8
Davar G, Hans G, Fareed MU, Sinnott C, and Strichartz G Behavioral signs of acute pain produced by application of endothelin-1 to rat sciatic nerve Neuroreport 13 Jul 1998 9(10):2279 83
De Conno F, Ripamonti C, Sbanotto A, Barletta L, Zecca E, Martini C, and Ventafridda V A clinical study on the use of codeine, oxycodone, dextropropoxyphene, buprenorphine, and pentazocine in cancer pain Journal of Pain & Symptom Management Oct 1991 6(7):423 7
De Conno F, Saita L, Ripamonti C, and Ventafridda V Subcutaneous octreotide in the treatment of pain in advanced cancer patients Journal of Pain & Symptom Management Jan 1994 9(1):34 8
De Conno F, Ripamonti C, Saita L, MacEachern T, Hanson J, and Bruera E Role of rectal route in treating cancer pain: a randomized crossover clinical trial of oral versus rectal morphine administration in opioid-naive cancer patients with pain Journal of Clinical Oncology Apr 1995 13(4):1004 8
De Conno F, Groff L, Brunelli C, Zecca E, Ventafridda V, and Ripamonti Clinical experience with oral methadone administration in the treatment of pain in 196 advanced cancer patients Journal of Clinical Oncology Oct 1996 14(10):2836 42
de Wit R, van Dam F, Zandbelt L, van Buuren A, van der Heijden K, Leenhouts G, and Loonstra S A pain education program for chronic cancer pain patients: follow-up results from a randomized controlled trial Pain Oct 1997 73(1):55 69
Dellemijn PL, Verbiest HB, van Vliet JJ, Roos PJ, and Vecht CJ Medical therapy of malignant nerve pain. A randomised double-blind explanatory trial with naproxen versus slow-release morphine European Journal of Cancer 1994 30A(9):1244 50 7999406
Deschamps M, Band PR, Hislop TG, Rusthoven J, Iscoe N, and Warr D The evaluation of analgesic effects in cancer patients as exemplified by a double-blind, crossover study of immediate-release versus controlled-release morphine Journal of Pain & Symptom Management Oct 1992 7(7):384 92
Dhaliwal HS, Sloan P, Arkinstall WW, Thirlwell MP, Babul N, Harsanyi Z, and Darke AC Randomized evaluation of controlled-release codeine and placebo in chronic cancer pain Journal of Pain & Symptom Management Nov 1995 10(8):612 23
Donner B and Zenz M Transdermal fentanyl: a new step on the therapeutic ladder Anti-Cancer Drugs Apr 1995 6(Suppl 3):39 43
Donner B, Zenz M, Strump M, and Raber M Long-term treatment of cancer pain with transdermal fentanyl Journal of Pain & Symptom Management Mar 1998 15(3):168 75
Dougherty PM and Staats PS Intrathecal drug therapy for chronic pain: from basic science to clinical practice Anesthesiology Dec 1999 91(6):1891 918
Doyle D, Hanke GWC, and MacDonald N (eds). Oxford textbook of palliative medicine 2nd ed. New York: Oxford University Press. 1998.
Du Pen SL, Peterson DG, Williams A, and Bogosian AJ Infection during chronic epidural catheterization: diagnosis and treatment Anesthesiology Nov 1990 73(5):905 9
Du Pen SL, Du Pen AR, Polissar N, Hansberry J, Kraybill BM, Stillman M, Panke J, Everly R, and Syrjala K Implementing guidelines for cancer pain management: results of a randomized controlled clinical trial Journal of Clinical Oncology Jan 1999 17(1):361 70
Edwards JE, McQuay HJ, Moore RA, and Collins SL Reporting of adverse effects in clinical trials should be improved: lessons from acute postoperative pain Journal of Pain & Symptom Management Dec 1999 18(6):427 37
Eisenach JC. Drug combination studies. In: Max M (ed). Pain 1999 -- An Updated Review. Seattle:IASP Press. 1999:309-313.
Eisenach JC, DuPen S, Dubois M, Miguel R, and Allin D Epidural clonidine analgesia for intractable cancer pain Pain Jun 1995 61(3):391 9
Eisenberg DM, Kessler RC, Foster C, Norlock FE, Calkins DR, and Delbanco TL Unconventional medicine in the United States. Prevalence, costs, and patterns of use [see comments] N Engl J Med 28 Jan 1993 328(4):246 52
Eisenberg E, Berkey CS, Carr DB, Mosteller F, and Chalmers T Efficacy and safety of nonsteriodal antiinflammatory drugs for cancer pain: a meta-analysis Journal of Clinical Oncology 1994 12(12):2756 65 7989953
Eisenberg E, Carr DB, and Chalmers TC Neurolytic celiac plexus block for treatment of cancer Anesth Analg 1995 80(290):
Eisenberg JM Ten lessons for evidence-based technology assessment JAMA 17 Nov 1999 282(19):1865 9 10573279
Ellemann K, Sjogren P, Banning AM, Jensen TS, Smith T, and Geertsen P Trial of intravenous lidocaine on painful neuropathy in cancer patients Clinical Journal of Pain Dec 1989 5(4):291 4
Elliott TE, Murray DM, Oken MM, Johnson KM, Elliott BA, and Post-White J The Minnesota Cancer Pain Project: design, methods, and education strategies Journal of Cancer Education 1995 10(2):102 12 7669532
Elliott TE, Murray DM, Oken MM, Johnson KM, Braun BL, Elliott BA, and Post-White J Improving cancer pain management in communities: main results from a randomized controlled trial Journal of Pain & Symptom Management Apr 1997 13(4):191 203
Ellison N, Loprinzi CL, Kugler J, Hatfield AK, Miser A, Sloan JA, Wender DB, Rowland KM, Molina R, Cascino TL, Vukov AM, Dhaliwal HS, and Ghosh C Phase III placebo-controlled trial of capsaicin cream in the management of surgical neuropathic pain in cancer patients Journal of Clinical Oncology Aug 1997 15(8):2974 80
Elomaa I, Blomqvist C, Grohn P, Porkka L, Kairento AL, Selander K, Lamberg-Allardt C, and Holmstrom T Long-term controlled trial with diphosphonate in patients with osteolytic bone metastases Lancet 22 Jan 1983 1(8317):146 9
Elomaa I, Kylmala T, Tammela T, Viitanen J, Ottelin J, Ruutu M, Jauhiainen K, Ala-Opas M, Roos L, Seppanen J, et al Effect of oral clodronate on bone pain. A controlled study in patients with metastic prostatic cancer International Urology and Nephrology 1992 24(2):159 66 1385586
Epstein JB and Stevenson-Moore P. Benzydamine hydrochloride in prevention and management of pain in oral mucositis associated with radiation therapy. Oral Surgery, Oral Medicine, Oral Pathology. 1986;62:145-8.
Erbman E. Observations on individual sensitiveness to pain. JAMA. 1934;102:335-41.
Ernst DS, MacDonald RN, Paterson AH, Jensen J, Brasher P, and Bruera E A double-blind, crossover trial of intravenous clodronate in metastatic bone pain Journal of Pain & Symptom Management Jan 1992 7(1):4 11
Ernst DS, Brasher P, Hagen N, Paterson AH, MacDonald RN, and Bruera E A randomized, controlled trial of intravenous clodronate in patients with metastatic bone disease and pain Journal of Pain & Symptom Management Jun 1997 13(6):319 26
Estape J, Vinolas N, Gonzalez B, Ingles F, Bofill T, Guzman MC, and Tarrago E Ketorolac, a new non-opioid analgesic: a double-blind trial versus pentazocine in cancer pain Journal of International Medical Research Jul 1990 18(4):298 304
Fadiman A. The spirit catches you and you fall down. A Hmong child, her American doctors, and the collision of two cultures. New York: Farrar, Straus and Giroux. 1997.
Farrar JT, Cleary J, Rauck R, Busch M, and Nordbrock E Oral transmucosal fentanyl citrate: randomized, double-blinded, placebo-controlled trial for treatment of breakthrough pain in cancer patients Journal of the National Cancer Institute 15 Apr 1998 90(8):611 6
Feinstein AR Meta-analysis: statistical alchemy for the 21st century [see comments]. [Review] [27 refs] Journal of Clinical Epidemiology Jan 1995 48(1):71 9 7853050
Fenstermaker RA, Sternau LL, and Takaoka Y CT-assisted percutaneous anterior cordotomy: technical note; discussion Surg Neurol Feb 1995 43(2):147 50
Ferrell B, Wisdom C, Wenzl C, and Brown J Effects of controlled-released morphine on quality of life for cancer pain Oncology Nursing Forum Jul 1989 16(4):521 6
Ferrell BR and Ferrell BA. Pain in the elderly. A report of the Task Force on Pain in the Elderly of the International Association for the Study of Pain. Seattle: IASP Press. 1996.
Ferrer-Brechner T and Ganz P Combination therapy with ibuprofen and methadone for chronic cancer pain American Journal of Medicine 13 Jul 1984 77(1A):78 83
Field MJ and Cassel CK (eds.) Approaching death. Improving care at the end of lifeInstitute of MedicineWashington, DC: National Academy Press 1997
Fields HL. Core curriculum for professional education in pain. A report of the task force on professional education of the International Association for the Study of Pain. Seattle: IASP Press. 1995a.
Filos KS, Goudas LC, Patroni O, and Tassoudis V Analgesia with epidural nimodipine Lancet 23 Oct 1993 342(8878):
Filshie J, Golding S, Robbie DS, and Husband JE Unilateral computerised tomography guided coeliac plexus block: a technique for pain relief Anaesthesia May 1983 38(5):498 503 6859483
Finn JW, Walsh TD, MacDonald N, Bruera E, Krebs LU, and Shepard KV Placebo-blinded study of morphine sulfate sustained-release tablets and immediate-release morphine sulfate solution in outpatients with chronic pain due to advanced cancer Journal of Clinical Oncology May 1993 11(5):967 72 8487059
Firestone L and Lebowitz P. Clinical anesthesia procedures of the Massachusetts General Hospital. Boston: Little, Brown and Company. 1988.
Foley KM The treatment of cancer pain N Engl J Med 1985 313(2):84 95 2582259
Foley KM Advances in cancer pain Archives of Neurology 1999 56(4):413 7 10199328
Foley KM and Payne RM. Current therapy of pain. Toronto: B C Decker, Inc. 1989.
Foley KM, Bonica JJ, Ventafridda V, and Callaway MV (eds). Advances in pain research and therapy. Second International Congress on Cancer Pain. New York: Raven Press. 1990;Vol. 16.
Fossa SD, Aaronson NK, Newling D, van Cangh PJ, Denis L, Kurth KH, and DePauw M Quality of life and treatment of hormone resistant metastatic prostatic cancer. The EORTC Genito-Urinary Group European Journal of Cancer 1990 26(11-12):1133 6 2149995
Francke AL, Garssen B, Luiken JB, De Schepper AM, Grypdonck M, and Abu Saad HH Effects of a nursing pain programme on patient outcomes Psycho-Oncology Dec 1997 6(4):302 10
Fraser SC, Dobbs HJ, Ebbs SR, Fallowfield LJ, Bates T, and Baum M Combination or mild single agent chemotherapy for advanced breast cancer? CMF vs epirubicin measuring quality of life British Journal of Cancer Feb 1993 67(2):402 6
Freeman WJ. Societies of brains: A study in the neuroscience of love and hate. Hillsdale, NJ: Lawrence Erlbaum Associates, Inc.; 1995.
Fuccella LM, Conti F, Corvi G, Mandelli V, Randelli M, and Stefanelli G Double-blind study of the analgesic effect of indoprofen (K 4277) Clinical Pharmacology & Therapeutics 1975 17(3):277 83 47280
Gagnon B, Bielech M, Watanabe S, Walker P, Hanson J, and Bruera E The use of intermittent subcutaneous injections of oxycodone for opioid rotation in patients with cancer pain Supportive Care in Cancer Jul 1999 7(4):265 70
Gallagher RM (ed) The medical clinics of North America: chronic pain Vol 83No 3.Philadelphia: WB Saunders Company 1999
Gallucci M, Toscani F, Mapelli A, Cantarelli A, Veca G, and Scaricabarozzi I Nimesulide in the treatment of advanced cancer pain. Double-blind comparison with naproxen Arzneimittel-Forschung Aug 1992 42(8):1028 30
Ganzini L, Nelson HD, Schmidt TA, Kraemer DF, Delorit MA, and Lee MA Physicians' experiences with the Oregon Death with Dignity Act [see comments] N Engl J Med 24 Feb 2000 342(8):557 63
Gebhart GF (ed). Visceral pain. The Bristol-Myers Squibb Symposium on Pain Research. Seattle: IASP Press. 1995;Vol. 5.
Gebhart GF. Visceral pain and its modulation. In New England Pain Association's 2000 Annual Winter Conference on Pain Management. Richmond, VA: American Pain Society and the New England Pain Association: 2000.
Ger LP, Ho ST, Wang JJ, and Cherng CH The prevalence and severity of cancer pain: a study of newly-diagnosed cancer patients in Taiwan Journal of Pain & Symptom Management May 1998 15(5):285 93 9654833
Gershon E, Vatine JJ, Shir Y, Wu TX, Azaria M, Zeltser R, Belfer I, Max M, Diehl SR Seltzer Z. Correlation between phantom limb pain and other phantom sensory phenomena in human amputees. III European Federation of IASP Chapters Congress. Nice France: Sept 2000.
Gerteis MG, Edgman-Levitan S, Daley J, and Delbanco TL. Through the patient's eyes. Understanding and promoting patient-centered care. San Francisco: Jossey-Bass Publishers. 1999.
Gilbert JP, McPeek B, and Mosteller F Statistics and ethics in surgery and anesthesia Science 18 Nov 1977 198(4318):684 9
Gilbert MR and Grossman SA Incidence and nature of neurologic problems in patients with solid tumors American Journal of Medicine Dec 1986 81(6):951 4
Gildenberg PL and Hirshberg RM Limited myelotomy for the treatment of intractable cancer pain J Neurol Neurosurg Psychiatry Jan 1984 47(1):94 6
Giles BE and Walker JS. Gender differences in pain. Current Opinion in Anaesthesiology. 1999;12:591-5. [pmid: 17016254].
Glover D, Lipton A, Keller A, Miller AA, Browning S, Fram RJ, George S, Zelenakas K, Macerata RS, and Seaman JJ Intravenous pamidronate disodium treatment of bone metastases in patients with breast cancer. A dose-seeking study Cancer 01 Dec 1994 74(11):2949 55
Goisis A, Gorini M, Ratti R, and Luliri P Application of a WHO protocol on medical therapy for oncologic pain in an internal medicine hospital Tumori 1989 75(5):470 2 2481351
Gottlieb A Naproxen sodium infusion for exacerbation of cancer pain [letter] Journal of Pain & Symptom Management Apr 1990 5(2):
Goudas LC and Carr DB Value of presenting the time-course of pain relief in analgesic trials Anesthesiology Dec 1998 89(6):1602 3
Goughnour BR, Arkinstall WW, and Stewart JH Analgesic response to single and multiple doses of controlled-release morphine tablets and morphine oral solution in cancer patients Cancer 01 Jun 1989 63(11 Suppl):2294 7
Gourlay GK, Plummer JL, Cherry DA, Onley MM, Parish KA, Wood MM, and Cousins MJ Comparison of intermittent bolus with continuous infusion of epidural morphine in the treatment of severe cancer pain Pain Nov 1991 47(2):135 40
Gray JA Muir. Evidence-based healthcare. How to make health policy and management decisions. New York: Churchill Livingstone. 1997.
Greenhalgh T, Hurwitz B (eds). Narrative based medicine. Dialogue and discourse in clinical practice. London: BMJ Publishing Group. 1998.
Greenland S Invited commentary: a critical look at some popular meta-analytic methods [see comments] American Journal of Epidemiology 01 Aug 1994 140(3):290 6 8030632
Greenwald HP, Bonica JJ, and Bergner M The prevalence of pain in four cancers Cancer 15 Nov 1987 60(10):2563 9
Grochow L, Sheidler V, Grossman S, Green L, and Enterline J Does intravenous methadone provide longer lasting analgesia than intravenous morphine? A randomized, double-blind study Pain Aug 1989 38(2):151 7
Grond S, Zech D, Schug SA, Lynch J, and Lehmann KA The importance of non-opioid analgesics for cancer pain relief according to the guidelines of the World Health Organization International Journal of Clinical Pharmacology Research 1991a 11(6):253 60
Grond S, Zech D, Schug SA, Lynch J, and Lehmann KA Validation of World Health Organization guidelines for cancer pain relief during the last days and hours of life Journal of Pain & Symptom Management Oct 1991b 6(7):411 22
Grond S, Zech D, Diefenbach C, Radbruch L, and Lehmann KA Assessment of cancer pain: a prospective evaluation in 2266 cancer patients referred to a pain service Pain Jan 1996 64(1):107 14
Grond S, Zech D, Lehmann KA, Radbruch L, Breitenbach H, and Hertel D Transdermal fentanyl in the long-term treatment of cancer pain: a prospective study of 50 patients with advanced cancer of the gastrointestinal tract or the head and neck region Pain Jan 1997 69(1-2):191 8
Grond S, Radbruch L, Meuser T, Sabatowski R, Loick G, and Lehmann KA Assessment and treatment of neuropathic cancer pain following WHO guidelines Pain 1999 79(1):15 20 9928771
Gross CP, Anderson GF, and Powe NR The relation between funding by The National Institutes of Health and the burden of disease N Engl J Med 1999 340(24):1881 7 10369852
Guyatt GH, Sinclair J, Cook D, and Glaziou P User's guides to the medical literature. XVI. How to use a treatment recommendation JAMA 1999 281(19):1836 43 10340372
Gybels JM and Sweet WH (eds). Neurosurgical treatment of persistent pain. "Physiological and pathological mechanisms of human pain" 11. Basel: Karger. 1989.
Hammack JE, Mailliard JA, Loprinzi CL, Rospond RM, O'Fallon JR, Wilwerding MB, Reuter NF, Michalak JC, Fidler P, and Miser AW Transdermal fentanyl in the management of cancer pain in ambulatory patients: an open-label pilot study Journal of Pain & Symptom Management Oct 1996 12(4):234 40
Hanks GW, Twycross RG, and Bliss JM Controlled release morphine tablets: a double-blind trial in patients with advanced cancer Anaesthesia Aug 1987 42(8):840 4
Harwood A (ed). Ethnicity and medical care. Cambridge: Harvard University Press. 1981.
Hassenbusch SJ, Portenoy RK Current practices in intraspinal therapy -- a survey of clinical trends and decision making Journal of Pain and Symptom Management Aug 2000 20(2):S4 11
Hays H, Hagen N, Thirlwell M, Dhaliwal H, Babul N, Harsanyi Z, and Darke AC Comparative clinical efficacy and safety of immediate release and controlled release hydromorphone for chronic severe cancer pain Cancer 15 Sep 1994 74(6):1808 16
Heiskanen T and Kalso E Controlled-release oxycodone and morphine in cancer related pain Pain Oct 1997 73(1):37 45
Higginson IJ and Hearn J A multicenter evaluation of cancer pain control by palliative care teams Journal of Pain & Symptom Management Jul 1997 14(1):29 35
Hill HF, Coda BA, Mackie AM, and Iverson K Patient-controlled analgesic infusions: alfentanil versus morphine Pain Jun 1992 49(3):301 10
Hill Jr CS and Fields WS (eds). Drug treatment of cancer pain in a drug-oriented society 11. New York: Raven Press. 1989.
Hindley AC, Hill EB, Leyland MJ, and Wiles AE A double-blind controlled trial of salmon calcitonin in pain due to malignancy Cancer Chemotherapy & Pharmacology 1982 9(2):71 4 6756666
Hiraga K, Mizuguchi T, and Takeda F The incidence of cancer pain and improvement of pain management in Japan Postgraduate Medical Journal 1991 67(Suppl 2):S14 S25 1758814
Hoffman DE Pain management and palliative care in the era of managed care: issues for health insurers J Law Med Ethics 1998 26(267):
Honore P and Mantyh PW. Bone cancer pain: from mechanism to model to therapy. Pain Medicine. Dec 2000;1:303-9.
Hortobagyi GN, Theriault RL, Porter L, Blayney D, Lipton A, Sinoff C, Wheeler H, Simeone JF, Seaman J, and Knight RD Efficacy of pamidronate in reducing skeletal complications in patients with breast cancer and lytic bone metastases. Protocol 19 Aredia Breast Cancer Study Group [see comments] N Engl J Med 12 Dec 1996 335(24):1785 91
Hoskin PJ, Poulain P, and Hanks GW Controlled-release morphine in cancer pain. Is a loading dose required when the formulation is changed? Anaesthesia Nov 1989 44(11):897 901
Hoskin PJ, Price P, Easton D, Regan J, Austin D, Palmer S, and Yarnold JR A prospective randomised trial of 4 Gy or 8 Gy single doses in the treatment of metastatic bone pain Radiotherapy & Oncology Feb 1992 23(2):74 8
Houde RW, Wallenstein SL, and Rogers A Clinical pharmacology of analgesics:a method of assaying analgesic effect Clinical Pharmacology & Therapeutics 1960 1(163):
Hughes A, Wilcock A, and Corcoran R Ketorolac: continuous subcutaneous infusion for cancer pain Journal of Pain & Symptom Management Jun 1997 13(6):315 6
Ioannidis JPA and Lau J. Can quality of clinical trials and meta-analyses be quantified?. The Lancet. 1998;352:590-1.
Ioannidis JP, Lau J Completeness of safety reporting in randomized trials: an evaluation of 7 medical areas JAMA Jan 2001 28(4):437 43
Ischia S, Luzzani A, Ischia A, and Pacini L Role of unilateral percutaneous cervical cordotomy in the treatment of neoplastic vertebral pain Pain Jun 1984a 19(2):123 31
Ischia S, Luzzani A, Ischia A, and Maffezzoli G Bilateral percutaneous cervical cordotomy: immediate and long-term results in 36 patients with neoplastic disease J Neurol Neurosurg Psychiatry Feb 1984b 47(2):141 7
Ischia S, Ischia A, Polati E, and Finco G Three posterior percutaneous celiac plexus block techniques. A prospective, randomized study in 61 patients with pancreatic cancer pain Anesthesiology Apr 1992 76(4):534 40
Ischia S, Polati E, Finco G, Gottin L, and Benedini B 1998 Labat Lecture: the role of the neurolytic celiac plexus block in pancreatic cancer pain management: do we have the answers? Regional Anesthesia & Pain Medicine Nov 1998 23(6):611 4
Jacox A, Carr DB, Payne R, CB Berde, Brietbart W, Cain JM, Chapman CR, Cleeland CS, Ferrell BR, and Hester NO. Management of cancer pain. Clinical practice guideline. AHCPR Publication No. 94-0592 ed. Rockville, MD: Agency for Health Care Policy and Research. U.S. Department of Health and Human Services. 1994.
Jadad AR. Meta-analysis of randomised clinical trials in pain relief [Doctoral thesis]. Oxford: University of Oxford; 1994.
Jadad AR. Meta-analysis in pain relief: a valuable but easily misused tool. Current Opinion in Anaesthesiology. 1996;9:426-9.
Jadad AR. Randomised controlled trials: A user's guide. London: BMJ Books. 1998.
Jadad AR, Cepeda MS Clinical trials in pain relief: 10 challenges Pain Clinical Update 1999 7(2):1 4
Jadad AR and Browman GP The WHO analgesic ladder for cancer pain management. Stepping up the quality of its evaluation JAMA 20 Dec 1995 274(23):1870 3
Jeremic B, Shibamoto Y, Acimovic L, Milicic B, Milisavljevic S, Nikolic N, Aleksandrovic J, and Igrutinovic I A randomized trial of three single-dose radiation therapy regimens in the treatment of metastatic bone pain International Journal of Radiation Oncology, Biology, Physics 01 Aug 1998 42(1):161 7
Pain assessment and management standards. In Comprehensive accreditation manual for hospitals: the official handbook. Oakbrook: The Commission. 2000.
Joishy SK and Walsh D The opioid-sparing effects of intravenous ketorolac as an adjuvant analgesic in cancer pain: application in bone metastases and the opioid bowel syndrome Journal of Pain & Symptom Management 1998 16(5):334 9 9846029
Joranson D. Information about regulatory issues in pain management. www.medsch.wisc.edu/painpolicy. June 1998.
Joranson DE, Ryan KM, Gilson AM, and Dahl JL Trends in medical use and abuse of opioid analgesics JAMA 05 Apr 2000 283(13):1710 4
Juni P, Witschi A, Bloch R, and Egger M. The hazards of scoring the quality of clinical trials for meta-analysis. JAMA. 1999;282:1054-60. [pmid: 10493204].
Kaiko RF, Kanner R, Foley KM, Wallenstein SL, Canel AM, Rogers AG, and Houde RW Cocaine and morphine interaction in acute and chronic cancer pain Pain Oct 1987 31(1):35 45
Kalso E. Better standardisation will improve the quality of analgesic studies. Acta Anaesthesiol Scand. 1996;40:397-8. [pmid: 8738681].
Kalso E and Vainio A Morphine and oxycodone hydrochloride in the management of cancer pain Clinical Pharmacology & Therapeutics May 1990 47(5):639 46 2188774
Kalso E, Tasmuth T, and Neuvonen P Amitriptyline effectively relieves neuropathic pain following treatment of breast cancer Pain Feb 1996 64(2):293 302
Kalso E, Heiskanen T, Rantio M, Rosenberg PH, and Vainio A Epidural and subcutaneous morphine in the management of cancer pain: a double-blind cross-over study Pain Oct 1996 67(2-3):443 9
Kane RL, Bernstein L, Wales J, and Rothenberg R Hospice effectiveness in controlling pain JAMA 10 May 1985 253(18):2683 6
Kanner R. Diagnosis and management of pain in patients with cancer 10. Basel: Karger. 1988.
Kawamata M, Ishitani K, Ishikawa K, Sasaki H, Ota K, Omote K, and Namiki A Comparison between celiac plexus block and morphine treatment on quality of life in patients with pancreatic cancer pain Pain Mar 1996 64(3):597 602
Kelsen DP, Portenoy RK, Thaler HT, Niedzwiecki D, Passik SD, Tao Y, Banks W, Brennan MF, and Foley KM Pain and depression in patients with newly diagnosed pancreas cancer Journal of Clinical Oncology Mar 1995 13(3):748 55
Kelson MC. Consumer collaboration, patient-defined outcomes and the preparation of Cochrane Reviews. 129-35. In Rice and Katz (eds) Health Expectations. London: Blackwell Science Ltd. 1999.
Korte W, de Stoutz N, and Morant R Day-to-day titration to initiate transdermal fentanyl in patients with cancer pain: short- and long-term experiences in a prospective study of 39 patients Journal of Pain & Symptom Management Mar 1996 11(3):139 46
Kravitz RL, Delafield JP, Hays RD, Drazin R, and Conolly M Bedside charting of pain levels in hospitalized patients with cancer: a randomized controlled trial [see comments] Journal of Pain & Symptom Management Feb 1996 11(2):81 7
Kylmala T, Tammela T, Risteli L, Risteli J, Taube T, and Elomaa I Evaluation of the effect of oral clodronate on skeletal metastases with type 1 collagen metabolites. A controlled trial of the Finnish Prostate Cancer Group European Journal of Cancer 1993 29A(6):821 5 7683480
Kylmala T, Taube T, Tammela TL, Risteli L, Risteli J, and Elomaa I Concomitant i.v. and oral clodronate in the relief of bone pain--a double-blind placebo-controlled study in patients with prostate cancer British Journal of Cancer 1997 76(7):939 42 9328156
Labianca R, Pancera G, Aitini E, Barni S, Beretta A, Beretta GD, Cesana, Comella G, Cozzaglio L, and Cristoni M Folinic acid + 5-fluorouracil (5-FU) versus equidose 5-FU in advanced colorectal cancer. Phase III study of 'GISCAD' (Italian Group for the Study of Digestive Tract Cancer) Annals of Oncology Oct 1991 2(9):673 9
Lahtinen R, Laakso M, Palva I, Virkkunen P, and Elomaa I Randomised, placebo-controlled multicentre trial of clodronate in multiple myeloma Lancet 31 Oct 1992 340(8827):1049 52 [published erratum appears in Lancet 1992 Dec 5;340(8832):1420]
Laird NM and Mosteller F Some statistical methods for combining experimental results Int J Technol Assess Health Care 1990 6(1):5 30 2361819
Landis SH, Murray T, Bolden S, and Wingo PA Cancer Statistics, 1999 CA: A Cancer Journal for Clinicians 1999 49(1):8 11 10200775
Lang SS and Patt RB. You don't have to suffer. A complete guide to relieving cancer pain for patients and their families. New York: Oxford University Press. 1994.
Larue F, Colleau SM, Brasseur L, and Cleeland CS Multicentre study of cancer pain and its treatment in France [see comments] BMJ 22 Apr 1995 310(6986):1034 7
Lasch KE, Wilkes GM, Leonard C, Chew P, Montouri L, and Hilton SM Using focus group methods to develop multicultural cancer pain education materials Pain Management Nursing 2000 1(4):129 138 11709866
Lasagna L (ed). Combination drugs. Their use and regulation. New York: Stratton Intercontinental Medical Book Corp. 1975.
Lasagna L, Mosteller F, von Felsinger JM, and Beecher HK. A study in placebo response. American Journal of Medicine. Jun 1954:770-9.
Lau J, Ioannidis JP, and Schmid CH Quantitative synthesis in systematic reviews Ann Intern Med Nov 1997 127(9):820 6
Lauretti GR, Reis MP, Mattos AL, Gomes JM, Oliveira AP, and Pereira NL Epidural nonsteroidal antiinflammatory drugs for cancer pain Anesthesia & Analgesia 1998 86(1):117 8 9428863
Levick S, Jacobs C, Loukas DF, Gordon DH, Meyskens FL, and Uhm K Naproxen sodium in treatment of bone pain due to metastatic cancer Pain Dec 1988 35(3):253 8
Lewington VJ, McEwan AJ, Ackery DM, Bayly RJ, Keeling DH, Macleod PM, Porter AT, and Zivanovic MA A prospective, randomised double-blind crossover study to examine the efficacy of strontium-89 in pain palliation in patients with advanced prostate cancer metastatic to bone European Journal of Cancer 1991 27(8):954 8 1716935
Li QS, Cao SH, Xie GM, Gan YH, Ma HJ, Lu JZ, and Zhang ZH Combined traditional Chinese medicine and Western medicine Relieving effects of Chinese herbs, ear-acupuncture and epidural morphine on postoperative pain in liver cancer Chinese Medical Journal Apr 1994 107(4):289 94
Liew E and Hui YL A preliminary study of long-term epidural morphine for cancer pain via a subcutaneously implanted reservoir Ma Tsui Hsueh Tsa Chi Anaesthesiologica Sinica Mar 1989 27(1):5 12
Lijmer JG, Mol BW, Heisterkamp S, Bonsel GJ, Prins MH, van der Meulen JH, and Bossuyt PM Empirical evidence of design-related bias in studies of diagnostic tests [see comments] JAMA 15 Sep 1999 282(11):1061 6
Lillemoe KD, Cameron JL, Kaufman HS, Yeo CJ, Pitt HA, and Sauter PK Chemical splanchnicectomy in patients with unresectable pancreatic cancer. A prospective randomized trial Ann Surg May 1993 217(5):447 57 7683868
Lipman AG, Jackson KC II, Tyler LS. Evidence-Based Symptom Control in Palliative Care. Binghamton NY:Haworth Press. 2000.
Little M Assignments of meaning in epidemiology Soc Sci Med 1998 47(9):1135 45 9783856
Loeser JD. Evaluation of the pain patient. In Loeser JD, Butler SH, Chapman CR, Turk DC (eds). Bonica's Management of Pain, 3^rd^ ed. Philadelphia:Lippincott, Williams & Wilkins. 2001:265-266.
Loeser JD The future: will pain be abolished or just pain management specialists? Pain: Clinical Updates. Dec 2000 8(6)1 4
Loeser JD and Egan KJ (eds). Managing the chronic pain patient. Theory and practice at the University of Washington Multidisciplinary Pain Center. New York: Raven Press. 1989.
Loeser JD and Melzack R Pain: an overview Lancet 1999 353(9164):1607 9 10334273
Macbeth FR, Bolger JJ, Hopwood P, Bleehen NM, Cartmell J, Girling DJ, Machin D, Stephens RJ, and Bailey AJ Randomized trial of palliative two-fraction versus more intensive 13-fraction radiotherapy for patients with inoperable non-small cell lung cancer and good performance status. Medical Research Council Lung Cancer Working Party [see comments] Clinical Oncology (Royal College of Radiologists) 1996 8(3):167 75
Macrae WA and Bavies HTO. Chronic postsurgical pain. In Crombie IK, Croft PR, Linton SJ, LeResche L, and von Korff M (eds). Epidemiology of Pain. Seattle: IASP Press. 1999:125-42.
Madrid JL, Fatela LV, Alcorta J, Guillen F, and Lobato RD Intermittent intrathecal morphine by means of an implantable reservoir: a survey of 100 cases Journal of Pain & Symptom Management 1988 3(2):67 71 3356916
Madsen EL Painful bone metastasis: efficacy of radiotherapy assessed by the patients: a randomized trial comparing 4 Gy X 6 versus 10 Gy X 2 International Journal of Radiation Oncology, Biology, Physics Dec 1983 9(12):1775 9
Mant D Can randomised trials inform clinical decisions about individual patients? Lancet 27 Feb 1999 353(9154):743 6 10073531
Mark DH and Glass RM Impact of new technologies in medicine: a global theme issue [editorial] JAMA 17 Nov 1999 282(19):
Martino G, Ventafridda V, Parini J, and Emanueli A. A controlled study on the analgesic activity of indoprofen in patients with cancer pain. [Monograph] In Bonica JJ and Albe-Fessard D eds. Pharmacological Agents in Chronic Pain, Advances in Pain Research and Therapy. New York: Raven Press. 1976;Vol 1:573-8.
Martino G, Emanueli A, Mandelli V, and Ventafridda V A controlled study of the analgetic effect of two non-steroidal anti-inflammatory drugs in cancer pain Arzneimittel-Forschung 1978 28(9):1657 9 383108
Martoni A, Guaraldi M, Camera P, Biagi R, Marri S, Beghe F, and Pannuti F Controlled clinical study on the use of dichloromethylene diphosphonate in patients with breast carcinoma metastasizing to the skeleton Oncology 1991 48(2):97 101 1825515
Max B. Collecting better data about drug treatments for chronic pain. In Cohen and Campbell (eds). Pain treatment centers at the crossroads: a practical and conceptual reappraisal. Seattle: IASP Press. 1996:163-72.
Max M. Methodological issues in the design of analgesic clinical trials. In Max M (ed). Pain 1999 - An updated review: Refresher course syllabus. Seattle: IASP Press. 1999;6:299-308.
Max MB Thirteen consecutive well-designed randomized trials show that antidepressants reduce pain in diabetic neuropathy and postherpetic neuralgia Pain Forum 1995 4(4):248 53
Max MB, Portenoy RK, and Laska EM (eds). Advances in pain research and therapy: the design of analgesic clinical trials. New York: Raven Press. 1991;Vol. 18.
Max MB and Portenoy RK. Pain research: designing clinical trials in palliative care. Oxford textbook of palliative medicine 2^nd^ ed. New York: Oxford University Press, Inc. 1998:167-178.
McCaffery M and Pasero C. Pain clinical manual. 2nd ed. St. Louis: Mosby, Inc. 1999.
McCloskey EV, MacLennan IC, Drayson MT, Chapman C, Dunn J, and Kanis JA A randomized trial of the effect of clodronate on skeletal morbidity in multiple myeloma. MRC Working Party on Leukaemia in Adults British Journal of Haematology Feb 1998 100(2):317 25
McCorkle R, Benoliel JQ, Donaldson G, Georgiadou F, Moinpour C, and Goodell A randomized clinical trial of home nursing care for lung cancer patients Cancer 15 Sep 1989 64(6):1375 82
McQuay H Opioids in pain management Lancet 1999 353(9171):2229 33 10393001
McQuay H, Carroll D, Jadad AR, Wiffen P, and Moore A Anticonvulsant drugs for management of pain: a systematic review BMJ 21 Oct 1995 311(7012):1047 52
McQuay H and Moore A. An evidence-based resource for pain relief. Oxford: Oxford University Press. 1998.
McQuay HJ, Tramer M, Nye BA, Carroll D, Wiffen PJ, and Moore RA A systematic review of antidepressants in neuropathic pain [see comments] Pain Dec 1996 68(2-3):217 27
McQuay HJ, Carroll D, and Moore RA Radiotherapy for painful bone metastases: a systematic review Clinical Oncology (Royal College of Radiologists) 1997 9(3):150 4
Medical Research Council (MRC) randomised trial of palliative radiotherapy with two fractions or a single fraction in patients with inoperable non-small-cell lung cancer (NSCLC) and poor performance status British Journal of Cancer Jun 1992 65(6):934 41
Meglio M and Cioni B The role of percutaneous cordotomy in the treatment of chronic cancer pain Acta Neurochir (Wien) 1981 59(1-2):111 21 7315556
Mercadante S. Celiac plexus block versus analgesics in pancreatic cancer pain. Pain. 1993;52:187-92. [pmid: 8455966].
Mercadante S Pain treatment and outcomes for patients with advanced cancer who receive follow-up care at home [see comments] Cancer 15 Apr 1999a 85(8):1849 58 10223581
Mercadante S World Health Organization Guidelines: problem areas in cancer pain management Cancer Control: Journal of the Moffitt Cancer Center 1999b 6(2):191 7 10758549
Mercadante S, Maddaloni S, Roccella S, and Salvaggio L Predictive factors in advanced cancer pain treated only by analgesics Pain 1992 50(2):151 5 1408310
Mercadante S, Armata M, and Salvaggio L Pain characteristics of advanced lung cancer patients referred to a palliative care service Pain Oct 1994 59(1):141 5
Mercadante S, Sapio M, Caligara M, Serretta R, Dardanoni G, and Barresi L Opioid-sparing effect of diclofenac in cancer pain Journal of Pain & Symptom Management 1997 14(1):15 20 9223838
Mercadante S, Salvaggio L, Dardanoni G, Agnello A, and Garofalo S Dextropropoxyphene versus morphine in opioid-naive cancer patients with pain Journal of Pain & Symptom Management Feb 1998 15(2):76 81
Mercadante S, Casuccio A, Agnello A, Pumo S, Kargar J, and Garofalo S Analgesic effects of nonsteroidal anti-inflammatory drugs in cancer pain due to somatic or visceral mechanisms Journal of Pain & Symptom Management May 1999 17(5):351 6 10355213
Merskey H and Bogduk N (eds). Classification of chronic pain. Description of chronic pain syndromes and definitions of pain terms. 2nd ed. Seattle: IASP Press. 1994.
Meuret G and Jocham H Patient-controlled analgesia (PCA) in the domiciliary care of tumour patients Cancer Treatment Reviews Jan 1996 22(Supplement A):137 40
Meyers CA Neurocognitive dysfunction in cancer patients Oncology Jan 2000 14(1):75 9 10680150
Miaskowski C and Levine JD. Does opioid analgesia show a gender preference for females?. Pain Forum. 1999;8:34-44.
Miaskowski C. Pain Management: quality assurance and changing practice. In Gebhart G, Hammond D, and Jensen TS (eds). Proceedings of the 7^th^ World Congress of Pain. Seattle: IASP Press. 1994:75-96.
Mignault GG, Latreille J, Viguie F, Richer P, Lemire F, Harsanyi Z, and Stewart JH Control of cancer-related pain with MS Contin: a comparison between 12-hourly and 8-hourly administration [see comments] Journal of Pain & Symptom Management Aug 1995 10(6):416 22
Miller AB (ed.). The World Health Organisation Global Programme for Cancer Control. National Cancer Control Programmes. Policies and managerial guidelines. Geneva: World Health Organisation. 1993.
Miller AB, Hoogstraten B, Staquet M, and Winkler A Reporting results of cancer treatment Cancer 01 Jan 1981 47(1):207 14
Minotti V, Patoia L, Roila F, Basurto C, Tonato M, Pasqualucci V, Maresca V, and Del Favero A Double-blind evaluation of analgesic efficacy of orally administered diclofenac, nefopam, and acetylsalicylic acid (ASA) plus codeine in chronic cancer pain Pain Feb 1989 36(2):177 83
Minotti V, Betti M, Ciccarese G, Fumi G, Tonato M, and Del Favero A A double-blind study comparing two single-dose regimens of ketorolac with diclofenac in pain due to cancer Pharmacotherapy May 1998a 18(3):504 8
Minotti V, De Angelis V, Righetti E, Celani MG, Rossetti R, Lupatelli M, Tonato M, Pisati R, Monza G, Fumi G, and Del Favero A Double-blind evaluation of short-term analgesic efficacy of orally administered diclofenac, diclofenac plus codeine, and diclofenac plus imipramine in chronic cancer pain Pain Feb 1998b 74(2-3):133 7
Miser AW, McCalla J, Dothage JA, Wesley M, and Miser JS Pain as a presenting symptom in children and young adults with newly diagnosed malignancy Pain Apr 1987 29(1):85 90
Miser AW, Dothage JA, Wesley RA, and Miser JS The prevalence of pain in a pediatric and young adult cancer population Pain Apr 1987 29(1):73 83
Mitchell JD. Global populations growing older. In Brown L, Renner M, Flavin C, Starke L et al., (eds). Vital signs 1997. The environmental trends that are shaping our future. New York: W.W. Norton. 1997:124-5.
Modell W. Relief of symptoms. 2nd ed. St. Louis: CV Mosby Company. 1961.
Moertel CG, Ahmann DL, Taylor WF, and Schwartau N Relief of pain by oral medications. A controlled evaluation of analgesic combinations JAMA 01 Jul 1974 229(1):55 9
Mogil JS. The genetic mediation of individual differences in sensitivity to pain and its inhibition. Proceedings of the National Academy of Sciences, USA. 1999;96:7744-51.
Moher D, Dulberg CS, Wells GA. Statistical power, sample size, and their reporting in randomized controlled trials. JAMA. 1994;272:122-4. [pmid: 8015121].
Moher D, Jadad AR, Nichol G, Penman M, Tugwell P, and Walsh S Assessing the quality of randomized controlled trials: an annotated bibliography of scales and checklists Control Clin Trials Feb 1995 16(1):62 73
Moore R and Brodsgaard I. Cross-cultural investigations of pain. Crombie I (ed). Epidemiology of pain. Seattle: IASP Press. 1999:53-80.
Moore RA, Gavaghan D, Tramer MR, Collins SL, and McQuay HJ Size is everything--large amounts of information are needed to overcome random effects in estimating direction and magnitude of treatment effects Pain Dec 1998 78(3):209 16
Morley JS New perspectives in our use of opioids Pain Forum 1999 8(4):200 5
Morris DB. Illness and culture in the postmodern age. Berkeley: University of California Press; 1998.
Moulin DE, Kreeft JH, Murray-Parsons N, and Bouquillon AI Comparison of continuous subcutaneous and intravenous hydromorphone infusions for management of cancer pain Lancet 23 Feb 1991 337(8739):465 8
Moulin DE, Johnson NG, Murray-Parsons N, Geoghegan MF, Goodwin VA, and Chester MA Subcutaneous narcotic infusions for cancer pain: treatment outcome and guidelines for use CMAJ Mar 1992 146(6):891 7
Mulrow C and Cook D. Systematic reviews. Synthesis of best evidence for health care decisions. Philadelphia: American College of Physicians. 1998.
Mulrow CD and Oxman AD (eds). Cochrane collaboration handbook [updated September 1997]. How to conduct a cochrane systematic review. In The Cochrane Library [database on disk and CDROM]. Issue 4. Oxford: Update Software. 1997.
Myers KG and Trotman IF Use of ketorolac by continuous subcutaneous infusion for the control of cancer-related pain Postgraduate Medical Journal May 1994 70(823):359 62 8016008
Myles PS Why we need large randomized studies in anaesthesia Br J Anaesth Dec 1999 83(6):833 4 10700777
Nagaro T, Amakawa K, Yamauchi Y, Tabo E, Kimura S, and Arai T Percutaneous cervical cordotomy and subarachnoid phenol block using fluoroscopy in pain control of costopleural syndrome Pain Sep 1994 58(3):325 30
Taking part in clinical trials: what cancer patients need to know. Rockville, MD: NIH, Jun 1998.
SEER cancer statistics. National Institutes of Health. 1999.
Acute pain management: scientific evidence. Sydney: National Health and Medical Research Council. 1999.
Nielsen OS, Bentzen SM, Sandberg E, Gadeberg CC, and Timothy AR Randomized trial of single dose versus fractionated palliative radiotherapy of bone metastases Radiotherapy & Oncology Jun 1998 47(3):233 40
Niewald M, Tkocz HJ, Abel U, Scheib T, Walter K, Nieder C, Schnabel K, Berberich W, Kubale R, and Fuchs M Rapid course radiation therapy vs. more standard treatment: a randomized trial for bone metastases International Journal of Radiation Oncology, Biology, Physics 01 Dec 1996 36(5):1085 9
Nitescu P, Sjoberg M, Appelgren L, and Curelaru I Complications of intrathecal opioids and bupivacaine in the treatment of "refractory" cancer pain Clinical Journal of Pain Mar 1995 11(1):45 62
O'Brien T, Mortimer PG, McDonald CJ, and Miller AJ A randomized crossover study comparing the efficacy and tolerability of a novel once-daily morphine preparation (MXL capsules) with MST Continus tablets in cancer patients with severe pain Palliative Medicine Nov 1997 11(6):475 82
O'Rourke N, McCloskey E, Houghton F, Huss H, and Kanis JA Double-blind, placebo-controlled, dose-response trial of oral clodronate in patients with bone metastases Journal of Clinical Oncology Apr 1995 13(4):929 34
What are clinical trials all about? A booklet for patients with cancer. 97-2706. Bethesda, MD: National Institutes of Health. U.S. Department of Health and Human Services. 1997.
Okawa T, Kita M, Goto M, Nishijima H, and Miyaji N Randomized prospective clinical study of small, large and twice-a-day fraction radiotherapy for painful bone metastases Radiotherapy & Oncology Oct 1988 13(2):99 104
Osterweis M, Kleinman A, and Mechanic D. Pain and disability: Clinical, behavioral, and public policy perspectives. Committee of Pain Disability and Chronic Illness Behavior. Institute of Medicine. Washington, DC: National Academy Press. 1987.
Oyama T, Jin T, Yamaya R, Ling N, and Guillemin R Profound analgesic effects of beta-endorphin in man Lancet Jan 1980 1(8160):122 4
Panich A and Charnvej L Comparison of morphine slow release tablet (MST) and morphine sulphate solution (MSS) in the treatment of cancer pain Journal of the Medical Association of Thailand Dec 1993 76(12):672 6
Papo I and Visca A Phenol rhizotomy in the treatment of cancer pain Anesth Analg 1974 53(6):993 7 4139907
Parris WCV. Cancer pain management: principles and practice. Boston: Butterworth-Heinemann; 1997.
Pasqualucci V, Tantucci C, Paoletti F, Dottorini ML, Bifarini G, Belfiori R, Berioli MB, Grassi V, and Sorbini CA Buprenorphine vs. morphine via the epidural route: a controlled comparative clinical study of respiratory effects and analgesic activity Pain Jun 1987 29(3):273 86
Paterson AH, Powles TJ, Kanis JA, McCloskey E, Hanson J, and Ashley S Double-blind controlled trial of oral clodronate in patients with bone metastases from breast cancer Journal of Clinical Oncology Jan 1993 11(1):59 65
Patt RB. Cancer pain. Philadelphia: JB Lippincott Company. 1993.
Payne R and Gonzales G. Pathophysiology of pain in cancer and other terminal diseases. In Doyle D, Hanks G, MacDonald N (eds). Oxford textbook of palliative medicine. New York: Oxford University Press, Inc. 1999:299-309.
Payne R, Patt RB, and Hill CS. Assessment and treatment of cancer pain 12. Seattle: IASP Press. 1998.
Payne R, Mathias SD, Pasta DJ, Wanke LA, Williams R, and Mahmoud R Quality of life and cancer pain: satisfaction and side effects with transdermal fentanyl versus oral morphine Journal of Clinical Oncology Apr 1998 16(4):1588 93
Pellegrini A, Massidda B, Pellegrini P, Defraia E, Usai A, Parrinello L, Bruni G, Rigamonti G, and Sacchetti G Effect of i.v. indoprofen on cancer pain and serum prolactin and growth hormone levels - a controlled pharmocologic study vs i.m. morphine and placebo Int J Clin Pharmacol Ther Toxicol Sep 1983 21(9):483 6
Perkins FM and Kehlet H Chronic pain as an outcome of surgery. A review of predictive factors Anesthesiology. 2000 93(4):1123 33 11020770
Plummer JL, Cherry DA, Cousins MJ, Gourlay GK Onley MM, and Evans KH. Long-term spinal administration of morphine in cancer and non-cancer pain: a retrospective study Pain Mar 1991 44(3):215 20
Pocock SJ. Clinical trials: a practical approach. New York: John Wiley & Sons. 1998.
Polati E, Finco G, Gottin L, Bassi C, Pederzoli P, and Ischia S Prospective randomized double-blind trial of neurolytic coeliac plexus block in patients with pancreatic cancer Br J Surg Feb 1998 85(2):199 201
Portenoy RK, Maldonado M, Fitzmartin R, Kaiko RF, and Kanner R Oral controlled-release morphine sulfate. Analgesic efficacy and side effects of a 100-mg tablet in cancer pain patients Cancer 01 Jun 1989 63(11 Suppl):2284 8
Portenoy RK and Hagen NA Breakthrough pain: definition, prevalence and characteristics [see comments] Pain Jun 1990 41(3):273 81
Portenoy RK, Miransky J, Thaler HT, Hornung J, Bianchi C, Cibas-Kong I, Feldhamer E, Lewis F, Matamoros I, Sugar MZ, et al Pain in ambulatory patients with lung or colon cancer. Prevalence, characteristics, and effect Cancer Sep 1992 70(6):1616 24
Portenoy RK, Kornblith AB, Wong G, Vlamis V, Lepore JM, Loseth DB, Hakes T, Foley KM, and WJ Hoskins Pain in ovarian cancer patients. Prevalence, characteristics, and associated symptoms Cancer 01 Aug 1994 74(3):907 15
Portenoy RK and Lesage P. Management of cancer pain. Lancet. 1999;353:1695-700. [pmid: 10335806].
Porter AT, McEwan AJ, Powe JE, Reid R, McGowan DG, Lukka H, Sathyanarayana JR, Yakemchuk VN, Thomas GM, and Erlich LE Results of a randomized phase-III trial to evaluate the efficacy of strontium-89 adjuvant to local field external beam irradiation in the management of endocrine resistant metastatic prostate cancer International Journal of Radiation Oncology, Biology, Physics 02 Apr 1993 25(5):805 13
Price P, Hoskin PJ, Easton D, Austin D, Palmer SG, and Yarnold JR Prospective randomised trial of single and multifraction radiotherapy schedules in the treatment of painful bony metastases Radiotherapy & Oncology Aug 1986 6(4):247 55
Department of Health and Human Services. Healthy people 2000: national health promotion and disease prevention objectives. Washington, DC: U. S. Department of Health and Human Services. 1990.
Pud D, Eisenberg E, Spitzer A, Adler R, Fried G, and Yarnitsky D The NMDA receptor antagonist amantadine reduces surgical neuropathic pain in cancer patients: a double blind, randomized, placebo controlled trial Pain Apr 1998 75(2-3):349 54
Puglisi G and Garagiola U Pirprofen and Pentazocine in the treatment of cancer pain Current Therapeutic Research March 1989 45(3):333 338
Quilty PM, Kirk D, Bolger JJ, Dearnaley DP, Lewington VJ, Mason MD, Reed NS, Russell JM, and Yardley J A comparison of the palliative effects of strontium-89 and external beam radiotherapy in metastatic prostate cancer Radiotherapy & Oncology Apr 1994 31(1):33 40
Quinn SF, Murtagh FR, Chatfield R, and Kori SH CT-guided nerve root block and ablation Am J Roentgenol Dec 1988 151(6):1213 6
Raj PP. The practical management of pain. 2nd ed. St. Louis: Mosby Year Book. 1992.
Ramesh PR, Kumar KS, Rajagopal MR, Balachandran P, and Warrier PK Managing morphine-induced constipation: a controlled comparison of an Ayurvedic formulation and senna Journal of Pain & Symptom Management Oct 1998 16(4):240 4
Rees GJ, Devrell CE, Barley VL, and Newman HF Palliative radiotherapy for lung cancer: two versus five fractions Clinical Oncology (Royal College of Radiologists) 1997 9(2):90 5
Resche I, Chatal JF, Pecking A, Ell P, Duchesne G, Rubens R, Fogelman, Houston S, Fauser A, Fischer M, and Wilkins D A dose-controlled study of 153Sm-ethylenediaminetetramethylenephosphonate (EDTMP) in the treatment of patients with painful bone metastases European Journal of Cancer Sep 1997 33(10):1583 91
Rizzo M, Mazzei T, Mini E, Bartoletti R, and Periti P Leuprorelin acetate depot in advanced prostatic cancer: a phase II multicentre trial Journal of International Medical Research 1990 18(Suppl 1):114 25 2108883
Robertson AG, Reed NS, and Ralston SH Effect of oral clodronate on metastatic bone pain: a double-blind, placebo-controlled study Journal of Clinical Oncology Sep 1995 13(9):2427 30
Roca G, Aguilar JL, Gomar C, Mazo V, Costa J, and Vidal F Nimodipine fails to enhance the analgesic effect of slow release morphine in the early phases of cancer pain treatment Pain Dec 1996 68(2-3):239 43
Rodriguez M, Barutell C, Rull M, Galvez R, Pallares J, Vidal F, Aliaga, Moreno J, Puerta J, and Ortiz P Efficacy and tolerance of oral dipyrone versus oral morphine for cancer pain European Journal of Cancer 1994 30A(5):584 7 8080670
Rosser WW Application of evidence from randomised controlled trials to general practice Lancet 20 Feb 1999 353(9153):661 4 10030347
Roth A and Kolaric K Analgetic activity of calcitonin in patients with painful osteolytic metastases of breast cancer. Results of a controlled randomized study Oncology 1986 43(5):283 7 3531953
Rothbard MJ, Kotsilimbas DG, Jacobson SA, and Sall S Relief of intractable pain in cervical carcinoma with percutaneous radiofrequency cordotomy Obstet Gynecol Jul 1972 40(1):50 5
Rothman KJ and Michels KB The continuing unethical use of placebo controls N Engl J Med 11 Aug 1994 331(6):394 8
Sacchetti G, Camera P, Rossi AP, Martioni A, Bruni G, and Pannuti F. Injectable ketoprofen vs. acetylsalicylic acid for the relief of severe cancer pain: a double-blind, crossover trial. Drug Intelligence & Clinical Pharmacy. May 1984;18:403-6. [pmid: 6373214].
Sackett DL, Richardson SW, Rosenberg W, and Haynes RB. Evidence-based medicine. How to practice & teach EBM. New York: Churchill Livingsone. 1997.
Samuelsson H, Malmberg F, Eriksson M, and Hedner T Outcomes of epidural morphine treatment in cancer pain: nine years of clinical experience Journal of Pain & Symptom Management Feb 1995 10(2):105 12
Santillan R, Hurle MA, Armijo JA, de los Mozos, and Florez J Nimodipine-enhanced opiate analgesia in cancer patients requiring morphine dose escalation: a double-blind, placebo-controlled study Pain May 1998 76(1-2):17 26 9696455
Sawynok J and Cowan A (eds). Novel aspects of pain management: opioids and beyond. New York: Wiley-Liss. 1999.
Schechter NL, Berde CB, and Yaster M. Pain in infants, children, and adolescents. Baltimore: Williams & Wilkins. 1993.
Scheef W Analgesic efficacy and safety of oral flupirtine in the treatment of cancer pain Postgraduate Medical Journal 1987 63(Suppl 3):67 70 2451816
Schmidt JD, Scott WW, Gibbons RP, Johnson DE, Prout GR Jr, Loening SA, Soloway MS, Chu TM, Gaeta JF, Slack NH, Saroff J, and Murphy GP Comparison of procarbazine, imidazole-carboxamide and cyclophosphamide in relapsing patients with advanced carcinoma of the prostate Journal of Urology Feb 1979 121(2):185 9
Schug SA, Zech D, and Dorr U Cancer pain management according to WHO analgesic guidelines Journal of Pain & Symptom Management Feb 1990 5(1):27 32
Schug SA, Zech D, Grond S, Jung H, Meuser T, and Stobbe B A long-term survey of morphine in cancer pain patients Journal of Pain & Symptom Management Jul 1992 7(5):259 66
Schulz KF, Chalmers I, Hayes RJ, and Altman DG Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials JAMA 01 Feb 1995 273(5):408 12
Schwei MJ, Honore P, Rogers SD, Salak-Johnson JL, Finke MP, Ramnaraine ML, Clohisy DR, Mantyh PW Neurochemical and cellular reorganization of the spinal cord in a murine model of bone cancer pain J Neurosci 15 Dec 1999 19(24):10886 97
Serafini AN, Houston SJ, Resche I, Quick DP, Grund FM, Ell PJ, Bertrand, Ahmann FR, Orihuela E, Reid RH, Lerski RA, Collier BD, McKillop JH, Purnell GL, Pecking AP, Thomas FD, and Harrison KA Palliation of pain associated with metastatic bone cancer using samarium-153 lexidronam: a double-blind placebo-controlled clinical trial Journal of Clinical Oncology Apr 1998 16(4):1574 81
Siguan S, Damole A, and Megarito A Results of cancer pain treatment at Southern Islands Medical Center, Cebu, Philippines PSJJ 1992 47(4):173 6
Silberg WM, Lundberg GD, and Musacchio RA Assessing, controlling, and assuring the quality of medical information on the Internet: caveant lector et viewor--let the reader and viewer beware JAMA 16 Apr 1997 277(15):1244 5
Siris ES, Sherman WH, Baquiran DC, Schlatterer JP, Osserman EF, and Canfield RE Effects of dichloromethylene diphosphonate on skeletal mobilization of calcium in multiple myeloma N Engl J Med 07 Feb 1980 302(6):310 5
Sloan PA, Moulin DE, and Hays H A clinical evaluation of transdermal therapeutic system fentanyl for the treatment of cancer pain Journal of Pain & Symptom Management Aug 1998 16(2):102 11
Sloman R, Brown P, Aldana E, and Chee E The use of relaxation for the promotion of comfort and pain relief in persons with advanced cancer Contemporary Nurse Mar 1994 3(1):6 12
Smith GM, Egbert LD, Markowitz RA, Mosteller F, and Beecher HK An experimental pain method sensitive to morphine in man: the submaximum effort tourniquet technique Journal of Pharmacology & Experimental Therapeutics Nov 1966 154(2):324 32
Smith JA Jr Palliation of painful bone metastases from prostate cancer using sodium etidronate: results of a randomized, prospective, double-blind, placebo-controlled study Journal of Urology Jan 1989 141(1):85 7
Sniderman AD Clinical trials, consensus conferences, and clinical practice Lancet 24 Jul 1999 354(9175):327 30 10440326
Sorkin LS. Antibody activation and immune reactions: potential linkage to pain and neuropathy. Pain Medicine. Dec 2000;1:296-302. [pmid: 15101875].
Sorkin LS, Xiao WH, Wagner R, and Myers RR. Tumour necrosis factor-alpha induces ectopic activity in nociceptive primary afferent fibres. Neuroscience. 1997;81:255-62. [pmid: 9300418].
Spross JA, McGuire DB, and Schmitt RM Oncology Nursing Society position paper on cancer pain. Part I: Introduction and Background Oncology Nursing Forum 1990a 17(4):595 614
Spross JA, McGuire DB, and Schmitt RM Oncology Nursing Society position paper on cancer pain. Part II: Education Oncology Nursing Forum 1990b 17(5):751 60
Stambaugh JE Jr, Tejada F, and Trudnowski RJ Double-blind comparisons of zomepirac and oxycodone with APC in cancer pain J Clin Pharmacol Apr 1980a 20(4 Pt 2):261 70
Stambaugh JE Analgesic equivalence of Tylox and Percodan: double-blind crossover study of patients with pain from malignancy Current Therapeutic Research Feb 1980b 27(2):302 9
Stambaugh JE Jr Analgesic efficacy, safety and acceptability of zomepirac sodium in comparison to morphine sulfate in the treatment of pain secondary to malignancy Current Therapeutic Research Jun 1982a 31(6):922 9
Stambaugh JE Jr Additive analgesia of oral butorphanol/acetaminophen in patients with pain due to metastatic carcinoma Current Therapeutic Research Mar 1982b 31(3):386 92
Stambaugh JE Jr and Sarajian C Analgesic efficacy of zomepirac sodium in patients with pain due to cancer J Clin Pharmacol Nov 1981 21(11-12 Pt 1):501 7
Stambaugh JE Jr and Lane C Analgesic efficacy and pharmacokinetic evaluation of meperidine and hydroxyzine, alone and in combination Cancer Investigation 1983 1(2):111 7 6199095
Stambaugh JE Jr and McAdams J Comparison of the analgesic efficacy and safety of oral ciramadol, codeine, and placebo in patients with chronic cancer pain J Clin Pharmacol Feb 1987a 27(2):162 6
Stambaugh JE Jr and McAdams J Comparison of intramuscular dezocine with butorphanol and placebo in chronic cancer pain: a method to evaluate analgesia after both single and repeated doses Clinical Pharmacology & Therapeutics Aug 1987b 42(2):210 9
Stambaugh J and Drew J A double-blind parallel evaluation of the efficacy and safety of a single dose of ketoprofen in cancer pain J Clin Pharmacol Dec 1988a 28(12 Suppl):S34 S39
Stambaugh JE Jr and Drew J The combination of ibuprofen and oxycodone/acetaminophen in the management of chronic cancer pain Clinical Pharmacology & Therapeutics Dec 1988b 44(6):665 9
Staquet M Effect of parenteral dezocine and placebo in cancer pain Current Medical Research & Opinion 1980a 6(9):634 7 6996934
Staquet MJ Analgesic effect of ciramadol in patients with chronic pain Current Medical Research & Opinion 1980b 6(7):475 7 6988174
Staquet MJ A double-blind study with placebo control of intramuscular ketorolac tromethamine in the treatment of cancer pain J Clin Pharmacol Nov 1989 29(11):1031 6 2689472
Staquet M, Gantt C, and Machin D Effect of a nitrogen analog of tetrahydrocannabinol on cancer pain Clinical Pharmacology & Therapeutics Apr 1978 23(4):397 401
Staquet M and Renaud A Double-blind, randomized trial of piroxicam and codeine in cancer pain Current Therapeutic Research 1993 53(4):435 9
Start R, Yu AL, Yaksh TL, and Sorkin LS. An animal model of pain produced by systemic administration of an immunotherapeutic anti-ganglioside antibody. Pain. 1997;69:119-25. [pmid: 9060021].
Stevens PE, Dibble SL, and Miaskowski C Prevalence, characteristics, and impact of postmastectomy pain syndrome: an investigation of women's experiences Pain Apr 1995 61(1):61 8
Strang P, Nilsson S, Brandstedt S, Sehlin J, Borghede G, Varenhorst E, Bandman U, Borck L, Englund G, and Selin L The analgesic efficacy of clodronate compared with placebo in patients with painful bone metastases from prostatic cancer Anticancer Research Nov 1997 17(6D):4717 21
Stuart GJ, Davey EB, and Wight SE Continuous intravenous morphine infusions for terminal pain control: a retrospective review Drug Intelligence & Clinical Pharmacy Dec 1986 20(12):968 72
Sullivan BA, McKinnis R, and Laufman LR Quality of life in patients with metastatic colorectal cancer receiving chemotherapy: a randomized, double-blind trial comparing 5-FU versus 5-FU with leucovorin Pharmacotherapy Sep 1995 15(5):600 7
Sunshine A and Olson NZ Analgesic efficacy of ketoprofen in postpartum, general surgery, and chronic cancer pain J Clin Pharmacol Dec 1988 12(12 Suppl):S47 S54
Swerdlow M. The therapy of pain. Lancaster: MTP Press Limited. 1986.
Sykes NP The relationship between opioid use and laxative use in terminally ill cancer patients Palliative Medicine Sep 1998 12(5):375 82 9924600
Syrjala KL, Cummings C, and Donaldson GW Hypnosis or cognitive behavioral training for the reduction of pain and nausea during cancer treatment: a controlled clinical trial [see comments] Pain Feb 1992 48(2):137 46
Syrjala KL, Donaldson GW, Davis MW, Kippes ME, and Carr JE Relaxation and imagery and cognitive-behavioral training reduce pain during cancer treatment: a controlled clinical trial Pain Nov 1995 63(2):189 98
Takeda F. Japan's WHO cancer pain relief program. Advances in Pain Research and Therapy. 1990;16:475-83.
Tannock IF, Osoba D, Stockler MR, Ernst DS, Neville AJ, Moore MJ, Armitage GR, Wilson JJ, Venner PM, Coppin CM, and Murphy KC Chemotherapy with mitoxantrone plus prednisone or prednisone alone for symptomatic hormone-resistant prostate cancer: a Canadian randomized trial with palliative end points Journal of Clinical Oncology Jun 1996 14(6):1756 64
Task Force on Pain Management Practice guidelines for cancer pain management. A report by the American Society of Anesthesiologists Task Force on Pain Management, Cancer Pain Section Anesthesiology 1996 84(5):1243 57 8624021
Practice Guidelines for chronic pain management. A report by the American Society of Anesthesiologists Task Force on Pain Management, Chronic Pain Section Anesthesiology 1997 86(4):995 1004 9105246
Tasmuth T, von Smitten K, and Kalso E Pain and other symptoms during the first year after radical and conservative surgery for breast cancer British Journal of Cancer Dec 1996 74(12):2024 31
Tengs TO, Adams ME, Pliskin JS, Safran DG, Siegel JE, Weinstein MC, and Graham JD Five-hundred life-saving interventions and their cost-effectiveness [see comments] Risk Analysis Jun 1995 15(3):369 90
Teshima T, Inoue T, Ikeda H, Murayama S, Yamazaki H, Ohtani M, Kishi K, and Miyata Y Symptomatic relief for patients with osseous metastasis treated with radiation and methylprednisolone: a prospective randomized study Radiation Medicine Jul 1996 14(4):185 8
Thirlwell MP, Sloan PA, Maroun JA, Boos GJ, Besner JG, Stewart JH, and Mount BM Pharmacokinetics and clinical efficacy of oral morphine solution and controlled-release morphine tablets in cancer patients Cancer 01 Jun 1989 63(11 Suppl):2275 83
Tonachella R, Curcio C, and Grossi E Diclofenac sodium in cancer pain: A double-blind within-patients comparison with pentazocine Current Therapeutic Research Jun 1985 37(6):1130 3
Tong D, Gillick L, and Hendrickson FR The palliation of symptomatic osseous metastases: final results of the study by the Radiation Therapy Oncology Group Cancer 01 Sep 1982 50(5):893 9
Toscani F, Barosi K, Scazzina M, Camerini S, and Gallucci M Sodium naproxen: continuous subcutaneous infusion in neoplastic pain control Palliative Medicine 1989(3):207 11
Toscani F, Gallucci M, and Scaricabarozzi I Nimesulide in the treatment of advanced cancer pain. Double-blind comparison with naproxen Drugs 1993 46(Suppl 1):156 8 7506159
Toscani F, Piva L, Corli O, Gallucci M, Speranza R, Tamburini M, De Conno F, and Ventafridda V Ketorolac versus diclofenac sodium in cancer pain Arzneimittel-Forschung Apr 1994 44(4):550 4
Trowbridge R, Dugan W, Jay SJ, Littrell D, Casebeer LL, Edgerton S, Anderson J, and O'Toole JB Determining the effectiveness of a clinical-practice intervention in improving the control of pain in outpatients with cancer Academic Medicine Sep 1997 72(9):798 800
Turk DC, Sist TC, Okifuji A, Miner MF, Florio G, Harrison P, Massey J, Lema ML, and Zevon MA Adaptation to metastatic cancer pain, regional/local cancer pain and non-cancer pain: role of psychological and behavioral factors Pain Feb 1998 74(2-3):247 56
Turk DC and Okifuji A Directions in prescriptive chronic pain management based on diagnostic characteristics of the patient APS Bulletin 2000 8(5):1 18
Turnbull R and Hills LJ Naproxen versus aspirin as analgesics in advanced malignant disease Journal of Palliative Care 1986 1(2):25 8 3450812
Turner JA, Deyo RA, Loeser JD, Von Korff M, and Fordyce WE The importance of placebo effects in pain treatment and research [see comments]. [Review] [61 refs] JAMA 25 May 1994 271(20):1609 14
Twycross RG The measurement of pain in terminal carcinoma Journal of International Medical Research 1976 4(2 Suppl):58 67 67975
Twycross RG Choice of strong analgesic in terminal cancer: diamorphine or morphine? Pain Apr 1977 3(2):93 104 69290
Unruh AM. Gender variations in clinical pain experience. Pain. 1996;65:123-67. [pmid: 8826503].
US population statistics. Washington DC: U.S. Bureau of the Census. 1999.
Vainio A and Auvinen A Prevalence of symptoms among patients with advanced cancer: an international collaborative study. Symptom Prevalence Group Journal of Pain & Symptom Management Jul 1996 12(1):3 10
van Holten-Verzantvoort AT, Bijvoet OL, Cleton FJ, Hermans J, Kroon HM, Harinck HI, Vermey P, Elte JW, Neijt JP, and Beex LV Reduced morbidity from skeletal metastases in breast cancer patients during long-term bisphosphonate (APD) treatment Lancet 31 Oct 1987 2(8566):983 5
van Holten-Verzantvoort AT, Zwinderman AH, Aaronson NK, Hermans J, van, Emmerik B, van Dam FS, van den Bos B, Bijvoet OL, and Cleton FJ The effect of supportive pamidronate treatment on aspects of quality of life of patients with advanced breast cancer European Journal of Cancer 1991 27(5):544 9 1675865
van Holten-Verzantvoort AT, Kroon HM, Bijvoet OL, Cleton FJ, Beex LV, Blijham G, Hermans J, Neijt JP, Papapoulos SE, and Sleeboom HP Palliative pamidronate treatment in patients with bone metastases from breast cancer Journal of Clinical Oncology Mar 1993 11(3):491 8
Ventafridda V, Martino G, Mandelli V, and Emanueli A Indoprofen, a new analgesic and anti-inflammatory drug in cancer pain Clinical Pharmacology & Therapeutics Mar 1975 17(3):284 9
Ventafridda V, De Conno F, Guarise G, Tamburini M, and Savio G Chronic analgesic study on buprenorphine action in cancer pain. Comparison with pentazocine Arzneimittel-Forschung 1983 33(4):587 90 6683540
Ventafridda V, Ripamonti C, Bianchi M, Sbanotto A, and De Conno F A randomized study on oral administration of morphine and methadone in the treatment of cancer pain Journal of Pain & Symptom Management 1986 1(4):203 7 3537160
Ventafridda V, Oliveri E, Caraceni A, Spoldi E, De Conno F, Saita L, and Ripamonti G A retrospective study on the use of oral morphine in cancer pain Journal of Pain & Symptom Management 1987 2(2):77 81 3647083
Ventafridda V, Bonezzi C, Caraceni A, De Conno F, Guarise G, Ramella G, Saita L, Silvani V, Tamburini M, and Toscani F Antidepressants for cancer pain and other painful syndromes with deafferentation component: comparison of amitriptyline and trazodone Italian Journal of Neurological Sciences Dec 1987 8(6):579 87
Ventafridda V, Tamburini M, Caraceni A, De Conno F, and Naldi F A validation study of the WHO method for cancer pain relief Cancer 15 Feb 1987 59(4):850 6
Ventafridda V, Saita L, Barletta L, Sbanotto A, and De Conno F Clinical observations on controlled-release morphine in cancer pain Journal of Pain & Symptom Management Sep 1989 4(3):124 9
Ventafridda V, Toscani F, Tamburini M, Corli O, Gallucci M, Gottlieb A, Speranza R, and De Conno F Sodium naproxen versus sodium diclofenac in cancer pain control Arzneimittel-Forschung Oct 1990a 40(10):1132 4
Ventafridda V, De Conno F, Panerai AE, Maresca V, Monza GC, and Ripamonti C Non-steroidal anti-inflammatory drugs as the first step in cancer pain therapy: double-blind, within-patient study comparing nine drugs Journal of International Medical Research Jan 1990b 18(1):21 9
Ventafridda V, Caraceni A, and Gamba A. Field-testing of the WHO guidelines for cancer pain relief: Summary report of demonstration projects. Advances in Pain Research and Therapy. 1990;16:451-64.
Vijayaram S, Ramamani PV, Chandrashekhar NS, Sudharshan R, Heranjal R, Lobo B, Obedullah D, and Bhargava MK Continuing care for cancer pain relief with oral morphine solution. One-year experience in a regional cancer center Cancer 01 Oct 1990 66(7):1590 5
Vinholes JJ, Purohit OP, Abbey ME, Eastell R, and Coleman RE Relationships between biochemical and symptomatic response in a double-blind randomised trial of pamidronate for metastatic bone disease Annals of Oncology Dec 1997 8(12):1243 50
von Korff M. Epidemiological Methods. In: Crombie IK, Croft PR, Linton SJ, LeResche L, and von Korff M eds. Epidemiology of Pain. Seattle: IASP Press. 1999:7-15.
Vuorinen E Pain as an early symptom in cancer Clinical Journal of Pain Dec 1993 9(4):272 8 8118092
Walker S, Goudas L, Cousins MJ, Carr DB. Spinal analgesia -- Opioids, non-opioids and emerging options. Anesthesia and Analgesia. In Press. 2001.
Wall PD and Melzack R (eds). Textbook of pain. Edinburgh: Churchill Livingstone. 1984.
Wall PD and Melzack R (eds). Textbook of pain. 3rd ed. Edinburgh: Churchill Livingstone. 1994.
Wall PD and Melzack R (eds). Textbook of pain. 4th ed. Edinburgh: Churchill Livingston. 1999.
Wall VJ and Womack W Hypnotic versus active cognitive strategies for alleviation of procedural distress in pediatric oncology patients American Journal of Clinical Hypnosis Jan 1989 31(3):181 91
Walsh D. Palliative medicine and supportive care of the cancer patient. Seminars in Oncology. 1 (Feb 2000):1-108.
Walsh TD, MacDonald N, Bruera E, Shepard KV, Michaud M, and Zanes R A controlled study of sustained-release morphine sulfate tablets in chronic pain from advanced cancer American Journal of Clinical Oncology Jun 1992 15(3):268 72
Warfield CA Guidelines for the use of MS Contin tablets in the management of cancer pain Postgraduate Medical Journal 1991 67(Supplement 2):S9 12 Discussion S-13 1758825
Warfield CA (ed). Principles and practice of pain management. New York: McGraw-Hill, Inc. 1993.
Weingart WA, Sorkness CA, and Earhart RH Analgesia with oral narcotics and added ibuprofen in cancer patients Clinical Pharmacy Jan 1985 4(1):53 8
Wenk R, Diaz C, Echeverria M, Aparicio A, Bertucelli N, Courtalon M, De Felipe M, Ocariz J, Clerici M, and Pacini T Argentina's WHO Cancer Pain Relief Program: a patient care model Journal of Pain & Symptom Management 1991 6(1):40 3 1703199
Cancer pain relief and palliative care. World Health Organization Technical Report Series No. 804 Geneva: World Health Organization. 1990.
Wilder-Smith CH, Schimke J, Osterwalder B, and Senn HJ Oral tramadol, a mu-opioid agonist and monoamine reuptake-blocker, and morphine for strong cancer-related pain Annals of Oncology Feb 1994 5(2):141 6
Wilkinson TJ, Robinson BA, Begg EJ, Duffull SB, Ravenscroft PJ, and Schneider JJ Pharmacokinetics and efficacy of rectal versus oral sustained-release morphine in cancer patients Cancer Chemotherapy & Pharmacology 1992 31(3):251 4 1464164
Wilwerding MB, Loprinzi CL, Mailliard JA, O'Fallon JR, Miser AW, van Haelst C, Barton DL, Foley JF, and Athmann LM A randomized, crossover evaluation of methylphenidate in cancer patients receiving strong narcotics Supportive Care in Cancer Mar 1995 3(2):135 8
Wolfe J, Grier HE, Klar N, Levin SB, Ellenbogen JM, Salem-Schatz S, Emanuel EJ, and Weeks JC Symptoms and suffering at the end of life in children with cancer N Engl J Med 2000 342(5):326 33 10655532
Wolff SN. Epidemiology: the distribution and determination of adult cancer. In Parris W, Foster H, and Melzack R (eds). Cancer Pain Management: Principles and Practice. Boston: Butterworth-Henmann. 1997:25-30.
Wong JO, Chiu GL, Tsao CJ, and Chang CL Comparison of oral controlled-release morphine with transdermal fentanyl in terminal cancer pain [published erratum appears in Acta Anaesthesiol Sin 1997 Sep;35(3):191] Acta Anaesthesiologica Sinica Mar 1997 35(1):25 32
Wool C, Prandoni P, Polistena P, and Ruol A Ketorolac suppositories in the treatment of neoplastic pain: A randomized clinical trial versus diclofenac Current Therapeutic Research May 1991 49(5):854 61
Woolf CJ, GB Bennett, M Doherty, Dubner R, Kidd B, Koltzenburg M, Lipton R, Loeser JD, Payne R, and Torebjork E. Towards a mechanism-based classification of pain?. Pain. 1998;77:227-9. [pmid: 9808347].
Woolf CJ and Mannion RJ Neuropathic pain: aetiology, symptoms, mechanisms, and management Lancet 1999 353(9168):1959 64 10371588
Pain in children with cancer: The World Health Organization-IASP Guidelines Cancer Pain Release 1999 12(1):1 8
Wright IV C. Hypothesis Confirmation - Form Follows Function. 315-21. Pain 1999 - An updated review: refresher course syllabus. Seattle: IASP Press. 1999.
Yajnik S, Singh GP, Singh G, and Kumar M Phenytoin as a coanalgesic in cancer pain Journal of Pain & Symptom Management May 1992 7(4):209 13 1517643
Yalcin S, Gullu I, Tekuzman G, and Savas C Ketorolac tromethamine in cancer pain Acta Oncologica 1997 36(2):231 2 9140446
Yalcin S, Gullu IH, Tekuzman G, Savas C, and Firat D A comparison of two nonsteroidal antiinflammatory drugs (diflunisal versus dipyrone) in the treatment of moderate to severe cancer pain: a randomized crossover study American Journal of Clinical Oncology Apr 1998 21(2):185 8
Young RF, Post EM, and King GA Treatment of spinal epidural metastases. Randomized prospective comparison of laminectomy and radiotherapy Journal of Neurosurgery Dec 1980 53(6):741 8
Zatzick DF and Dimsdale JE. Cultural variations in response to painful stimuli. Psychosomatic Medicine. 1990;52:544-57. [pmid: 2247560].
Zech DF and Lehmann KA Transdermal fentanyl in combination with initial intravenous dose titration by patient-controlled analgesia Anti-Cancer Drugs Apr 1995 6(Supplement 3):44 9
Zech DF, Grond S, Lynch J, Hertel D, and Lehmann KA Validation of World Health Organization Guidelines for cancer pain relief: a 10-year prospective study Pain Oct 1995 63(1):65 76
Zeltzer L and LeBaron S Hypnosis and nonhypnotic techniques for reduction of pain and anxiety during painful procedures in children and adolescents with cancer Journal of Pediatrics Dec 1982 101(6):1032 5
Zenz M, Piepenbrock S, and Tryba M Epidural opiates: long-term experiences in cancer pain Klinische Wochenschrift 01 Mar 1985 63(5):225 9