# Acknowledgments

We would like to thank Phyllis Wingo, PhD, MS, Director of the Surveillance Research Program, and Ms. Sherry Bolden, Program Specialist, both of the Department of Epidemiology and Surveillance Research at the American Cancer Society, for assistance with cancer prevalence information.

We would like to thank William Gouevia, MS, Director of the Pharmacy Department, and Ms. Soumana Chamoun, MS, R Pharm, Research Pharmacist, both of the Pharmacy Department at the New England Medical Center, for assistance in gathering cost data for pharmaceuticals.