# Future Research

This report documents a paucity of rigorous data within the existing literature on cancer pain control. The lack of high-quality evidence required that nearly every key question be answered on the basis of suboptimal or incomplete data. Comprehensive epidemiologic figures provide an accurate picture of the incidence and prevalence of cancer in the United States, and meticulous actuarial data document with precision the survival rates for each major neoplastic disorder. Credible though less comprehensive evidence indicates that undertreated pain adds substantially to the disease burden of cancer and impairs quality of life in patients with cancer (Bergman, Sullivan and Sorenson 1991; Cleeland, 1991; Ahmedzai, 1995). At present, however, only limited cross-sectional data link tumor type and stage with pain quality or intensity (Caraceni, Portenoy, and the IASP Working Group, 1999), and there are no corresponding longitudinal, tumor-specific data during chronic treatment of cancer-related pain. Tumor- and population-specific data of this nature are needed if the natural history of cancer pain and its relief is to be understood with sufficient precision to advise individual patients and their families in the selection of pain control options.

## Better Assessment of Cancer Pain is Required

Prospective assessment of pain will soon be required in health care organizations, owing to a recent decision by the Joint Commission on Accreditation of Healthcare Organizations to add items on pain assessment and treatment to its standards. To implement this requirement in an increasingly diverse society creates a need for developmentally appropriate and culturally sensitive pain assessment instruments that are reliable and easy to administer. Instruments to assess health-related quality of life, particularly functional status, have been widely applied in recent years during cancer treatment trials. Analgesic trials for the most part have omitted such instruments, and those that incorporated them did so in a heterogeneous fashion. Such trials in aggregate suggest that optimal pain relief has a "ripple effect" that benefits many dimensions of quality of life. The growth in sophistication of quality-of-life assessment and advances in the field of chronic pain treatment that model relationships between pain, disability, and impairment offer a valuable opportunity to understand these interactions in the context of cancer pain.

## The Quality of Cancer Pain Studies Must Be Improved

In nearly every respect (number of trials, sample size, representative study populations, and study design (Moher, Dulberg and Wells, 1994), the quality of the scientific evidence on cancer pain treatment compares unfavorably with that for cancer treatment. Leading investigators in the area of cancer pain relief trials have repeatedly called for improving the quality of trials in this area (Foley, Bonica, Ventafridda, et al., 1990; Max, 1996; McQuay and Moore, 1998; Jadad and Cepeda, 1999). This goal cannot be achieved simply by incorporating standardized pain assessment and health-related quality-of-life measurements into cancer treatment trials. Although such a strategy is laudable, data so gathered cannot be generalized to the treatment of pain during intervals of stable disease, or to patients who are in remission but who continue to experience residual pain. Cancer may regress or progress during therapy, and in so doing exacerbate or reduce pain. Hence, carefully designed trials with pain or pain relief as a primary outcome are required in diverse populations with well-defined disease (Max, Portenoy, Laska, 1991; Max and Portenoy, 1998; Max, 1996). These groups include patients with stable disease; those with treatment-induced, incident, or breakthrough pain; and those with pain syndromes (such as postmastectomy syndrome) during disease remission.

Standards for cancer pain treatment trials must adhere to those for clinical trials in general (Pocock, 1998), as expected by editors of most leading medical journals (Begg, Cho, Eastwood, et al., 1996). Random assignment to treatment and control groups to minimize bias is essential in trials of pain relief (Berlin and Rennie, 1999). High-quality trials of cancer pain relief should enroll greater numbers of patients (Moore, Gavaghan, Tramer, Collins, et al., 1998; Myles, 1999) for longer intervals than has generally been true in the past, apply blinding and active placebos when appropriate (Rothman and Michels, 1994) or uniform control treatments otherwise (Lasagna, Mosteller, von Felsinger, et al., 1954; Berde and Glick, 1994; Turner, Deyo, Loeser, et al., 1994), employ adequate between-arm washout intervals and consider advancing disease state in crossover trials, and assess side effects (Edwards, McQuay, Moore, et al., 1999), pain mechanisms, and rest, incident, or breakthrough pain in a standardized, combinable fashion.

To these criteria must be added the need to study the influences of gender, race, age, ethnicity, and culture upon pain and analgesia with greater precision than in the past, to avoid overgeneralization of results. Categorization of patients by tumor type and stage, and by mechanism of pain, with inclusion criteria that yield homogeneous groups within individual studies, appears to offer the best chance of translating preclinical advances into improved clinical analgesia. Pilot studies that reveal gender (Unrah, 1996; Giles and Walker, 1999; Miaskowski and Levine, 1999), genetic (Gershon, Vatine, Shir, Wu, et al., 2000; Mogil, 1999), and ethnic differences in analgesic pharmacokinetics and pharmacodynamics merit larger scale follow-up in the context of cancer pain relief, as do other insights into differences in the effects of different opioids (Morley, 1999). Small-scale, short-term randomized controlled trials that establish treatment efficacy for purposes of Food and Drug Administration approval are not designed to prove effectiveness in larger scale, long-term applications in the treatment of cancer pain relief. To meet this need, outcomes research can provide valuable data that are not feasible to acquire through controlled trials.

## Systematic Reviews of Cancer Pain Studies are Needed

Systematic reviews of the best available evidence on cancer pain control, which incorporate quantitative and qualitative methods, are needed until large trials are accomplished and accepted as definitive (Mulrow and Cook, 1998). Increasing numbers of systematic reviews on pain, palliative, and supportive care (Lipman, Jackson, and Tyler, 2000) are appearing through groups such as the Cochrane Collaboration (Carr, Wiffen, Fairman, et al., 1999). Preparation of these systematic reviews is necessary to provide a foundation of best available evidence on which to base current treatment and future investigation (Chalmers and Altman, 1995). Frequent updating of such reviews will be necessary to keep pace with the accelerating numbers of cancer pain relief trials (Jadad, 1994). The scientific challenges of coping with the existing literature, whose low quality will only slowly improve, and of assessing interventions that have rarely been evaluated in randomized controlled trials (Gilbert, McPeek and Mosteller, 1977; Bunker, Hinkley and McDermott, 1978; Eisenberg 1999; Mark and Glass 1999), must be met in creative ways. These varied approaches to evidence-based cancer pain relief must be encouraged and supported (Gray, 1997; McQuay and Moore, 1998; Sackett, Richardson, Rosenberg et al., 1997; Jadad and Cepeda, 1999).

## Translation and Dissemination of Knowledge About Cancer Pain Management is Critical

Closely linked to synthesis of the best evidence on cancer pain assessment and treatment is the translation of that evidence for students, professionals, and patients. Outstanding efforts by State cancer pain initiatives, the Joint Commissions for the Accreditation of Healthcare Organizations, and numerous other organizations at every level from workshops to the Internet have placed cancer pain on the agenda of mainstream health care (Miaskowski, 1994). However, the application and dissemination of such evidence, and its incorporation within health care information systems to guide frontline care (Rosser, 1999), is just in its infancy (Du Pen, Du Pen, Polissar, et al., 1999; Elliott, Murray, Oken, et al., 1995). Better means to deal with everyday, but still complex, clinical decision making in cancer pain control will be required to implement therapeutic advances (Mant 1999; Sawynok and Cowan, 1999). For example, just as combination chemotherapy is employed to treat many forms of malignancy, the practice of analgesia increasingly relies on drug coadministration to treat pain (Carr and Cousins, 1998). Indeed, preclinical and, to some degree, clinical evidence argues that pain itself -- particularly if prolonged -- displays features of a pathophysiological condition independent of its cause. Methods are needed to synthesize published evidence on drug interactions and to apply and extend existing methods (now employed in acute pain studies) to characterize such interactions during long-term cancer pain treatment. Related to this area is the important issue of developing clinical evidence on optimal strategies for the sequence of drug therapies employed for cancer pain control (that is, the efficacy and effectiveness of WHO model versus other models), and the optimal means to combine drug and nondrug therapies. Trials to address these issues, like those to evaluate one component of a multidrug antitumor regimen, are effort intensive and may require large numbers of subjects per treatment arm.

## Additional Studies Are Needed to Address Specific Questions

Our literature review indicates that many drug and nondrug interventions are effective in decreasing cancer-related pain, yet data on individual variation in preferences for, responses to, and costs of different therapies are limited. The refinement of therapeutic agents and delivery systems affects many areas of cancer pain control. For example, the spinal route of analgesia is widely employed (Carr and Cousins, 1998; Dougherty and Staats, 1999; Hassenbusch and Portenoy, 2000), but much remains to be learned about optimal patient selection, the comparative efficacy of spinal drug infusion and systemic drug administration, and the selection of initial or secondary agents or combinations (Lasagna, 1975; Eisenach, 1999; Walker, Goudas, Cousins and Carr, 2001). Drug interactions during long-term cancer pain treatment require clarification. A host of complementary therapies are now employed, but with little rigorous testing of their efficacy (Eisenberg, Kessler, Foster et al., 1993). It is unclear whether a mechanism-based approach to diagnosing and relieving each component of pain in an individual is more effective than an empiric regimen in which each patient's treatment is based on pain intensity alone. Another key unanswered question is how to optimally combine drug with nondrug therapies given that the latter are safe and inexpensive. Despite the importance of pediatric cancer pain control practically no analgesic drug trials focus on children.

The low numbers of (or absence of) studies that address a variety of clinically meaningful questions may reflect that to date, many analgesic drug trials are efficacy trials conducted for purposes of FDA approval of a new pharmaceutical product. Such trials may enroll the minimum number of subjects to establish efficacy (for example, by showing equivalence between a new preparation and an established, approved one). If a product has no commercial potential (e.g., because it is no longer patented), funding to support its investigation will likely suffer. Case series suggest that individual differences in the analgesic response to different opioids often exceed those expected from relative potency ratios determined in group studies, so that opioid rotation may be a useful, low-cost, and simple therapeutic strategy. The range of adjuvants is broad, but many are off patent and unprofitable. Because each of these treatment options may be important for clinical care, their evaluation is an important agenda for future work on cancer pain control. Mechanisms to support rigorous evaluation of noncommercial products must be adequately funded if such trials are ever to take place. Indeed, as major shifts occur in the means by which patients pay for medical care, the impact of economic factors on assessment and treatment of cancer pain requires urgent evaluation (Tengs, Adams, Pliskin et al., 1995; Cohen and Campbell, 1996). Regulatory and other dimensions of health policy likewise carry substantial practical importance for cancer pain control. Because this area is dynamic, ongoing efforts will be required to understand these interactions (Loeser, 2000).

The challenge for the health care research community transcends the biomedical dimension of cancer pain control to encompass its societal (Freeman, 1995) and human aspects (Chochinov, Tatuya, Clinch, et al., 1999). Research studies must address prospectively and in increasing depth issues of importance to patients and clinicians (patient preferences, satisfaction with care, the proportion who improve with care, treatment side effects), providers and payers (costs), and researchers (optimal trial design and reporting) (Office of Cancer Communications, 1997; National Cancer Institute, 1998). Patients and their families must be invited not only to participate in clinical trials but also to help formulate research priorities and to advise in the design of trials themselves, such as in suggesting outcomes of interest and novel ways to assess them, e.g., via the Internet (Silbeg, Lundberg and Musacchio, 1997; Kelson, 1999). By devoting greater attention and resources to the care of people who may not return to being earners and taxpayers, and in the process valuing their comfort and internal experience, society affirms its most enduring values (Cassel and Foley, 1999).