# Conclusions

## Overview

In this chapter we discuss the conclusions related to the six key questions addressed in this evidence report. In addition, we describe the limitations of the existing evidence base related to cancer pain treatment.

This report summarizes the scientific evidence on several specific questions on the epidemiology and treatment of cancer-related pain. We searched approximately 19,000 titles and identified 22 epidemiologic surveys, 188 randomized controlled trials, and 100 nonrandomized studies of treatments of cancer-related pain. In this literature review, we defined cancer-related pain as pain caused by the disease itself or by its treatment, such as surgery, radiation therapy, or chemotherapy. Pain assessment in cancer care involves not simply nociceptive evaluation but also comorbid medical and psychosocial problems, the meaning and impact of pain on the patient and significant others, and its effect on quality of life. The subjective nature of pain presents challenges, yet asking about this aspect of a patient's personal, internal experience affirms the importance of it and provides a welcome contrast to a disease-centered approach to care.

### Specific Questions

1. What are the epidemiological characteristics of cancer-related pain, including pain caused by cancer, by procedures used to treat cancer, and by the side effects of cancer treatment?

Cancer pain adds substantially to the already considerable national disease burden of cancer, particularly in minorities, women, and the elderly. Survey data for the most part do not distinguish between different causes and mechanisms of cancer pain, nor do they track pain and other symptoms longitudinally across time. Epidemiological data indicate persuasively that the number of patients enrolled in methodologically sound trials of cancer pain relief is a tiny fraction of those receiving care. In addition to the relatively small number of patients enrolled per trial, the number of published randomized controlled trials relative to patients under care is much lower than for nearly all other high-impact, costly conditions. The epidemiological literature on cancer pain is influenced by the fact that more than half of all patients identified in surveys of the incidence and prevalence of cancer pain were participants from a single Japanese study (Hiraga, 1991).

2. What is the relative efficacy of current analgesics for cancer pain?

The number of randomized controlled trials evaluating analgesic drugs for cancer pain relief is small, although it is increasing. Direct interclass comparisons of efficacy are possible between opioids and NSAIDs. The trials included in this literature review do not differentiate the relative efficacy of these two types of agents administered through various routes to patients with mild, moderate, or severe cancer pain. There is evidence of an opioid dose-sparing effect from coadministration of an NSAID but no consistent reduction in side effects from doing so. Placebo controls, particularly in analgesic trials, are valuable to prevent overestimation of treatment effects, yet for ethical reasons such controls are rare in cancer pain trials. The heterogeneity of existing trials precludes meta-analyses to address most subquestions. Ten studies addressed the relative analgesic efficacy of various NSAIDs versus other NSAIDs or placebo. Of these, only one study disclosed a significant difference in analgesic efficacy between two NSAIDs. These 10 studies could not be combined because of heterogeneity in the outcomes assessed, drug doses and schedules compared, and study duration. Trials to compare the efficacy of NSAIDs with "weak" opioids (i.e., opioids commonly prescribed for mild to moderate pain) reveal no difference in analgesic efficacy between these two classes of agents, even when the latter are coadministered with the former. These trials enroll relatively small numbers of patients and follow them for intervals of hours to days, and only occasionally as long as 2 weeks. Many examine drugs not available in the United States or not generally employed for cancer pain relief (e.g., pentazocine). Our efforts to strengthen such evidence by examining nonrandomized trials were not fruitful. One randomized controlled trial evaluated oral transmucosal fentanyl citrate for breakthrough pain (using a study design in which rescue doses of morphine were available) and demonstrated its superiority to placebo. We found no randomized controlled trials addressing analgesic efficacy and safety of NSAIDs selective for the cyclooxygenase-2 isozyme in treating cancer pain.

3. Are different formulations and routes of administration associated with different patient preferences or different efficacy rates?

Published trials within the NSAID and, separately, opioid drug classes demonstrate no differences in efficacy between oral tablets or rectal suppositories within each class. Extremely limited data suggest that parenteral (intramuscular or intravenous) administration offers no advantage from a purely analgesic standpoint over enteral administration. However, the studies do not evaluate relative speed of onset using the two routes, which for many drugs is known to be more rapid after parenteral administration. For opioids, no evidence indicates improved analgesia with controlled-release oral formulations versus immediate-release formulations or transdermal delivery. Specifically, eight studies that compared oral controlled-release morphine with oral immediate-release morphine solution found no differences with respect to efficacy (reduction of pain intensity or increased pain relief). These studies enrolled a total of 344 patients with a wide range of cancer types and pain types, of which 271 were evaluated (78.7 percent). Although the majority of these trials were double-blind, the results still may not be reliable because of the high dropout rates (10 percent to 40 percent). Because these eight studies addressed the same study question using roughly comparable methods, we were able to perform a meta-analysis using average pain intensity (during 4 to 14 days of treatment) as the outcome of interest. The benefit of less frequent doses that encourage better compliance is a possible advantage of the controlled-release formulation.

Three studies addressed comparative analgesic efficacy and adverse effects between oral and rectal administration of morphine. Two found no difference in efficacy and the third observed a small but significant difference in the onset of pain relief and the duration of analgesia in favor of the rectal route. No significant differences with respect to adverse effects were observed between the two routes in two studies, but in a third, a small but significant lowering of nausea scores favored the rectal route. The generalizability of the results from these studies is limited because of the small number of patients. One study compared controlled-release rectal suppositories with subcutaneous morphine and reported no differences in overall pain scores, sedation or nausea, or rescue analgesic intake. The failure to establish the general superiority of one route over another does not negate the value of a particular route in a specific clinical situation (for example, employing suppositories or transdermal administration when dysphagia limits oral dosing). Insufficient information exists to reveal differences in patient preference for specific routes and administration, or acceptability of side effects.

4. What is the relative analgesic efficacy of palliative pharmacological (chemotherapy, biphosphonates, or calcitonin) and nonpharmacological cytotoxic or cytostatic (radiation or radionuclide) therapy?

We found 31 studies addressing this question, including ^153^Samarium-EDTMP, etidronate, aminohydroxypropylidine disodium (APD, pamidronate), salmon calcitonin, and clodronate. The biphosphonate trials are heterogeneous with respect to inclusion criteria, concomitant medical and radiotherapeutic treatments, disease categories, dosage regimens, choice of agent, and duration of follow-up. Differences in pain assessment methods were also great, ranging from analgesic intake to the "requirement" for palliative radiation therapy. However, many studies showed a positive effect, some showed no effect, and no study showed a detrimental effect of biphosphonate therapy on skeletal symptoms of metastatic disease or myeloma. Positive effects were less common in the presence of concurrent hormonal or chemotherapy that might themselves have a favorable effect on bone symptoms. The evidence in aggregate suggests that biphosphonates are effective in reducing pain symptoms from bone involvement by tumor, although this benefit may be relatively less when such therapy is combined with other tumor-directed therapy.

Two studies compared strontium-89 with inactive strontium and external radiotherapy, respectively, for bone pain. Strontium-89 was more effective than placebo (inactive strontium) and as effective as external radiation.

The literature on the effects of various chemotherapeutic and hormone therapy regimens on pain is quite heterogeneous, with differing inclusion criteria and therapeutic regimens. The concurrent use of analgesic medication is reported in a minority of these studies. In only one chemotherapy trial, and no hormonal therapy trial, was there a significant difference in pain outcome between treatment arms.

Fourteen trials, involving a total of 3,859 patients, compared fractional dosing schedules of external radiotherapy for pain from bone metastases. Although external radiation as a modality is effective in decreasing pain, no trial found more than a transient difference in pain between fractionation schedules. Meta-analysis was not possible as a result of heterogeneity of the dosing schedules, variability in the anatomic sites and fields treated, and outcomes assessed. Short courses of palliative treatment with higher doses appear to produce results similar to those of longer courses that deliver a lower dose per treatment. Even single-dose (unfractionated) radiation appears to have similar effects on bone pain as fractionated dosing, although the minimal total dose of radiation to provide pain relief has not yet been determined.

5. What is the relative efficacy of current adjuvant (nonpharmacological/noninvasive) physical or psychological (relaxation, massage, heat and cold, music, and exercise) treatments in the management of cancer-related pain?

The number of studies is small, and variability as to types of intervention precludes any broad conclusions. Studies evaluated different interventions applied to patients, medical staff, and the community at large. Also, different types of pain seemed to be addressed, although specifics were not always provided.

Only a few randomized trials examined hypnosis in conjunction with cognitive-behavioral techniques, in the context of acute procedure-related pain and oral mucositis pain after bone marrow transplant. They include studies in the pediatric and adult age groups. Hypnosis seems to help with both procedural and mucositis-related pain. Cognitive-behavioral treatments may also be helpful. More studies are needed, with larger numbers of patients and with control groups.

6. What is the relative efficacy of current invasive surgical and nonsurgical treatments, such as acupuncture, nerve blocks, and neuroablation, on the treatment of cancer-related pain?

The evidence available to answer these questions is, with few exceptions, in the form of case series that do not enroll control groups (Caratozzolo, Lirici, Consalvo, et al., 1997). Sufficient randomized controlled trials on neurolytic celiac plexus block (NCPB) for pain relief in pancreatic and other visceral cancers were identified to indicate the efficacy of this modality. NCPB lowered pain scores or produced a prolonged dose-sparing effect on analgesic drug requirement. The near absence of randomized or controlled trials on the efficacy of spinally administered opioids or other agents led us to retrieve nonrandomized reports in an effort to estimate the efficacy of this modality. These supplemental reports, although positive, were case series without control groups and hence did not yield data on relative efficacies of the spinal versus systemic routes of drug administration. Similarly, the efficacies of ablative neurosurgical interventions such as cordotomy or rhizotomy were addressed only in case series. No included trials addressed the efficacy of acupuncture.

## The Quality of Cancer Pain Treatment Trials

The average number of patients in trials of the primary analgesics, NSAIDs and opioids, was 84 and 68 (range 24-180 and 10-699, respectively). Studies of biphosphonates enrolled an average of 111 patients (range 13-614). Trials of the palliative use of primary cancer treatment, chemotherapy and radiotherapy, enrolled an average of 226 patients (range 38-1016). These results raise the possibility that expectations of investigators and peer reviewers for methodological rigor are lower in studies that evaluate drugs with purely analgesic effects than in those that evaluate drugs that may cure disease. Leading investigators in the area of cancer pain relief trials, however, have repeatedly called for improving the quality of trials in this field.

This contrast resembles that between the substantial, ongoing investment of resources into detailed monitoring of trends related to cancer incidence, prevalence, and survival and the much less comprehensive and precise picture we now have of the natural history of cancer pain and its response to analgesic interventions as a function of tumor type, grade, and stage.

The number of meta-analyses we were able to perform concerning the treatment of cancer pain was constrained by inconsistent definition of outcomes and incomplete reporting of results. The primary outcome of pain intensity or pain relief is easily susceptible to bias in studies that are not double-blind. The lack of reporting of data on variability of the outcome estimates makes it difficult, if not impossible, for meta-analyses to be performed. Most studies use the term "pain" without specifying whether it is pain at rest, movement-related pain, or breakthrough pain. Reporting on broad categories of probable mechanism of pain, that is, nociceptive or neuropathic, was inconsistent. Although the treatment of cancer pain is a high priority on the public health agenda of the World Health Organization and many professional organizations and governments around the world, the overall methodological quality and the reporting of treatment studies in this field lag behind those of other high-impact conditions.