# Methodology

This evidence report on the management of cancer pain is based on a systematic review of the literature. The EPC staff held meetings and teleconferences with technical experts representing several partner organizations to formulate the key questions addressed in this evidence report. We conducted a comprehensive search of the medical literature to identify studies available to address these questions.

This report used observational studies to estimate the prevalence of cancer-related pain and used randomized controlled trials (Jadad, 1998) to assess the efficacy of various treatments (Colditz, Miller, and Mosteller, 1989a and 1989b). We compiled evidence tables to summarize the study features and results and conducted meta-analyses of randomized controlled trials on specific questions when there were a sufficient number of adequately reported studies. AHRQ requested a supplemental analysis of about 100 nonrandomized studies to address areas for which there was insufficient randomized evidence. As part of the supplemental analysis, we explored the feasibility of conducting a meta-analysis of nonrandomized studies in order to compare the results with those derived from a meta-analysis of randomized controlled trials on the same question.

## Recruitment of Technical Experts

The American Pain Society nominated this topic and served as a partner organization for this evidence report. The role of a partner organization includes providing a technical expert to work with the EPC staff to refine key questions, helping to identify relevant studies, and helping to disseminate the results of the report. Because of the relevance of this topic to many professional organizations, the EPC staff identified additional partners through the membership lists of organizations concerned with pain management, including the Coalition to Improve Pain Management and the Robert Wood Johnson Last Acts Campaign.

In addition to the American Pain Society, we invited several other organizations to participate as partners in this evidence report. Six organizations responded and provided technical experts to participate: the American Cancer Society, American College of Physicians, American Society of Clinical Oncology, American Society of Anesthesiologists, American Society of Health-System Pharmacists, and Oncology Nursing Society.

We identified a group of "associate partners" to further broaden the involvement of relevant groups. We solicited comments from associate partners on the key questions developed by the partners. The associate partners include the following organizations: American Academy of Family Physicians, American Academy of Neurology, American Physical Therapy Association, Hospice and Palliative Nurses Association, and Hospice Association of America.

## Patient Population Studied

In this report, we accepted studies presenting data on three broad categories of patients:

- Patients with pain resulting from direct tumor involvement and modulation of nociceptive activity, from either local or distant metastases, such as in bone, soft tissue, or neural structures.
- Patients with pain resulting from a therapeutic, diagnostic, or palliative intervention (procedural pain), such as chronic postmastectomy or lumbar puncture pain.
- Patients with pain resulting from the side effects of antitumor treatment, such as herpetic pain or esophagitis pain.

We accepted all studies of patients with a diagnosis of cancer who suffered from pain due to cancer or treatment of cancer. We excluded studies on postoperative pain of cancer patients subjected to surgery as part of their treatment. We placed no restrictions on the patients' age, gender, ethnicity, level of advancement of the primary disease (staging) or presence of metastases, or designation from the various cancer-related pain classification systems. We also placed no restriction according to the classification of pain in terms of pathophysiological mechanism, site(s) involved, or duration.

## Key Questions

Working with technical experts representing the partner organizations, we formulated the key questions addressed in this evidence report after four teleconferences. Additional communications among technical experts and EPC staff also took place between teleconferences. We used the results of a preliminary literature search to prepare a pool of study questions as a starting point to assist the formulation and refinement of key questions. We abstracted the study questions of about 70 randomized controlled trials from the preliminary literature search. These questions were sorted into several broad treatment categories and presented to the technical experts with instructions to recommend and refine the key questions and subquestions.

The following six main questions and 20 subquestions emerged after several iterations:

### Question 1. What are the epidemiological characteristics of cancer-related pain, including pain caused by cancer, by procedures used to treat cancer, and by the side effects of cancer treatment?

1.1 What is the nature and extent of the problem of cancer pain, especially as it relates to quality of life?

### Question 2. What is the relative efficacy of analgesics currently used for cancer pain?

Analgesics may be primary analgesics, which can be used alone to alleviate or reduce pain -- such as opioids or nonsteroidal anti-inflammatory drugs (NSAIDs) -- or adjuvant analgesics, which are used to enhance the analgesic efficacy of opioids, treat concurrent symptoms that exacerbate pain, and provide independent analgesia for specific types of pain.

2.1 What is the efficacy of NSAIDs in the management of bone pain?

2.2 What are the side effects of the different opioid analgesics?

2.3 What is the efficacy of opioids, antidepressants, and anticonvulsants in treating neuropathic pain?

2.4 What is the efficacy of alternative therapies (e.g., herbs, vitamins) in the management of cancer pain?

2.5 What are the patient preferences, efficacy, costs, and side effects of different opioid analgesics (e.g., morphine versus hydromorphone)?

2.6. What are the efficacy and side effects of the following adjuvant analgesics in the management of cancer pain: steroids, anticonvulsants (e.g., gabapentin), antidepressants (e.g., selective serotonin reuptake inhibitors), local anesthetics, hydroxyzine, psychostimulants (e.g., methylphenidate, cocaine), diphenhydramine, clonidine, and NMDA blockers (e.g., ketamine, dextromethorphan)? What is their efficacy alone and as coanalgesics with opioids?

2.7 What is the analgesic efficacy and safety of COX-2 selective NSAIDs in treating cancer pain?

2.8 What is the efficacy of medications given for symptomatic relief of analgesic drug-related side effects (e.g., antiemetics for opioid-induced nausea)?

### Question 3. Are different formulations and routes of administration associated with different patient preferences or different efficacy rates?

3.1 What are the patient preferences, efficacy, costs, and side effects of different routes of opioid administration (e.g., sustained release opioids versus transdermal delivery)?

3.2 What are neuropsychological effects of chronic neuraxial versus oral opioids?

3.3 What are the relative costs of spinal, oral, intravenous, subcutaneous, and transdermal administration of opioids?

3.4 What is the long-term safety of epidural and intrathecal administration of opioids for cancer pain?

3.5 Is the potential benefit of avoiding sedation and cognitive failure with spinal opioids offset by the risks of chronic spinal catheterization?

### Question 4. What is the relative analgesic efficacy of palliative pharmacological (chemotherapy, biphosphonates, or calcitonin) and nonpharmacological cytotoxic or cytostatic (radiation or radionuclide) therapy?

4.1 What is the efficacy of biphosphonates in treating metastatic bone pain?

4.2 What is the efficacy of radionuclides in treating metastatic bone pain?

4.3 What is the efficacy of chemotherapeutic drugs in treating cancer pain (e.g., gemcitabine)?

4.4 What is the efficacy of external-beam radiation and radionuclides in treating cancer pain?

### Question 5. What is the relative efficacy of current adjuvant (nonpharmacological/noninvasive) physical or psychological treatments (relaxation, massage, heat and cold, music, exercise, and so on) in the management of cancer-related pain?

5.1 What is the efficacy of cognitive-behavioral interventions in treating cancer pain?

### Question 6. What is the relative efficacy of current invasive surgical and nonsurgical treatments, such as acupuncture, nerve blocks, and neuroablation, in the treatment of cancer-related pain?

6.1 What is morbidity and mortality of cordotomy in treating cancer pain?

### Supplemental analysis of nonrandomized studies

We held a teleconference with the panel of technical experts to identify specific questions to be addressed with the nonrandomized studies. The following key questions were formulated:

- What are the side effects of the different opioid analgesics and of different routes of opioid administration? (questions 2.2, 3.1, and 3.4);
- What are the morbidity and mortality of cordotomy in treating cancer pain? (question 6.1). In addition, the supplemental analysis explored the feasibility of conducting a meta-analysis of nonrandomized evidence and comparing the results with those of a meta-analysis of randomized controlled trials addressing the same question.

## Literature Search

### Sources

We performed computer literature searches of the National Library of Medicine's Medline and CancerLit databases. Overlapping reports between the Medline and CancerLit databases were excluded from the CancerLit search. We also searched the Cochrane Controlled Trials Registry, consulted technical experts, examined references of published meta-analyses, and selected review articles for additional studies.

### Search terms and strategies

We did not restrict our literature search only to randomized controlled trials, since the number of usable studies of this type was not initially known, but also sought to identify nonrandomized studies such as cohorts and case series. Table 2 lists the details of our Medline search strategy for relevant clinical studies. We used a sensitive search strategy to retrieve potential abstracts to minimize the problem of missing relevant randomized controlled trials that may have been incorrectly indexed. The search was restricted to human clinical studies published in English. A search of 1966 to December 1998 with the keywords "neoplasm," "analgesia," "analgesics," and "pain" as Medical subject heading (MeSH) terms and text words yielded 18,681 published reports, of which 17,893 were in the broad category of "journal article." Within the category of journal articles were 756 randomized controlled trials indexed by Medline, which constitutes a high-yield group of directly relevant clinical studies for this evidence report. We performed supplemental searches in the Medline database using "cancer," "tumor," "malignant," and "oncology" as MeSH terms and text words to avoid omissions. The supplemental searches added only one qualified randomized trial to this report.

Table 2. Medline search strategy for cancer pain trials Database: MEDLINE ALL <1966 - December 1998>

1 | exp neoplasms/ or "neoplasms".mp. | 1149458
2 | exp analgesia/ or "analgesia".mp. | 25754
3 | exp analgesics/ or "analgesics".mp. | 154660
4 | exp pain/ or "pain".mp. | 163910
5 | 2 and 3 and 4 | 6126
6 | 2 or 3 or 4 | 305982
7 | 1 and 6 | 27427
8 | limit 7 to (human and english language) | 18681
9 | limit 8 to addresses | 0
10 | limit 8 to bibliography | 3
11 | limit 8 to biography | 5
12 | limit 8 to classical article | 2
13 | limit 8 to clinical conference | 67
14 | limit 8 to clinical trial | 1861
15 | limit 8 to clinical trial, phase i | 127
16 | limit 8 to clinical trial, phase ii | 243
17 | limit 8 to clinical trial, phase iii | 32
18 | limit 8 to clinical trial, phase iv | 1
19 | limit 8 to comment | 234
20 | limit 8 to consensus development conference | 7
21 | limit 8 to consensus development conference, nih | 1
22 | limit 8 to controlled clinical trial | 185
23 | limit 8 to "corrected and republished article" | 1
24 | limit 8 to dictionary | 0
25 | limit 8 to directory | 1
26 | limit 8 to duplicate publication | 2
27 | limit 8 to editorial | 107
28 | limit 8 to festschrift | 0
29 | limit 8 to guideline | 26
30 | limit 8 to historical article | 15
31 | limit 8 to interview | 3
32 | limit 8 to journal article | 17893
33 | limit 8 to lectures | 1
34 | limit 8 to legal brief | 3
35 | limit 8 to letter | 552
36 | limit 8 to meeting report | 24
37 | limit 8 to meta analysis | 18
38 | limit 8 to monograph | 32
39 | limit 8 to multicenter study | 327
40 | limit 8 to news | 64
41 | limit 8 to overall | 2
42 | limit 8 to periodical index | 0
43 | limit 8 to practice guideline | 19
44 | limit 8 to published erratum | 1
45 | limit 8 to randomized controlled trial | 756
46 | limit 8 to retracted publication | 0
47 | limit 8 to retraction of publication | 0
48 | limit 8 to review | 2217
49 | limit 8 to review literature | 89
50 | limit 8 to review of reported cases | 479
51 | limit 8 to review, academic | 91
52 | limit 8 to review, multicase | 49
53 | limit 8 to review, tutorial | 1154
54 | limit 8 to technical report | 1
55 | limit 8 to twin study | 0

We performed a separate search strategy (see Table 3) specifically to identify epidemiological studies on the prevalence and incidence of pain in cancer patients to address the first key question. The strategy consisted of the keywords "neoplasia," "pain," "epidemiology," "prevalence," and "incidence" and yielded 464 studies.

Table 3. Medline search strategy : Epidemiology of cancer pain Database: MEDLINE ALL <1966 - February 1999>

1 | "NEOPLASIA".mp. | 14694
2 | exp Pain/ | 102919
3 | exp Epidemiology/ | 5033
4 | 1 and 2 and 3 | 0
5 | exp prevalence/ | 36051
6 | 1 and 2 and 5 | 0
7 | 2 and 5 | 882
8 | 1 and 7 | 0
9 | exp incidence/ or "incidence".mp. | 203351
10 | 1 and 2 and 9 | 1
11 | exp prevalence/ or "prevalence".mp. | 97935
12 | 1 and 2 and 11 | 1
13 | exp neoplasms/ or "cancer".mp. | 1181318
14 | 2 and 9 and 13 | 367
15 | 2 and 11 and 13 | 112
16 | 14 or 15 | 464
17 | 3 and 16 | 0
18 | from 16 keep 1-200 | 200
19 | from 16 keep 201-400 | 200
20 | from 16 keep 401-464 | 64
21 | "NEOPLASIA".mp. | 14694
22 | exp Pain/ | 102919
23 | exp Epidemiology/ | 5033
24 | 21 and 22 and 23 | 0
25 | exp prevalence/ | 36051
26 | 21 and 22 and 25 | 0
27 | 22 and 25 | 882
28 | 21 and 27 | 0
29 | exp incidence/ or "incidence".mp. | 203351
30 | 21 and 22 and 29 | 1
31 | exp prevalence/ or "prevalence".mp. | 97935
32 | 21 and 22 and 31 | 1
33 | exp neoplasms/ or "cancer".mp. | 1181318
34 | 22 and 29 and 33 | 367
35 | 22 and 31 and 33 | 112
36 | 34 or 35 | 464
37 | 23 and 36 | 0
38 | from 36 keep 1-200 | 200
39 | from 36 keep 201-400 | 200
40 | from 36 keep 401-464 | 64
41 | "NEOPLASIA".mp | 14694
42 | exp Pain/ | 102919
43 | exp Epidemiology/ | 5033
44 | 41 and 42 and 43 | 0
45 | exp prevalence/ | 36051
46 | 41 and 42 and 45 | 0
47 | 42 and 45 | 882
48 | 41 and 47 | 0
49 | exp incidence/ or "incidence".mp | 203351
50 | 41 and 42 and 49 | 1
51 | exp prevalence/ or "prevalence".mp | 97935
52 | 41 and 42 and 51 | 1
53 | exp neoplasms/ or "cancer".mp | 1181318
54 | 42 and 49 and 53 | 367
55 | 42 and 51 and 53 | 112
56 | 54 or 55 | 464
57 | 43 and 56 | 0
58 | from 56 keep 1-200 | 200
59 | from 56 keep 201-400 | 200
60 | from 56 keep 401-464 | 64

## Study Selection

We screened 756 randomized controlled trials and 464 epidemiological reports for directly relevant studies. We also manually screened about 17,000 abstracts for additional studies. Two physician members of the EPC staff, one with expertise in pain management and the other with expertise in systematic review methodology, screened the abstracts.

### Screening of abstracts

From the 17,893 abstracts, we selected those studies that met all of the following criteria:

- All or part of the population studied suffered from cancer.
- Pain was a measured primary or secondary outcome.
- Pain was attributed to the cancer itself, to cancer treatment (procedural pain), or to the side effects of cancer pain treatment.

We did not place any restrictions on age, gender, ethnicity, study location, type or stage of cancer, or severity of cancer pain. Because it was difficult to discern the relevance of the articles to the questions by reading only the abstracts, reports that appeared to be primarily pharmacokinetic studies were retrieved in full for scrutiny. Comparative studies of two or more treatments that did not explicitly mention randomization were also retrieved and examined.

The abstracts of 464 epidemiology studies were screened to identify studies that involved

- Cancer at any stage and geographic location
- Any pain assessment instrument
- Patients with any type of pain or concurrent treatment of pain or primary disease
- Prevalence or incidence of cancer-related pain.

### Screening for the supplemental analysis of nonrandomized studies

We examined the 17,893 Medline and CancerLit titles from the initial search to identify nonrandomized studies that addressed the questions in the supplemental analysis. In addition, we updated the literature search through October 1999 using the same general Medline search strategy defined earlier. References from selected meta-analyses and review articles were also screened. The same screening criteria were used as for the randomized controlled trials, except that pain did not have to be a primary or secondary outcome (although the treatment must have been for pain). Also, single-arm or comparative studies were included, and a minimum of five subjects must have been included.

Four hundred twenty-five articles met the above criteria, of which 285 articles were relevant to the key questions. Per AHRQ contract budgetary limitation, we limited the supplemental analysis to 100 articles. We used a minimum study size as the inclusion criterion where necessary.

Four routes of opioid treatment and two types of NSAID treatments (with and without opioids) were assessed for side effects. We limited the number of articles for each of the categories to between seven and 10 to ensure coverage of all the topics. For topics that had more than 10 articles, we used the following minimum study size criteria to determine which studies were included: 180 patients for oral opioids; 50 patients for parenteral opioids; 30 patients for transdermal fentanyl; 100 patients for spinal opioids; 30 patients for NSAIDs; and 500 patients for WHO protocol.

## Data Abstraction

The full articles for selected abstracts were retrieved and examined in detail for possible inclusion in the evidence tables. For treatment efficacy studies, we used a data abstraction screening form to capture information about the study design features, demographics, patient characteristics, treatment comparisons, and outcomes (see Appendix C). Additional information needed to create the evidence tables was directly entered into spreadsheets. Six physician members of the EPC with expertise in pain management or systematic review performed the data abstraction. One physician member of the EPC team abstracted the data from each study and another physician team member with pain management expertise verified this data. We performed additional data extraction on studies that qualified for meta-analyses. Only numerically reported outcomes data were abstracted and used for meta-analyses. Results reported only as graphs without accompanying numerical data were not used. A meta-analysis methodologist verified numerical data prior to analysis.

## Methods for Summarizing Results

We sum up the evidence in this report using three complementary approaches. Evidence tables provide detailed information about the features and results of all the epidemiologic and treatment studies examined in this report. A narrative description of individual studies along with an evidence-grading scheme summarizes the evidence used to address each study question (Greenhalgh and Hurwitz, 1998). Finally, when a sufficient number of studies address a specific question, meta-analysis provides a quantitative summary of treatment effects (Bailar, 1995; Greenland, 1994 Chalmers and Altman, 1995). As discussed in the beginning of this chapter, whenever possible, we used randomized controlled trials to evaluate the efficacy of various interventions. For several questions randomized evidence was insufficient, so we expanded the evaluation to include nonrandomized studies. We also used nonrandomized studies to evaluate treatment side effects.

### Evidence tables

We grouped studies that met the inclusion criteria according to six broad treatment categories derived from the earlier Management of Cancer Pain Clinical Practice Guideline (Jacox, Carr, Payne, et al., 1994):

- Primary pharmacological interventions (opioids, acetaminophen and NSAIDs, local anesthetics)
- Secondary pharmacological interventions or adjuvant analgesics (psychostimulants, alpha-2 agonists, tricyclic antidepressants, etc.)
- Nonpharmacological interventions (physical, psychosocial, and educational interventions; e.g., hypnosis, massage, transcutaneous electrical nerve stimulation [TENS], music, relaxation, and acupuncture)
- Nonpharmacological invasive interventions (neuroaugmentation, neurolytic block)
- Antineoplastic interventions (radiotherapy, chemotherapy, biphosphonates)
- Other various treatments interventions (not under previous categories)

Data from studies addressing the same question were included in the same category of evidence table. Variables that generally apply to any clinical trial (e.g., study design) as well as more specific variables (e.g., therapy for breakthrough pain) that apply only to studies on cancer pain management were considered in selecting variables to be included in the evidence tables.

### Grading of the evidence for randomized controlled trials

Grading of evidence can be useful in appreciating the overall "quality" of a group of studies addressing a question. Over two dozen scales have been proposed to evaluate the quality of randomized controlled trials (Moher, Jadad, Nichol, et al., 1995). While it may be desirable to have a simple evidence-grading system using a single quantity dimension, the quality of evidence is multidimensional, and a single metric cannot fully capture information needed to interpret a clinical study (Ioannidis and Lau, 1998). A recent empirical study applied 25 quality scales to one meta-analysis and found that different quality scales could result in different conclusions; hence quality scales are inconsistent among themselves (Juni, Witschi, Bloch, et al., 1999). Another empirical study demonstrated the greater usefulness of assessing studies according to specific study design features (Lijmer, Mol, Heisterkamp, et al., 1999).

The evidence tables contain detailed information about the study characteristics, population and disease characteristics, patient demographics, treatment comparisons, and outcome measures (Wright, 1999). We used this information to derive an evidence grade that indicates the quality of each of the randomized controlled trials used to address the key questions. This evidence-grading scheme captures four dimensions of a study that are important for the proper interpretation of the evidence: internal validity, applicability, magnitude of treatment effect, and size of the study. This evidence-grading scheme is used as part of the reporting of the results.

#### Internal validity

Internal validity addresses the design, conduct, and reporting of the clinical trial. Some of the items belonging to this entity have been widely used in various "quality" scales and usually include items such as concealment of random allocation, treatment blinding, and handling of dropouts. In this evidence report, we define a four-category internal validity scale: A (least bias), B (susceptible to some bias), C (likely to have large bias), I (unable to assess due to lack of reported information). Further details of each category are as follows:

A. Double-blinded, well-concealed randomization, few dropouts, and no (or only minor) reporting problem of the trial that is likely to cause significant bias.

B. Single-blinded only, unclear concealment of randomization, or some inconsistency in the reporting of the trial but is unlikely to result in major bias.

C. Unblinded study, inadequate concealment of random allocation, high dropout rate, or substantial inconsistencies in the reporting of the trial such that it may result in large bias.

I. Inadequately reported (very often trials do not report certain data; this may occur by intent or due to oversight).

#### Applicability

Applicability, also known as generalizability or external validity, addresses the issue of whether the evidence from the study population is broad enough to generalize to the population at large. Individual studies are often unable to achieve broad applicability due to restricted study population characteristics and small number of study subjects (Lau, Ioannidis, and Schmid, 1997). We define the applicability grade as below:

A. Patients enrolled in the trial represent a broad spectrum of the population (high degree of applicability). Typically this would be a large study, although a large study in itself does not guarantee a high degree of generalizability.

B. Patients enrolled included only a narrow/restricted population, but the result is relevant to similar types of patient population (restricted applicability). Typically this would be a small study, but may also be a large study of a very homogeneous population.

C. Patients enrolled were part of an outlier population that is not immediately relevant to the study question (very limited direct applicability or not applicable), or the study reported only limited information.

I. Not reported or insufficient information to assess external validity issues (uncertain applicability).

Because the efficacy of pain treatments may depend on the baseline level of pain, we also extracted data on baseline pain intensity of the study population to assist in the interpretation of results. We report in the evidence-grading tables, along with the applicability rating, the baseline pain intensity expressed as visual analog scale (VAS) of 0-10 cm (or 0-100 mm) when these data are reported in the study. Studies that did not provide 0-10 cm VAS data but reported qualitative descriptions or other scales are so noted in the tables.

#### Study size

The study size is used as a measure of the weight of the evidence. Some studies have a high dropout rate due to deaths from the underlying cancer; we provide both the enrolled and evaluable number of patients when these data are reported. A large study provides a more precise estimation of the treatment effect but does not automatically confer broad applicability unless the study included a broad spectrum of patients. Very small studies, taken individually, cannot achieve broad applicability, but several small studies that enrolled diverse populations, taken together, may have broad applicability. The study size is also included as a separate dimension used to assist the assessment of applicability.

#### Magnitude of the treatment effect

In each of the result tables, "effect size" reflects the difference between outcomes in the treatment arms of the study, not pretreatment versus posttreatment comparisons in the experimental group.

The following effect size scale is employed for studies that provide consistent reporting of a pain-related outcome:

+++ | Large difference in effect (>20 mm on VAS between control and experimental group)
++ | Modest difference in effect (10-20 mm on VAS between control and experimental group)
+ | Small difference in effect (5-10 mm on VAS between control and experimental group)
± | No difference in effect (0-4 mm on VAS between control and experimental group)
- | negative (harmful) effect (applicable only to placebo trial)

For example, if an experimental opioid were compared with morphine, and both treatments were found to have a large effect on pain scores, then the effect size assigned to this study would be a "±".

It should be noted that large difference in effect does not necessarily imply a statistically significant difference.

The outcomes reported by available studies on some of the questions were heterogeneous and not amenable to categorizing the effect size on the same scale. This group of heterogeneous outcomes includes drug consumption, pain relief, and quality-of-life related indices. Further, pain intensity may not have been reported using a VAS. Pain management experts evaluated these studies and assigned a qualitative score for the effect size as follows:

+++ | Large beneficial effect
++ | Modest beneficial effect
+ | Small beneficial effect
± | No beneficial effect

### Grading of the evidence for nonrandomized studies

Nonrandomized studies that reported treatment effects represent a diverse category of study designs and reporting. There is no current standard approach to assess the methodological quality and the reliability of these studies. In this report, we used a similar evidence-grading scheme for randomized controlled trials with several modifications described below.

#### Internal validity

Each nonrandomized study was assigned a grade that comprised the study design and adequacy of reporting. The grades for study design are defined as follows:

A Prospective controlled trial
B Cohort
C Case series

We also provided subscripts that correspond to a separate assessment of the adequacy of reporting of study design, patient population characteristics, disease (pain and cancer), treatment(s), and outcomes:

1. Completely or mostly described
2. Fair reporting but some important data are missing
3. Interpretation is difficult because many data are missing

For example, a cohort study with excellent reporting would be graded as B_1_.

#### Applicability

Three criteria were used to assess the applicability of a nonrandomized study:

- The study directly addressed the question in the evidence report
- The study had a well-defined study population
- The study did not use a restricted population

A three-category grade was assigned to each, as follows:

A All three criteria were met
B Two of the three criteria were met
C Only one criterion was met

#### Magnitude of the treatment effect

Most nonrandomized studies we examined were cohorts or case series, and these studies typically provide only a response rate for a single treatment arm (e.g., pain intensity score at the end of treatment, or the difference before and after treatment). We reported these rates or scores as the treatment effects in the summary tables.

### Summarizing the evidence addressing each key question

In addition to assigning evidence grades to each study that was used to address the key questions, we also summarized the evidence grades across several dimensions to obtain an impression of the quality of the totality of the evidence. We tallied the number of studies assigned different internal validity grades and estimated an average of the quality score. We assessed the generalizability of the collection of studies as follows:

A The studies involved a diverse collection of patients, and the totality of evidence is likely to be generalizable. This status may be achieved through a large trial of a diverse patient population or several trials of homogeneous subjects that each studied a different relevant population (each study must have received an applicability grade of B or higher)
B Limited generalizability due to scarcity of studies involving diverse populations.

We performed meta-analyses to estimate the overall benefit of treatments when the data were sufficient. When a group of studies addressing the same question was too heterogeneous to allow a meta-analysis, we noted the trend of treatment effect reported by the studies.

### Summarizing the reporting of side effects

Summarizing side effects is problematic due to nonstandard reporting across individual studies (Edwards, McQuay, Moore, et al., 1999). Studies frequently do not define side effects, do not report the same side effects, or do not use the same metric to report the same side effect; many simply do not report side effects (Ioannidis and Lau, 2001). Therefore, we were not able to perform meta-analyses of side effects. We summarized the side effect data as a range of reported occurrence of these outcomes. Due to the many diverse ways that side effect data were reported, where appropriate, we combined related events into a single group.

### Meta-analysis of randomized controlled trials

Guided by the key questions and when a sufficient number of randomized controlled trials addressed these questions, we attempted meta-analyses to provide quantitative estimations of the treatment effects. We assessed the combinability of the studies prior to undertaking a meta-analysis on a study question. Meta-analyses can sometimes be appropriately performed on several studies evaluating different drugs belonging to the same class (i.e., different NSAIDs) to determine the class effect. However, when there are too few studies (two or three), such meta-analysis can be misleading. For example, two studies of different NSAIDs do not necessarily constitute a class effect (because there are many different types of NSAIDs), and therefore a meta-analysis should not be performed. In addition, each of the studies used in the meta-analysis must have appropriately defined outcome measures and the necessary numerical data (outcome estimates and standard error or confidence interval). We did not use studies that reported only graphical results.

We identified studies addressing each subquestion from the evidence tables. We evaluated the possibility of performing a meta-analysis when more than one study addressed a subquestion by examining the following conditions:

- Whether the study evaluated pain as an outcome and which assessment instrument was used (i.e., visual analog scale, Likert scale)
- Whether pain assessment data were provided and in what format (e.g., mean and standard deviation of visual analog scale measures, graphical, descriptive)
- The study design, including its time course (Goudas and Carr, 1998)
- The study population (e.g., type of cancer, demographic characteristics, length of assessment period).

### Meta-analysis of nonrandomized clinical studies

Comparison of results from meta-analysis of randomized controlled trials with results from meta-analysis of nonrandomized studies was one of the objectives of the supplemental analysis of nonrandomized evidence. The meta-analysis of randomized controlled trials that compared NSAID with NSAID plus weak opioid analyzed the pain intensity difference on the last day of the study. Thus, we planned to perform a meta-analysis of nonrandomized studies by combining single-arm NSAID studies and single-arm NSAID-plus-opioid studies that reported the pain intensity on the last day of the study. We explored the feasibility of this comparison and found it was not possible. We were not able to perform the meta-analysis of nonrandomized studies due to the extreme heterogeneity of the nonrandomized studies. Nonetheless, we describe below the method for a meta-analysis of nonrandomized studies, had it been possible. We provide a detailed description of the nonrandomized studies we analyzed at the end of Chapter 3.

Similar to meta-analysis of randomized controlled trials, such analysis of nonrandomized studies must meet several basic criteria: the studies must address a similar question, be performed under similar settings, study similar patient populations, have clearly defined similar outcomes, and report sufficient data to allow quantitative synthesis. In addition to the treatment effect estimates, studies must also have reported standard errors or standard deviations of the results.

Nonrandomized studies include prospective and retrospective designs. Prospective studies may consist of nonrandomized parallel comparisons or observations of a cohort. Retrospective studies are usually case series. Data from nonrandomized comparisons that report differences between two treatment groups may be analyzed similar to data from randomized controlled trials, if appropriate. Single-treatment studies typically provide an overall response rate or the before and after treatment response rates of an intervention. The response rates from individual studies of the same treatment are combined using a random effect model. The combined response rates from each of the treatments are compared and the difference taken as an estimation of the benefit of one treatment over the other. However, indirect comparisons of response rates between single-arm studies are fraught with hazards. These may come from inappropriate estimates of treatment effect resulting from dissimilarities of patient populations, treatment protocols, methods of assessing outcomes, and other biases. We collected data, if reported, from the nonrandomized studies about specific study design features and patient characteristics. We used subgroup and regression analyses to try to understand differences in reported effect sizes.

We acknowledge that meta-analyses of nonrandomized studies may not be reliable, and we do not advocate their routine use (Feinstein 1995; Jadad 1996; Sniderman, 1999). The reasons for attempting this type of meta-analysis is that in areas where there are no randomized trials, synthesis of nonrandomized data may represent the best evidence currently available for decision making. Another goal for attempting the comparison of randomized and nonrandomized data is to evaluate the magnitude of potential bias that may arise from such data. Understanding factors in nonrandomized studies that contribute to differences in their results may provide insights into interpreting their findings.

### Statistical methods of combining studies

Studies that qualify for meta-analysis were combined using a random effects model (Laird and Mosteller, 1990). The risk ratio was used to combine dichotomous outcome data from comparative studies. A random effects model was used to combine pain outcomes such as pain intensity or pain relief score and other outcomes reported as continuous variables. A random effects model incorporates both the within-study variation (sampling error) and the between-study variation (true treatment effect differences) into the estimation of the overall treatment effect. It gives a wider confidence interval (compared with the fixed effect model, which considers only within-study variability) when heterogeneity is present.

A common problem of using meta-analysis to combine studies with continuous data is that the outcomes (pain score and standard error) are reported as the pre- and posttreatment group means for the treatment and control groups; however, the correlated standard errors of the pre- and posttreatment of each treatment arm were frequently not reported. When the correlated standard errors were not reported, we used a method we previously described to estimate the correlated standard error in order to perform our meta-analysis (Ballantyne, Carr, deFerranti, et al., 1998). Sensitivity analyses using several levels of correlation were used to test the robustness of the results.

## Estimations of Drug Costs

To assess the costs associated with NSAIDs and opioid analgesics and routes of administration, we used the dose and dose equivalence data for NSAIDs and opioid analgesics reported in Tables 9 and 10 of the AHCPR cancer pain guideline (Jacox, Carr, Payne et al., 1994). Table 9 of this guideline presented the usual dose for adults and children with body weight greater than 50 kilograms, and Table 10 presented equianalgesic dose equivalents for opioid-naive adults and children with body weight greater than 50 kilograms. Using the usual dose for NSAIDs or the approximate equianalgesic oral and parenteral dose for opioids, we determined the average wholesale dollar price (AWP) per unit gram or gram per milliliter of each drug using the pharmaceutical industry's 1999 Red Book (Anonymous, 1999). Where the AWP price differed from the price quoted in the pharmacy drug database, the hospital-based pharmacist working with the EPC confirmed the AWP directly with the relevant pharmaceutical company. The AWP was then used to derive the price per daily (24-hour) dose.

Table 9. Summary of grading of individual randomized controlled trials on complementary therapies for the treatment of neuropathic pain

Primary author, year, unique identifier | Study size* | Baseline pain (VAS 0-10 cm) | Effect size | Internal validity | Applicability
Li, 1994 94374211 | 16 | 2.2±1.8 2.4±1.7 2.0±6.8 in the three study arms | ± | C | B

*Number of evaluable patients shown in parentheses if different from enrolled.

Table 10. Summary of grading of randomized controlled trials evaluating the relative potency of opioids in cancer pain

Number of studies | Patients enrolled/evaluated | Internal validity | Applicability
7 | 392/354 (90.3% evaluable) | A = 0 B = 7 C = 0 | A = 0 B = 7 C = 0

A straightforward comparison of costs associated with various routes of administration is problematic due to the wide variability in prices and costs of certain components of drug administration. These include costs of the skilled labor, drug delivery devices, family and professional support systems, and even the delivery setting. In addition, not every route of administration is equally available to each patient, as some patients are simply unable to tolerate a certain route. An analysis of costs should consider the incremental costs and consequences of alternative treatments or, in this case, routes of administration. However, this is not possible, as some patients have no alternatives. Therefore, we have focused the analysis on drug costs, and in the case of opioid costs, on the equianalgesic dose of drugs used by oral or parenteral route. A more detailed review of costs, as well as analysis of cost-effectiveness, is beyond the scope of this evidence report.