# Appendix C. Screening Form

CANCER PAIN TASK FORCE INITIAL ARTICLE SCREEN FORM | UI: __ __ __ __ __ __ __
-12-98 Screen1.DOC REFMAN DATABASE/ID____________ | Date of Screen:________________
Author(first):_______________________________________________________________________________________________________________________________
Journal:______________________________________________________________________________ | Volume_____Year________

Data Extractor: LG RB PC MG JL ML _____
_ - one answer only [image] - multiple answers possible | | | [image]_ - answer only if required
_ 1. Cancer pain treatment (meets inclusion criteria)? | | | Yes | No Unclear (Stop if No)
Inclusion Criteria:
1. Disease studied: cancer, 2.Outcome: Pain as a primary or secondary outcome
3. Pain attributable to cancer and other reasons i.e. surgery in cancer patients
[where is #2?]
[image]3. Study Question: Treatment Other________________________________ | | | | | (Stop if Other)
_ 4. Article Type: Rct__ Case control___ Case series___ Non-controlled cohort___ Case report___ Other___
(Stop if Other)
_ 5. Age: | Pediatric (<18) | Adult (>=18) | Both | Overlap (age range:_______________) | No Data
[image]6. Setting: Outpatient ED | | Hospital (in-patient) Hospice No Data oTher_____________________
[image]7. Study Arms (if comparative study): N= | | | | | (1,2,3 etc)
[image]8. Treatments compared (circle one): PP PA | | | PS | NPI PAL X (circle more than one if necessary)
------------------------------------------------------------------- | | | | Other___________________________ | [image] (OTH)
| [image] Treatment Studies | | | route: (oral, IV, IM, SC, Epidural, Spinal)___________________
[image]9. Treatments under study: | | | | mode: (PCA)__________________________________________
Specify name of treatment (e.g., morphine, buprenorphine) | | | | formulation: (slow release, patch)_______________________
Pharmacologic (primary) [code PP]:
Opioid___________________________ | | [image] (OP) | | *Pharmacologic (adjuvant-not used as a single agent) [code PA]:
route: (oral, IV, IM, SC, Epidural, Spinal)_________________ | | | | Psychostimulants (amphetamine, ritalin) | [image]
mode: (PCA)__________________________________________ | | | | A_2_ adrenergics (Clonidine)_ | [image]
formulation: (slow release, patch)_______________________ | | | | NMDA blockers (Ketamine) | [image]
| | | | Local anesthetics (Xylocaine) | [image]
| | | | Tricyclic Antidepressants - SSRI s (Amitriptyline) | [image]
Acetaminophen____________________ | | [image] (ACET) | | Ca^++^ Channel blockers (Nimodipine) | [image]
route: (oral, IV, IM, SC, Epidural, Spinal)_________________ | | | | Anti-seizure medication (Gabapentin) | [image]
mode or formulation: (PCA, slow release)_________________ | | | | Mixtures: | [image]
| | | | Homeopathic medication: | [image]
NSAIDS_________________________________ | | [image] (NSAID) | | Other: | [image]
route: (oral, IV, IM, Epidural, Spinal)____________________ | | | | * provide name and route:
mode or formulation: (PCA, slow release)_________________
Local anesthetic__________________ | | [image] (LA/TA) | | Non-Pharmacologic (Physical/psychological) [code PS]:
Infiltration | | [image]
Epidural and intrathecal | | [image] | | Psychosocial______________________ | [image] (PSY)
Interpleural | | [image] | | Education[image]Music[image]Relaxation/Yoga[image]Biofeedback[image]
Emulsion | | [image] | | Parent presence[image]Hypnosis/Imagery[image]other[image]
Patch | | [image]
Other (describe)_______________________________________ | | | | TENS__________________________ | [image] (TENS)
Placebo......................................... | | [image] (PLA)
route: (oral, IV, IM, SC, Epidural, Spinal)___________________ | | | | Acupuncture_____________________ | [image] (ACU)
| | | | treatment side effect | [image]
Physical therapeutic_______________ | | [image] (PHY)
Heat[image]Cold[image]
Massage[image]Active and Passive exercise[image]immobilization[image]other[image] | | | | other | [image]
| | | | [image]13. Core question that this study relates to:
Non-Pharmacologic (invasive) [code NPI]:
| | | | 2 [image]
Neuroaugmentation________________ | | [image] (NAUG) | | 3 [image]
Deep brain stimulation | | [image] | | 4 [image]
Spinal Cord stimulation | | [image] | | 5 [image]
Commisurotomy | | [image] | | 6 [image]
Cordotomy | | [image]
other | | [image]
*Neurolytic blocks_____________________ | | [image] (NB)
Celiac | | [image]
Hypogastric | | [image] | | Comments-notes:
Epidural | | [image]
Intrathecal | | [image]
Peripheral | | [image]
Intercostal | | [image]
* neurolytic agent (phenol,other)_______________
Pharmacologic or non-Pharmacologic (palliative) [code PAL]:
Radiotherapy_____________________ | | [image] (RT)
Local field[image]Wide field[image]
Fractionation; Single dose[image]Multidose[image]
Brachytherapy[image]
b- emitting radiopharmaceuticals[image]
Biphosphonates_____________________ | | [image] (BP)
name:____________________________________
route of administration:_______________________
mode (single bolus, repeated)___________________
Chemotherapy_____________________ | | [image] (CM)
name:
*Other [code X]:
* describe
[image]10. Duration of study:
[image]11. Instrument for assessment of pain:
[image]12.Pain was due to:
cancer [image]
cancer- related intervention [image]