# Appendix B. Peer Reviewers

The partner organizations for the evidence report nominated individuals to participate in the peer review of the evidence report. Additional individuals with appropriate methodological and clinical expertise were identified by the EPC. Review of the evidence report by these individuals does not represent endorsement of the report. We are grateful to the peer reviewers for generously offering their time and clinical knowledge.

- Michael A. Ashburn, MD, MPH
- University of Utah Medical Center
- Salt Lake City, Utah
- Representing: American Society of Anesthesiologists

- David L. Brown, MD
- University of Iowa
- Iowa City, Iowa
- Representing: American Society of Anesthesiologists

- C. Richard Chapman, PhD
- University of Washington
- Seattle, Washington
- Representing: American Pain Society

- Gilbert J. Fanciullo, MD MS
- Dartmouth Medical School
- Lebanon, New Hampshire
- Representing: American Society of Anesthesiologists

- Kathleen Foley, MD
- Memorial-Sloan Kettering Cancer Center
- New York, New York

- Ruth Goltz, RN, MS, AOCN
- Cincinnati, Ohio
- Representing: Oncology Nursing Society

- Lee Ann Hansen, Pharm D
- Virginia Commonwealth University
- Richmond, Virginia
- Representing: American Society of Health-System Pharmacists

- Alex Jadad, MD, D Phil
- McMaster University
- Hamilton, Ontario

- Mark J. Lema, MD PhD
- State University of New York at Buffalo
- Buffalo, New York
- Representing: American Society of Anesthesiologists

- Patricia McGrath, PhD
- Child Health Research Institute
- Children's Hospital of Western Ontario
- London, Ontario

- Christine Miaskowski, PhD, RN, FAAN
- University of California School of Nursing
- San Francisco, California
- Representing: American Pain Society

- Judith Paice, PhD, RN
- Northwestern Memorial Hospital
- Chicago, Illinois

- Sunil J. Panchal, MD
- Johns Hopkins University
- Baltimore, Maryland
- Representing: American Society of Anesthesiologists

- Russell Portenoy, MD
- Beth Israel Medical Center
- New York, New York
- Representing: American Pain Society

- Derek Raghavan, MD
- Norris Cancer Center
- University of South California
- Los Angles, California
- Representing: American College of Physicians

- James P. Rathmell, MD
- University of Vermont College of Medicine
- Burlington, Vermont
- Representing: American Society of Anesthesiologists