# Appendix A. Evidence Report Staff and Technical Expert Advisory

## Group

### Evidence-based Practice Center Staff

- EPC/Project Director:
- Joseph Lau, MD

- Assistant Project Director:
- Leonidas Goudas, MD, PhD

- Primary Technical Expert:
- Daniel Carr, MD

- Investigators:
- Rina Bloch, MD; Ethan Balk, MD, MPH; John P.A. Ioannidis, MD

- Statistician:
- Norma Terrin, PhD

- Project Manager:
- Deirdre DeVine, M Litt

- Research Associates:
- Priscilla Chew, MPH; Maria Gialeli-Goudas, LLM

- Technical Editor:
- Thomas A. Lang, MA

- Research Assistant:
- David Liu, BA

### Technical Expert Advisory Group

- Jane Ballantyne, MD
- Department of Anesthesiology
- Massachusetts General Hospital
- Boston, Massachusetts

- Claudia Bannon
- American Cancer Society
- Atlanta, Georgia
- Representing: American Cancer Society

- Ada Jacox, PhD, RN
- College of Nursing
- Wayne State University
- Detroit, Michigan
- Representing: American Pain Society

- Leslie Jaggers, Pharm D
- Professional and Scientific Affairs
- American Society of Health System Pharmacists
- Bethesda, Maryland
- Representing: American Society of Health System Pharmacists

- Jacqueline LaPierre, RPH
- Pain Program
- H. Lee Moffitt Cancer & Research Institute
- Tampa, Florida
- Representing: American Society of Health System Pharmacists

- Douglas Merrill, MD
- Valley Pain Treatment Center
- Phoenix, Arizona
- Representing: American Society of Anesthesiologists

- Richard Payne, MD
- Department of Neurology
- Memorial-Sloan Kettering Cancer Center
- New York, New York
- Representing: American Society of Clinical Oncology

- Karen Stanley, MSN, RN
- Claremont, California
- Representing: Oncology Nursing Society

- Vincent Jay Vanston, MD
- Scranton-Temple Residency Program
- Temple University Medical School
- Scranton, Pennsylvania
- Representing: American College of Physicians

### Partner Organizations

Partners

American Cancer Society

American College of Physicians

American Pain Society

American Society of Anesthesiologists

American Society of Clinical Oncology

American Society of Health-System Pharmacists

Oncology Nursing Society

Associate Partners

American Academy of Family Physicians

American Academy of Neurology

American Physical Therapy Association

Hospice Association of America

Hospice and Palliative Nurses Association