# Appendixes

Appendix A. Evidence Report Staff and Technical Expert Advisory

Appendix B. Peer Reviewers

Appendix C. Screening Form