# Evidence Tables

Evidence Table 1. Invasive treatment of uterine fibroids

Study | Design and interventions | Patient population | Outcomes reported | Results | Notes/Quality score
Acien and Querada, 1996 | Design: Case series, no controls Intervention: Abdominal myomectomy Dates: 1982-1994 Location: Alicante, Spain Length of followup: Mean 3.5 years, range 0.3-12 years | No. of subjects at start: 80 Dropouts: N/A Loss to followup: 6 No. of subjects at end: 74 Setting: University hospital Inclusion criteria: Symptomatic fibroids, infertility, or early pregnancy complications (n=67), pain during pregnancy (n=10), during c-section (n=3) Exclusion criteria: None specified Age: Mean 30.9±4.5 (range 18-43) Race: N/S Parity: Nulligravid: 48.8% Recurrent loss: 3.8% At least one pregnancy: 47.4% Baseline uterine size: N/S Baseline fibroid size: Solitary: 8.5±3.9 cm diameter, Range 2-16 Multiple: Largest mean 6.4 - 3.2 cm diameter, range 1-16 cm Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Drop-out rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: + N) Location of fibroids: + O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: + S) Standardized measures: − Note: Multiple analyses of small subgroups
  1) | Conception rates
  2) | Predictors of pregnancy
  3) | Recurrence rates
  4) | Reoperation rates
  1) | Conception rates: All patients attempting pregnancy (n=40): 78.7% at 5 years Infertility, recurrent abortion (n=22): 62.7% at 5 years Unexplained infertility (n=5): 100% at 2 years
  2) | Predictors of pregnancy: number of fibroids, age > 30, and duration of infertility > 3 years negatively associated with conception rates
  3) | Recurrence rates: Crude rate 8.7% at 12 years, 38.3% at 10 years by life-table analysis
  4) | Reoperation rates: Crude rate 7.5% at 12 years, 18% at 10 years by life-table analysis
Andrei, Crovini, and Rosi, 1999 | Design: Case series, no controls Intervention(s): Laparoscopic myomectomy (n = 332) Dates: 1990-May 1998 Location: Parma, Italy Length of followup: N/S | No. of subjects at start: 332 Dropouts: N/A Loss to followup: N/S No. of subjects at end: N/S Setting: Hospital Inclusion criteria: Consecutive patients who underwent laparoscopic myomectomy for symptomatic fibroids Exclusion criteria: Submucous fibroids; myomas > 15 cm after 3-month treatment with GnRH Age: Median, 36; range, 16-52 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: Mean, 2.1 Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: − E) Loss to followup: − F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: + N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Pregnancy rate
  2) | Conversion to laparotomy
  3) | Complications
  4) | Length of stay
  1) | Pregnancy rate: 14.7% (49/332) "desired pregnancy" Of these, 67.6% (25/49) cumulative pregnancy rate
  2) | Conversion to laparotomy: 0.9%
  3) | Complications: Blood transfusion: 1.2% Fever: 0.7% Abdominal wall hematomas: 1%
  4) | Length of stay: Median, 3 days
Ashraf, 1997 | Design: Case series (retrospective), no controls Intervention(s): Abdominal (n = 77) or vaginal (n = 4) hysterectomy; or abdominal (n = 26) or vaginal (n = 9) myomectomy Dates: Jun 1989-May 1991 Location: Karachi, Pakistan Length of followup: N/A (in-hospital outcomes only) | No. of subjects at start: 116 Dropouts: N/A Loss to followup: N/A No. of subjects at end: 116 Setting: Hospital Inclusion criteria: Women with symptomatic uterine leiomyomas who underwent hysterectomy or myomectomy during study period Exclusion criteria: None specified Age: Mean, 42; range, 22-55 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: + O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: − S) Standardized measures: −
  1) | Length of stay
  2) | Adverse events
  1) | Length of stay (days): Abd myomectomy: 8.2 Vag/abd hysterectomy: 10.2
  2) | Adverse events: Hemorrhage: Abd myomectomy: 15.9% Vag/abd hysterectomy: 1.2% Wound infection: Abd myomectomy: 11.5% Vag/abd hysterectomy: 7.3% Peritonitis: Abd myomectomy: 11.5% Vag/abd hysterectomy: 4.9% Fever: Abd myomectomy: 23% Vag/abd hysterectomy: 35% Ileus: Abd myomectomy: 11.5% Vag/abd hysterectomy: 2.4%
Babaknia, Rock, and Jones, 1978 | Design: Case series, no controls Intervention(s): Abdominal myomectomy in patients with infertility whose only abnormality was fibroids, only therapy myomectomy (n = 46) Dates: Jan 1951-Dec 1975 Location: Baltimore, MD Length of followup: "2 or more years" | No. of subjects at start: 46 Dropouts: N/A Loss to followup: N/S No. of subjects at end: N/S Setting: Hospital; outpatient clinic/physician office Inclusion criteria: No other cause of infertility Exclusion criteria: None specified Age: Mean, N/S; 2 patients 20-25; 23 patients 26-30; 15 patients 31-35; 6 patients > 35 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: − F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: N/A R) Clinical care: − S) Standardized measures: − Note: No statistical testing.
  1) | Pregnancy rate, stratified by age, primary/secondary infertility, abnormality of uterine cavity
  2) | Pregnancy outcome, by primary/secondary infertility, and abnormality of cavity
  1) | Pregnancy rate: Overall: 22/46 (48%) conceived By age and primary/secondary infertility:
    Age | Primary (n) | Secondary (n)
    20-25 | 2/2 | 0/0
    26-30 | 10/15 | 7/8
    31-35 | 3/11 | 0/4
    > 35 | 0/6 | 0/0
  | By preoperative uterine cavity and type of infertility:
    Cavity | Primary | Secondary
    Regular | 13/27 | 3/6
    Irregular | 1/3 | 5/6
  2) | Pregnancy outcome: Overall: 19/22 term pregnancies (86%), 3/22 spontaneous abortions (14%) By infertility type: Primary: 13/14 term pregnancy (93%) Secondary: 6/8 term pregnancy (75%) By preoperative uterine cavity and infertility type:
    Cavity | Primary | Secondary
    Regular | 12/13 | 2/3
    Irregular | 1/1 | 4/5
Baggish, Sze, and Morgan, 1989 | Design: Case series, no controls Intervention(s): Hysteroscopic myomectomy, using Nd:YAG laser. All patients received danazol preoperatively for 6 weeks; those unable to tolerate danazol received megestrol acetate. All had D+C. Dates: Jul 1985-Jan 1989 Location: Syracuse, NY Length of followup: N/S | No. of subjects at start: 23 Dropouts: N/A Loss to followup: N/S No. of subjects at end: N/S Setting: Hospital Inclusion criteria: N/S Exclusion criteria: N/S Age: Mean, 38; range, 31-48 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: − E) Loss to followup: − F) Dropout rates: N/A G) Statistical issues: N/A EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: + O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Bleeding
  2) | Pregnancy rate
  3) | Adverse event
  1) | Bleeding (n = 23): Post: 96% "normal menses"
  2) | Pregnancy rate (n = 5): Posttreatment: 60%
  3) | Adverse event: Pulmonary edema/Hyskon reaction: 4%
Ben-Baruch, Schiff, Menashe, et al., 1988 | Design: Case series, compared to "arbitrarily" chosen women undergoing abdominal myomectomy in same period Intervention(s): vaginal myomectomy of prolapsed pedunculated submucous fibroid Dates: 1977-1986 Location: Tel Aviv, Israel Length of followup: Median 5.5 years, range 6 months-10 years | No. of subjects at start: 46 Dropouts: N/A Loss to followup: 9 No. of subjects at end: 37 Setting: Teaching hospital Inclusion criteria: All patients with histologically confirmed prolapsed fibroid Exclusion criteria: Not stated Age: Mean 44 years Race: N/S Parity: Mean gravidity 4.5, parity 3.2 Baseline uterine size: 89% <12 weeks Baseline fibroid size: 26% > 5 cm Number of fibroids: Baseline Hgb/Hct: Mean Hgb 9.1±1.1 | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Drop-out rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: + N) Location of fibroids: + O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: − Note: Presentation represented 2.5% of all cases for fibroids, presentation markedly different (59% admitted with acute bleeding episode, 13% with signs of fever before surgery) compared to abdominal myomectomy group.
  1) | Perioperative complications
  2) | Length of stay
  3) | Symptomatic recurrence
  1) | Perioperative complications: 4/46 required transfusion prior to surgery 3/46 converted to abdominal case (2 hysterectomy, 1 myomectomy)
  2) | Length of stay: Mean 2.4 days (range 1-13)
  3) | Symptomatic recurrence: 27/34 no symptoms 2 hysterectomies 3 repeat vaginal myomectomy 2 D&C
Berkeley, DeCherney, and Polan, 1983 | Design: Case series, no controls Intervention(s): Abdominal myomectomy, divided into 4 groups: Dates: Jul 1967-Aug 1977 Location: New Haven, CT Length of followup: Median, 58.7 months; range, 17-127 months | No. of subjects at start: 50 Dropouts: N/A Loss to followup: 0 No. of subjects at end: 50 Setting: Hospital; outpatient clinic/physician office Inclusion criteria: See under "Intervention(s)," at left Exclusion criteria: < 1 cm subserosal fibroids removed at time of surgery unrelated to infertility; unavailable for followup; vaginal myomectomy; pregnancy Age: Median, 29 Race: 56% White; 44% Black, Hispanic, or Other Parity: 56% nulligravid Baseline uterine size: N/S Baseline fibroid size: Mean, 283 g Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: + J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: + S) Standardized measures: − Note: Nostatistical testing.
  A) | Patients with pelvic mass wishing to preserve fertility (n = 22)
  B) | Patients with infertility with other potential causes in addition to fibroids (n = 19)
  C) | Patients with habitual abortion (n = 3)
  D) | Patients with fibroids as only potential cause of infertility (n = 6)
  1) | Complications
  2) | Pregnancy rates, by group and prior pregnancy, and by age, size, and number of fibroids
  3) | Pregnancy outcomes
  4) | Need for subsequent treatment
  1) | Complications: Reoperation: 1/50 (bowel obstruction) Transfusion: 9/50 (18%) Fever: 14/50 (28%) UTI: 8/50 (16%)
  2) | Pregnancy rates: Overall: 25/50 (50%) By group and prior pregnancy:
    | A | B | C | D
    Nulligravid | 10/14 | 4/9 | - | 1/6
    Multigravid | 5/8 | 4/10 | 1/3 | -
  | Pregnancy rate decreased in women over 30. Women unable to conceive after 30 more likely to have fibroids > 200 g, 4 or more fibroids (no statistical testing).
  3) | Pregnancy outcomes: Overall viable pregnancies: 20/25 (80%) By group and prior pregnancy:
    | A | B | C | D
    Nulligravid | 13/15 | 3/4 | - | 1/1\|
    Multigravid | 4/5 | 2/4 | 1/1 | -
  4) | Need for subsequent treatment: Hysterectomy: 4/50 (3 for recurrent fibroids) Laparoscopy: 4/50 (unable to conceive; adhesions noted)
Bernard, Darai, Poncelet, et al., 2000 | Design: Case series, no controls Intervention(s): Hysteroscopic myomectomy (n = 31) Dates: Jul 1994-Jun 1997 Location: Paris, France Length of followup: > 12 months | No. of subjects at start: 31 Dropouts: N/A Loss to followup: 0 No. of subjects at end: 31 Setting: N/S Inclusion criteria: Patients with infertility and submucous myomas (> 50% of myoma protruded into endometrial cavity) who underwent hysteroscopic myomectomy Exclusion criteria: None specified Age: Mean, 35; range, 22-40 Race: N/S Parity: 29% nulliparous Baseline uterine size: N/S Baseline fibroid size: Mean largest, 20 mm (10-50 mm) Number of fibroids: 71% of patients had 1 fibroid; 16% had 2; 10% had 3; and 3% had 4 Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: + N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: + Note: 48% ofpatients underwent concurrent tubal surgery, which likely confounds pregnancyrate results.
  1) | Pregnancy rate
  2) | Length of stay
  3) | Rate of repeat hysteroscopic myomectomy (due to incomplete resection or complication)
  4) | Complications
  1) | Pregnancy rate: 35.5%
  2) | Length of stay (mean): 36 hours
  3) | Rate of repeat hysteroscopic myomectomy: 6.5%
  4) | Complications: Uterine perforation: 3.3% Hemorrhage (no transfusion): 3.3%
Brooks, Loffer, and Serden, 1989 | Design: Case series, no controls Intervention(s): Hysteroscopic resection of fibroids (n = 62, 5 with concomitant endometrial ablation) Dates: N/S Location: Los Angeles, CA Length of followup: Minimum of 3 months | No. of subjects at start: 62 Dropouts: N/A Loss to followup: N/S No. of subjects at end: N/S Setting: Ambulatory surgery facility; outpatient clinic/physician office Inclusion criteria: Abnormal uterine bleeding or infertility; prior office hysteroscopy; "refused or poor risk for hysterectomy or myomectomy" Exclusion criteria: None specified Age: Mean, N/S; range, 30-49 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: − F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Relief of menorrhagia
  2) | Pregnancy rate
  1) | Relief of menorrhagia: 46/57 "improved" 4/57 "not improved"
  2) | Pregnancy rate: 4/13
Brown, Fletcher, Myrie, et al., 1999 | Design: Case series with concurrent controls Intervention(s): Dates: N/S Location: Kingston, Jamaica Length of followup: N/A (in-hospital outcomes only) | No. of subjects at start: 32 Dropouts: N/A Loss to followup: N/A No. of subjects at end: 32 Setting: Hospital Inclusion criteria: N/S Exclusion criteria: N/S Age (means): 33.4±3.6 (cesarean myomectomy), 24.6±6.5 (cesarean only) (P < 0.0001) Race: N/S Parity: Myomectomy: 7 pts with 1 pregnancy 7 pts with 2 pregnancies 2 pts with > 3 pregnancies No myomectomy 4 pts with 1 pregnancy 6 pts with 2 pregnancies 6 pts with > 3 pregnancies Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: Median, 2 (range, 1-6) Baseline Hgb: Myomectomy: Mean Hgb 11.7±1.1 No myomectomy: Mean Hgb 11.4±1.2 Baseline Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: + N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: − S) Standardized measures: +
  1) | Myomectomy at time of cesarean section (n = 16)
  2) | Cesarean section without myomectomy (in patients without fibroids) (control) (n = 16)
  1) | Blood loss
  2) | Transfusions
  3) | Febrile morbidity
  4) | Length of stay
  1) | Blood loss: Myomectomy: Mean change in Hgb −1.64±1.7 No myomectomy: Mean change in Hgb 1.4±1.3 Not significant
  2) | Transfusions: Myomectomy 1 No myomectomy 1
  3) | Febrile morbidity (mean highest temperature [°F]): Myomectomy: 100.5 (range 98-104) No myomectomy: 100.4 (range 100-102.6) Not significant
  4) | Length of stay: Myomectomy: Median, 3 (range 2-7) No myomectomy: Median, 4 (range 3-5) Not significant
Candiani, Fedele, Parazzini, et al., 1991 | Design: Case series, no controls Intervention(s): Abdominal myomectomy Dates: Jan 1970-Dec 1984 Location: Milan, Italy Length of followup: Median 102 months | No. of subjects at start: 622 Dropouts: N/A Loss to followup: 120 (19%) No. of subjects at end: 502 Setting: University hospital Inclusion criteria: Myomectomy for at least one fibroid greater than 5 cm Exclusion criteria: None specified Age: Mean 33, range 22-44 Race: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Drop-out rates: N/A G) Statistical issues: + EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: + N) Location of fibroids: + O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: − Note: Anatomic vs symptomatic recurrence not described separately.
  Parity: | 0: 72%
  Parity: | 1: 19%
  Parity: | 2: 4%
  Parity: | > 3: 2%
  Number of fibroids: | 1: 50%
  Number of fibroids: | 2: 16%
  Number of fibroids: | 3: 11%
  Number of fibroids: | > 4: 23%
  1) | Recurrence (defined as symptoms or change on pelvic exam, confirmed by ultrasound)
  2) | Predictors of recurrence
  1) | Recurrence: 10-year cumulative risk 27%
  2) | Predictors of recurrence: Multivariate Fibroid location not associated with risk of recurrence
    Age | OR | 95% CI
    < 30 | 1 | Reference
    > 30 | 1.0 | 0.8-1.1
    No. pregnancies before surgery
    0 | 1 | Reference
    > 1 | 1.0 | 0.8-1.2
    No. fibroids removed
    1 | 1 | Reference
    2-3 | 1.2 | 0.9-1.5
    > 4 | 2.1 | 1.7-2.8
    No. pregnancies after surgery
    0 | 1 | Reference
    > 1 | 0.6 | 0.4-0.9
Carlson, Miller, and Fowler, 1994 | Design: Prospective cohort study Intervention(s): Hysterectomy (n = 418) (39% for fibroids); 73% abdominal, 37% vaginal Dates: Jun 1989-Jan 1991 Location: Maine (multiple sites) Length of followup: 12 months | No. of subjects at start: 418 Dropouts: N/A Loss to followup: 13 No. of subjects at end: 405 (355 completed data for all time points) Setting: Hospitals Inclusion criteria: Age 25-50; planned hysterectomy for nonmalignant condition or carcinoma in situ; access to telephone Exclusion criteria: No access to telephone Age: 25-34, 25%; 35-44, 47%; 45-50, 33% Race: 98% White Parity: N/S Baseline uterine size: 49% > 12 weeks Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: 21% with Hgb < 10 or Hct < 32% | (Results not stratified by indication) | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: N/A G) Statistical issues: + EXTERNAL VALIDITY H) Age: + I) Race: + J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: − S) Standardized measures: + Note: Results not stratified by operative indication; datafor patients with fibroids not reported separately.
  1) | Complications
  2) | Change in symptoms
  3) | Change in QoL, as measured by Mental Health and General Health Index scores
  4) | Development of new problems
  1) | Complications in 3 months after surgery: During hospitalization: 7% Readmission: 3% Nonroutine MD contacts: 48%
  2) | Change in symptoms (% reporting symptom "very often" in past month):
    | Before surgery | 12 mos postop
    Pelvic pain | 56% | 3%
    Back pain | 34% | 8%
    Dyspareunia | 32% | 5%
    Abd swelling | 42% | 11%
    Urinary frequency | 32% | 8%
    Incontinence | 20% | 6%
    Fatigue | 47% | 9%
    Depression | 21% | 6%
    Anxiety | 19% | 6%
    Decreased interest in sex | 18% | 5%
    Decreased enjoyment of sex | 20% | 5%
  All changes significant, p < 0.001
  3) | Changes in QoL scores by preop severity of symptoms:
    | Before | 12 months
    Mental Health
    None | 79 | 82
    Mild | 69 | 78*
    Moderate | 61 | 74*
    Severe | 55 | 73*
    *p < 0.001
    General Health
    None | 79 | 86+
    Mild | 64 | 82*
    Moderate | 57 | 81*
    Severe | 42 | 75*
    +p < 0.05, *p < 0.001
    Activity
    None | 81 | 88
    Mild | 62 | 85*
    Moderate | 55 | 82*
    Severe | 42 | 77*
    *p < 0.001
  3) | New problems 12 months after surgery: Weight gain: 12% Hot flashes: 13% Depression: 8% Anxiety: 6% Diminished sexual interest: 7%
Carter and McCarus, 1997 | Design: Case series, concomitant controls Intervention(s): Laparoscopic myomectomy with: All patients treated with GnRH agonist preoperatively for 3 months Vasopressin used intra-operatively Dates: Jan 1995-Mar 1996 Location: Mission Viejo, CA and Blue Island, IL Length of followup: 6 months | No. of subjects at start: 28 (assuming no loss to followup) Dropouts: N/A Loss to followup: N/S No. of subjects at end: 28 Setting: N/S Inclusion criteria: N/S, except that procedures performed as part of the surgical management of menorrhagia and pelvic pain Exclusion criteria: N/S Age: Mean, 39; range, 30-49 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: Mean, 152 g (range, 30-410) (manual morcellation group); 160 g (20-475) (power morcellation group) Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: + E) Loss to followup: − F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: − S) Standardized measures: − Notes: Procedures performed by 2 different surgeons at 2 different centers. Unclear if all of one procedure performed by one surgeon or if both procedures performed by both surgeons. Method/scale for assessing satisfaction with uterine bleeding or pain not described.
  1) | Manual morcellation (n = 14)
  2) | Power morcellation (n = 14)
  1) | Abnormal uterine bleeding
  2) | Pelvic pain
  3) | Length of stay
  4) | Estimated blood loss
  1) | Abnormal uterine bleeding: At 6 months postoperation, "all patients satisfied with current bleeding pattern" (no other details given)
  2) | Pelvic pain: At 6 months postoperation, "80% of patients whose chief complaint was pain were satisfied with their current level of pain" (no other details given)
  3) | Length of stay: Laparoscopic myomectomy with: Power morcellation 24 hr Manual morcellation 36 hr P < 0.01
  4) | Estimated blood loss: Laparoscopic myomectomy with: Power morcellation 165 ml Manual morcellation 200 ml P < 0.01
Chapman, 1998 | Design: Case series, no controls Intervention(s): LITT, 293 patients with KTP/YAG laser via laparoscope or hysteroscope, and 7 with diode laser, 5 treated percutaneously All pretreated with GnRH agonist (6 weeks to 3 months) Dates: N/S Location: London, UK Length of followup: 6 months-6 years | No. of subjects at start: 300 Dropouts: N/S Loss to followup: N/S No. of subjects at end: N/S Setting: Hospital Inclusion criteria: ? Exclusion criteria: ? Age: Range, 23-60; "most" 40-50 Race: N/S; 30% English; 50% from Africa and the Indian subcontinent Parity: 20% nulliparous Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: + E) Loss to followup: − F) Dropout rates: − G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: + J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Symptom relief
  2) | Need for subsequent therapy
  1) | Symptom relief: Menorrhagia or other bleeding problems: preoperative: 276/300 postoperative: 30/276 (89.1%) without symptoms Pelvic pain or dysmenorrhea: preoperative: 156/300 postoperative: 24/156 (84.7%) without symptoms Dyspareunia: preoperative: 12/300 postoperative: 0/12 (100%) without symptoms Urinary frequency: preoperative: 24/300 postoperative: 0/24 without symptoms
  2) | Need for subsequent therapy: Additional LITT: 27/276 (10%) Hysterectomy: 6/300 (2%)
Coppen, Bishop, Beard, et al., 1981 | Design: RCT, method of randomization not described Intervention(s): Dates: N/S Location: Surrey, England Length of followup: 1-3 years | No. of subjects at start: 62 Dropouts: N/S Loss to followup: N/S No. of subjects at end: N/S Setting: Hospital Inclusion criteria: Premenopausal; surgery performed for menorrhagia or fibroids in all but 2 subjects Exclusion criteria: None specified Age: Mean, 41.7 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: − C) Pt selection criteria: − D) Length of followup: + E) Loss to followup: − F) Dropout rates: − G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: − S) Standardized measures: + Notes: Intention-to-treat analysis not performed (6 estrone pts not analyzed based on compliance). Dropout rate in years 2, 3 limits power. Sample size issues not addressed.
  1) | Estrone after hysterectomy (n = 23)
  2) | Placebo after hysterectomy (n = 25)
  3) | No treatment after hysterectomy (n = 14)
  1) | GHQ (used to identify patients with "non-psychotic psychiatric illness")
  2) | BDI
  3) | Validity scale of Marke Nyman temperament scale, measure of "energy available for psychological activity"
  4) | Frequency of intercourse
  5) | Frequency of orgasm
  6) | Headaches
  7) | Hot flashes
  1) | Mean GHQ:
    | Baseline | 1yr | 2yr | 3yr
    Estrone | 30.5 | 27.5 | 23.5* | 26.2
    Placebo | 28.9 | 22.4* | 18.4 | 21.1
    No treatment | | 30.0 | 26.5
    *p < 0.005 compared to baseline
  2) | Mean BDI:
    | Baseline | 1yr | 2yr | 3yr
    Estrone | 8.9 | 4.4* | 3.4* | 6.5*
    Placebo | 6.1 | 3.0* | 2.1* | 1.9
    No treatment | | 6.6 | 7.4*
    *p < 0.01 compared to baseline
  3) | Validity score (treatment groups only):
    | Baseline | 1yr
    Estrone + | 9.3 | 10.4*
    Placebo
    *p < 0.025
  4) | Mean frequency of intercourse per 6 weeks:
    | Baseline | 1yr | 2yr | 3yr
    Estrone | 3.5 | 3.8 | 4.3 | 5.8
    Placebo | 4.7 | 6.2 | 6.4 | 6.0
  5) | Frequency of orgasm: "No change"
  6) | Headaches: "No change in frequency"
  7) | % reporting > 1 hot flashes per day (both groups):
    Baseline | 1yr | 2yr | 3yr
    4% | 2% | 17% | 8%
Corson and Brooks, 1991 | Design: Case series, no controls Intervention(s): Hysteroscopic myomectomy (n = 92) In patients with myoma > 4 cm, danazol 600-900 mg per day or depot leuprolide 7.5 mg every month x 10-12 weeks given preoperatively (number so treated not reported); 15% of patients also treated with endometrial ablation Dates: Sep 1986-Dec 1989 Location: Philadelphia, PA and Los Angeles, CA Length of followup: Mean, 17 months; minimum, 8 months | No. of subjects at start: 92 Dropouts: N/A Loss to followup: 1 No. of subjects at end: 91 Setting: Hospital Inclusion criteria: Consecutive patients undergoing hysteroscopic myomectomy for menorrhagia (80%), dysmenorrhea (28%), or recurrent pregnancy loss (6%) Exclusion criteria: None specified Age: Mean, 40.1; range, 25-66 Race: N/S Parity: 0.8 Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: + L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Menorrhagia
  2) | Dysmenorrhea
  3) | Pregnancy rate
  4) | Complications
  5) | Additional surgery required
  1) | Menorrhagia:
  1) | Treatment success | 81%
  1) | Failure | 19%
  2) | Dysmenorrhea:
  2) | Treatment success | 85%
  2) | Failure | 15%
  3) | Pregnancy rate:
  3) | Fecundity rate | 0.08
  3) | Pregnancy rate "of couples who attempted conception" | 76%
  4) | Complications:
  4) | Transfusions | 1.1%
  4) | Uterine perforation | 3.2%
  4) | Fever | 1.1%
  4) | Bowel injury | 0%
  4) | Cardiovascular/pulmonary | 0%
  5) | Additional surgery required:
  5) | Overall | 17.3%
  5) | Repeat hysteroscopic myomectomy | 7.6%
  5) | Abdominal myomectomy | 2.1%
  5) | Hysterectomy | 3.2%
  5) | Endometrial ablation | 4.3%
Cravello, D'Ercole, Boubli, et al., 1995 Subset of patients with menstrual irregularities (n = 196) followed up in Cravello, Farnarier, De Montgolfier, et al., 1999 | Design: Case series (retrospective), no controls Intervention(s): Hysteroscopic myomectomy (n = 239); 19 patients underwent concurrent endometrial ablation (n = 19); 39 patients were Pretreated with GnRH agonists Dates: Oct 1987-Dec 1992 Location: Marseilles, France Length of followup: 2.5 years (range, 0.5-5.6 years) | No. of subjects at start: 239 Dropouts: N/A Loss to followup: 18 No. of subjects at end: 221 Setting: Hospital Inclusion criteria: Consecutive women with one or more submucous fibroids who underwent surgical hysteroscopy Exclusion criteria: None specified Age: Mean, 45.1; range, 25.3-67.7 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size (diameter): Mean, 2.32 cm; range, 0.5-6 cm Number of fibroids: 85% of patients had 1 fibroid, 10% had 2, and 5% had 3 Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: N/A G) Statistical issues: N/A EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: + N) Location of fibroids: + O) Measurement timing: − P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Complications
  2) | Pregnancy rate
  3) | Postmenopausal bleeding
  4) | Abnormal uterine bleeding (Premenopausal)
  5) | Length of stay
  6) | O/R time
  7) | Rate of repeat hysteroscopic myomectomy
  1) | Complications:
  1) | Transfusions: | 0%
  1) | Uterine perforation: | 2.3%
  1) | Electrolyte disturbance: | 1.8%
  2) | Pregnancy rate (among patients who desired pregnancy, n = 16): 25%
  3) | Postmenopausal bleeding (n = 27):
  3) | Lost to followup: | 4%
  3) | Success: | 89%
  3) | Failure: | 7%
  3) | Success = "patient satisfied and could lead normal life"
  4) | Abnormal uterine bleeding (n = 196):
  4) | Lost to followup: | 8%
  4) | Success*: | 81%
  4) | Failure: | 11%
  4) | Success = "patient satisfied and could lead normal life"
  5) | Length of stay: Mean, 2.5 days; range, 1-9 days
  6) | O/R time: Mean, 41.5 min; range, 11-85 min
  7) | Rate of repeat myomectomy: 16%
Cravello, Farnarier, De Montgolfier, et al., 1999 Followup of subset of patients from Cravello, D'Ercole, Boubli, et al., 1995 | Design: Cohort study Intervention(s): Hysteroscopic myomectomy (n = 196) Dates: Oct 1987-Dec 1992 Location: Marseilles, France Length of followup: Mean, 73 months; range, 50-104 | No. of subjects at start: 196 Dropouts: N/A Loss to followup: 26 No. of subjects at end: 170 Setting: Hospital Inclusion criteria: Submucous fibroids; abnormal uterine bleeding Exclusion criteria: None specified Age: N/S Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | Results reported at followup (mean, 73 months). | INTERNAL VALIDITY A) Random − B) Methods and blinding: − C) Pt selection criteria: − D) Length of followup: + E) Loss to followup: + F) Dropout rates: N/A G) Statistical issues: + EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: − S) Standardized measures: −
  1) | Symptomatic improvement
  2) | Need for repeat hysteroscopic procedure
  3) | Need for hysterectomy
  4) | Recurrent bleeding
  1) | Symptomatic improvement: 134/196 patients (68%)
  2) | Need for repeat hysteroscopic procedure: 26 patients (15 with resections of fibroids and 11 for endometrial ablation)
  3) | Need for hysterectomy: 25 patients (13%)
  4) | Recurrent bleeding: 10 patients (5%)
Daniell, 1995 | Design: Case series, no controls Intervention(s): Laparoscopic myomectomy with argon beam coagulator (n = 32); 28/32 patients received preoperative GnRH agonists; 10/32 received intramyoma vasopressin Dates: May 1991-Jan 1994 Location: Nashville, TN Length of followup: Range, 6-36 months | No. of subjects at start: 32 Dropouts: N/A Loss to followup: 2 No. of subjects at end: 30 Setting: Hospital Inclusion criteria: Consecutive women who underwent laparoscopic myomectomy with argon beam coagulator Exclusion criteria: None specified Age: N/S Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: Median, 8 cm in diameter; range, 3-8 cm Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: + E) Loss to followup: + F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: − I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Abnormal uterine bleeding
  2) | Dysmenorrhea
  3) | Pelvic pain
  4) | Pregnancy rate
  5) | Estimated blood loss
  6) | Operating time
  7) | Hospital days
  1) | Abnormal uterine bleeding (n = 10): Complete or partial relief: 100%
  2) | Dysmenorrhea (n = 20): Complete relief: 40% Partial relief: 60%
  3) | Pelvic pain (n = 7): Complete relief: 29% Partial relief: 57% No relief: 14%
  4) | Pregnancy rate (for infertility patients, n = 12): 0%
  5) | Estimated blood loss: Mean, 28 ml (range, 10-100)
  6) | O/R time: Mean, 83 min (range, 55-110)
  7) | Hospital days: All less than 24 hrs
Daraï, Dechaud, Benifla, et al., 1997 | Design: Case series (retrospective), no controls Intervention(s): Laparoscopic myomectomy (n = 143) Dates: Jan 1990-Oct 1995 Location: Paris, France Length of followup: > 12 months | No. of subjects at start: 143 Dropouts: N/A Loss to followup: N/A (only patients with followup period of > 12 months included) No. of subjects at end: 143 Setting: N/S Inclusion criteria: Consecutive patients who underwent laparoscopic myomectomy with > 12 months followup Exclusion criteria: None specified Age: Mean, 38.3; range, 24-55 Race: 58% White; 38.5% Black; 3.5% Asian Parity: 68% nulliparous Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: + E) Loss to followup: N/A F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: + J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: + N) Location of fibroids: + O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Conversion to laparotomy
  2) | Pregnancy rate
  3) | Delivery rate
  4) | Pregnancy complications
  5) | Transfusion rate
  6) | Number of myomas removed
  7) | Size of largest fibroid removed
  8) | O/R time
  9) | Blood loss
  10) | Length of stay
  1) | Conversion to laparotomy: "Laparoscopically assisted myomectomy" (Pfannenstiel incision < 5 cm): 15/143 (10.5%) "Gasless laparoscopy": 5/143 (3.5%) Both of the above considered under the heading "laparoscopy" by authors. Laparoconversion: 41/143 (28.7%)
  2) | Pregnancy rate: Overall (n = 70): 32% Laparoscopy (n = 44): 39% Laparoconversion (n = 26): 23%
  3) | Delivery rate: Overall (n = 70): 17% Laparoscopy (n = 44): 25% Laparoconversion (n = 26): 4%
  4) | Pregnancy complications (n = 70): Preterm delivery: 1.4% Uterine rupture: 0%
  5) | Transfusion rate (n = 143): 1.4%
  6) | Number of myomas removed (mean, with range): Laparoscopy (n = 102): 1.5 (14) Laparoconversion (n = 41): 3.0 (1-15) (P = 0.045)
  7) | Size of largest fibroid removed (mean diameter): Laparoscopy (n = 102): 54 mm Laparoconversion (n = 41): 75 mm (P = 0.001)
  8) | O/R time (mean, with range): Laparoscopy (n = 102): 37 min (30-370) Laparoconversion (n = 41): 153 min (70-210) (P = not significant)
  9) | Blood loss (g/100 ml): Laparoscopy (n = 102): 1.9 Laparoconversion (n = 41): 2.2 (P = not significant)
  10) | Length of stay (mean): Laparoscopy (n = 102): 3.5 days Laparoconversion (n = 41): 5.8 days (P = 0.0001)
Davies, Hart, and Magos, 1999 | Design: Case series (prospective), no controls Intervention(s): Myomectomy via vaginal approach (n = 35); 8.6% prior c-section, 11.4% prior pelvic surgery 71.4% pretreated with GnRH Dates: N/S Location: London, UK Length of followup: N/S (mean interval of 3 months to "first followup visit") | No. of subjects at start: 35 Dropouts: N/A Loss to followup: 4 No. of subjects at end: 31 Setting: Hospital Inclusion criteria: Uterus < 16 weeks in size; good uterine mobility; adequate vaginal access; intramural or subserosal fibroids; no adnexal pathology Exclusion criteria: None specified Age: Mean, 37; range, 28-49 Race: N/S Parity: 65.7% nulliparous Baseline uterine size: Mean, 9 weeks (range, 6-16) Baseline fibroid size: Mean, 5.2 cm Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: + L) Fibroid/uterine size: + M) Number of fibroids: + N) Location of fibroids: + O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: − Note: Sample size issues not discussed; IRB issues discussed ("not required for this surgical study because it did not involve randomization or the use of novel equipment").
  1) | Conversion to laparotomy
  2) | Number of fibroids removed
  3) | Weight of fibroids removed
  4) | EBL
  5) | O/R time
  6) | Length of stay
  7) | Complications
  8) | Symptom relief
  9) | Pregnancy rate
  1) | Conversion to laparotomy: 3/35 (8.6%) required laparotomy
  2) | Number of fibroids removed: Mean, 2.5 (95% CI, 1.7-3.4)
  3) | Weight of fibroids removed: Mean, 113.8 g (95% CI, 84.2-143.44)
  4) | EBL: Mean, 313.6 ml (95% CI, 206.1-421.1)
  5) | O/R time: Mean, 77.9 min (95% CI, 65.9-89.9)
  6) | Length of stay: Mean, 3.9 days (95% CI, 3.1-4.7)
  7) | Complications: Transfusions: 4/35 (11.4%) Hematoma: 4/35 (11.4%) UTI : 4/35 (11.4%) Reoperation: 1/35 (suturing of colpotomy site) Readmission: 2/35 (5.7%), both with infection
  8) | Symptom relief (n = 31): Menorrhagia: 15/21 improved Pelvic pain: 6/7 improved Pressure/urinary frequency: 2/2 improved
  9) | Pregnancy rate (n = N/S): 3 patients became pregnant after surgery, all term deliveries (number attempting pregnancy not reported)
De Blok, Dijkman, and Hemrika, 1996 | Design: Case series with concomitant controls Intervention(s): Hysteroscopic myomectomy after 8 weeks of 3.75 mg leuprolide (n = 109) No intervention (n = 54) Dates: 1990-1992 Location: Amsterdam, the Netherlands Length of followup: Mean, 2.8 years; range, 18-50 months | No. of subjects at start: 109 (results not reported for no-intervention group) Dropouts: 0 Loss to followup: 2 No. of subjects at end: 107 Setting: Hospital Inclusion criteria: Abnormal uterine bleeding, with submucous fibroids as only identifiable cause Exclusion criteria: Uterine length > 12 cm; fibroid > 6 cm in diameter Age: Mean, 40; range, 29-55 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: Range, 3.5-7 cm in diameter Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: + O) Measurement timing: + P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: +
  1) | Number of procedures, by stage
  2) | Hysteroscopic findings at 3-6 months
  3) | Symptomatic relief
  4) | Need for additional surgery
  1) | Number of procedures, by stage: Stage 0 (pedunculated) Stage I (< 50% intramural) Stage II (> 50% intramural)
    No. of procedures | Stage
    No. of procedures | 0 | I | II
    1 | 49 | 34 | 8
    2 | 2 | 10 | 4
    3 | - | 2 | -
    (p < 0.001)
  2) | Hysteroscopic findings: 85 normal cavity 8 necrotic fibroid 2 lost to followup 8 refused hysteroscopy
  3) | Symptomatic relief: 101/109 (93%) obtained relief from abnormal bleeding
  4) | Need for hysterectomy: 6 patients 2 with sarcomatous change 4 cases for "personal reasons desiring complete amenorrhea"
De Lia, Michelin, Johnson, et al., 1995 | Design: Case series, concomitant controls Intervention(s): Abdominal hysterectomy through a Cherney incision (n = 18 cases) or through a vertical midline incision (n = 19 controls) Abdominal myomectomy through a Cherney incision (n = 2 cases) or through a vertical midline incision (n = 1 control) Dates: Sep 1991-Aug 1993 Location: Milwaukee, WI Length of followup: N/A (in-hospital outcomes only) | No. of subjects at start: 40 (20 cases, 20 controls) Dropouts: N/A Loss to followup: N/A No. of subjects at end: 40 Setting: Hospital Inclusion criteria: Symptomatic uterine fibroids > 350 g Exclusion criteria: None specified Age: Mean, 43.3 Race: N/S Parity: 1.5±1.8 (Cherney group); 2.2±2.3 (vertical midline group) Baseline uterine size: 948±449 g (Cherney group); 908±415 g (vertical midline group) Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb: N/S Baseline Hct: 35.4±5.0% (Cherney group); 35.4±4.0% (vertical midline group) | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: − Q) Measurement reliability: + R) Clinical care: − S) Standardized measures: − Note: Unable to separate results of hysterectomy from results of myomectomy. Outcomes stratified only by incision type.
  1) | Uterine weight
  2) | Length of stay
  3) | Complications
  4) | Estimated blood loss
  5) | O/R time
  | | Cherney | Vertical
  1) | Uterine weight (g): | 948±449 | 908±415
  1) | (P = not significant)
  2) | Length of stay (days): | 4.5±1.9 | 4.9±1.5
  2) | (P = not significant)
  3) | Complications:
  Transfusion: | | 10% | 30%
  Immediate reoperation: | | 5% | 0%
  Wound infection: | | 0% | 10%
  Superficial wound separation: | | 20% | 5%
  Cystotomy: | | 5% | 0%
  Cystitis: | | 15% | 20%
  Ileus: | | 5% | 15%
  Hematoma: | | 5% | 5%
  (P-values not reported)
  4) | EBL (ml): | 430±233 | 480±546
  5) | O/R time (minutes): | 140±19 | 129±42
Dequesne and Schmidt, 1996 | Design: Case series, no controls Intervention(s): Hysteroscopic myomectomy; some patients also received GnRH agonists, but details not provided Dates: N/S Location: Lausanne, Switzerland Length of followup: 22 months | No. of subjects at start: "Over 300" Dropouts: N/A Loss to followup: N/S No. of subjects at end: N/S Setting: Hospital Inclusion criteria: Abnormal bleeding or infertility Exclusion criteria: None specified Age: N/S Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random − B) Methods and blinding: − C) Pt selection criteria − D) Length of followup: + E) Loss to followup: − F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: − I) Race: − J) Pregnancy history: − K) Surgical history: + L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: + O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: − S) Standardized measures: −
  1) | Adverse effects
  2) | 12-month followup results
  3) | 22-month followup results
  1) | Adverse effects: In more than 300 laser hysteroscopic myomectomies, there was one case of hypernatremia, 2 cases of fluid overload, and 2 cases of postoperative endometritis
  2) | 12-month followup results: In a 12-month followup of a subset of 73 patients, 20 patients with type 1 (pedundulated myomas) reported a 100% good result, 27 patients with type 2 (submucous) fibroids reported 95% good results, and 26 patients with type 3 (small intramural) myomas reported 80% good results
  3) | 22-month followup results: In a 22-month followup, 169 patients with types 1 and 2 myomas were classified as 95% with good results, 71 patients with type 3 were assessed as having 91% good results, and 45 infertility patients were considered 68% successful (of these, 31 term pregnancies and 3 SABs resulted).
Derman, Rehnstrom, and Neuwirth, 1991 | Design: Case series (retrospective), no controls Intervention(s): Hysteroscopic resection of submucous fibroids (n = 108) Dates: Nov 1973-Nov 1988 Location: New York, NY Length of followup: 1-16 years | No. of subjects at start: 108 Dropouts: N/A Loss to followup: 14 No. of subjects at end: 94 Setting: Hospital Inclusion criteria: Uterus sounding < 10 cm; fibroids < 3 cc; benign endometrium Exclusion criteria: None specified Age: Mean, 36.6; range, 26-50 Race: N/S Parity: N/S Baseline uterine size: All < 12 weeks Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: + O) Measurement timing: + P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: − Note: Multivariate survival analysis not performed.
  1) | Complications
  2) | Symptom relief
  3) | Need for subsequent surgery
  1) | Complications: Transfusions: 4/108 Need for laparotomy: 2/108 Adverse reaction to Hyskon: 0/108
  2) | Symptom relief: Recurrent bleeding: 20 /80 (25%)
  3) | Need for subsequent surgery: Overall: 15/108 7 repeat hysteroscopic procedures 7 hysterectomy 1 myomectomy Life-table analysis:
    F/U (yrs) in | N interval | Cumulative risk of surgery
    1 | 18 | 0.096
    2 | 12 | 0.131
    3 | 11 | 0.145
    4 | 22 | 0.161
    5 | 8 | 0.161
    6 | 4 | 0.161
    7 | 3 | 0.161
    8 | 5 | 0.161
    9 | 2 | 0.161
    10 | 2 | 0.161
    11 | 3 | 0.161
    12 | 2 | 0.371
    13 | 0 | 0.371
    14 | 1 | 0.371
    15 | 0 | 0.371
    16 | 1 | 0.371
Donnez, Gillerot, Bourgonjon, et al., 1990 | Design: Case series, no controls Intervention(s): Hysteroscopic myomectomy using Nd:YAG laser; pretreatment with GnRH (Zoladex® implants, dose not specified) (n = 60) Dates: N/S Location: Brussels, Belgium Length of followup: N/S | No. of subjects at start: 60 Dropouts: N/A Loss to followup: N/S No. of subjects at end: N/S Setting: University hospital Inclusion criteria: N/S Exclusion criteria: N/S Age: Mean, 34; range, 23-40 Race: N/S Parity: N/S Baseline uterine size: All with area of 10 sq cm on HSG preprocedure Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: − E) Loss to followup: − F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Reduction in uterine size
  2) | Complications
  3) | Symptomatic relief
  4) | Pregnancy rates
  1) | Reduction in uterine size: Mean decrease 36% by 8 weeks of GnRH therapy (p < 0.01)
  2) | Complications: None
  3) | Symptomatic relief: 100% "normal flow"
  4) | Pregnancy: 16/24 within 8 months (66%)
Dubuisson, Chapron, Chavet, et al., 1996 | Design: Case series (prospective), no controls Intervention(s): Laparoscopic myomectomy (n = 21) Dates: Oct 1990-Oct 1993 Location: Paris, France Length of followup: N/S | No. of subjects at start: 21 Dropouts: N/A Loss to followup: N/S No. of subjects at end: N/S Setting: Hospital Inclusion criteria: Intramural fibroids > 5 cm in diameter; infertility (12/21 patients had other potential causes of infertility) Exclusion criteria: Pedunculated fibroids Age: Mean, 37.4 Race: N/S Parity: Primary infertility, 38%; secondary infertility, 62% Baseline uterine size: N/S Baseline fibroid size: Mean N/S (but had to be > 5 cm in diameter) Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: − E) Loss to followup: − F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: + N) Location of fibroids: + O) Measurement timing: − P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: + S) Standardized measures: − Note: Sample size issues not addressed.
  1) | Operative time
  2) | Number of fibroids removed
  3) | Size of largest fibroid removed
  4) | Length of stay
  5) | Complications
  6) | Drop in hemoglobin
  7) | Pregnancy rate
  8) | Pregnancy outcome
  1) | Operative time: 133±64 minutes
  2) | Number of fibroids removed: 2.23±2.09 (range, 1-10)
  3) | Size of largest fibroid removed: 61.90±16.00 mm (range, 50-100)
  4) | Length of stay: 2.60±0.57 days
  5) | Complications: Transfusions: 0 Conversion to laparotomy: 0 Reoperation: 0 Fever: 1/21
  6) | Drop in hemoglobin: 1.4±1.1 g/100 ml (range, 0.0-3.8)
  7) | Pregnancy rate: Overall: 7/21 (33.3%), 3 after IVF By presence of other causes of infertility: Other cause present: 3/12 (25%) No other cause: 4/9 (44%) (Not significant) By distortion of uterine cavity: Cavity distorted: 5/9 (55.6%) Not distorted: 2/12 (16.7%) (No statistical testing reported)
  8) | Pregnancy outcome: Ectopics: 0 Uterine rupture: 0 c-section: 4/7 (all elective) Vaginal delivery: 1/7 2nd trimester loss: 2/7 (22 and 29 weeks)
Dubuisson, Chapron, and Levy, 1996 and Dubuisson, Chapron, and Fauconnier, 1997 | Design: Case series, no controls Intervention(s): Laparoscopic myomectomy (n = 213) (41.8% underwent additional procedures) Dates: Jan 1990-Jun 1995 Location: Paris, France Length of followup: N/S | No. of subjects at start: 213 (assuming no loss to followup) Dropouts: N/A Loss to followup: N/S No. of subjects at end: 213 Setting: University hospital Inclusion criteria: Indications for procedure: menometrorrhagia unresponsive to medical therapy (18.8%); pelvic pain (21.1%); "voluminous polymyomatous uterus" (31.9%); infertility (32.4%) Exclusion criteria: None specified Age: Mean, 37.5; range, 20-64 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: Mean size of largest fibroid, 5.3±2.2 cm in diameter (range, 1-12 cm) Number of fibroids: One: 49.3% Two: 21.6% Three: 13.6% Four or more: 15.5% Baseline Hgb/Hct: N/S | | Mean size of largest fibroid 7.1 cm in conversions vs. 5.1 in laparoscopic cases (p = 0.0001). Risk also increased with fibroid in anterior wall (statistical test results not given). | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: − E) Loss to followup: − F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: + N) Location of fibroids: + O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Operating time
  2) | Conversion to laparotomy
  3) | Complications
  4) | Pregnancy outcomes
  5) | Relationship between conversion or complications and baseline characteristics
  1) | Operating time: Mean, 130±56.1 min; range, 30-300 min
  2) | Conversion to laparotomy: 16/213 (7.5%), for following reasons: 9/16: difficulties closing uterine incision 5/16: intraoperative hemorrhage 1/16: hypercapnia 1/16: technical difficulty (adenomyosis)
  3) | Complications: Total: 3.8% 0 transfusions 1 hypercapnia 4 fevers > 38 C 1 hepatitis 1 thrombophlebitis
  4) | Pregnancy outcomes: 34 total pregnancies: 3 first trimester losses 1 late loss 1 intrauterine death 8 cesarean sections 19 vaginal deliveries 1 uterine rupture 1 not delivered at time of report
  5) | Relationship between baseline characteristics and conversion/complication:
Dubuisson, Fauconnier, Chapron, et al., 1998 | Design: Case series, no controls Intervention(s): Second-look laparoscopic myomectomy (n = 45) Dates: Oct 1990-Oct 1996 Location: Paris, France Length of followup: N/A (in-hospital outcomes only). Mean time since first surgery, 14 months (range, 0.6-49.4 months). | No. of subjects at start: 45 Dropouts: N/A Loss to followup: N/A No. of subjects at end: 45 Setting: Hospital Inclusion criteria: Myomectomy performed between Mar 31, 1989, and Aug 16, 1996 Exclusion criteria: None specified Age: Mean, 34; range, 24-50 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: 41±22 cc (before original surgery) Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: − Note: This is what appears to be a convenience sample with biases resulting due to reason for second look (i.e., persistent infertility or cesarian section). Also age group is younger than expected due to these reasons.
  1) | Pelvic adhesions
  2) | Bilateral adnexal adhesions
  1) | Pelvic adhesions: Overall: 35.6% Post L/S myomectomy alone: 26.9% Prior adhesions: 19.6% No prior adhesions: 11.5% Posterior myomectomy: 33.3% Anterior/fundal myomectomy: 4.8%
  2) | Bilateral adnexal adhesions: Overall: 11% Post L/S myomectomy alone: 0%
Dubuisson, Lecuru, Foulot, et al., 1991 Preliminary report on case series described in Dubuisson, Lecuru, Foulot, et al., 1992 | Design: Case series, no controls Intervention(s): Laparoscopic myomectomy (n = 43) Dates: Jan 1990-Mar 1991 Location: Paris, France Length of followup: N/A (in-hospital outcomes only) | No. of subjects at start: 43 Dropouts: N/A Loss to followup: N/A No. of subjects at end: 43 Setting: Hospital Inclusion criteria: Consecutive patients undergoing laparoscopic myomectomy Exclusion criteria: None specified Age: Mean, 35.8; range, 27-50 Race: N/S Parity: 74% nulliparous Baseline uterine size: N/S Baseline fibroid size: 38.9±19.3 mm (10-110 mm) (diameter) Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: + N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Fibroid diameter
  2) | Number of fibroids
  3) | Length of stay
  4) | Complications
  5) | Blood loss
  6) | Conversion to laparotomy
  1) | Fibroid diameter: 39.9±19.3 mm
  2) | Number of fibroids: 2.1
  3) | Length of stay: 2.8±1.2 days
  4) | Complications: Transfusion: 0% Injury to organ: 0%
  5) | Blood loss: Hgb decreased mean 0.69±.87g/dl
  6) | Conversion to laparotomy: 11.6%
Dubuisson, Lecuru, Foulot, et al., 1992 Preliminary report on this case series provided in Dubuisson, Lecuru, Foulot, et al., 1991 | Design: Case series, no controls Intervention(s): Laparoscopic myomectomy (n = 70) (46 of whom received leuprorelin acetate preoperatively) Dates: Jan 1990-Oct 1991 Location: Paris, France Length of followup: N/S | No. of subjects at start: 70 Dropouts: N/A Loss to followup: N/S No. of subjects at end: N/S Setting: Hospital Inclusion criteria: Laparoscopic myomectomy performed Exclusion criteria: Multiple or voluminous myomas Age: N/S Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: − E) Loss to followup: − F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: − I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: − Note: Retrospective descriptive study. There was no separation of patients treated with leuprorelin acetate in analysis. Twenty-four of 70 patients had additional procedures, making interpretation of the pregnancy data difficult.
  1) | Pregnancy rate for infertile patients
  2) | Pregnancy complications
  3) | Operative complications
  1) | Pregnancy rate for infertile patients (n = 21) (followup time unclear): 14%
  2) | Pregnancy complications: 33%
  3) | Operative complications: 0% Transfusion: 0%
Dueholm, Forman, and Ingerslev, 1998 | Design: Case series, no controls Intervention(s): Hysteroscopic myomectomy (n = 45). Followed by HSE at 2 weeks and 3 months. Repeat hysteroscopic myomectomy as needed. Dates: N/S Location: Aarhus, Denmark Length of followup: Minimum 3 months; later followup N/S | No. of subjects at start: 45 Dropouts: N/A Loss to followup: 0 No. of subjects at end: 45 Setting: University hospital Inclusion criteria: Submucous fibroids between 1.5 and 5 cm in diameter Exclusion criteria: None specified Age: N/S Race: N/S (likely 100% white) Parity: N/S Baseline uterine size: N/S Baseline fibroid size: Mean diameter, 3.2 cm (range, 1.5-5.0) Number of fibroids: 43 patients had 1 fibroid; 2 patients had "multiple" fibroids Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: + E) Loss to followup: + F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: − I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: + N) Location of fibroids: + O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: − S) Standardized measures: −
  1) | Residual fibroid tissue (measured by HSE)
  2) | Need for additional surgery
  3) | Complications
  4) | Relationship between preoperative size and response
  5) | Hysteroscopy after the 3-month HSE followup
  1) | Residual fibroid tissue: Complete resection at initial surgery: 7/45 no residual tissue
  2 weeks postoperative (n = 38 patients with residual tissue): 5/38 no residual tissue 3 months postop: 13/30 no residual tissue
  2) | Need for additional surgery: First 3 months: 3/38 (2 further resection of fibroids, 1 endometrial resection)
  After 3 months: 5/14 (4 re-resections, 1 hysterectomy)
  3) | Complications: 2 uterine perforations, no need for additional surgery
  4) | Relationship between preoperative size and response not statistically significant
  5) | Hysteroscopy (n = 18) consistent with HSE
Ecker, Foster, and Friedman, 1995 | Design: Case series with concomitant unrandomized controls Intervention(s): Abdominal hysterectomy (n=204) or abdominal myomectomy (n=109) Dates: July 1990-June 1991 Location: Boston, MA Length of followup: N/A (hospital-based outcomes) | No. of subjects at start: 313 Dropouts: N/A Loss to followup: N/A No. of subjects at end: 313 Setting: Teaching hospital Inclusion criteria: Admissions coded with fibroids as diagnosis and hysterectomy or myomectomy as procedures (n=697) Exclusion criteria: Age <15 or > 50 (n=89); hysterectomy or myomectomy not performed (n=61); procedure performed outside of time period (n=1); fibroids not diagnosed preoperatively or principal indication for procedure (n=91); procedures not limited to TAH±oophorectomy or myomectomy only (n=142) Age: Hysterectomy: 42.8±0.3 Myomectomy: 35.8±0.5 (p<0.0001) Race: N/S Parity: Hysterectomy 1.4±0.1 Myomectomy 0.3±0.1 (p<0.0001) Baseline uterine size: Hysterectomy 15.1±0.3 weeks Myomectomy 14.7±0.4 weeks Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: N/A E) Loss to followup: N/A F) Drop-out rates: N/A G) Statistical issues: + EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: + N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: − S) Standardized measures: − Note: Multivariate analysis not performed.
  1) | Duration of procedure
  2) | Estimated blood loss
  3) | Length of stay
  4) | Febrile morbidity
  5) | Blood transfusion
  6) | Other complications
  1) | Duration of procedure: Hysterectomy 114±3 minutes Myomectomy 111± 4 minutes (not significant)
  2) | Estimated blood loss: Hysterectomy: 438±24 ml Myomectomy: 315±25 ml (p<0.01)
  3) | Length of stay: Hysterectomy: 4.6±0.1 days Myomectomy: 4.3±0.1 days (not significant)
  4) | Febrile morbidity: Hysterectomy: 25% Myomectomy: 45% (p<0.001)
  5) | Blood transfusion: Autologous Hysterectomy 46.5% donated Myomectomy 60.5% donated (p<0.05) Hysterectomy: 22.1% transfused Myomecotmy: 29.4% transfuse (not significant) Homologous Hysterectomy 4.4% transfused Myomectomy 4.6% transfused (not significant)
  6) | Other complications: Hysterectomy 1 ileus 1 small bowel obstruction 2 hematomas 1 DVT 1 readmission Myomectomy 2 ileus 2 pelvic hematomas 1 subfascial hematoma ±1 DVT 1 readmission
Egwuatu, 1989 | Design: Case series (retrospective), historical controls Intervention(s): Dates: Jan 1980-Dec 1982 Location: Enugu, Nigeria Length of followup: 1-4 years | No. of subjects at start: 146 cases (141 myomectomy; 55 hysterectomy); 270 age- and parity-matched controls undergoing laparotomy for other benign gynecological conditions Dropouts: N/A Loss to followup: 46 myomectomy patients; N/S for hysterectomy patients No. of subjects at end: 95 myomectomy patients; N/S for hysterectomy patients Setting: Hospital Inclusion criteria: Admitted for myomectomy or hysterectomy for fibroids; controls (undergoing laparotomy for other benign conditions) matched for age and parity Exclusion criteria: None specified Age: Mean, 33.4; range, 20-55 Race: 100% Black Parity: 0.9±1.16 (myomectomy group); 4.8±2.8 (hysterectomy group) Baseline uterine size: 34% < 12 wks; 58% > 12 wks; 8% N/S Baseline fibroid size: N/S Number of fibroids: N/S (reported only as outcome measure) Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: + J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: + N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: − S) Standardized measures: −
  1) | Abdominal myomectomy (n = 141) or
  2) | Abdominal hysterectomy (n = 55)
  1) | Number of fibroids removed
  2) | Complications
  3) | Pregnancy rate
  4) | Need for subsequent surgery
  1) | Number of fibroids removed (myomectomy patients only, n = 141): Mean, 6 fibroids; range, 1-53
  2) | Complications:
    | Myo | Hyst
    Fever > 37.5° C: | 71.8% | N/S
    Hemorrhage: | 2.7% | N/S
    UTI: | 2.7% | 9.1%
    Ileus: | 1.0% | N/S
    Wound infection: | 10.9% | 5.5%
    Dehiscence: | 3.6% | N/S
    Hematoma: | 3.6% | N/S
    Bowel obstruction: | 2.7% | N/S
    Incisional hernia: | N/S | 1.8%
  3) | Pregnancy rate (reported only for myomectomy patients at followup, n = 95): 25 pregnant (unclear how many actively trying to conceive)
  4) | Need for subsequent surgery (n = 95 myomectomy patients at followup): Recurrence: 13/95 Repeat myomectomy: 10/95 Hysterectomy: 3/95
Eldar-Geva, Meagher, Healy, et al., 1998 | Design: Case series (retrospective), concomitant controls Intervention(s): Controlled ovarian hyper-stimulation, plus IVF or ICSI Dates: Jan 1995-May 1997 Location: Melbourne, Australia Length of followup: N/S | No. of subjects at start: 337 total (88 with fibroids [33 subserosal, 46 intramural, 9 submucosal]; 249 with normal uteri) Dropouts: N/A Loss to followup: N/S No. of subjects at end: N/S Setting: Hospital; outpatient clinic/physician office Inclusion criteria: Fibroids diagnosed by ultrasound (cases); undergoing assisted reproductive technology treatment Exclusion criteria: Previous myomectomy; other uterine anomalies Age: Mean, 35.4; range, 25-42 (fibroids patients) Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: Range, 6-51 mm Number of fibroids: Range, 1-7 Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: − E) Loss to followup: − F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: + N) Location of fibroids: + O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: + S) Standardized measures: + Note: No correction for multiple comparisons.
  1) | Pregnancy rate
  2) | Pregnancy outcome
  1) | Pregnancy rate: "Clinical pregnancies" per transfer: Control: 30.1% Subserosal: 34.1% Intramural (IML): 16.4%* Submucous: 10%* *p < 0.05 compared to control and subserosal Implantation rates per transfer: Control: 15.8% Subserosal: 15.7% Intramural (IML): 6.4%* Submucous: 4.3% *p < 0.005 compared to controls, p < 0.02 compared to subserosal
  2) | Pregnancy outcome:
    | Control (n = 98) | Subserosal (n = 14) | IML (n = 9)
    Liveborn
    Singleton | 48 | 9 | 6
    Twins | 27 | 2 | -
    Triplets | 3 | - | -
    Early abortion | 15 | 2 | 3
    Late abortion | 1 | - | -
    Ectopic | 4 | 1 | -
    Birth weight | 3275 g | 3062 g | 3065 g
Emanuel, Wamsteker, Hart, et al., 1999 | Design: Case series (prospective), no controls Intervention(s): Hysteroscopic myomectomy (n = 285) Dates: Aug 1987-Jan 1995 Location: Amsterdam, the Netherlands Length of followup: Median, 42 months; range, 16-104 months | No. of subjects at start: 285 Dropouts: 2 (diagnosis of fibroids not confirmed by pathologic examination: 1 leiomyosarcoma, and 1 cellular leiomyoma of dubious malignancy grade) Loss to followup: 17 No. of subjects at end: 266 Setting: Hospital Inclusion criteria: Consecutive patients with menorrhagia or metrorrhagia and > 1 submucous myoma Exclusion criteria: Malignancy Age: Mean, 38.1; range, 23-62 Race: N/S Parity: 0.78±1.06; range, 0-5 Baseline uterine size: 68% normal; 32% enlarged Baseline fibroid size: N/S Number of fibroids: At hysteroscopy, 1.63±1.73 (range, 1-15); at laparoscopy, 0.77±1.32 (range, 0-8) Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: + G) Statistical issues: + EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: + N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Pregnancy rate
  2) | Complications
  3) | Additional surgery required
  4) | Subsequent hysterectomy
  1) | Pregnancy rate: 46%
  2) | Complications: Transfusion: 0% Uterine perforation: 0.3% Pulmonary edema: 0.3%
  3) | Additional surgery required (cumulative rate; includes hysterectomy): @ 2 years postop: 9.5% @ 5 years postop: 20.5% @ 8 years postop: 26.7%
  4) | Subsequent hysterectomy (cumulative rate): @ 2 years postop: 5.1% @ 5 years postop: 10.8% @ 8 years postop: 10.8% Enlarged uterus, number of myomas, and incomplete resection of myoma independent predictors of subsequent surgery (p < 0.001)
Farhi, Ashkenazi, Feldberg, et al., 1995 | Design: Case series (retrospective), concomitant controls Intervention(s): IVF in 46 women with fibroids (cases), compared to 50 patients with tubal factor and normal uteri (controls) Dates: 1986-1992 Location: Tel Aviv, Israel Length of followup: N/S | No. of subjects at start: 96 (46 with fibroids; 50 controls) Dropouts: N/A Loss to followup: N/S No. of subjects at end: N/S Setting: Hospital; outpatient clinic/physician office Inclusion criteria: Infertile IVF patients. Fibroids group: Fibroids confirmed by at least 2 of the following: physical exam, hysterosalpingography, hysteroscopy, or vaginal pelvic ultrasonography; uterine size < 12 weeks. Control group: Pure tubal factor, normal uterus confirmed by physical exam, ultrasound, and hysteroscopy. Exclusion criteria: None specified Age: 34.0±4.5 (fibroids group); 33.5±4.1 (control group) Race: N/S Parity: Among fibroids patients, 63% had primary infertility; 37% secondary infertility. Parity of controls N/S. Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: − E) Loss to followup: − F) Dropout rates: N/A G) Statistical issues: + EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: + S) Standardized measures: + Note: Sample size discussed.
  1) | Pregnancy rate
  2) | Pregnancy outcome
  1) | Pregnancy rate: Overall: Fibroid patients: Per transfer: 31/140 (22.1%) Per embryo: 31/471 (6.5%) Control patients: Per transfer: 32/127 (25.1%) Per embryo: 35/357 (9.7%) (Differences not significant)
  Among fibroid patients, by status of uterine cavity on hysterosalpingography:
    Cavity | Per transfer | Per embryo
    Normal (n = 28) | 30% | 8.9%
    Abnormal (n = 18) | 2.7%** | 9%*
    (*p < 0.01; **p < 0.001)
  2) | Pregnancy outcome: Overall: Fibroid patients Ectopic: 1/30 1st trimester loss: 10/30 Multiple gestation: 1/30 (resulted in 2nd trimester loss) Term pregnancies: 18/30 Control patients: 1st and 2nd trimester loss: 8/32 (Not significant compared to fibroid patients) In fibroid patients by status of uterine cavity:
    Cavity | Deliveries | Loss
    Normal | 15/28 | 3/18
    Abnormal | 9/28 | 2/18
    (No statistical testing done)
Fedele, Parazzini, Luchini, et al., 1995 | Design: Case series, no controls Intervention(s): Abdominal myomectomy (n = 143) Dates: 1987-1991 Location: Milan, Italy Length of followup: Median, 49 months; range, 12-84 months | No. of subjects at start: 145 Dropouts: N/A Loss to followup: 23 No. of subjects at end: 122 Setting: Ambulatory surgery facility Inclusion criteria: Uterine fibroids, with at least 1 myoma > 5 cm; menorrhagia, pelvic pain, or recurrent miscarriage Exclusion criteria: None specified Age: Median, 38; range, 21-52 Race: 100% white Parity: 72% nulliparous Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S (reported only as outcome measure) Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: + J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: + N) Location of fibroids: + O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Number of fibroids removed
  2) | Pregnancy rate
  3) | Cumulative 5-year probability of fibroid recurrence (determined via ultrasound)
  1) | Number of fibroids removed: 1 fibroid, 40%; > 2 fibroids, 60%
  2) | Pregnancy rate: 27%
  3) | Cumulative 5-year probability of fibroid recurrence: 51% (% with symptoms or need for additional treatment not reported)
Fletcher, Frederick, Hardie, et al., 1996 | Design: RCT, randomization by odd/even numbers on slips drawn from box Intervention(s): Dates: Mar 1994-Feb 1995 Location: Kingston, Jamaica Length of followup: N/A (in-hospital outcomes only) | No. of subjects at start: 52 Dropouts: 0 Loss to followup: N/A No. of subjects at end: 52 Setting: Hospital Inclusion criteria: Age 24-45; uterus with leiomyomas > 10 wks size Exclusion criteria: Cardiovascular disease; contraindications to vasopressin Age: Mean, 34.2 Race: N/S Parity: % nulliparous: 81% (vasopressin group); 77% (tourniquet group) Baseline uterine size: 16.5±4.0 wks (vasopressin group); 16.6±3.8 wks (tourniquet group) Baseline fibroid size: 6.6±4.4 cc (vasopressin group); 9.4±6.1 cc (tourniquet group) (p = 0.06) Number of fibroids: N/S Baseline Hgb: 11.9±1.4 g/dl (vasopressin group); 12.2±1.1 g/dl (tourniquet group) Baseline Hct: N/S | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: + C) Pt selection criteria: + D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: − Note: Claims no baseline differences between two groups, but not enough power with confounders to determine this. There were possibly important differences in fibroid size and need to enter uterine cavity. Also underpowered to determine significance of difference in transfusion rates.
  1) | Myomectomy with vasopressin (n = 26)
  2) | Myomectomy with tourniquet (n = 26)
  1) | EBL (mean)
  2) | EBL > 1000 cc
  3) | Transfusion
  4) | Hemoglobin fall
  5) | postoperative fever
  6) | Ileus
  7) | WBC count
  1) | EBL: Vasopressin: 287.3±195 Tourniquet: 512.7±400 (p = 0.036)
  2) | EBL > 1000 cc: Vasopressin: 0% Tourniquet: 19% (p = 0.02)
  3) | Transfusion: Vasopressin: 4% Tourniquet: 19% (p = 0.19)
  4) | Hemoglobin fall: Vasopressin: 1.7±0.8 g/dl Tourniquet: 2.4±1.5 g/dl (p = 0.098)
  5) | postoperative fever: Vasopressin: 12% Tourniquet: 19% (p = not significant)
  6) | Ileus: Vasopressin: 4% Tourniquet: 0% (p = not significant)
  7) | WBC count (x10^9^/l): Vasopressin: 10.4±4.4 Tourniquet: 11.5±4.2
Frederick, Fletcher, Simeon, et al., 1994 | Design: RCT, randomization by odd/even numbers on slips drawn from box Intervention(s): Dates: N/S Location: Kingston, Jamaica Length of followup: N/A (in-hospital outcomes only) | No. of subjects at start: 20 Dropouts: 0 Loss to followup: N/A No. of subjects at end: 20 Setting: Hospital Inclusion criteria: > 14-week size leiomyomatous uterus Exclusion criteria: Contra-indications to vasopressin; cardiovascular disease; respiratory disease Age: Mean, 32; range, 24-40 Race: N/S Parity: Median, 0; range, 0-1 Baseline uterine size: Medians (with ranges): 17 wks (14-24) (vasopressin group); 18 wks (14-24) (placebo group) Baseline fibroid size (diameter): Medians (with ranges): 8.6 cm (5.3-14) (vasopressin group); 10 cm (6-12) (placebo group) Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: + C) Pt selection criteria: + D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: +
  1) | Myomectomy with vasopressin injected into the broad ligament and largest fibroid capsule (n = 10)
  2) | Myomectomy with placebo (n = 10)
  1) | EBL
  2) | Blood transfusion
  3) | Hct fall (pre- to post-treatment)
  4) | Hgb fall (pre- to post-treatment)
  5) | postop WBC count
  6) | postop fever
  1) | EBL (median, with range): Vasopressin: 225 ml (150-400) Placebo: 675 ml (500-800) (p < 0.001)
  2) | Blood transfusion: Vasopressin: 50% Placebo: 0% (p = 0.03)
  3) | Hct fall: Vasopressin: 5% (1-10) Placebo: 13% (7-19) (p < 0.001)
  4) | Hgb fall: Vasopressin: 1.7 g/dl (0.7-2.3) Placebo: 5.3 g/dl (4.0-6.4) (p < 0.001)
  5) | postop WBC count: "No significant difference"
  6) | postop fever: "No significant difference"
Gatti, Falsetti, Viani, et al., 1989 | Design: Case series (retrospective), no controls Intervention(s): Abdominal myomectomy for infertility Dates: 1982-1987 Location: Brescia, Italy Length of followup: N/S | No. of subjects at start: 30 (assuming no loss to followup) Dropouts: N/A Loss to followup: N/S No. of subjects at end: 30 Setting: Hospital Inclusion criteria: Myomectomy performed for infertility, 1982-1987 Exclusion criteria: None specified Age: Mean, 33.3; range, 26-42 Race: N/S Parity: Median, 0 Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | No statistical analysis performed. | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: − E) Loss to followup: − F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: + N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability:− R) Clinical care: + S) Standardized measures: −
  1) | Pregnancy rate (by number of fibroids removed, size of largest fibroid removed, number of years of infertility prior to myomectomy, and age)
  1) | Pregnancy rate: By number of fibroids removed: Single (n = 11): 46% Multiple (n = 19): 27% By size of largest fibroid removed: < 5 cm (n = 16): 44% 6-10 cm (n = 14): 22% By number of years of infertility prior to myomectomy: 2 years (n = 7): 45% 3-5 years (n = 12): 58% 6-10 years (n = 9): 0% > 10 years (n = 2): 0% By age: 20-29 (n = 7): 29% 30-34 (n = 11): 27% 35-39 (n = 11): 45% > 40 (n = 1): 0%
Gehlbach, Sousa, Carpenter, et al., 1993 | Design: Retrospective cohort study Intervention(s): Abdominal myomectomy for infertility (n = 37) Dates: Jan 1976-Dec 1989 Location: Baltimore, MD Length of followup: At least 1 year | No. of subjects at start: 37 Dropouts: N/A Loss to followup: 1 No. of subjects at end: 36 Setting: Hospital Inclusion criteria: Abdominal myomectomy as primary treatment for infertility Exclusion criteria: Other indications for myomectomy, such as endometriosis, pelvic adhesions, or distal tubal obstruction; < 1 year of followup available Age: Mean, 34; range, 27-42 Race: 70% white, 27% black, 3% other Parity: 38% nulliparous Baseline uterine size: Mean, 12.3 weeks Baseline fibroid size: N/S Number of fibroids: 3 (range, 1-17) Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: + J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: + N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: − Note: This is a mostly descriptive retrospective chart review; underpowered to draw any negative conclusions; no controls.
  1) | Pregnancy rate
  2) | SAB rate
  3) | Pregnancy influences
  1) | Pregnancy rate (length of followup unclear, but at least 1 year): At 1 year: 42% Overall: 57%
  2) | SAB rate: 32%
  3) | Pregnancy influences:
    Uterine size:
    + Preg | −Preg
    12.9±0.9 wks | 11.6±1.1 wks
    Myoma size:
    + Preg | −Preg
    8.2±0.9 cc | 7.8±0.6 cc
    Number of myomas:
    + Preg | −Preg
    2.5±0.4 | 3.5±1.0
    Cavity entry:
    + Preg | −Preg
    2 pts | 3 pts
    Number of uterine incisions:
    + Preg | −Preg
    1.8±0.2 | 2.0±0.3
    (p = not significant for all)
Giatras, Berkeley, Noyes, et al., 1999 | Design: Case series (retrospective), no controls Intervention(s): Hysteroscopic myomectomy; 3 patients (7%) were treated with GnRH for 3 months preoperatively for myomas > 4 cm in diameter Dates: Feb 1992-Feb 1996 Location: New York, NY Length of followup: N/S | No. of subjects at start: 41 Dropouts: N/A Loss to followup: 0 No. of subjects at end: 41 Setting: Hospital Inclusion criteria: Primary or secondary infertility; underwent hysteroscopic myomectomy during inclusion dates Exclusion criteria: None specified Age: Mean, 40.2; range, 28-44 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: − E) Loss to followup: + F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: − S) Standardized measures: − Note: Length of folllowup not specified. Of the patients who conceived, five had twins and one had triplets, suggesting use of advanced reproductive technologies, but this is not discussed in the text.
  1) | Pregnancy rates by age
  2) | Pregnancy rates by myoma size
  3) | Overall pregnancy rates
  4) | O/R time
  5) | Recurrence of fibroids
  6) | Adverse outcomes
  7) | Menorrhagia
  1) | Pregnancy rates by age: Age < 34 (n = 10): 90.9% Age 35-37 (n = 4): 36.4% Age 38-40 (n = 8): 61.5% Age > 40 (n = 3): 50%
  2) | Pregnancy rates by myoma size: Myomas < 2 cm: 1/6 Myomas 2-3 cm: 18/26 Myomas 3.1-4 cm: 4/6 Myomas > 4 cm: 2/3
  3) | Overall pregnancy rates: 25/41 (60.9%) conceived
  4) | O/R time: 35.4±7.5 min
  5) | Recurrence of fibroids: 2 patients
  6) | Adverse outcomes: n = 1 with Asherman's
  7) | Menorrhagia: Of 25 patients with bleeding preop, 20 (80%) reported postop resolution
Ginsburg, Benson, Garfield, et al., 1993 | Design: RCT, randomization by table of random numbers Intervention(s): Dates: N/S Location: Boston, MA Length of followup: N/A (in-hospital outcomes only) | No. of subjects at start: 25 Dropouts: 4 Loss to followup: N/A No. of subjects at end: 21 Setting: Hospital Inclusion criteria: Age 21-45; pelvic exam with enlarged uterus; ultrasound suggestive of fibroids; moderate-severe symptoms due to fibroids; normal coagulation profile Exclusion criteria: Prior myomectomy; extensive abdominal adhesions; adnexal mass; coagulopathy Age: Mean, 36 Race: N/S Parity: N/S Baseline uterine size: 833±202 cc (vasopressin group); 650±138 cc (tourniquet group) Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb: N/S Baseline Hct: 34.0±1.3% (vasopressin group); 35.5±1.2% (tourniquet group) | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: + C) Pt selection criteria: + D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: − Note: Baseline uterine volume and resected fibroid weight higher in vasopressin group; transfusion rate and fever higher in tourniquet group. Differences not significant, but study underpowered.
  1) | Myomectomy plus vasopressin (n = 10)
  2) | Myomectomy and tourniquet (n = 11)
  AND
  1) | Myomectomy < 600 cc (n = 11)
  2) | Myomectomy > 600 cc (n = 10)
  1) | EBL
  2) | O/R time
  3) | Hct
  4) | Transfusion
  5) | Length of stay
  6) | postop fever
  | | Vaso | Tourn
  1) | EBL (cc):
  1) | Total | 461±177 | 379±95
  1) | Uterine | 430±180 | 333±90
  1) | Abd. wall | 31±6 | 46±8
  1) | (p = not significant)
  2) | O/R time (min):
  2) | Total | 72±6 | 66±7
  2) | Uterine | 37±5 | 34±6
  2) | Abd. wall | 35±2 | 32±3
  2) | (p = not significant)
  3) | Hct (%):
  3) | preop | 34.0±1.3 | 35.5±1.2
  3) | postop | 29.5±1.0 | 29.9±1.2
  3) | (p = not significant)
  4) | Transfusion: | 10% | 27%
  4) | (p = not significant)
  5) | Length of stay (days):
  5) | | 3.6±0.2 | 4.0±0.3
  5) | (p = not significant)
  6) | postop fever: | 10% | 36%
  6) | (p = not significant)
  Uterine Size | | < 600 cc | >600 cc
  1) | EBL (cc):
  1) | Total | 288±49 | 627±175
  1) | Uterine | 187±44 | 591±176
  1) | Abd. Wall | 41±7 | 36±9
  1) | (p < 0.05)
  2) | O/R time (min):
  2) | Total | 61±5 | 77±7
  2) | Uterine | 30±4 | 40±6
  2) | Abd. Wall | 31±3 | 37±2
  2) | (p < 0.05)
  3) | Hct - Not reported
  4) | Transfusion: | 18% | 20%
  5) | Length of stay (days):
  5) | | 3.7±0.2 | 3.9±0.2
  6) | postop fever: | 18% | 30%
Goldfarb, 1995 | Design: Case series, concomitant controls Intervention(s): Dates: N/S Location: Montclair, NJ, and New York, NY Length of followup: 6 months | No. of subjects at start: 300 Dropouts: 0 Loss to followup: 0 No. of subjects at end: 300 Setting: N/S Inclusion criteria: Symptomatic subserosal and intramural myomas < 10 cm Exclusion criteria: Interest in future fertility; endometrial hyperplasia; premalignant or malignant conditions Age: N/S Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: − I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: − S) Standardized measures: ? Note: Makes claim of no difference but no power calculation performed, and study may not have enough power to make this claim. Also, pt selection and number of myomas important, and these issues are not addressed.
  1) | LA 3.75 mg every 28 days for > 3 cycles, followed by laparoscopic bipolar needle coagulation of myomas (n = 150)
  2) | LA followed by laparoscopic coagulation of myomas using a Nd:YAG laser (n = 150)
  1) | Myoma size
  1) | Myoma size (cm):
  With Nd:YAG laser:
  # pts | Pre LA | Post LA | 6-mo F/U
  27 | 10.0-13.7 | 5.0-9.6 | 2.8-5.0
  48 | 8.0-9.9 | 5.9-7.0 | 2.7-4.8
  41 | 6.0-7.9 | 3.8-5.0 | 2.0-4.7
  25 | 4.0-5.9 | 2.8-4.5 | 1.3-2.9
  9 | 2.0-3.9 | 1.8-2.3 | 0.0-1.4
  With bipolar needle:
  # pts | Pre LA | Post LA | 6-mo F/U
  11 | 10.0-12.4 | 6.7-8.9 | 3.0-5.3
  46 | 8.0-9.9 | 4.9-7.6 | 2.7-5.4
  52 | 6.0-7.9 | 3.9-6.3 | 1.9-4.2
  28 | 4.0-5.9 | 3.2-4.4 | 2.0-3.1
  13 | 2.0-3.9 | 1.0-2.6 | 0.0-2.0
Goodwin, McLucas, Lee, et al., 1999 | Design: Case series (retrospective), no controls Intervention(s): Uterine artery embolization Dates: N/S Location: Los Angeles, CA Length of followup: Mean, 16.3±6.3 months; range, 3.5-28.5 months | No. of subjects at start: 60 Dropouts: N/A Loss to followup: 1 No. of subjects at end: 59 Setting: University hospital Inclusion criteria: N/S Exclusion criteria: N/S Age: Mean, 43.5; range, 27-66 Race: white, 47.4%; black, 32.3%; other, 20.3% Parity: 42% prior pregnancy Baseline uterine size: Mean, 844.1±1280.5 cc; range, 120.2-9272.8 cc Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: + E) Loss to followup: + F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: + J) Pregnancy history: + K) Surgical history: + L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: + O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Reduction in uterine volume
  2) | Reduction in fibroid volume
  3) | Need for additional treatment
  4) | Complications
  5) | Clinical response
  6) | Predictors of response
  1) | Reduction in uterine volume: Mean, 42.8±31.7%; range, 87% reduction to 29% increase in uterine volume
  2) | Reduction in fibroid volume: Mean 48.8±84.2%; range, 100% reduction to 522% increase in volume
  3) | Need for additional treatment: Hysterectomy: 10% 2 for persistent symptoms 1 for uteral compression 1 for hematometra 1 for infectious complication of therapy 1 for unrelated carcinoma 1 unknown Repeat embolization: 2/59 (3%)
  4) | Complications: 1 permanent amenorrhea 1 groin hematoma 1 endometritis 27 same-day admission for pain control 20 fever > 100.4 F (6 readmissions) 4 spontaneous passage of fibroids
  5) | Clinical response: Bleeding: Marked or complete improvement: 27 Moderate or significant improvement: 25 No improvement: 2 Pain: Marked or complete improvement: 22 Moderate or significant improvement: 19 Slight or no improvement: 4
  6) | Predictors of outcome: Larger percent reduction in volume less likely to undergo hysterectomy (p < 0.001) Younger patients more likely to have clinical failure (p < 0.02) Previous myomectomy less likely to have subsequent hysterectomy (p < 0.02)
Guillaume, Benjamin, and Spitzer, 1998 | Design: Case series, concomitant controls Intervention(s): Dates: N/S; "10-year period" Location: New York, NY (Brooklyn, Queens, and Jamaica) Length of followup: Mean, 2 years | No. of subjects at start: 45 (assuming no dropouts or loss to followup) Dropouts: N/S Loss to followup: N/S No. of subjects at end: 45 Setting: N/S Inclusion criteria: Normal semen analysis; normal Postcoital test; normal premenstrual endometrial biopsy; normal basal body temperature recording; normal endocrine work-up; bilateral proximal tubal obstruction Exclusion criteria: None specified Age: Mean, 29.3 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: − F) Dropout rates: − G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: − Note: Claims no difference because tests not significant, but not enough power to make this claim.
  1) | Tuboplasty alone in pts with fibroids (n = 15)
  2) | Tuboplasty plus myomectomy (n = 30) for infertility
  1) | Pregnant at 2 years
  2) | Pregnancy complications (as % of pregnancies)
  1) | Pregnant at 2 years: Tuboplasty alone: 73% Tuboplasty + myo: 63.3%
  2) | Pregnancy complications (as % of pregnancies): SAB: Tuboplasty alone: 45% Tuboplasty + myo: 16% Ectopic: Tuboplasty alone: 18% Tuboplasty + myo: 26.3% Viable birth: Tuboplasty alone: 36.0% Tuboplasty + myo: 57.9% Birth rate: Tuboplasty alone: 27% Tuboplasty + myo: 36.7% (p = not significant for all of these)
Hallez, 1995 | Design: Case series (retrospective), no controls Intervention(s): Hysteroscopic myomectomy (n = 274) Dates: N/S Location: Paris, France Length of followup: 5 to > 63 months | No. of subjects at start: 274 Dropouts: N/A Loss to followup: At 6 months, 9; at 20 months, 149; at 38 months, 202; at 62 months, 222; at > 63 months, 231 No. of subjects at end: At 6 months, 265; at 20 months, 125; at 38 months, 72; at 62 months, 52; at > 63 months, 43 Setting: Hospital; ambulatory surgery facility Inclusion criteria: Isolated submucous myoma Exclusion criteria: None specified Age: Mean, 45; range, 25-70 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: + O) Measurement timing: + P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Percentage of patients free of myomas and/or symptoms
  2) | Primary complications
  3) | Secondary complications
  4) | Pregnancy
  1) | Percentage of patients free of myomas and/or symptoms:
    Months | %
    6 | 95.6
    12 | 94.6
    18 | 91.1
    24 | 89.7
    36 | 87.8
    48 | 83.0
    60 | 76.3
    72 | 73.2
    84 | 67.6
    106 | 67.6
  2) | Primary complications: Uterine perforation: 0.3% Vascular overload: 0% Electrolyte imbalance: 0%
  3) | Secondary complications: Bleeding: 4% Synechiae: 10%
  4) | Pregnancy: Primary infertility (n = 9): 0% Secondary infertility (n = 23): 78%
Han, 1996 | Design: Case series, no controls (retrospective) Intervention(s): TAH (total n = 43; with fibroids n = 18) TVH with vaginal repairs (total n = 128; with fibroids n = 33) TVH without vaginal repairs (total n = 178; with fibroids n = 64) Dates: Jan 1990-Dec 1993 Location: Sylva, NC Length of followup: N/A (in-hospital outcomes only) | No. of subjects at start: 349 total, 61 with fibroids; demographic and baseline data below for entire population of 349 Dropouts: N/A Loss to followup: N/A No. of subjects at end: 349 total, 61 with fibroids Setting: Hospital Inclusion criteria: Consecutive patients undergoing hysterectomy Exclusion criteria: "Early in the study, uterine size greater than 14 gestational weeks was a reason for exclusion, but with greater experience as the study progressed, uterine size up to 16-18 gestational weeks was included for a vaginal route." Age: Means (and ranges): TAH, 51.1 (32-81); TVH + repairs, 46.2 (24-86); TVH without repairs, 38.8 (22-81) Race: "Most" patients white, with "a few" Native Americans Parity: TAH, 2.1; TVH + repairs, 2.6; TVH without repairs, 2.1 Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | Outcomes of patients with fibroids reported separately only for a subgroup of patients who underwent TVH without vaginal repairs or other concurrent surgery (n = 16). | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: + J) Pregnancy history: + K) Surgical history: + L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: − S) Standardized measures: −
  1) | Anesthesia time
  2) | Operation time
  3) | Uterine weight
  1) | Anesthesia time: TVH with salpingoopherectomy: 116 minutes (95-145) TVH without salpingoopherectomy: 128 minutes (100-175)
  2) | Operation time: TVH with salpingoopherectomy: 92 minutes (65-120) TVH without salpingoopherectomy: 98 minutes (50-125)
  3) | Mean uterine weight: 398 g
Hart, Molnar, and Magos, 1999 | Design: Case series (prospective), no controls Intervention(s): Hysteroscopic myomectomy (n = 122) Dates: N/S Location: London, UK Length of followup: Mean, 2.3 years; range, 1-7 years | No. of subjects at start: 122 Dropouts: N/A Loss to followup: 15 No. of subjects at end: 107 Setting: Ambulatory surgery facility Inclusion criteria: Consecutive patients who underwent hysteroscopic myomectomy; the majority were treated for abnormal uterine bleeding Exclusion criteria: None specified Age: Mean, 43.2; interquartile range, 36-48 Race: N/S Parity: 59% nulliparous Baseline uterine size: Mean, 7.5 weeks (interquartile range, 6-8) Baseline fibroid size: Largest: Mean, 3.4 cm (interquartile range, 2-4) Number of fibroids: N/S (reported as outcome measure only) Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: + E) Loss to followup: + F) Dropout rates: N/A G) Statistical issues: + EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: + N) Location of fibroids: + O) Measurement timing: + P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: − Notes: Appropriate use of survival analysis. Method/scale of measurement for determining menstrual bleeding or dysmenorrhea not described.
  1) | Number of fibroids removed
  2) | O/R time
  3) | Menstrual bleeding
  4) | Dysmenorrhea
  5) | Pregnancy rate
  6) | Pregnancy complications
  7) | Additional surgery required
  8) | Patient satisfaction
  1) | Number of fibroids removed: Mean, 1.6
  2) | O/R time: Mean, 28.1 minutes; range, 15-33
  3) | Menstrual bleeding: Significant improvement: 86%
  4) | Dysmenorrhea: Significant improvement: 72%
  5) | Pregnancy rate: Overall: 11% Of those who "wanted to become pregnant": 42%
  6) | Pregnancy complications: Uterine rupture: 11%
  7) | Additional surgery required: 21% in first 4 years postop; > 4 years postop, no additional patients required surgery Preoperative uterine size < 6 weeks (RR, 0.12; 95% CI, 0.016-0.96; p = 0.0082) and intra-cavitary position of myoma (< 50% intramural) (RR, 0.33; 95% CI, 0.18-1.02; p = 0.0504) significant independent predictors of avoiding additional surgery.
  8) | Patient satisfaction: 72% reported being "satisfied" with their outcome
Hasson, Rotman, Rana, et al., 1992 | Design: Case series, no controls Intervention(s): Laparoscopic myomectomy (n = 56) Dates: Oct 1988-Aug 1991 Location: Chicago, IL Length of followup: Mean, 9 months; range, 2-36 months | No. of subjects at start: 56 Dropouts: N/A Loss to followup: 0 No. of subjects at end: 56 Setting: Hospital Inclusion criteria: N/S Exclusion criteria: N/S Age: Mean, 37.1; range, 25-51 Race: 57% white, 38% black, 5% other Parity: 36% nulliparous, 28% nulligravid Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: + E) Loss to followup: + F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: + J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: − Note: Scale for scoring adhesions not described.
  1) | O/R time
  2) | EBL
  3) | Transfusion
  4) | postop fever
  5) | Subcutaneous emphysema
  6) | Pregnancy rate in infertile patients
  7) | Adhesions on second look
  1) | O/R time: 157 min (range, 45-443)
  2) | EBL: 75 cc (range, 10-400)
  3) | Transfusion: 0%
  4) | postop fever: 2%
  5) | Subcutaneous emphysema: 5%
  6) | Pregnancy in infertile pts (n = 17): 71%
  7) | Adhesions on second look (n = 24): None: 33% Minimal: 21% Moderate/extensive: 46%
Hillis, Marchbanks, and Peterson, 1996 | Design: Cohort study Intervention(s): Abdominal hysterectomy (n = 446); results stratified by uterine weight Dates: 1978-1981 Location: Multicenter (U.S.) Length of followup: 4-12 weeks | No. of subjects at start: 446 Dropouts: N/A Loss to followup: 0 No. of subjects at end: 446 Setting: Hospital Inclusion criteria: Age 15-44 years; nonemergency hysterectomy; abdominal hysterectomy; fibroids confirmed by pathology Exclusion criteria: Malignancy; pregnancy; sterilization Age: N/S Race: 37% white, 57% black, 6% Other Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: N/A G) Statistical issues: + EXTERNAL VALIDITY H) Age: − I) Race: + J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: − S) Standardized measures: +
  1) | Complications Crude rates Unadjusted relative risks Adjusted odds ratios (adjusted for history of previous abdominal or gynecologic surgery, race, type of insurance, preoperative weight)
  1) | Complications (results stratified by uterine weight) *p for trend < 0.05 Unadjusted relative risks for previously published complications (from Reiter et al.), weight > 500 g compared to < 500g: Adjusted odds ratios, weight >500 g compared to < 500 g:
    Crude rates: | < 250g | 251-500 g | > 500 g
    Fever | 20.5% | 20.0% | 17.8%
    Transfusion* | 13.7% | 14.2% | 26.7%
    Unintended procedures | 1.1% | 1.9% | 1.0%
    Rehospitalization* | 1.8% | 3.5% | 1.1%
    Life-threatening event | 0.53% | 0.65% | 0%
    Death | 0% | 0.65% | 0%
    RR (95% CI)
    EBL > 500 cc | 1.9 (1.4-2.8)
    Any complication | 1.3 (1.1-1.7)
    UTI | 1.3 (0.8-2.2)
    Febrile morbidity | 0.88 (0.55-1.4)
    Nonpelvic thrombosis | 3.4 (0.87-13.3)
    Cuff cellulitis | 2.1 (1.1-3.9)
    Pelvic hematoma | 0.85 (0.18-4.0)
    Wound infection | 2.8 (1.2-6.5)
    Bowel obstruction | 0.57 (0.13-2.5)
    Readmission | 0.42 (0.05-3.1)
    Transfusion | 1.9 (1.3-2.9)
    EBL > 500 cc | 2.5 (1.5-4.2)
    Transfusion | 2.4 (1.3-4.3)
    Cuff cellulitis | 2.8 (1.3-6.2)
    Wound infection | 2.4 (0.87-6.5)
    Any complication | 1.6 (1.0-4.0)
Hoffman, deCesare, and Kalter, 1994 | Design: Case series (retrospective), concomitant controls Intervention(s): TAH (n = 112) (controls) Dates: Cases, Jul 1987-Jun 1993; controls, Jul 1986-June 1992 Location: Tampa, FL Length of followup: N/A (in-hospital outcomes only) | No. of subjects at start: 162 Dropouts: N/A Loss to followup: N/A No. of subjects at end: 162 Setting: Hospital Inclusion criteria: Cases: No malignancy; no adnexal abnormality; anatomically feasible (mobile uterus, < 18 wks, "roomy pelvis"). Controls: Matched for age, uterine weight, medical problems. Exclusion criteria: None specified Age: Mean, 42.5 Race: N/S Parity: 2.8 (VH group); 2.7 (TAH group) Baseline uterine size: 335 g (VH group); 336 g (TAH group) Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: − S) Standardized measures: − Note: O/R time did not include oopherectomy for VH, but did for TAHs. Also, residents were operating, which will make O/R times vary. Controls were supposedly matched, but there was not an even 1-2 ratio between cases and controls, therefore don't know how exactly the matching occurred. Also, does not discuss controlling for matched factors.
  1) | Vaginal hysterectomy with morcellation (n = 50) (cases)
  1) | O/R time
  2) | EBL
  3) | Complications
  4) | Length of stay
  1) | O/R time: VH: 122 TAH: 148 (p < 0.05)
  2) | EBL: VH: 527 cc TAH: 586 cc (p = not significant)
  3) | Complications: Cystotomy VH: 0% TAH: 2% Transfusion VH: 6% TAH: 19% Soft tissue infection VH: 10% TAH: 12% (p = not significant for all 3)
  4) | Length of stay: VH: 3.6±1.1days TAH: 5.1±1.5 days (p < 0.001)
Hutchins, Worthington-Kirsch, Berkowitz, 1999 | Design: Case series, no controls (Single operator) Intervention(s): Uterine artery embolization (n = 305) Dates: N/S Location: Philadelphia, PA Length of followup: 3 months (n = 240), 6 months (n = 180), 1 year (n = 109) | No. of subjects at start: 305 Dropouts: N/A No. of subjects at end: N/A (variable lengths of followup) Setting: Hospital Inclusion criteria: Fibroids confirmed by ultrasound causing menorrhagia and/or bulk related symptoms Exclusion criteria: Pregnancy, active pelvic infection, severe contrast allergy, arteriovenous fistula, undiagnosed pelvic mass Age: NS Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: + E) Loss to followup: + F) Drop-out rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: − I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: −+ Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: − Note: Loss to followup with increasing time raises possibility of worse outcomes in patients lost to followup, with lower overall long-term success rates.
  Loss to followup: | 3 months: 23%
  Loss to followup: | 6 months: 33%
  Loss to followup: | 1 year: 46%
  1) | Technical success (completion of procedure)
  2) | Complications/side effects
  3) | Improvement in symptoms
  4) | Global satisfaction
  5) | Subsequent therapy
  1) | Technical success: 96%
  2) | Complications: 1/305: N/V with hematemesis 2/305: Readmission for pain control (one with subsequent hysterectomy) 4/305: Hematomas
  Side effects:
  | 13/305: spontaneous expulsion of fibroids "Many": persistent mucoid discharge up to 3 months 40%: Fever in first 2 weeks after procedure
  3) | Improvement in symptoms Menorrhagia
    3 months: (n = 179)
    Complete | 55 (30.7%)
    "Great" | 79 (44%)
    "Moderate" | 21 (11.7%)
    "Slight" | 13 (7.3%)
    "None" | 9 (5%)
    "Worse" | 2 (1.1%)
    6 months: (n = 116)
    Complete | 37 (31.9%)
    "Great" | 50 (43.1%)
    "Moderate" | 14 (12.1%)
    "Slight" | 7 (6%)
    "None" | 7 (6%
    "Worse" | 1 (0.8%)
    1 year: (n = 58)
    Complete | 24 (41.3%)
    "Great" | 23 (39.6%)
    "Moderate" | 3 (5.2%)
    "Slight" | 6 (10.3%)
    "None" | 0
    "Worse" | 2 (3.4%)
  Bulk symptoms
  | 3 months: (n = 121)
    Complete | 43 (35.5%)
    "Great" | 21(17.3%)
    "Moderate" | 19 (15.7%)
    "Slight" | 5 (4%)
    "None" | 10 (8.3%)
    "Worse" | 3 (2.5%)
  | 6 months: (n = 86)
    Complete | 44 (51.1%)
    "Great" | 21 (24.4%)
    "Moderate" | 6 (7%)
    "Slight" | 2 (2.3%)
    "None" | 10 (11.6%)
    "Worse" | 3 (3.5%)
  | 1 year : (n = 42)
    Complete | 23 (54.8%)
    "Great" | 10 (23.8%)
    "Moderate" | 3 (7.1%)
    "Slight" | 2 (4.8%)
    "None" | 4 (9.6%)
    "Worse" | 0
  4) | Global satisfaction: ("Would you have procedure again?")
    | Yes | Maybe | No
    3 months (n = 185) | 83.8% | 12.4% | 3.8%
    6 months (n = 121) | 85.1% | 9.9% | 5%
    1 year (n = 59) | 86.4% | 6.8% | 6.8%
  5) | Subsequent procedures: 2 repeat procedures for persistent symptoms; both showed occluded arteries 6 hysterectomies 5 myomectomies
Ikpeze and Nwosu, 1998 | Design: Case series, no controls Intervention(s): Abdominal myomectomy (n = 72) Dates: Jan 1994-Dec 1996 Location: Onitsha, Nigeria Length of followup: N/A (in-hospital outcomes only) | No. of subjects at start: 72 Dropouts: N/A Loss to followup: N/A No. of subjects at end: 72 Setting: Hospital Inclusion criteria: Consecutive patients with symptomatic fibroids diagnosed clinically and by ultrasound and treated by myomectomy during study period Exclusion criteria: None specified Age: Mean, 32.3; range, 25-49 Race: N/S (though implied 100% Black) Parity: Median, 0; range, 0-6 Baseline uterine size: < 12 weeks, 33%; > 12 and < 16 weeks, 51%; > 16 weeks, 16% Baseline fibroid size: Range, 20-2140 cc Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: + O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Drop in Hgb
  2) | Adverse events
  3) | Incision type
  1) | Drop in Hgb (mean): 1.6 g/dl
  2) | Adverse events: Transfusion: 15.3% Fever: 17% "Mild sepsis": 7%
  3) | Incision type: Vertical: 46% Transverse: 54%
Indman, 1993 | Design: Case series, no controls Intervention(s): Hysteroscopic resection of myomas without endometrial ablation (n = 13) Dates: Sep 1987-Apr 1991 Location: San Jose, CA Length of followup: Mean, 2.2 years; range, 1-5 years | No. of subjects at start: 51 Dropouts: N/A Loss to followup: N/S No. of subjects at end: N/S Setting: Hospital Inclusion criteria: Menorrhagia; submucous or intramural uterine leiomyomas Exclusion criteria: Anovulation prior to trial of medical therapy Age: Mean, 44.2; range, 27-55 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: − F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: − Note: Patients in ablation group were not candidates for hysterectomy due to medical problems/anticoagulation; bias may have been introduced.
  1) | Hysteroscopic resection of myomas with endometrial ablation (n = 38)
  1) | Pad count
  2) | Dysmenorrhea
  3) | Satisfaction
  4) | Hysterectomy needed in followup period
  1) | Pad count (median/mean): H/S myo + ablation Pre: 21.4/18.0 Post: 1.7/0 H/S myo alone: Pre: 17.8/15.0 Post: 6.8/4.0 p < 0.05 for pre→post in both groups; no p-value between groups given
  2) | Dysmenorrhea: H/S myo + ablation
    Severe | Mod | Mild | None
    Pre (%): | 29 | 32 | 18 | 21
    Post: 5 | 8 | 8 | 79
    H/S myo alone:
    Severe | Mod | Mild | None
    Pre (%): | 45 | 18 | 36 | 0
    Post: 0 | 18 | 36 | 45
  3) | Extremely satisfied: H/S myo + ablation: 92% H/S myo alone: 60%
  4) | Hysterectomy needed during followup: H/S myo + ablation: 8% H/S myo alone: 0%
Itzkowic, 1993 | Design: Case series, no controls Intervention(s): Hysteroscopic myomectomy (n = 37) Dates: May 1988-Feb 1989 and Jan 1991-May 1992 Location: Sydney, Australia Length of followup: Mean, 14 months; range, 4-51 months | No. of subjects at start: 40 procedures in 37 patients Dropouts: N/A Loss to followup: 1 patient with 1 procedure No. of subjects at end: 39 procedures in 36 patients Setting: Hospital (n = 19); outpatient clinic/physician office (n = 18) Inclusion criteria: Patients undergoing hysterectomy during study period Exclusion criteria: Fibroid diameter > 5 cm; fibroid mass predominantly intramural rather than submucosal (1 exception); uterine cavity > 10 cm (2 exceptions) Age: Mean, 44; range, 23-68 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: 30 mm Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: − Note: Included in this study were four repeat procedures that counted as failures the first time. Descriptive study without statistical analysis.
  1) | Conversion to hysterectomy
  2) | Repeat procedure needed
  3) | Bleeding
  4) | Postoperative infection
  1) | Conversion to hysterectomy: 2.5%
  2) | Repeat procedure needed: 7.5%
  3) | Bleeding improved: 83%
  4) | postoperative infection: 2.5%
Iverson, Chelmow, Strohbehn, et al., 1996 Possible overlap with patients described in Iverson, Chelmow, Strohbehn, et al., 1999 | Design: Cohort study (retrospective) Intervention(s): Abdominal hysterectomy (n = 89) or myomectomy (n = 103) Dates: May 1988-May 1993 Location: Boston, MA Length of followup: N/A (in-hospital outcomes only) | No. of subjects at start: 192 Dropouts: N/A Loss to followup: N/A (in-hospital outcomes only) No. of subjects at end: 192 Setting: Hospital Inclusion criteria: Myomectomy or TAH for fibroids Exclusion criteria: Age > 45; surgery for conditions other than fibroids; preoperative fever or infection; pregnancy; intended vaginal hysterectomy; procedures performed by gynecologic oncology service Age: Mean, 36.6 Race: N/S Parity: 0.2 (myomectomy group); 1.3 (hysterectomy group) Baseline uterine size: 11.5 wks (myomectomy group); 15.2 wks (hysterectomy group) Baseline fibroid size (largest fibroid): 193.2 ml (myomectomy group); 247.7 ml (hysterectomy group) Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: − S) Standardized measures: +
  1) | Complications
  2) | Fever > 38.0° C
  3) | Fever > 38.5° C
  4) | Transfusions
  5) | Operative time
  6) | EBL
  1) | Complications: Myomectomy: 0 intraoperative injuries 1 reoperation for bleeding Hysterectomy: 2 ureteral injuries 1 bladder injury 1 bowel injury 1 femoral nerve injury 2 reoperations for bowel obstruction
  2) | Fever > 38.0° C: Myomectomy: First 48 hours: 67.3% After 48 hours: 32% Hysterectomy: First 48 hours: 76.4% After 48 hours: 49.4%
  3) | Fever > 38.5° C: Myomectomy: First 48 hours: 34.7% After 48 hours: 13.3% Hysterectomy: First 48 hours: 27% After 48 hours: 15.7%
  4) | Transfusions: Myomectomy: Any: 28.2% Autologous: 21.8% Random: 7.9% Elective: 6.8% Hysterectomy: Any: 32.6% Autologous: 23.6% Random: 10.1% Elective: 2.2% Not significant
  5) | Operative time: Myomectomy: 148 min Hysterectomy: 149 min Not significant
  6) | EBL: Myomectomy: 464 ml Hysterectomy: 796 ml P < 0.05 Multivariate analysis, controlling for age, GnRH agonist use, service, procedure, and uterine size. Uterine size only significant predictor of EBL.
Iverson, Chelmow, Strohbehn, et al., 1999 Possible overlap with patients described in Iverson, Chelmow, Strohbehn, et al., 1996 | Design: Cohort study (retrospective) Intervention(s): Myomectomy (n = 101) or abdominal hysterectomy (n = 160, including 70 without fibroids) Dates: May 1988-Jun 1993 Location: Boston, MA Length of followup: N/A (in-hospital outcomes only) | No. of subjects at start: 261 Dropouts: N/A Loss to followup: N/A No. of subjects at end: 261 Setting: Hospital Inclusion criteria: All myomectomies; all hysterectomies performed for benign disease Exclusion criteria: Age > 45; surgery for infertility, pregnancy, vaginal hysterectomy; gynecological oncology service; hysterectomy for bleeding complications of myomectomy Age: Mean, 36.4 Race: N/S Parity: % parous: 15.8% (myomectomy group); 60% (hysterectomy group) Baseline uterine size: 12.1±4.2 wks (myomectomy group); 11.7±6.1 wks (hysterectomy group) Baseline fibroid size (largest fibroid): 191.4±242.6 ml (myomectomy group); 212.4±303.6 ml (hysterectomy group) Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: N/A G) Statistical issues: + EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: − S) Standardized measures: +
  1) | Operative time
  2) | EBL
  3) | Fever > 38.0° C
  4) | Fever > 38.5° C
  5) | Predictors of fever > 38.5° C
  1) | Operative time (minutes): Myomectomy: Mean 149.8±52.6 Hysterectomy: Mean 155.4±54.8
  2) | EBL (ml): Myomectomy: Mean 445±629 Hysterectomy: Mean 672±705
  3) | Fever > 38.0° C: Myomectomy: First 48 hours: 67% After 48 hours: 31% Hysterectomy: First 48 hours: 64% After 48 hours: 46% Not significant
  4) | Fever > 38.5° C: Myomectomy: First 48 hours: 33% After 48 hours: 11% Hysterectomy: First 48 hours: 26% After 48 hours: 15% Not significant
  5) | Predictors of fever > 38.5° C in first 48 hours after surgery (logistic regression):
    | OR | 95% CI
    Myomectomy | 3.93 | 1.82-8.51
    Age | 0.94 | 0.87-1.01
    Parity | 1.6 | 1.21-2.10
    General service (compared to Endocrine)
    | 3.25 | 1.63-6.50
    EBL (per 100 ml) | 1.064 | 1.015-1.114
Kadar, 1996 | Design: Case series, no controls Intervention(s): Laparoscopically assisted vaginal hysterectomy (uterine artery and uterosacral ligaments divided laparoscopically) (n = 28; however, outcomes reported only for subjects with uterine weight > 500 g, n = 13). Dates: N/S Location: Secaucus, NJ Length of followup: N/A (in-hospital outcomes only) | No. of subjects at start: 13 patients with uterine weight > 500 g out of total series of 28 Dropouts: N/A Loss to followup: N/A No. of subjects at end: 13 Setting: Hospital Inclusion criteria: All patients undergoing extraperitoneal laparoscopic hysterectomy for fibroids over a 12-month period Exclusion criteria: None specified Age: Mean, 51; range, 39-58 Race: N/S Parity: Median, 2 Baseline uterine size: Mean weight, 874 g Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: N/A G) Statistical issues: N/A EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: + L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: + S) Standardized measures: +
  1) | Length of stay
  2) | Complications
  3) | EBL
  4) | Change in Hgb
  5) | O/R time
  1) | Length of stay: Mean, 1.5 days
  2) | Complications: Transfusion: 15% Injury to organ: 0%
  3) | EBL: Mean, 565 ml
  4) | Change in Hgb: Mean, 2.7 g/dl
  5) | O/R time: Mean, 3.25 hrs
Kjerulff, Langenberg, Rhodes, et al., 2000 | Design: Cohort study (prospective) Intervention(s): Hysterectomy (n = 1,299) Dates: Feb 1992-Dec 1995 Location: Baltimore, MD Length of followup: 24 months | No. of subjects at start: 1,299 (48.1% with fibroids as primary indication) Dropouts: (Not reported separately from loss to followup) Loss to followup: 10.6% overall after 2 years No. of subjects at end: 1,162 Setting: Hospitals Inclusion criteria: Age > 18 years; scheduled for hysterectomy for benign indication Exclusion criteria: None specified Age: Mean, 43.3 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: + G) Statistical issues: + EXTERNAL VALIDITY H) Age: + I) Race: + J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: − S) Standardized measures: + Note: Results not reported separately for fibroids, but "few significant or consistent differences in outcomes associated with principal diagnosis."
  1) | Symptomatic relief
  2) | Psychological function (Profile of Mood States)
  3) | Quality of life (Medical Outcome Study Short Form, General Health Survey)
  4) | Complication rate
  5) | Predictors of poor outcome
  1) | Symptomatic relief: (Problems at "problematic-severe" level) Vaginal bleeding Before surgery 59.2% 1 year 0.5% 2 years 0.3% Pelvic pain Before surgery 63.1% 1 year 8.5% 2 years 7.8% Activity limitation Before surgery 57.5% 1 year 4.1% 2 years 2.4% All comparisons "highly significant"
  2) | Psychological function: Depressed Before surgery 28.0% 1 year 11,9% 2 years 12.4% Anxious Before surgery 65.4% 1 year 30.6% 2 years 25.1% All comparisons "highly significant"
  3) | Quality of life: Limited physical function Before surgery 47.7% 1 year 23.6% 2 years 23.1% Limited social function Before surgery 23.1% 1 year 5.1% 2 years 4.9% Poor health perceptions Before surgery 78.6% 1 year 32.0% 2 years 31.9% All comparisons "highly significant"
  4) | Complication rate: No complications: 21.4% One or more mild complications: 66.8% One or more moderate complications: 11.1% One or more serious complications: 0.7% Cumulative readmission rate 1 year: 4.0% 2 years: 5.4%
  5) | Predictors of poor outcome (defined as same or more symptoms at problematic-severe levels after surgery compared with before): Income (> 35,000 vs. < 35,000): 1 year: O/R 0.48 (95% CI, 0.29-0.82) 2 years: O/R 0.37 (0.24-0.59) In psychotherapy: 1 year: O/R 3.56 (1.59-8.0) 2 years: O/R 3.46 (1.84-6.51) Bilateral oophorectomy: 1 year: O/R 1.48 (0.80-2.75) 2 years: O/R 2.01 (1.14-3.53)
LaMorte, Lalwani, Diamond, 1993 | Design: Case series (retrospective), no controls Intervention(s): Abdominal myomectomy (n = 128). Minor comparisons between myomectomy with tourniquet and/or Pitressin® (n = 44) vs. myomectomy with nothing (n = 84). Dates: Oct 1985-Dec 1988 Location: New Haven, CT Length of followup: N/A (in-hospital outcomes only) | No. of subjects at start: 128 Dropouts: N/A Loss to followup: N/A No. of subjects at end: 128 Setting: Hospital Inclusion criteria: Procedure code indicating myomectomy; abdominal approach not associated with cesarean Exclusion criteria: Myomectomy by hysteroscopic or laparoscopic approach Age: Mean, 33; range, 19-46 Race: N/S Parity: N/S Baseline uterine size: 14±1 wks Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | EBL
  2) | Transfusion
  3) | Unintended hysterectomy
  4) | postoperative complications
  1) | EBL (cc): Overall: 342±37 Tourniquet/Pitressin®: 266±45 Nothing: 385±51 (p < 0.05 for tourniquet/Pitressin® vs. nothing)
  2) | Transfusion: Overall: 20% Tourniquet/Pitressin®: 23% Nothing: 19%
  3) | Unintended hysterectomy: 1%
  4) | Postoperative complications: Febrile morbidity: 12% DVT: 1% Wound infection: 1%
Lee and Soong, 1995 | Design: RCT, randomization by computer-generated random numbers Intervention(s): LAVH without ureter dissection (n = 30) Dates: Mar 1991-Oct 1993 Location: Taipei, Taiwan Length of followup: N/A (in-hospital outcomes only) | No. of subjects at start: 60 (41/60 had uterine fibroids; unable to determine distribution between interventions) Dropouts: N/A Loss to followup: N/A No. of subjects at end: 60 Setting: Hospital Inclusion criteria: Myoma uteri, adenomyosis, menorrhagia with medical treatment failure, or endometriosis with severe pelvic adhesions Exclusion criteria: None specified Age: N/S Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: + C) Pt selection criteria: + D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: − I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | (LAVH with ureter dissection (n = 30)
  1) | Estimated blood loss
  2) | Operative time
  3) | Length of stay
  4) | Recovery time
  5) | Complications
  1) | Estimated blood loss (cc): LAVH with ureter dissection: 120 LAVH without ureter dissection: 140
  2) | Operative time (minutes): LAVH with ureter dissection: 144 LAVH without ureter dissection: 125
  3) | Length of stay (days): LAVH with ureter dissection: 2.4 LAVH without ureter dissection: 2.2
  4) | Recovery time (days): LAVH with ureter dissection: 14 LAVH without ureter dissection: 14
  5) | Complications: 3.3% fever and 3.3% ileus in each group No ureter injuries identified
Li, Mortimer, and Cooke, 1999 | Design: Case series (retrospective), no controls Intervention(s): Abdominal myomectomy (n = 51) Dates: May 1991-Dec 1996 Location: Sheffield, UK Length of followup: Mean 12.6 months; range, 3-60 | No. of subjects at start: 51 Dropouts: N/A Loss to followup: 0 No. of subjects at end: 51 Setting: Hospital Inclusion criteria: Age < 45; laparotomy + myomectomy with microsurgical techniques for intramural or subserosal fibroids; desire to conceive; no other significant fertility factors Exclusion criteria: None specified Age: Mean, 33.7; range, 25-44 Race: N/S Parity: 41 (80%) nulliparous Baseline uterine size: Median, 14 weeks Baseline fibroid size: Median largest fibroid diameter, 6 cm; range, 1-17 Number of fibroids: 43% had 1, 23% had 2, 16% had 3, 12% had > 4 (6% N/S) Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: N/A G) Statistical issues: + EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: + N) Location of fibroids: + O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: + R) Clinical care: − S) Standardized measures: −
  1) | Pregnancy rate
  2) | Live birth rate
  3) | Pregnancy loss rate
  4) | Effect of location, number, and size of fibroids on conception rates
  5) | Postmyomectomy pregnancy rates by age
  1) | Pregnancy rate: Overall pregnancy rate after myomectomy: 29/51 patients (57%)
  2) | Live birth rate: Premyomectomy: 16 births/40 conceptions (40%) Postmyomectomy: 25/33 = 76%
  3) | Pregnancy loss rate: Premyomectomy: 24/40 (60%) Postmyomectomy: 8/24 (24%) (p < 0.001)
  4) | Effect of location, number, and size of fibroids on conception rates: No significant impact on conception rate
  5) | Postmyomectomy pregnancy rates by age: Age < 35: 74% conception rate Age > 36: 30% conception rate (p < 0.005).
Lin, Iwata, and Liu, 1994 | Design: Case series (prospective), no controls Intervention(s): Buserelin acetate 900 mg IN per day for 4-6 weeks, followed by hysteroscopic myomectomy (n = 25). Second-look hysteroscopy performed at 3 months, and third-look hysteroscopy at 9 months Dates: N/S Location: Kawasaki, Japan Length of followup: 9 months | No. of subjects at start: 25 Dropouts: 0 Loss to followup: N/S No. of subjects at end: N/S Setting: Hospital Inclusion criteria: All of following: Severe menorrhagia (10 pads/day or more) and/or intractable metrorrhagia; uterus < 10 wks in size; submucous myoma < 60 mm in diameter; no malignancy Exclusion criteria: None specified Age: Mean, 38; range, 25-54 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb: 7.7 | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: − F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Fibroid size
  2) | O/R time
  3) | Complications
  4) | Recurrent fibroids
  5) | Symptoms
  6) | Pregnancy rate
  1) | Fibroid size: 78.5 g (50-145)
  2) | O/R time: 49 minutes (13-118)
  3) | Complications: No uterine perforations No blood transfusions No laparotomy required 4% cervical laceration.
  4) | Recurrent fibroids: 12%
  5) | Symptoms: 88% of patients "had improvement of anemia and menorrhagia, with markedly reduced requirement for pads/tampons during menses"
  6) | Pregnancy rate: 8%
Loffer, 1990 | Design: Case series, no controls Intervention(s): Hysteroscopic myomectomy (n = 43) Dates: 1984-1990 Location: Phoenix, AZ Length of followup: 45/53 pts were followed up for > 12 months; range, 0-48 months | No. of subjects at start: 53 (43 with fibroids, 10 with endometrial polyps) Dropouts: N/A Loss to followup: 8 No. of subjects at end: 45 Setting: Ambulatory surgery facility Inclusion criteria: Excessive bleeding, infertility, or both Exclusion criteria: None specified Age: Mean, 40; range, 24-59 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: Means N/S, but 30 pts had 1 fibroid > 1.5 cm or 8 g; 13 pts had more than one Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: + E) Loss to followup: + F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Symptoms
  2) | Pregnancy rate
  3) | Additional surgery required
  4) | Complications
  1) | Symptoms: "Excessive menstrual bleeding controlled in 93%"
  2) | Pregnancy rate: 13% overall 58% (7/12) in patients whose indication for surgery was infertility
  3) | Additional surgery required: Overall: 24.4% Hysterectomy: 9.4% Hysteroscopy: 9.4% Other: 5.6%
  4) | Complications: Uterine perforation: 1.8% Hyponatremia: 3.7%
Lomano, 1991 | Design: Case series (prospective), no controls Intervention(s): Hysteroscopic endometrial ablation and myomectomy with Nd:YAG laser (n = 33) All patients treated with danazol 800 mg/day x 4 weeks preoperatively Dates: N/S Location: Columbus, OH Length of followup: Mean, 8 months; range, 6-55 months | No. of subjects at start: 33 with fibroids (of total study population of 161) Dropouts: 0 Loss to followup: 0 No. of subjects at end: 33 Setting: Ambulatory surgery facility Inclusion criteria: Refractory menorrhagia; at least one previous dilation and curettage; candidate for hysterectomy Exclusion criteria: Uterus > 16 wks in size Age: Mean, 40; range, 24-70 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | Preoperative menstrual pattern: Pads or tampons/menses Postoperative menstrual pattern: Pads or tampons/menses | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Menstrual pattern
  0 | (Amenorrhea) | 0%
  1-10 | (Light flow) | 6%
  11-20 | (Normal flow) | 3%
  21-40 | (Heavy flow) | 33%
  >40 | (Severe flow) | 58%
  0 | (Amenorrhea) | 49%
  1-10 | (Light flow) | 39%
  11-20 | (Normal flow) | 12%
  21-40 | (Heavy flow) | 0%
  >40 | (Severe flow) | 0%
Mais, Ajossa, Guerriero, et al., 1996 | Design: RCT, randomization by sealed envelope Intervention(s): Laparoscopic myomectomy (n = 20) Dates: Jan 1993-Jul 1994 Location: Cagliari, Italy Length of followup: 180 days | No. of subjects at start: 40 Dropouts: N/S Loss to followup: N/S No. of subjects at end: N/S Setting: Hospital Inclusion criteria: Premenopausal; nonpregnant; age 22-44 years; symptomatic subserous or intramural myomas; absence of associated ovarian lesions; 1-4 myomas; largest myoma 3-6 cm in diameter Exclusion criteria: Submucosal myomas (hysteroscopy); not fit for general anesthesia; systemic infection; psychiatric illness Age: Mean, 34.1 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: Mean diameter of largest myoma: 4.4 ±0.8 cm (laparoscopic group); 4.7±1.3 cm (abdominal group) Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: + C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: − F) Dropout rates: − G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Abdominal myomectomy (n = 20)
  1) | Estimated blood loss
  2) | Operative time
  3) | Complications
  4) | Time to discharge
  5) | Recurrence of myoma
  1) | Estimated blood loss (cc): Laparoscopic myo: 200±50 Abdominal myo: 230±44
  2) | Operative time (minutes): Laparoscopic myo: 100±31 Abdominal myo: 93±7
  3) | Complications: None in either group
  4) | Discharge by postoperative day 3: Laparoscopic myo: 90% Abdominal myo: 10%
  5) | Recurrence of myoma (by transvaginal ultrasound at 180 days postop): Laparoscopic myo: 10% Abdominal myo: 5%
Mais, Ajossa, Piras, et al., 1995 | Design: RCT, randomization by sealed envelope Intervention(s): Laparoscopic myomectomy without oxidized regenerated cellulose absorbable barrier (n = 25) Second-look laparoscopy performed at 12-14 weeks (investigator blinded). Dates: Jan 1993-Jun 1994 Location: Cagliari, Italy Length of followup: 12-14 weeks | No. of subjects at start: 50 Dropouts: N/S Loss to followup: N/S No. of subjects at end: N/S Setting: Hospital Inclusion criteria: Premenopausal; nonpregnant; absence of adhesions; subserosal or intramural myomas; 1-4 myomas; largest myoma 4-6 cm in diameter Exclusion criteria: None specified Age: Mean, 33.7; range, 23-42 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: Mean diameter of largest fibroid: 4.5±0.9 cm (without barrier); 4.3±0.9 (with barrier) Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: + C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: − F) Dropout rates: − G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Laparoscopic myomectomy with oxidized regenerated cellulose absorbable barrier (Interceed®, TC7) (n = 25)
  1) | Length of stay
  2) | Complications
  3) | Adhesion status at 2nd-look laparoscopy (12-14 weeks postop)
  1) | Length of stay: Mean for both intervention(s): 2 days
  2) | Complications (both interventions): Blood transfusions: none Febrile morbidity: none Laparotomy: none
  3) | Adhesion-free (%) at 2nd-look laparoscopy: Laparoscopic myomectomy with oxidized regenerated cellulose absorbable barrier: 60% Laparoscopic myomectomy without oxidized regenerated cellulose absorbable barrier: 12%
Malone, 1969 | Design: Case series, no controls Intervention(s): Abdominal myomectomy (n=125) Dates: 1944-1962 Location: Boston, MA Length of followup: Minimum 5 years (total length of followup, time to followup not described) | No. of subjects at start: 125 (unclear if number represents total number of procedures or total with followup data available) Dropouts: N/A Loss to followup: N/S No. of subjects at end: 125 (see note above) Setting: Teaching hospital Inclusion criteria: At least 5 years since surgery, with followup data available; all fibroids detected at surgery removed; patients in "reproductive years without menopausal symptoms" at time of surgery Exclusion criteria: N/S Age: NS Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: − E) Loss to followup: − F) Drop-out rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: − I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: + N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: − S) Standardized measures: −
  Solitary fibroids:
  | < 4 cm: | 33%
  | 5-8 cm: | 47%
  | 9-19 cm: | 20%
  Multiple: Range | | 1-14 cm
  Number of fibroids:
  | 1: 36% | > 1: 64%
  1) | Recurrence
  2) | Need for subsequent surgery
  1) | Recurrence: Solitary: 26.6% Multiple: 58.8%
  2) | Need for subsequent surgery: Solitary: 11.1% (all hysterectomy) Multiple: 26.3% (16 hysterectomy, 5 myomectomy) (No statistical testing done)
Mazdisnian, Kurzel, Coe, et al., 1995 | Design: Case series (retrospective), no controls Intervention(s): Abdominal (n = 49) or vaginal (n = 79) hysterectomy Dates: Dec 1990-Mar 1994 Location: Los Angeles, CA Length of followup: N/A (in-hospital outcomes only) | No. of subjects at start: 128 Dropouts: N/A Loss to followup: N/A No. of subjects at end: 128 Setting: Hospital Inclusion criteria: Women undergoing hysterectomy for fibroids; uterine weight 100-1000 g; fibroids confirmed by pathology Exclusion criteria: Patients undergoing laparoscopic-assisted vaginal hysterectomy Age: Mean, 44.7 Race: N/S Parity: 3.0±1.3 (vaginal hysterectomy, uterine weight 300-1000 g); 2.8±1.8 (vaginal hysterectomy, uterine weight 100-299 g); 1.8±1.4 (abdominal hysterectomy) Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | Outcomes reported for Groups I, II, and III, defined as follows: I = vaginal hysterectomy, uterine weight 300-1000 g; II = vaginal hysterectomy, uterine weight 100-299 g; III = abdominal hysterectomy | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: − S) Standardized measures: −
  1) | Length of stay
  2) | Operative time
  3) | EBL
  4) | Operative complications
  5) | Failed vaginal hysterectomies
  6) | Transfusions
  1) | Length of stay (days): Group I: 2.2 Group II: 2.7 Group III: 4.0 (P < 0.000 for Group III compared with Groups I and II)
  2) | Operative time (minutes): Group I: 127 Group II: 106 Group III: 135 min (P = 0.01)
  3) | EBL (ml): Group I: 416 Group II: 245 Group III: 314 (p = 0.01)
  4) | Complications: Not significant between groups
  5) | Failed vaginal hysterectomy: Group I: 6/37 (16%) could not be completed vaginally Group II: 2/42 failed
  6) | Transfusions: Group I: 3 (8%) Group II: 2 (5%) Group III: 4 (8%)
Mettler, Alvarez-Rodas, and Semm, 1995 | Design: Case series, no controls Intervention(s): Laparoscopic myomectomy (n = 482); 116 pts (24%) also received GnRH agonists preoperatively (leuprorelin or triptorelin 3.75 mg SC per month x 3-6 months) Dates: Jan 1990-Dec 1992 Location: Kiel, Germany Length of followup: N/A (in-hospital outcomes only) | No. of subjects at start: 482 Dropouts: N/A Loss to followup: N/A No. of subjects at end: 482 Setting: Hospital Inclusion criteria: Laparoscopic myomectomy performed for infertility, bleeding, or pain/pressure Exclusion criteria: None specified Age: Mean, 43.2; range, 21-69 Race: N/S Parity: Mean, 0.7; range, 0-5; 60% nulliparous Baseline uterine size: N/S Baseline fibroid size: N/S (reported as outcome measure only) Number of fibroids: N/S (reported as outcome measure only) Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: + N) Location of fibroids: + O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Number of fibroids removed
  2) | Size of fibroids removed
  3) | Length of stay
  4) | Adverse events
  5) | O/R time
  6) | Location of fibroids
  7) | Type of myoma
  8) | Length of GnRH treatment
  1) | Number of fibroids removed: Mean, 2.8; range, 1-6
  2) | Size of fibroids removed: 670 fibroids 1-< 4 cm; 709 fibroids 4-11 cm
  3) | Length of stay: Mean, 4 days (range, 2-9)
  4) | Adverse events: No transfusions or major complications reported
  5) | O/R time: Mean, 100 minutes (range, 30-220)
  6) | Location of fibroids: 36% were on the fundus, 39% in posterior, and 26% in multiple locations
  7) | Type of myoma: 579 (42%) subserous, 119 (9%) pedunculated, and 800 (58%) interstitial
  8) | Effect of length of preoperative GnRH treatment on size of fibroid: 3 versus 6 months of treatment showed no difference in fibroid size; after 3 months, the therapy had already reached its maximum effect
Miller, Johnston, and Rundell, 1996 | Design: Case series (prospective), concomitant controls Abdominal myomectomy (n = 11) Some patients received preop GnRH agonist for 3-6 months (n = N/S). Dates: N/S Location: Park Ridge, IL Length of followup: N/S | No. of subjects at start: 51 Dropouts: 0 Loss to followup: 1 No. of subjects at end: 50 Setting: N/S Inclusion criteria: Subserosal or intramural uterine fibroids, > 4 cm in diameter, entering, distorting, or impinging on endometrial canal, or 6 cm+ near endometrial canal; habitual abortion; primary or secondary infertility, with previous treatment unsuccessful Exclusion criteria: Myomas > 10 cm; or > 3 myomas > 4 cm; or > 5 myomas total Age: N/S Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: − E) Loss to followup: + F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: − I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: − S) Standardized measures: −
  Intervention(s):
  1) | Laparoscopic myomectomy (n = 40)
  1) | Pregnancy rate
  2) | Live birth rate at 1 year
  3) | Length of stay
  1) | Pregnancy rate: Laparoscopic myo: 75% Abdominal myo: 55%
  2) | Live birth rate at 1 year: Laparoscopic myo: 65% Abdominal myo: 45%
  3) | Length of stay: Laparoscopic myo: < 23 hrs Abdominal myo: N/S
Mints, Radestad, and Rylander, 1998 | Design: Case series (retrospective), no controls Intervention(s): Hysteroscopic myomectomy with endometrial ablation (n = 62) Dates: 1990-1995 Location: Stockholm, Sweden Length of followup: Mean, 29 months; range, 12-60 months | No. of subjects at start: 62 (of total series of 97; 35 pts did not have fibroids and underwent endometrial ablation alone) Dropouts: N/A Loss to followup: 0 No. of subjects at end: 62 Setting: Hospital Inclusion criteria: Severe menorrhagia with failed medical management; normal Pap, benign endometrial histology; no future pregnancy desired Exclusion criteria: None described Age: Mean, 44.5; range, 34-55 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: + E) Loss to followup: + F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: − S) Standardized measures: − Notes: Outcomes based on mailed questionnaire. Method/instrument used to determine magnitude of menstrual flow not described. No baseline data reported. Adverse event rates reported, but unable to separate rates of group with hysteroscopic myomectomy with endometrial ablation from group with endometrial ablation alone.
  1) | Improvement of menorrhagia
  2) | Subsequent hysterectomy
  1) | Improvement of menorrhagia (n = 62): Amenorrhea/hypomenorrhea: 74%
  2) | Subsequent hysterectomy (n = 62): 12%
Mollica, Pittini, Minganti, et al., 1996 | Design: Case series with historical controls Conservative management (observation) (n = 88) Dates: 1983-1984 Location: Ferrara, Italy Length of followup: N/S | No. of subjects at start: 106 pregnant women with fibroids and 2,463 historical controls Dropouts: 0 Loss to followup: 0 No. of subjects at end: 106 Setting: University hospital Inclusion criteria: Pregnant, with fibroids. Indications for surgery were recurrent pain; large, rapidly growing fibroids; and lower uterine segment myomas Exclusion criteria: None specified Age: N/S Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: − E) Loss to followup: + F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: − I) Race: − J) Pregnancy history: − K) Surgical history: + L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  Intervention(s):
  1) | Myomectomy (n = 18); or
  1) | Spontaneous abortion rate
  2) | C-section rate
  1) | Spontaneous abortion rate: In the operative group (n = 18), there were no spontaneous abortions. In the conservative management group (n = 88), 13.6% miscarried, and in the control group (n = 2,463) 9.3% miscarried.
  2) | C-section rates: In the operative group, 93.7% had a c-section; in the conservative management group, 34%; and in the controls, 16.3%.
Motashaw, Dave, and Paghdiwalla, 1995 | Design: Case series, no controls Intervention(s): Hysteroscopic myomectomy (n = 73) Dates: Jan 1985-Dec 1992 Location: Bombay, India Length of followup: N/S | No. of subjects at start: 73 Dropouts: N/A Loss to followup: N/S No. of subjects at end: N/S Setting: Hospital Inclusion criteria: Consecutive women with submucous myomata who underwent hysteroscopic myomectomy Exclusion criteria: None specified Age: Mean, N/S; range, 21-70 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: − E) Loss to followup: − F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: + O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Abnormal uterine bleeding
  2) | Postmenopausal bleeding
  3) | Pregnancy rate
  4) | Length of stay
  5) | Transfusions
  6) | Injury to organ
  7) | Metabolic abnormalities
  8) | Additional surgery necessary
  1) | Abnormal uterine bleeding (n = N/S): 82% "happy with result of hysteroscopic resection"
  2) | Postmenopausal bleeding (n = N/S): 100% "happy with result of hysteroscopic resection"
  3) | Pregnancy rate (n = 11 desired pregnancy): 64%
  4) | Length of stay: All but 5 less than 24 hrs
  5) | Transfusions: 4%
  6) | Injury to organ: 1% (uterine perforation)
  7) | Metabolic/electrolyte abnormalities: 0%
  8) | Additional surgery necessary: 1% (hysterectomy for bleeding)
Nezhat, Nezhat, Bess, et al., 1994 | Design: Case series (retrospective), no controls Intervention(s): Laparoscopically assisted myomectomy (n = 57). preoperatively, 39 pts (68%) received GnRH agonists for 1-4 months; 1 (2%) received danazol 800 mg daily for 6 weeks Dates: N/S Location: Atlanta and Macon, GA, and Tel-Hashomer, Israel Length of followup: Mean 11.35 months; range, 3-24 months | No. of subjects at start: 57 Dropouts: N/A Loss to followup: 0 No. of subjects at end: 57 Setting: Hospital Inclusion criteria: Laparoscopically assisted myomectomy performed for infertility, abnormal uterine bleeding, dysmenorrhea and pelvic pain, or discomfort due to uterine enlargement Exclusion criteria: None specified Age: Mean, 37.7; range, 29-46 Race: N/S Parity: N/S Baseline uterine size: Range, 8-26 weeks Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: + E) Loss to followup: + F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | O/R time
  2) | Length of stay
  3) | EBL
  4) | Complications
  5) | Return to normal activity
  6) | Relief of symptoms
  1) | O/R time: Mean 127 min (range 40-285)
  2) | Length of stay: 41 discharged on or before day 1; 12 on day 2; 4 after 72 hours
  3) | EBL: Mean, 267 cc (range, 50-1600)
  4) | Complications: Incisional hernia: 1 Klebsiella pneumonia: 1
  5) | Return to normal activity: All returned to normal activity within 3 weeks
  6) | Relief of symptoms: All patients with menorrhagia reported improvement; 14 with pelvic pain reported complete relief, and 9 partial relief
Nezhat, Nezhat, Silfen, et al., 1991 | Design: Case series, no controls Intervention(s): Laparoscopic myomectomy (n = 158); 77 patients (49%) were treated preoperatively with lupron for 1-4 months Dates: Jul 1987-Dec 1990 Location: Atlanta, GA Length of followup: Range, 3 months to 3 years | No. of subjects at start: 158 Dropouts: 4 (excluded from analysis due to large myomas) Loss to followup: 0 No. of subjects at end: 154 Setting: Ambulatory surgery facility Inclusion criteria: Laparoscopic myomectomy for pelvic pain, low abdominal pressure, abnormal uterine bleeding Exclusion criteria: Fibroids > 15 cm in diameter Age: Mean, N/S; range, 19-51 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: + E) Loss to followup: + F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Length of procedure
  2) | Complications
  3) | Length of stay
  4) | Pregnancy outcome
  1) | Length of procedure: Mean, 116 min (range, 50-190)
  2) | Complications: Major: 2 transfusions, 1 abdominal wall bleeder requiring second-look laparoscopy, 1 fluid overload. Minor: 5 abdominal wall ecchymosis, 2 superficial wound infections
  3) | Length of stay: Mean, 19.6 hours (range, 7-48 hours)
  4) | Pregnancy outcome: 6 patients achieved pregnancy. Of these, 2 abortions, 2 c-sections and 2 vaginal deliveries
Nezhat, Roemisch, Nezhat, et al., 1998 | Design: Case series (retrospective), no controls Intervention(s): Laparoscopic myomectomy (n = 114) Dates: May 1985-Nov 1994 Location: Palo Alto, CA Length of followup: Mean, 37 months; range, 6-120 months | No. of subjects at start: 114 (assuming no dropouts) Dropouts: N/A Loss to followup: N/S No. of subjects at end: N/S Setting: Tertiary referral center Inclusion criteria: N/S Exclusion criteria: N/S Age: Mean, 38; range, 25-57 Race: N/S Parity: Median, 0; range, 0-6 Baseline uterine size: N/S Baseline fibroid size: 21% of pts had fibroids 0-2.5 cm in diameter; 44%, 2.6-5 cm; 23%, 5.1-7.5 cm; 3%, 7.6-10 cm; 9%, > 10 cm Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: + E) Loss to followup: − F) Dropout rates: N/A G) Statistical issues: + EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: + O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: + S) Standardized measures: + Note: Survival analysis techniques used; pregnancy results not reported.
  1) | O/R time
  2) | EBL
  3) | Length of stay
  4) | Side effects/complications
  5) | Recurrence
  6) | Need for further surgery
  1) | O/R time: Mean, 2.3 hours (range, 1-6 hours)
  2) | EBL: Median, 200 cc (range, < 25-1200 cc)
  3) | Length of stay: 94.7% discharged within 24 hours Maximum 4 days (n = 1)
  4) | Complications: Transfusions: 7% Fever: 2/114 Bladder injury: 1/114
  5) | Recurrence: Overall: 38 (33.3%) Cumulative risk: 1 year: 10.6% 3 years: 31.7% 5 years: 51.4%
  6) | Need for further surgery: 24/38 recurrences, no treatment 8/38 additional myomectomy (of these 8, one had subsequent 3rd myomectomy, one had hysterectomy) 7/38 hysterectomy (one with interval myomectomy)
Nimaroff, Dimino, and Maloney, 1996 | Design: Case series (retrospective), no controls Intervention(s): LAVH with supracervical amputation (n = 15) or traditional technique (n = 5) Dates: Jul 1991-Jul 1993 Location: Manhasset, NY Length of followup: N/A (in-hospital outcomes only) | No. of subjects at start: 20 Dropouts: N/A Loss to followup: N/A No. of subjects at end: 20 Setting: Hospital Inclusion criteria: Patients undergoing LAVH with uteri > 12 weeks in size and > 450 g in weight Exclusion criteria: N/S Age: N/S Race: N/S Parity: N/S Baseline uterine size: Mean (with range): 607 g (460-736) (traditional technique group); 744 g (450-1700) (supracervical amputation group) Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: − I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: + S) Standardized measures: + Note: Sample size issues not discussed.
  1) | Complications
  2) | Length of stay
  3) | Operative time
  1) | Complications: Traditional: 1/5 (cystotomy) Supracervical: 2/15 (1 fever and 1 transfusion of autologous blood) Not significant
  2) | Length of stay (days): Traditional: Mean, 1.8 (range, 1-2) Supracervical: Mean, 2.0 (range, 1-5) Not significant
  3) | Operative time (minutes): Traditional: Mean, 217 Supracervical: Mean, 165 P < 0.05
Nisolle, Smets, Malvaux, et al., 1993 | Design: Case series, no controls Intervention(s): Laparoscopic myolysis (with Nd:YAG laser) (n = 48) Dates: 1989-1991 Location: Brussels, Belgium Length of followup: 1 year; 15 patients (31%) were followed up again at 3 years | No. of subjects at start: 48 Dropouts: N/A Loss to followup: N/S for 6 weeks through 1 year; 33 through 3 years No. of subjects at end: 15 (at 3 years) Setting: Hospital Inclusion criteria: Intramural fibroids up to 8 cm in diameter; age > 35; no desire to bear children; pelvic pain; compression symptoms; uterine volume 9-12 weeks Exclusion criteria: None specified Age: Mean, 42; range, 35-48 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: Range, 3-8 cm in diameter Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: + E) Loss to followup: + F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids- − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Decrease in fibroid size after myolysis
  2) | Adverse effects of procedure
  3) | EBL
  4) | O/R time
  5) | Second look laparoscopy
  1) | Decrease in fibroid size after myolysis (mean, with range): 6 weeks: 4% (0-6%) 12 weeks: 12% (2%-18%) 6 months: 41% (18%-62%) 1 year: Results "similar to those after 6 months"
  2) | Adverse effects: Of 48 laparoscopic myolysis procedures, there were no cases of infection or hemorrhage, and no injuries to organs
  3) | EBL: Less than 50 cc in all but one case
  4) | O/R time: 20-45 minutes
  5) | Second-look laparoscopy performed at 6 months: In 7 of first 20 patients, revealed dense and fibrous adhesions
Pelage, Le Dref, Soyer, et al., 2000 | Design: Case series, no controls Intervention(s): Uterine artery embolization Dates: June 1991-December 1996 Location: Paris, France Length of followup: 2 years | No. of subjects at start: 80 Dropouts: N/A Loss to followup: 0? No. of subjects at end: 80 Setting: Hospital Inclusion criteria: "Hemorrhage related to uterine leiomyomata," confirmed by ultrasound; failure of medical therapy Exclusion criteria: Planning pregnancy Age: Mean, 44.7; range, 30-54 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: mean diameter 5.8 cm, range 2.1-10 cm Number of fibroids: 31% 16% 21% >3 31% Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: − F) Drop-out rates: N/A G) Statistical issues: + EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: + L) Fibroid/uterine size: + M) Number of fibroids: + N) Location of fibroids: + O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Improvement in symptoms
  2) | Complications/side effects
  3) | Subsequent procedures
  4) | Reduction in size
  1) | Improvement in symptoms Complete resolution: 90% "Marked" improvement: 4% No change: 6%
  2) | Complications/side effects 8% amenorrhea (2/6 transient, 4/6 permanent) 6% passage of fibroids 85% pelvic pain, managed by narcotics 9% fever within first 2 weeks
  3) | Subsequent procedures 4 myomectomies, 1 hysterectomy
  4) | Reduction in largest fibroid size 2 months: 20% reduction 6 months: 52% reduction
Pelosi and Pelosi, 1997 | Design: Case series (retrospective), no controls Intervention(s): Laparoscopic-assisted transvaginal myomectomy; 5 pts (24%) were treated preoperatively with leuprolide (for anemia) Dates: 1992-1995 Location: Bayonne, NJ Length of followup: Up to 3 years (unclear) | No. of subjects at start: 21 Dropouts: N/A Loss to followup: N/S No. of subjects at end: N/S Setting: Hospital; ambulatory surgery facility; outpatient clinic/physician office Inclusion criteria: Laparoscopic myomectomy with transvaginal removal of fibroid; largest myoma on the fundus or on the posterior uterine wall, extending into the inner third of the myometrium (as determined by ultrasound) Exclusion criteria: Inadequate vaginal exposure (as determined by physical examination) Age: Mean, N/S; range, 27-43 Race: N/S Parity: Range, 0-3 Baseline uterine size: N/S Baseline fibroid size: Range, 4-17 cm in diameter Number of fibroids: Single myomas in 5 patients Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: − F) Dropout rates: N/A G) Statistical issues: N/A EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: + L) Fibroid/uterine size: + M) Number of fibroids: + N) Location of fibroids: + O) Measurement timing: − P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Fibroid weight removed
  2) | EBL
  3) | Pregnancy
  4) | Pregnancy complications
  5) | O/R time
  1) | Fibroid weight removed (mean): 230 g
  2) | EBL (mean, with range): 130 cc (50-450)
  3) | Pregnancy (n = 9): 66%
  4) | Pregnancy complications: 33%
  5) | O/R time (mean, with range): 88 min (49-100)
Phillips, Milim, Nathanson, et al., 1997 | Design: Case series (prospective), no controls Myolysis in conjunction with TEMR, TSR of submucous leiomyomas, or both (for patients who also had chronic menorrhagia; n = 52) 164 pts (98%) were treated with leuprolide for 3 months preoperatively. Dates: Feb 1992-Mar 1995 Location: Stony Brook, NY Length of followup: Mean, 36 months | No. of subjects at start: 167 Dropouts: N/A Loss to followup: 0 No. of subjects at end: 167 Setting: Community and teaching hospitals Inclusion criteria: Leiomyoma by pelvic exam; pain/pressure symptoms and/or intractable chronic menorrhagia Exclusion criteria: None specified Age: Mean, 44.7; range, 22-52 Race: N/S Parity: Mean, 2.0; range, 0-6 Baseline uterine size: 637±35.7 cc (myolysis alone); 582±25.1 cc (TEMR/TSR) Baseline fibroid size (before leuprolide): 198±13.9 cc (myolysis alone); 181±10.9 cc (TEMR/TSR) Number of fibroids: N/S Baseline Hgb/Hct: N/S | | No p values < 0.05 | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: + O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: +
  Intervention(s):
  1) | Myolysis alone (for patients with symptoms of pressure, pain, or both; n = 115), or
  1) | Uterine size
  2) | Fibroid size
  3) | Adverse outcomes
  4) | Need for further surgical treatment
  1) | Uterine size (mean cc):
    | Myolysis alone | Myolysis + TEMR/TSR
    Pre: | 637±35.7 | 582±25.1
    Post
    (7-12 mos): | 139±8.0 | 113±6.9
    % change: | 78% | 81%
  2) | Fibroid size (mean cc):
    | Myolysis alone | Myolysis + TEMR/TSR
    Pre: | 198±13.9 | 181±10.9
    Post
    (7-12 mos): | 31±2.5 | 27±2.3
    % change: | 85% | 85%
  3) | Adverse outcomes:
    | Myolysis alone | Myolysis + TEMR/TSR
    UTI: | 1.7% | 1.9%
    Fever: | 3.5% | 7.7%
    Abd wall
    hematoma: | 0% | 3.8%
  4) | Need for further surgical treatment: Myolysis alone: 1.2% Myolysis + TEMR/TSR: 4.2%
Phillips, Nathanson, Meltzer, et al., 1995 | Design: Case series (prospective), concomitant controls Intervention(s): Hysteroscopic resection of fibroids alone (n = 120), or hysteroscopic myomectomy + endometrial ablation (n = 88) Dates: Mar 1988-Mar 1994 Location: Stony Brook, NY Length of followup: Resection only: Mean, 34 months; range, 1-78 months. Resection + ablation: Mean, 33 months; range, 1-78 months. | No. of subjects at start: 208 Dropouts: N/A Loss to followup: 23 No. of subjects at end: 185 Setting: Hospital Inclusion criteria: Chronic menorrhagia; steroid therapy ineffective, contraindicated, not tolerated, or refused; submucous fibroid; desire to retain fertility (hysteroscopic resection only); endometrial ablation considered if no desire for retaining fertility, patient not candidate for hysterectomy Exclusion criteria: Malignant or premalignant lesions, uterine cavity greater than 12 cm long, endometrial polyps, concomitant laparoscopic myolysis Age: Range, 32-63;. Means: resection only, 37.9; resection + ablation, 43.2 (p < 0.05) Race: N/S Parity: N/S Baseline uterine size (means): Resection only, 7.2 wks; resection + ablation, 6.8 wks (p < 0.05) Baseline fibroid size: Range, 1-8.5 cm in diameter. Means: resection only, 2.6 cm; resection + ablation, 3.2 cm Number of fibroids: 161 patients (77%) had only one, 47 (23%) >1 Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: + N) Location of fibroids: + O) Measurement timing: + P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Complications
  2) | Length of surgery
  3) | Need for additional treatment
  4) | Clinical response
  1) | Complications: Resection only: 4.2% (3 fluid overload, 1 dilutional hyponatremia, 1 postoperative hemorrhage) Resection + ablation: 3.4% (3 fluid overload)
  2) | Length of surgery (minutes): Resection only: 30.2 (range, 10-85) Resection + ablation: 39.5 (range, 10-98) (p < 0.05)
  3) | Need for additional treatment within 6 months: Resection only: Repeat resection: 2.7% Endometrial ablation: 1.1% Abdominal myomectomy: 0.9% Hysterectomy: 0.5% Resection + ablation: Repeat resection + ablation: 1.1% Endometrial ablation: 0.5% Hysterectomy: 1.6%
  4) | Clinical response (long-term results up to 6 years): Resection only: Amenorrhea: 7.5% Hypomenorrhea: 0% Eumenorrhea: 76.6% Unsatisfactory: 15% Resection + ablation: Amenorrhea: 62.8% Hypomenorrhea: 14.1% Eumenorrhea: 11.5% Unsatisfactory: 11.5%
Phillips, Nathanson, Milim, et al., 1996 | Design: RCT, randomization by sealed envelope Hysteroscopic myomectomy without vasopressin infusion (n = 25) Dates: Apr 1994-Nov 1995 Location: New York, NY Length of followup: N/A (in-hospital outcomes only) | No. of subjects at start: 51 pts with myomas (of larger study population of 106); demographic data given for total population Dropouts: 0 Loss to followup: N/A No. of subjects at end: 51 Setting: Hospital; ambulatory surgery facility Inclusion criteria: Chronic menorrhagia unresponsive to medical treatment; intracavity myoma Exclusion criteria: Uterine cavity sounded to > 12 cm Age: Mean, 40.7 Race: 92% white, 5% African-American, 3% Hispanic Parity: 2.5 (vasopressin group); 2.6 (control group) Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: + C) Pt selection criteria: + D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: + J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  Intervention(s):
  1) | Hysteroscopic myomectomy with dilute vasopressin infusion into cervical stroma (n = 26)
  1) | Operative blood loss
  2) | Operative time
  3) | Operative complications
  1) | Operative blood loss: Vasopressin: 37 ml Control: 32 ml
  2) | Operative time: Vasopressin: 37 min Control: 40.9 min
  3) | Operative complications: No blood transfusion, uterine perforation, hyponatremia, or fluid overload in either group
Pooley, Ewen, and Sutton, 1998 | Design: Case series (retrospective), no controls Intervention(s): Transcervical resection of the endometrium (n = 380, 108 [28.4%] with fibroids); not all results given separately for patients with fibroids Dates: Aug 1988-Dec 1992 Location: Guildford, UK Length of followup: 2-5 years | No. of subjects at start: 380 Dropouts: N/A Loss to followup: N/S No. of subjects at end: N/S Setting: Hospital; ambulatory surgery facility Inclusion criteria: Menorrhagia; unable or unwilling to take medical treatment Exclusion criteria: Incomplete resection; other procedures without resection; resection of portion of endometrium Age: Mean, 42.3 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | 96% of all hysterectomies performed within 3 years of surgery Other results (not adjusted for fibroids): 5-year hysterectomy rate: Age > 45 years: 14.9% Age < 45 years: 35% (p < 0.01) Experience of surgeon: Senior surgeon: 12.6% Surgeons-in-training: 38% (p < 0.01) | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: − F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: + S) Standardized measures: + Note: Multivariate survival analysis not performed. Survival analysis accounted for varying length of followup.
  1) | Complications (not reported separately for patients with fibroids)
  2) | Need for subsequent hysterectomy
  1) | Complications: 1 failure to dilate cervix 13 (3.4%) intraoperative bleeding 1 transfusion 12 (3.2%) perforations, 10 requiring laparoscopy or laparotomy 6 (1.6%) intraoperative or early postoperative hysterectomy
  2) | Need for subsequent hysterectomy: Cumulative 5-year hysterectomy rate: 27.7% in women with fibroids, 29.3% in women without (not significant)
Reilly and Nour, 1998 | Design: Case series (retrospective), no controls Intervention(s): Abdominal myomectomy (n = 120) Dates: Oct 1989-Dec 1995 Location: Boston, MA Length of followup: N/A (in-hospital outcomes only) | No. of subjects at start: 120 Dropouts: N/A Loss to followup: N/A No. of subjects at end: 120 Setting: Hospital Inclusion criteria: Abdominal myomectomy during inclusion dates Exclusion criteria: None specified Age: Mean, 36.6; range, 25-42 Race: N/S Parity: N/S Baseline uterine size: 13.4 weeks Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: + N) Location of fibroids:− O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: − S) Standardized measures: +
  1) | EBL
  2) | O/R time
  3) | Transfusions
  4) | Need for hysterectomy
  5) | Number of fibroids removed
  6) | Complications
  1) | EBL: Mean, 207 ml; range, 50-800
  2) | O/R time: Mean, 92.4 min
  3) | Transfusions: No heterologous transfusions. 4.2% autologous transfusions
  4) | Need for hysterectomy: No hysterectomies performed in 120 consecutive myomectomies
  5) | Number of fibroids removed: Mean, 8.3
  6) | Complications: Hematoma: 1 Superficial wound separation: 1 postop fever: 14
Reiter, Wagner, and Gambone, 1992 | Design: Case series (retrospective), no controls Intervention(s): Hysterectomy (type not described) (n = 93) Dates: Jan 1986-Jan 1989 Location: San Diego, CA Length of followup: N/A (in-hospital outcomes only) | No. of subjects at start: 93 Dropouts: N/A Loss to followup: N/A No. of subjects at end: 93 Setting: Hospital Inclusion criteria: Hysterectomy for fibroids; diagnosis confirmed by pathology Exclusion criteria: None specified Age: Mean, 42.1 Race: N/S Parity: Mean, 2.2 Baseline uterine size: Mean, 374 g; 53 patients (57%) < 12 weeks; 40 patients (43%) > 12 weeks Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb: N/S Baseline Hct: Mean, 38.0% | | Results stratified by preoperative uterine size estimates (< 12 weeks [n = 53] versus > 12 weeks [n = 40]) | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: − S) Standardized measures: + Note: Multivariate analysis not performed; sample size issues not discussed.
  1) | EBL
  2) | Complications
  1) | EBL (cc): <12 weeks: 358±261 > 12 weeks: 428±330 Not significant
  2) | Complications: Total: Not significant Individual (n):
    | < 12 weeks: 28.3%
    | > 12 weeks: 27.5%
    | <12 weeks | > 12 weeks
    UTI | 1 | 0
    Temp > 101°F | 9 | 5
    DVT | 1 | 0
    Bowel obstruction | | 0 | 1
    Cuff cellulitis | 0 | 1
    Hematoma | 0 | 2
    Wound infection | | 1 | 0
    Readmission | 2 | 1
    Transfusion | 1 | 1
Ribeiro, Reich, Rosenberg, et al., 1999 | Design: Case series (retrospective), no controls Intervention(s): Laparoscopic myomectomy (n = 28); 2 patients had concomitant hysteroscopic myomectomy Dates: Mar 1986-Nov 1997 Location: New York, NY Length of followup: N/S | No. of subjects at start: 28 Dropouts: N/A Loss to followup: 0 No. of subjects at end: 28 Setting: Tertiary care advanced laparoscopic center Inclusion criteria: Infertility > 12 months; normal infertility evaluation; at least one fibroid > 5 cm in diameter Exclusion criteria: None specified Age: Mean, 36.4; range, 28-39 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: At least one fibroid > 5 cm in diameter Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: − E) Loss to followup: + F) Dropout rates: N/A G) Statistical issues: + EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: + S) Standardized measures: + Notes: Survival analysis not performed. Time to pregnancy not recorded.
  1) | Fertility rate
  2) | Pregnancy outcomes
  3) | Complications
  4) | Length of stay
  1) | Fertility rate: 18 patients (64.3%) pregnant "without the use of assisted reproductive techniques"
  2) | Pregnancy outcomes: 4/18 spontaneous abortion in 1st trimester 14 viable term infants, 6 vaginally, and 8 c-section
  3) | Complications: "No major postoperative complications"
  4) | Length of stay: Mean, 9 hours
Richardson, Bournas, and Magos, 1995 | Design: RCT, randomized using random numbers table (inadequate concealment). Results also reported for 75 patients included in an uncontrolled case series of laparoscopically assisted vaginal hysterectomy. LAVH, RCT (n = 22, 16 with fibroids) Vaginal hysterectomy, RCT (n = 23, 16 with fibroids) Dates: N/S Location: London, England Length of followup: 0-6 wks | No. of subjects at start: 45 (RCT); 75 (case series) Dropouts: N/A Loss to followup: N/S No. of subjects at end: N/S Setting: Hospital Inclusion criteria: Relative contraindications to vaginal surgery Exclusion criteria: Uterus > 16 wks; endometrial cancer; adnexal masses; known dense adhesions; moderate/severe endometriosis Age: Mean, 44.3; range, 22-71 Race: N/S Parity: % nulliparous: 17% (vaginal hysterectomy group), 27% (LAVH, RCT group), 26% (LAVH, case series) Baseline uterine size: 8 wks (range, 4-16) (vaginal hysterectomy group); 9 wks (range, 4-15) (LAVH, RCT group); 8 wks (range, 4-16) (LAVH, case series) Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: − C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: − F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: − Note: No statistical testing reported.
  Intervention(s):
  1) | LAVH, case series (n = 75)
  1) | O/R time
  2) | Length of stay
  3) | Return to normal activities (prospective calendar)
  4) | Return to work (prospective calendar)
  5) | EBL
  6) | Complications
  1) | O/R time (RCT results) (mean, with range): LAVH: 131.4 minutes (76-180) Vaginal hyst: 76.7 minutes (35-150) Statistical significance not assessed O/R time for vaginal hysterectomy related to uterine size, but no statistical testing reported.
  2) | Length of stay (RCT) (mean, with range): LAVH: 3.2 days (2-7) Vaginal hyst: 3.3 days (1-18)
  3) | Return to normal activities (mean, with range): LAVH: 23.1 days (7-56) Vaginal hyst: 22.2 days (7-56)
  4) | Return to work (mean, with range): LAVH: 6.4 weeks (2-11) Vaginal hyst: 5.7 weeks (1.5-11)
  5) | EBL: LAVH: 272 cc Vaginal hyst: 181 cc
  6) | Complications: Overall: LAVH: 36% Vaginal hyst: 30%
  | "Excluding complications not contributing to patient morbidity": LAVH: 18% Vaginal hyst: 13%
Rosenfeld, 1986 | Design: Case series, no controls Intervention(s): Abdominal myomectomy in patients with otherwise unexplained infertility (n = 23) Dates: 1977-1984 Location: New York, NY Length of followup: N/S | No. of subjects at start: 23 Dropouts: N/A Loss to followup: 0 No. of subjects at end: 23 Setting: Academic medical center hospital Inclusion criteria: Otherwise unexplained infertility Exclusion criteria: Any other cause of infertility Age: Mean, 34.2; range, 26-42 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: Diameter range 3-14 cm Number of fibroids: Solitary fibroids in 8 patients Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: − E) Loss to followup: + F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: + N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: − S) Standardized measures: + Note: No statistical testing reported. No discussion of sample size.
  1) | Pregnancy rate
  2) | Pregnancy outcome
  3) | Complications
  4) | Subsequent therapy
  1) | Pregnancy rate: Overall: 65.2% 10/15 primary infertility, 5/8 secondary infertility No clear relationship between age, duration of infertility, size or number of fibroids 14/15 conceived within 12 months, 1/15 20 months after procedure
  2) | Pregnancy outcomes: 56.5% delivery rate 1 ectopic pregnancy
  3) | Complications: "No operative complications, no blood transfusions"
  4) | Subsequent therapy: 1/28 hysterectomy (after 2 term deliveries)
Rossetti, Paccosi, Sizzi, et al., 1999 | Design: Case series (prospective), no controls Intervention(s): Laparoscopic myomectomy (n = 123) Dates: Jan 1994-May 1998 Location: Rome, Italy Length of followup: N/A (in-hospital outcomes only) | No. of subjects at start: 123 Dropouts: 27 patients excluded from analysis (27 with myomas > 8 cm, 2 whose myomectomies were converted to laparotomy, and 8 with myomas < 5 cm) Loss to followup: N/A No. of subjects at end: 96 Setting: Hospital Inclusion criteria: Uterine fibroids with infertility or recent significant uterine enlargement or symptoms (pain, menometrorrhagia, abnormal bleeding) Exclusion criteria: None specified Age: Mean, 38; range, 22-48 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: Mean diameter, 5.3±3.4 cm; range, 2-14 cm Number of fibroids: 45.5% of patients had more than one myoma, with a maximum of 7 Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: + N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Complications
  2) | Conversion to laparotomy
  3) | Number of fibroids removed
  4) | O/R time
  1) | Complications: No transfusions, injury to organs, or febrile morbidity
  2) | Conversion to laparotomy: 1.6%
  3) | Number of fibroids removed: Mean, 2.0 per patient (range, 1-7)
  4) | O/R time: Range, 40-240 minutes
Schneider, Merker, Martin, et al., 1997 | Design: Case series (prospective), concomitant controls Intervention(s): 1) LAVH (n = 30 cases) TAH (n = 30 controls) Dates: Apr 1994-Mar 1995 Location: Jena, Germany Length of followup: N/A (in-hospital outcomes only) | No. of subjects at start: 60 Dropouts: N/A Loss to followup: N/A No. of subjects at end: 60 Setting: Hospital Inclusion criteria: Symptomatic uterine fibroids; candidates for abdominal hysterectomy Exclusion criteria: None specified Age: Mean, 46.7 Race: N/S Parity: 2.1 (LAVH group); 1.5 (TAH group) Baseline uterine size: 254 ± 32 g (LAVH group); 216 ± 28 g (TAH group) Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb: 8.02 (LAVH group); 8.06 (TAH group) Baseline Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Hgb
  2) | Length of stay
  3) | Complications
  4) | Charges
  1) | Hgb (mmol/l):
  | | LAVH | TAH
  | preoperative Hgb: | 8.02 | 8.06
  | postoperative Hgb: 6.96 6.86 (P = not significant)
  2) | Length of stay (days): LAVH: 8.5 ± 2.4 TAH: 11.9 ± 3 (P < 0.05)
  3) | Complications:
  | | LAVH | TAH
  | Transfusions: | 7% | 20%
  | postop antibiotics: | 20% | 30%
  | Ureterovaginal fistula: | 0% | 3%
  | Wound infections: | 0% | 3%
  | (P-values not reported)
  4) | Total charges (European Union currency units): LAVH: 2901 TAH: 3644
Seinera, Arisio, Decko, et al., 1997 | Design: Case series (retrospective), no controls Intervention(s): Laparoscopic myomectomy (n = 54). Patients with leiomyomas > 5 cm and/or anemia (n = 16) were pretreated for 3 months with GnRH agonist. Dates: Jan 1992-Sep 1996 Location: Torino, Italy Length of followup: 6 months (unclear whether mean or median) | No. of subjects at start: 54 Dropouts: N/A Loss to followup: N/S No. of subjects at end: N/S Setting: Hospital; ambulatory surgery facility; outpatient clinic/physician office Inclusion criteria: Myomas > 3 cm Exclusion criteria: None specified Age: Mean, 34.6; range, 23-48 Race: N/S Parity: N/A Baseline uterine size: N/S Baseline fibroid size: Range, 3-8 cm Number of fibroids: Range, 1-4 Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: − F) Dropout rates: N/A G) Statistical issues: N/A EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: −K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: + N) Location of fibroids: + O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: -
  1) | Bleeding/ dysmenorrhea
  2) | Pregnancy rate
  3) | Length of stay
  4) | Adverse events
  1) | Bleeding/dysmenorrhea (n = 20): Posttreatment: 90% "had no complaints"
  2) | Pregnancy (n = 30): Posttreatment: 17% Complications: 0
  3) | Length of stay: 2.09 days (2-5)
  4) | Adverse events: Bleeding leading to take back: 1.8% Conversion to laparotomy: 1.8%
Seoud, Patterson, Muasher, et al., 1992 | Design: Case series (retrospective), no controls Intervention(s): IVF in patients with fibroids and no surgery (n = 11) and those with prior myomectomy (n = 47) Dates: Jan 1987-Dec 1990 Location: Norfolk, VA Length of followup: N/S | No. of subjects at start: 58 (11 with no prior surgery for fibroids; 47 with prior myomectomy) Dropouts: N/A Loss to followup: 0 No. of subjects at end: 58 Setting: Hospital; outpatient clinic/physician office Inclusion criteria: Fibroids, with prior myomectomy (if any) confirmed by surgery or pathology report Exclusion criteria: None specified Age: Mean, 36.3 Race: N/S Parity: % nulliparous: 90.9% (no-surgery group); 87.0% (prior surgery group) Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: − E) Loss to followup: + F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: - J) Pregnancy history: + K) Surgical history: + L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: + S) Standardized measures: + Note: Sample size issues not discussed.
  1) | Pregnancy rate after IVF, expressed as pregnancy/embryo transfer and stratified by category of infertility
  1) | Pregnancy rate (total = ongoing pregnancies, "chemical" pregnancies, and spontaneous abortion):
  | Myoma (n = 11):
  | Cause of infertility | Ongoing | Total
  | Tubal (10 cycles) | 40% | 70%
  | Pelvic factor (5 cycles) | 0% | 0%
  | Idiopathic (9 cycles) | 20.8% | 20.8%
  | Prior myomectomy (n = 47):
  | Cause of infertility | Ongoing | Total
  | Tubal (73 cycles) | 13.5% | 24.3%
  | Endometriosis (18 cycles) | 27.8% | 44.4%
  | Male factor (16 cycles) | 18.8% | 31.1%
  | Pelvic factor (16 cycles) | 18.8% | 43.8%
  | Differences not significant between groups, or compared to patients without fibroids undergoing IVF in same cycle.
Sirjusingh, Bassaw, and Roopnarine-singh, 1994 | Design: Case series (retrospective), no controls Intervention(s): Abdominal myomectomy (n = 114) Dates: 1983-1988 Location: Trinidad Length of followup: Range, 2-10 years | No. of subjects at start: 114 Dropouts: N/A Loss to followup: 11 No. of subjects at end: 103 Setting: Hospital Inclusion criteria: Consecutive patients undergoing abdominal myomectomy Exclusion criteria: None specified Age: Mean, 32.7; range, 21-42 Race: N/S Parity: 0.4; 72% nulliparous Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: − S) Standardized measures: −
  1) | Pregnancy rate
  2) | Term deliveries
  3) | Pregnancy complications
  4) | Transfusions
  5) | Recurrent fibroids
  6) | Additional surgery for fibroids
  1) | Pregnancy rate: 33%
  2) | Term deliveries: 23%
  3) | Pregnancy complications: Uterine rupture: 0%
  4) | Transfusions: 16.5%
  5) | Recurrent fibroids: 17%
  6) | Additional surgery for fibroids: Repeat myomectomy: 4% Hysterectomy: 8%
Siskin, Stainken, Dowling, et al., 2000 | Design: Case series (prospective), no controls Intervention(s): Outpatient uterine artery embolization (n = 49) Dates: N/S Location: Albany, NY Length of followup: 3 months in 53%; 6 months in 33% | No. of subjects at start: 49 Dropouts: N/S Loss to followup: 1 No. of subjects at end: 48 (16 with complete data) Setting: Hospital interventional radiology suite with Postprocedure discharge Inclusion criteria: Symptomatic fibroids Exclusion criteria: None specified Age: Mean, 44.5; range, 28-54 Race: N/S Parity: N/S Baseline uterine size: Mean, 688 cc; range, 71-2029 cc Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: − G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Technical success
  2) | Procedure duration
  3) | Postprocedure symptoms
  4) | Time to discharge
  5) | Complications
  6) | Satisfaction
  7) | Reduction in volume
  1) | Technical success: 48/49
  2) | Procedure duration: Mean, 74.3 minutes; range, 46-233
  3) | Postprocedure symptoms: Immediate: Mean pain rating scale, 5.7 (range, 1-9) 24 hours: 3.7% pelvic pain/cramping 5.5% fatigue 6.9% nausea/vomiting 8.4% vaginal discharge
  4) | Time to discharge: 96% discharged within 8 hours
  5) | Complications: 1 hysterectomy at 3 months for prolonged pain: path-myometrial necrosis 1 prolonged fever
  6) | Satisfaction: 88.5% improvement or elimination of presenting symptoms at 3 months
  7) | Reduction in volume at 6 months (n = 16 of 49): Mean, 47.5%
Smith and Uhlir, 1990 | Design: Case series, no controls Intervention(s): Abdominal myomectomy Dates: Jan 1981-Nov 1988 Location: Seattle, WA Length of followup: N/S | No. of subjects at start: 63 Dropouts: N/A Loss to followup: 2 No. of subjects at end: 61 Setting: Teaching hospital Inclusion criteria: Myomectomy for at least one fibroid greater than 5 cm Exclusion criteria: None specified Age: Mean 35.8, range 27-47 Race: N/S Parity: Nulligravid: 54% At least one pregnancy: 40% At least one live birth: 14% Baseline uterine size: > 12 weeks: 92% Baseline fibroid size: Mean weight 284 g, range 100-765 g Number of fibroids: Mean 5, range 1-29 Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: + E) Loss to followup: + F) Drop-out rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: + N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Pregnancy rate
  2) | Recurrence rate
  1) | Pregnancy rate: Pregnancies: 16/32 (50%) Live births: 12/32 (40%) Ectopics: 2 SAB: 2
  2) | Recurrence rate: 4/62 (6.4%) (2 hysterectomies, 1 myomectomy, other not specified)
Spies, Scialli, Jha, et al., 1999 | Design: Case series (prospective), no controls Intervention(s): Bilateral uterine artery embolization Dates: Jul 1997-Mar 1999 Location: Washington, DC Length of followup: Mean, 8.7 months; minimum, 3 months | No. of subjects at start: 61 Dropouts: N/A Loss to followup: 0 No. of subjects at end: 61 Setting: University hospital Inclusion criteria: Fibroids resulting in heavy menstrual bleeding, pelvic pain or pressure, and/or urinary frequency/ureteral compression; failure of, refusal of, or not candidates for medical therapy; first 50 patients had to have "exhausted" all alternatives except hysterectomy or repeat myomectomy Exclusion criteria: Endometrial hyperplasia/neoplasia Race: White, 47.5%; black, 47.5%; Hispanic, 5% Parity: N/S Baseline uterine size: Mean, 613±383 cc; median, 512 cc; range, 124-1764 Baseline fibroid size: ("Dominant fibroid") Mean, 204±210; median, 110; range, 9-918 Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: + J) Pregnancy history:− K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  Age: | 30-39: 23%
  | 40-49: 69%
  | 50-59: 8%
  1) | Change in uterine size
  2) | Change in fibroid size
  3) | Length of stay
  4) | Return to work
  5) | Complications/side effects
  6) | Symptomatic relief
  7) | Patient satisfaction
  8) | Need for additional therapy
  1) | Change in uterine size: 3 months: Mean volume reduction: 29±25% Median: 34% (range, 74 to +30%) 1 year: Mean: 48 ± 16% Median: 48% (range, 82 to -20%)
  2) | Change in fibroid size: 3 months: Mean reduction: 49±29% Median: 50% (range, 98 to +25%)
  | 1 year: Mean: 69±27% Median: 78 (range, 100 to -72%)
  3) | Length of stay: Same day: 15% One night: 77% Two nights: 8% Readmission to ER: 8% ER visit: 2%
  4) | Return to work or normal activity: Mean, 8.9 days; range, 2-18
  5) | Complications/side effects: Pelvic pain "most common side effect" (numbers not given) 35% had at least one "menopausal" symptom 1 dissection of uterine arteries (no significant sequelae) 1 urethral obstruction 1 expelled fibroid 3 weeks after procedure 2 fevers 3 and 21 weeks after procedure 7 patients with menstrual irregularity or amenorrhea (all patients with amenorrhea age 49 or 50 years)
  6) | Symptomatic relief: Menorrhagia: Markedly improved: 68% Moderately improved: 15% Slightly improved: 6% No change: 9% Slightly worse: 2% Pain/pressure: Markedly improved: 71% Moderately improved: 12% Slightly improved: 11% No change: 2% Slightly worse: 2%
  7) | Patient satisfaction: Very satisfied: 66% Moderately satisfied: 23% Slightly satisfied: 3% Neither satisfied or dissatisfied: 3% Slightly dissatisfied: 2% Very dissatisfied: 3%
  8) | Need for additional therapy: 1 hysteroscopic resection 1 D+C 2 hysterectomies (3 and 1 year postprocedure)
Spies, Warren, Mathias, et al., 1999 | Design: Case series, no controls Intervention: Uterine artery embolization Dates: Jul 1997-Jan 1999 Location: Washington, DC Length of followup: 6 months | No. of subjects at start: 50 Dropouts: N/A Loss to followup: 13/50 3 months 19/50 6 months No. of subjects at end: 31 at 6 months Setting: Hospital Inclusion criteria: Symptomatic fibroids, confirmed by ultrasound or MRI Exclusion criteria: None specified Age: N/S Race: White 38.8% Black 46.9% Hispanic 6.1% Asian 4.1% Other: 4.1% Parity: N/S Baseline uterine size: Mean 602 cc, ± 357 cc, range 124-1764 cc Baseline fibroid size: "Dominant" fibroid Mean 216 ± 213 cc, range 9 -918 cc Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Drop−out rates: N/A G) Statistical issues: + EXTERNAL VALIDITY H) Age: − I) Race: + J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: + S) Standardized measures: + Given small sample size, loss to followup of dissatisfied patients might affect conclusions
  1) | Change in health-related quality of life (including validated scales from Medical Outcomes Study): General health Comparative health perception Restricted activity Difficulty with activity Pain Energy/vitality Sleep Mental health Health distress Self-image Sexual functioning
  2) | Change in symptom- specific measures: Heavy bleeding Abdominal swelling Pelvic pain Backaches Bowel problems Painful menses Symptom frequency Symptom "bothersomeness" Overall symptoms
  3) | Global satisfaction
  1) | Change in overall quality of life Statistically significant positive changes in all measures comparing baseline to 3 months, baseline to 6 months
  2) | Change in symptom-specific measures Statistically significant positive changes in all symptom measures comparing baseline with 3 months, all except backache comparing baseline with 6 months
  3) | Satisfaction High satisfaction at 3 months, some decrease at 6 months; decrease not statistically significant
Starks, 1988 | Design: Case series, no controls Intervention(s): Myomectomy using CO_2_ laser (via abdominal route) Dates: Jan 1983-Jan 1986 Location: Kansas City, MO Length of followup: Median, 20 months; range, 12-36 months | No. of subjects at start: 32 Dropouts: N/A Loss to followup: 0 No. of subjects at end: 32 Setting: Hospital Inclusion criteria: Infertility and/or recurrent abortion; fibroids Exclusion criteria: None specified Age: N/S Race: N/S Parity: 8/32 pts (25%) had had prior pregnancy Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: − I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: + S) Standardized measures: +
  1) | Pregnancy rate
  2) | Pregnancy outcome
  3) | Adhesions
  4) | Complications
  5) | EBL
  1) | Pregnancy rate: Total: 63% 58% with primary infertility, 75% with secondary infertility Negative correlation between pregnancy rate and age, duration of infertility (no statistical testing done)
  2) | Pregnancy outcome: Viable term pregnancy: 17/20 Spontaneous abortion: 3/20
  3) | Adhesions: 20/32 had either 2nd-look laparoscopy (n = 10) or c-section (n = 10) 75% "minimal" adhesions, 25% "moderate" adhesions
  4) | Complications: "No operative complications or blood transfusions"
  5) | EBL: Mean, 150 (range, 50-400)
Stringer, 1996 | Design: Case series (retrospective), no controls Intervention(s): Laparoscopic myomectomy Dates: Apr 1993-Oct 1994 Location: Chicago, IL Length of followup: Mean, 17.9 months; range, 12-26 | No. of subjects at start: 41 Dropouts: N/A Loss to followup: 0 No. of subjects at end: 41 Setting: Hospital; ambulatory surgery facility Inclusion criteria: African-American; laparoscopic myomectomy performed during inclusion dates; failed treatment with NSAIDs Exclusion criteria: None specified Age: Mean, 37; range, 28-49 Race: 100% African-American Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: N/A G) Statistical issues: N/A EXTERNAL VALIDITY H) Age: + I) Race: + J) Pregnancy history: + K) Surgical history: + L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Pregnancy rate
  2) | "Symptoms"
  3) | O/R time
  4) | EBL
  5) | Compression injury
  6) | Length of stay
  1) | Pregnancy rate (n = 5): 100%
  2) | "Symptoms" (not specified): 91% "complete or significant" relief of symptoms
  3) | O/R time (minutes): Overall: 288 Uterine size 8 weeks: 204 9-11 weeks: 256 12-14 weeks: 327 15-20 weeks: 367
  4) | EBL (mean): Overall: 122.7cc Uterine size 8 weeks: 61.0 9-11 weeks: 71.2 12-14 weeks: 100 15-20 weeks: 258
  5) | Compression injury: 5%
  6) | Length of stay (% treated as inpatients; number of days): Uterine size 8 weeks: 13%; 2 days 9-11 weeks: 15%; 4 days 12-14 weeks: 75%; 3 days 15-20 weeks: 55%; 7 days
Stringer, 1998 | Design: Case series, no controls (retrospective chart review) Intervention(s): Laparoscopic myomectomy with ultrasonic scalpel; patients pretreated with GnRH agonist (lupron, leuprolide, or goserelin) (n = 100) Dates: Apr 1993-May 1997 Location: Chicago, IL Length of followup: N/A (in-hospital outcomes only) | No. of subjects at start: 100 Dropouts: N/A Loss to followup: N/A No. of subjects at end: 100 Setting: Hospital; ambulatory surgery facility Inclusion criteria: Laparoscopic myomectomy during period studied Exclusion criteria: None specified Age: N/S Race: N/S Parity: N/S Baseline uterine size: Median, 11 weeks; range, 8-19 Baseline fibroid size: N/S Number of fibroids: Mean, 3.2 (removed) Baseline Hgb/Hct: N/SS | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: − I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: + N) Location of fibroids: + O) Measurement timing: − P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Uterine size
  2) | Length of stay
  3) | Adverse events
  4) | Cost
  1) | Uterine size (median): PreGnRH: 11 (8-19) PostGnRH: 10 (8-16) % change: 9%
  2) | Length of stay: Outpatient: 79% Inpatient: 21%, mean stay 1.3 days
  3) | Adverse events: Transfusion: 1% Mean EBL: 119 cc Fever: 1% Conversion to XL: 1%
  4) | Cost (in 4/95 dollars): L/S Myo: $13,814 Open Myo: $14,461 (p = 0.65)
Stringer, McMillen, Jones, et al., 1997 | Design: Case series (retrospective), no controls Intervention(s): In 50 consecutive patients undergoing laparoscopic myomectomy, 22 had endometrial cavity entered and closure with running locked stitch involving endometrium and myometrium, and 28 had a modified closure of only myometriium; all done with Endo Stitch laparoscopic suturing device Dates: Oct 1994-Dec 1996 Location: Chicago, IL Length of followup: N/S | No. of subjects at start: 50 Dropouts: N/A Loss to followup: N/S No. of subjects at end: N/S Setting: Hospital; ambulatory surgery facility Inclusion criteria: Symptomatic fibroids Exclusion criteria: None specified Age: N/S Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: − E) Loss to followup: − F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: − I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | EBL
  2) | Surgical time
  3) | Mechanical problems
  4) | Pregnancy rates
  1) | EBL: Cavity entered: 139 ± 75 ml Cavity not entered: 79.81 ml.
  2) | Surgical time: Cavity entered (n = 21): 249.8 min Cavity not entered (n = 28): 218.6 min
  3) | Mechanical problems: 11/50 (22%) of total myomectomies had problems, such as device toggle jamming and needle detaching or breaking
  4) | Pregnancy rates: 1/1 attempted and conceived
Stringer, Walker, and Meyer, 1997 | Design: Case series with historical and concomitant controls Intervention(s): Laparoscopic myomectomy and open myomectomy Dates: Laparoscopic, Apr 1992-Dec 1995; open, Dec 1983-Apr 1995 Location: Chicago, IL Length of followup: N/S | No. of subjects at start: 98 Dropouts: N/S Loss to followup: N/S No. of subjects at end: N/S Setting: University hospital Inclusion criteria: Menometror-rhagia, pelvic pain, or enlarging myoma Exclusion criteria: None specified Age: Means, 36.7 (laparoscopic), 32.2 (open) (p = 0.0002) Race: N/S Parity: Laparoscopic: 1.2 ± 1.3, 47% nulliparous. Open: 0.4 ± 0.7, 71% nulliparous (p = 0.002). Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb: Laparoscopic: Mean, 11.4; range, 7-15. Open: Mean, 13.2; range, 9-15. Baseline Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: − E) Loss to followup: − F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: − I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: − Note: Selection criteria for controls unclear -- appear to have been matched by indication
  1) | Operating time
  2) | EBL
  3) | Length of stay
  4) | Complications
  5) | Pregnancy outcomes
  6) | Need for subsequent treatment
  1) | Operating time: Laparoscopic: 257.7 Open: 133.2 (p < 0.0001)
  2) | EBL: Laparoscopic: Mean, 110 ± 133.7; median, 50 Open: Mean, 340.1 ± 222; median, 300 (p < 0.0001)
  3) | Length of stay: Laparoscopic: 0.6 days; range, 0-3 Open: 5.6 days; range, 3-25 (p < 0.0001)
  4) | Complications: 0 transfusions in laparoscopic group, 3 in open group Overall: Laparoscopic: 10% Open: 35% (p = 0.0068) Laparoscopic: 2 bleeding from surgical site; 1 lower extremity paresthesia; 2 bradycardia after pitressin injection Open: 4 ileus; 6 UTI; 1 pneumonia; 1 pulmonary edema; 1 wound separation; 1 SBO
  5) | Pregnancy outcomes: Laparoscopic: 7 pregnancies (denominator unclear) 3 Cesearean deliveries, 2 spontaneous losses, 3 terminations Open: 9 pregnancies (denominator unclear) 4 cesarean deliveries, 3 terminations, 2 spontaneous losses
  6) | Need for subsequent treatment: Laparoscopic: 1 hysterectomy Open: 3 hysterectomies (p = 0.6171)
Takamizawa, Minakami, Usui, et al., 1999 | Design: Case series (retrospective), no controls Intervention(s): 923 hysterectomies (97% abdominal and 3% vaginal) performed for preoperative diagnosis of benign fibroids Dates: Jan 1983-Dec 1997 Location: Tochigi, Japan Length of followup: N/A (in-hospital outcomes only) | No. of subjects at start: 923 Dropouts: N/A Loss to followup: N/A No. of subjects at end: 923 Setting: Hospital Inclusion criteria: preoperative diagnosis of benign fibroids Exclusion criteria: None specified Age: Mean, 44.5; range, 26-75 Race: 100% Asian Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: + J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: − S) Standardized measures: + Note: Sample size issues not discussed; multivariate analysis not performed.
  1) | Complications
  2) | Uterine mALIGNancies
  1) | Complications
  | "Major complications"
  | Bladder lacerations | 0.5%
  | Ureteral injury | 0.5%
  | Bowel injury | 0.5%
  | Transfusion secondary to hemorrhage | 4.4%
  | Pulmonary embolus | 0.1%
  | Reoperation | 0.1%
  | "Minor complications"
  | Ileus | 0.7%
  | Vaginal vault "problem" | 0.8%
  | Wound dehiscence | 0.3%
  2) | Uterine mALIGNancies | 0.4%
  | 2 endometrial adenocarcinoma
  | 1 leiomyosarcoma
  | 1 endometrial stromal sarcoma
Tulandi, Murray, and Guralnick, 1993 | Design: Case series (retrospective), no controls Intervention(s): Abdominal myomectomy (n = 26), followed by 2nd-look laparoscopy and lysis of adhesions 6 weeks later Dates: N/S Location: Montreal, Canada Length of followup: 12 months | No. of subjects at start: 26 Dropouts: N/A Loss to followup: 0 at 6 weeks, though 1 pt with hydrosalpinx not analyzed; N/S for 12-month pregnancy data No. of subjects at end: N/S Setting: University hospital Inclusion criteria: Fibroids at least 16 weeks in size; no other cause of infertility Exclusion criteria: None specified Age: Mean, 33.4 Race: N/S Parity: Mean, 0 Baseline uterine size: 18.2 ± 0.6 weeks Baseline fibroid size: 388.1 ± 71.1 g Number of fibroids: 3.3 ± 1.8 Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: + E) Loss to followup: − F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: + S) Standardized measures: +
  1) | Presence of adhesions, by site of uterine incision
  2) | Severity of adhesions, by site of uterine adhesions
  3) | 1-year cumulative pregnancy rate
  1) | Presence of adhesions: Posterior incision: 93.7% (15/16) Anterior/fundal incision: 44.4% (5/9) (p = 0.04)
  2) | Severity of adhesions: Posterior adhesions: 22.2 ± 2.3 points on AFS scale Anterior/fundal adhesions: 2.7 ± 1.2 points (p < 0.0001)
  3) | Cumulative pregnancy rate at 1 year: 66.7% (not analyzed by uterine incision site)
Tulandi and Youseff, 1997 | Design: Case series (retrospective), concomitant controls Intervention(s): 1) LAM (n = 31 cases) Laparotomy (abdominal) myomectomy (n = 29 controls) Dates: 1994-1995 Location: Quebec, Canada Length of followup: N/A (in-hospital outcomes only) | No. of subjects at start: 60 Dropouts: 1 (patient developed cytomegalovirus and was excluded from analysis) Loss to followup: N/A No. of subjects at end: 59 Setting: Hospital Inclusion criteria: Large myomas > 16 weeks size; pressure symptoms; abnormal/heavy bleeding Exclusion criteria: None specified Age: 32.4 ± 1.3 (LAM group); 36.4 ± 1.2 (abdominal group) Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: 267.5 ± 36.0 g (LAM group); 332.6 ± 62.9 g (abdominal group) Number of fibroids: N/S (reported as an outcome measure only) Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: + N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Fibroid weight
  2) | Fibroid diameter
  3) | Number of fibroids removed
  4) | O/R time
  5) | EBL
  6) | Length of stay
  7) | Adverse events
  1) | Fibroid weight: LAM group: 267.5 ± 36.0 g. Abdominal group: 332.6 ± 62.9 g
  2) | Fibroid diameter: LAM group: 12.7 ± 3.5 cm Abdominal group: 9.1 ± 0.6 cm
  3) | Number of fibroids removed: LAM group: 2.9 ± 0.8 Abdominal group: 2.5 ± 0.4
  4) | O/R time: LAM group: 94.1 ± 7.0 min Abdominal group: 122.6 ± 22.4 min (Not significant)
  5) | EBL: LAM group: 110.5 ± 18.8 cc Abdominal group: 186.9 ± 33.5 cc (Not significant)
  6) | Length of stay: LAM group: 3.2 ± 0.2 days Abdominal group: 5.1 ± 0.3 days (p = 0.000003)
  7) | Adverse events: LAM group: 2 fevers and 1 heart block Abdominal group: None reported
Ugur, Turan, Mungan, et al., 1996 | Design: Case series, concomitant controls Intervention(s): SLL (n = 48) within 8 days after abdominal myomectomy for evaluation of adhesion formation and adhesiolysis. A third-look procedure was performed on 18 patients, 10 with laparoscopy, 8 with c-section Dates: Jan 1992-Jan 1995 Location: Ankara, Turkey Length of followup: Mean, 11.6 months | No. of subjects at start: 48 Dropouts: N/S Loss to followup: N/S No. of subjects at end: N/S Setting: Hospital; reproductive endocrinology and infertility clinic Inclusion criteria: Patients who had previous myomectomy with infertility, recurrent myomas, or symptomatic myomas, and who underwent second-look laparoscopy Exclusion criteria: None specified Age: Mean, 26.2; range, 18-43 Race: N/S Parity: N/S Baseline uterine size: 10.1 wks (7-18) Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: − F) Dropout rates: − G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: + Notes:Uncertain denominator in pregnancy outcome group. Of the 48 pts, mean adhesion score was 7.4 ± 8.1. In third-look outcome, figure used for comparison was 6.2 ± 6.4. Not clear why these values are different.
  1) | Degree of adnexal adhesions
  2) | Success of SLL by third-look evaluation
  3) | Pregnancy rate
  4) | Adverse events
  5) | Incision type
  1) | Degree of adnexal adhesions: Anterior uterine incisions resulted in fewer adhesions than posterior incisions (p < 0.001). More than three uterine incisions resulted in greater adhesion formation compared with 2-3 or 1 incision (p < 0.05). Same p-value and conclusion for number of myomas removed. Uterine size > 13 weeks resulted in greater adhesion score compared with uterine sizes of 9-12 weeks and < 8 weeks (p <. 0001). Adhesions scored using American Fertility Society Classification. Of all 48 patients, 40/48 (83.3%) had adhesions from uterine incision to omentum or intestines, and 31/48 (64.6%) had adnexal adhesions. The mean adhesion score was 7.4 ± 8.1.
  2) | Success of SLL by third-look evaluation: Adhesions at the third look were significantly lower than at the second look (6.2 ± 6.4 vs. 3.1 ± 3.4)
  3) | Pregnancy outcome: 60.7% (17 pregnancies) in the infertile group. Denominator unclear.
  4) | Adverse events: 2/48 nonautologous transfusions Postmyomectomy. No injuries to organs. Fevers in 4/48.
  5) | Incision type: Anterior uterine incisions (31/48) and posterior incisions (17/48)
Varasteh, Neuwirth, Levin, et al., 1999 | Design: Case series, no controls Intervention(s): Hysteroscopic polypectomy/myomectomy in infertile women; 119 had hysteroscopy, 92 were sent questionnaire, and 78 met inclusion criteria. Of the 78, 36 had L/S myomectomies, 23 had polypectomies, and 19 had normal uterine cavities All received conjugated estrogen 2.5 mg every day 7-10 days postmyomectomy Dates: 1975-1996 Location: New York, NY Length of followup: N/S | No. of subjects at start: 78 (assuming no dropouts or loss to followup) Dropouts: N/S Loss to followup: N/S No. of subjects at end: 78 Setting: Hospital Inclusion criteria: Age < 45; infertile > 12 months; at least 18 months of followup with attempts to conceive, including IVF Exclusion criteria: None specified Age: Mean, 36.4 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: − E) Loss to followup: − F) Dropout rates: − G) Statistical issues: + EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: − S) Standardized measures: −
  1) | Cumulative live birth rates
  2) | Fibroid size
  3) | SAB rates
  4) | Conception rates
  1) | Live birth rates: Hysteroscopic myomectomy group: 13/36 (36.1%) delivered. By fibroid size: If < 2 cm, 3/12 (25%); if > 2 cm, 10/24 (41.7%); and if > 3 cm, 6/8 (75%) delivered. In polypectomy group, 15/23 (65.2%). In normal, no-intervention group, 7/19 (36.8%).
  2) | Fibroid size: 33% = 4/12 were < 2 cm; 62.5% = 15/24 were > 2 cm
  3) | SAB rates: Myomectomy group = 31.5%, polypectomy = 27.7% and normals = 37.5%. Not significant
  4) | Conception rates: Myomectomy 19/36 = 52.8% Polypectomy 18/23 = 78.3% Normals 8/19 = 42.1%
Vercellini, Maddalena, de Giorgi, et al., 1999 | Design: Case series (retrospective), no controls Intervention(s): Retrospective review of 138 infertile women who underwent abdominal myomectomy; 40 patients were also treated with GnRH agonists if their Hgb was < 10 Dates: 1990-1997 Location: Milan, Italy Length of followup: Mean, 41 months; range, 9-103 months | No. of subjects at start: 466 women undergoing myomectomy Dropouts: 0 Loss to followup: 83 No. of subjects at end: 383, of whom 138 selected (infertile women) Setting: Hospital Inclusion criteria: Infertility; intramural or subserous fibroids Exclusion criteria: Persistent anovulation, bilateral tubal occlusion, male factor, moderate/severe endometriosis, adenomyosis, pelvic adhesions, uterine malformations, IVF postoperatively Age: Mean, 31 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: + E) Loss to followup: + F) Dropout rates: + G) Statistical issues: + EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Adverse events at myomectomy
  2) | Pregnancy outcomes
  1) | Adverse events at myomectomy: 466 women had myomectomies, 138 of whom were infertile. Of the 466 women, 11 had transfusions (2%), 83 (18%) had fevers not requiring treatment, and 9 had a second intervention (2%). One hysterectomy was performed for a myometrial abscess.
  2) | Pregnancy outcomes (in 138 infertile women only): 76/138 conceived (55%). Mean followup was 41 months. preoperative GnRH had no effect on pregnancy outcome (67% pregnant). Pregnancy outcomes independent of number of myomas removed, fibroid size, whether the fibroid did or did not distort uterine cavity, placement of oxidized regenerated cellulose surgical barrier, and location of largest fibroid with respect to uterine body (i.e., posterior vs. anterior). Variables associated with pregnancy outcomes were age at time of surgery (< 30 years, 87%; 30-35, 66%; > 35, 47%) and duration of infertility before surgery (> 1 < 2 years, 84%; > 2 years, 51%) and the presence of other minor infertility factors (absence 71%, presence, 56%); 66/76 went to term.
Vercellini, Oldani, de Giorgi, et al., 1998 | Design: Case series (prospective), no controls Intervention(s): Pilot study of safety of vaporizing electrode for endometrial ablation in women with menorrhagia (26 with submucous myomas, 14 without fibroids) Dates: Jul 1995-Feb 1996 Location: Milan, Italy Length of followup: 20.3 ± 2.4 months | No. of subjects at start: 40 (assuming no dropouts or loss to followup) Dropouts: N/S Loss to followup: N/S No. of subjects at end: 40 Setting: Hospital Inclusion criteria: Menorrhagia; age > 35; not responsive to medical management Exclusion criteria: None specified Age: Mean, 45.3 ± 4.7 Race: N/S Parity: N/S Baseline uterine size: 138 ± 49 ml Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb: 10.9 ± 1.5 | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: − F) Dropout rates: − G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: + O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: + S) Standardized measures: +
  1) | Hgb
  2) | Posttreatment bleeding
  3) | Menstrual score
  4) | O/R time
  5) | Adverse events
  6) | Patient satisfaction
  1) | Hgb: Pretreatment: 10.9 ± 1.5 Posttreatment: 13.6 ± 1.0 (6-mo F/U)
  2) | Posttreatment bleeding: Amenorrhea or spotting 23/40=57.5%, hypomenorrhea 10/40=25%, normal flow 6/40=15%, menorrhagia 1/40=2.5%
  3) | Menstrual score (median): By pictoral blood loss assessment chart. Dropped from 282.2 to 0 (p < 0.0001)
  4) | O/R time: 10 min (7-12.5)
  5) | Adverse events/complications: None
  6) | Patient satisfaction: Very satisfied 6/40 = 14%, satisfied 30/40 = 74%, uncertain 2/40 = 5%, dissatisfied 1/40 = 2.5%, very dissatisfied 1/40 = 2.5%
Vercellini, Zaina, Yaylayan, et al., 1999 | Design: Case series, no controls Intervention(s): Hysteroscopic myomectomy on symptomatic women with intracavitary fibroids (n = 108). 89/108 had medical Pretreatment, 66/108 with GnRH, 9/108 with progestins, 11/108 with estrogen/progestin combination, and 3/108 with danazol. Groups evaluated as: pedunculated myomas (n = 54), sessile myomas (n = 30), and intramural myomas (n = 24). Dates: 1991-1997 Location: Milan, Italy Length of followup: 41 ± 23 months | No. of subjects at start: 108 Dropouts: N/A Loss to followup: 13 No. of subjects at end: 95 Setting: Hospital Inclusion criteria: Symptomatic submucous leiomyomata; fibroids < 5 cm; consecutive patients who underwent hysteroscopic myomectomy during study period Exclusion criteria: Complete extracavity myomas > 2 cm; anovulation, bilateral tubal occlusion, severe male factor Age: Mean, 37.2 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb: 10.2 ± 2.0 (pedunculated group); 10.7 ± 1.8 (sessile group); 10.3 ± 1.6 (intramural group) | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: N/A G) Statistical issues: + EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: + O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: + S) Standardized measures: +
  1) | O/R time
  2) | Distension media deficit
  3) | Number of procedures needed
  4) | Recurrence of fibroids
  5) | Recurrence of menorrhagia
  6) | Conception rates
  7) | Pregnancy outcomes
  8) | Bleeding
  9) | Hgb
  1) | O/R time (means, in min): Pedunculated 18 ± 7 min, sessile 23 ± 9, intramural 32 ± 8
  2) | Distension media deficit (ml): Pedunculated 204 ± 276, sessile 278 ± 269, intramural 335 ± 272
  3) | Number of procedures needed: Need for repeat procedure to remove fibroid not significant between groups in analysis of one versus two or more interventions
  4) | Fibroid recurrence rate: No significant difference between groups: pedunculated 12/54, sessile 7/30, intramural 8/24
  5) | Menorrhagia recurrence rate: Recurrence of menorrhagia in 101 women who had menorrhagia at baseline: 9/51 in pedunculated group, 4/28 in sessile, 7/22 in intramural
  6) | Conception rates: In 40 infertile women: pedunculated 10/22, sessile 4/12, intramural 1/6. No significant difference. Total of 16 pregnancies, as one woman had two conceptions
  7) | Pregnancy outcomes: 14 delivered at term (not reported by groups) with one SAB and one TAB
  8) | Bleeding: Change in bleeding (by pictoral blood loss assessment chart score): pedunculated group 189 ± 92 to 65 ± 41; sessile group 165 ± 86 to 62 ± 34; intramural group, 182 ± 92 to 74 ± 43
  9) | Hgb: Pretreatment: Pedunculated 10.2 ± 2.0, sessile 10.7 ± 1.8, intramural 10.3 ± 1.6 Posttreatment: Pedunculated 12.4 ± 2.1, sessile 12.3 ± 1.8, intramural 12.1 ± 2.3
Wamsteker, Emanuel, and de Kruif, 1993 | Design: Case series, no controls Intervention(s): 51 patients who underwent transcervical resection of submucous myomas for abnormal uterine bleeding. A total of 66 procedures were done. The European Society of Hysteroscopy classification was used: Type 0 (pedunculated, submucous) (n = 25); Type I (sessile, < 50% intramural) (n = 14); and Type II (> 50% intramural) (n = 12). Some patients received danazol 600 mg qd for 2-3 weeks preop. All patients had a followup hysteroscopy 2-3 months after the final procedure. Dates: N/S; 3 years Location: Haarlem, the Netherlands Length of followup: Mean, 20 months; range, 10-34 months | No. of subjects at start: 51 Dropouts: 3 Loss to followup: 3 No. of subjects at end: 45 Setting: N/S Inclusion criteria: Excessive menstrual bleeding; submucous myoma Exclusion criteria: None specified Age: Mean, 38; range, 23-55 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: + N) Location of fibroids: + O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Number of resected fibroids
  2) | Number of resections
  3) | Bleeding followup
  4) | Complete resection of fibroid
  5) | Adverse events
  1) | Number of resected fibroids: 1-14
  2) | Number of resections: 35 patients had 1; 13 had 2; 2 had 3; no patient had more than three
  3) | Bleeding: 48/51 (94.1%) reported "controlled" bleeding after final procedure (of up to 3)
  4) | Complete resection of fibroids: 46/51 (90.2%) had complete resection, 9.8% had incomplete resection after final procedure (of up to 3)
  5) | Adverse events: No transfusions or organ injury reported; 3 patients had filmy adhesions at postop hysteroscopy; 3 patients (5.9%) had hysterectomy for bleeding problems
Worthington-Kirsch, Popky, and Hutchins, 1998 | Design: Case series, no controls Intervention(s): Uterine artery embolization in 53 women with severe menorrhagia; 31 of the 53 complained of "bulk" symptoms Dates: N/S Location: Philadelphia, PA Length of followup: 3 months | No. of subjects at start: 53 Dropouts: 1 Loss to followup: 0 No. of subjects at end: 52 Setting: Hospital Inclusion criteria: Severe menorrhagia with fibroids by ultrasound; premenopausal; desire to avoid surgery Exclusion criteria: None specified Age: Mean, 43; range, 33-58 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: − F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Successful completion of procedure
  2) | Change in uterine size
  3) | Improvement in bulk-related symptoms
  4) | Improvement in bleeding
  5) | Patient satisfaction
  6) | Complications
  7) | Hospital stay
  1) | Successful completion of procedure: 52/53 patients had technically successful procedures
  2) | Change in uterine size: Overall 46% decrease in uterine size by ultrasound evaluation (range, 0-81%)
  3) | Improvement in bulk symptoms: Overall, 29/31 (94%) improved. Complete improvement in 6/31 (19%), great improvement in 12/31 (39%), moderate in 11/31 (35%), no change in 2/31 (6%)
  4) | Improvement in bleeding: Stopped completely: 37% Greatly improved: 38% Moderately improved: 13% Slightly improved: 8% No change: 6% Worse: 0%
  5) | Patient satisfaction: 41/53 (79%) would choose therapy again, 8/53 (15%) would consider again, and 3/53 (6%) would choose another therapy
  6) | Complications: Postembolization syndrome requiring hysterectomy (n = 1), postembolization syndrome with no other problems (n = 1), one upper GI bleed with spontaneous resolution
  7) | Hospital stay: 51 patients stayed overnight, 4 stayed more than 24 hours
Wortman and Dagget, 1995 | Design: Case series, no controls Intervention(s): 75 women with menorrhagia and intracavitary myomas who underwent hysteroscopic myomectomy; 65 women (group 1) had this procedure combined with endometrial destruction (group 1a, n = 33 with ablation; group 1b, n = 32 with endomyometrial resection). A second cohort, group 2 (n = 10) only had myomectomy and wanted to retain childbearing potential; 35 had additional GnRH therapy before surgery for one injection of 3.75 mg depolupron. Dates: Nov 1988-Mar 1994 Location: Rochester, NY Length of followup: 22 ± 13.9 months (range, 6-58 months) | No. of subjects at start: 75 Dropouts: N/A Loss to followup: 3 No. of subjects at end: 72 (at least 6 months of followup) Setting: Ambulatory surgery facility Inclusion criteria: Menorrhagia, intracavitary myoma Exclusion criteria: Myoma "largely intramural" or uterine length > 14 cm Age: Mean, 43.2; range, 31-71 Race: N/S Parity: 1.7 ± 1.53 Baseline uterine size: 9.8 ± 1.45 cm (length); range, 7.5-13.5 cm Baseline fibroid size: 3.12 ± 1.32 cm (by ultrasound or direct measurement postop). Weight, 23.6 g (10.5-32 g). Number of fibroids: 77.3% had 1 fibroid; 22.7% had > 1 Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: + N) Location of fibroids: + O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Posttreatment bleeding (menstruation)
  2) | Fluid absorption with procedure
  3) | O/R time
  4) | Adverse events
  5) | Coexisting outcomes
  1) | Posttreatment bleeding (menstruation): In group 1: 47/62 (75.8%) reported amenorrhea, 12/62 (19.4%) hypomenorrhea, and 3/63 (4.8%) moderate improvement. This was a 6-month F/U. Thereafter, reported decreasing "n" for F/U so these data are not reported here. In group 1a, 19/33 (57.6%) amenorrhea, 12/33 (36.4%) hypomenorrhea, and 2/33 (6.1%) moderate improvement In 1b (n = 29), 82.8% amenorrhea, 6.9% hypomenorrhea, and 10.3% moderate improvement
  2) | Fluid absorption with procedure (mean): 967.7 ± 839.9 ml
  3) | O/R time: 47.1 ± 24.7 for all 75 patients
  4) | Adverse events: 3/75 (4%): 1 hemorrhage requiring uterine foley tamponade, 1 fever, 1 myometritis treated with postop antibiotics
  5) | Coexisting outcomes: 5 patients with adenomyosis, 4 with endometrial polyps, 3 with leiomyomas of uncertain mALIGNant potential underwent hysterectomy
Yamada, Yamashita, Terai, et al., 1997 | Design: Case series, no controls Intervention(s): 37 patients with abdominal myomectomies had Cell Saver used intraoperatively for autotransfusion. A matched group of 13 Cell Saver patients and 15 controls is reported, but because the numbers are small and there is no description of the controls, those data are not discussed here. Dates: 30 months, beginning in 1993 Location: Osaka, Japan Length of followup: N/A (in-hospital outcomes only) | No. of subjects at start: 37 Dropouts: N/A Loss to followup: N/A No. of subjects at end: 37 Setting: Hospital Inclusion criteria: Large fibroid uterus Exclusion criteria: None specified Age: Mean, 33.0 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Need for homologous transfusion
  2) | Volume of processed and reinfused blood
  3) | EBL
  4) | Adverse outcomes
  5) | Final pathology
  1) | Need for homologous transfusion: 35/37 patients only had autologous transfusions; 2 patients had additional homologous transfusions
  2) | Volume of transfusion (mean): 349 ± 274 ml (115-1319 ml)
  3) | EBL: 503 ± 465 ml (50-2070 ml)
  4) | Adverse outcomes: One repeat laparotomy for bleeding
  5) | Final pathology: N = 30 with fibroids, n = 3 with adenomyosis, n = 4 with leiomyomata with adenomyosis

Evidence Table 2. Medical management of uterine fibroids

Study | Design and interventions | Patient population | Outcomes reported | Results | Notes/Quality score
Abramovici, Dirnfeld, Auslander, et al., 1994 | Design: Case series (prospective), no controls Intervention(s): D-Trp6-LHRH (Decapeptyl®) 3.2 mg IM per month x 3-6 months (n = 23); 10 patients had myomectomy after treatment; 1 had a hysterectomy Dates: N/S Location: Haifa, Israel Length of followup: N/S | No. of subjects at start: 23 Dropouts: 0 Loss to followup: N/S No. of subjects at end: N/S Setting: Outpatient clinic/physician office Inclusion criteria: Infertility lasting > 18 months; no other causes of infertility; normal cycles; normal hormonal profile; fibroid confirmed by ultrasound Exclusion criteria: None specified Age: Mean, N/S; range, 24-44 Race: N/S Parity: 1/23 had had live child Baseline uterine size: 10-22 weeks; mean, 590 cc (range, 108.9-1774.6) Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: − E) Loss to followup: − F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: − S) Standardized measures: −
  1) | Uterine volume
  2) | Symptomatic relief
  3) | Pregnancy rate
  4) | Side effects/complications
  1) | Uterine volume: After treatment with Decapeptyl®: Mean volume decrease of 57% (range 22-86%) (P < 0.01 compared to pretreatment) % reduction greater with Decapeptyl® + surgery than with Decapeptyl® alone (P < 0.05, actual numbers not given) In 6/7 patients, uterine volume returned to pretreatment within 6 months of stopping therapy.
  2) | Symptomatic relief: Menorrhagia: 6/7 "normal" menses after 3 months of Decapeptyl®; 1/7 hysterectomy (after attempt at myomectomy) Pelvic discomfort/dyspareunia: 6/6 "disappearance" of symptoms after 3 months
  3) | Pregnancy rate: Decapeptyl® only: 1/12 Decapaptyl® + myomectomy: 5/10 (4 term deliveries, 1 loss at 24 weeks) (P < 0.05)
  4) | Side effects/complications: Hot flashes: 100% Vaginal dryness: 10/23 Surgical: 1 hysterectomy after failed attempt at myomectomy
Anteby, Yarkoni, and Ever Hadani, 1985 | Design: Case series (prospective), no controls Intervention(s): Indomethacin 1.5 mg per kg body weight PO per day (n = 16). Treatment started at initiation of menses and continued throughout maximal bleeding phase (4-5 days per cycle). Patients treated for mean of 10.2 cycles (range, 2-30) Dates: N/S Location: Jerusalem, Israel Length of followup: N/A (no posttreatment followup) | No. of subjects at start: 16 with submucous fibroids (of total series of 94) Dropouts: 0 Loss to followup: N/A No. of subjects at end: 16 Setting: Outpatient clinic/physician office Inclusion criteria: Prolonged distressing menorrhagia Exclusion criteria: History of GI bleeding; blood dyscrasias; bleeding tendency; pelvic inflammatory disease Age: Mean, 40; range, 38-48 Race: N/S Parity: Mean 1.8; range, 0-7 Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: + L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: + O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: − Note: Patients with fibroids represented a small subgroup of patients in larger series. Incomplete data were reported for this subgroup.
  1) | Duration of bleeding (days)
  1) | Duration of bleeding: Days of bleeding per menstrual cycle decreased by a mean of 2 days from 6.6 before treatment to 4.6 after treatment (p < 0.001) 14/16 patients had fewer bleeding days after treatment compared to before treatment (p < 0.01)
Ayala, Meza, Cervera, Aguilar, et al., 1995 | Design: Case series (prospective), no controls Intervention(s): Nafarelin (D-Nal-6-GnRH) 400 mcg nasal spray every 12 hours for 3 months (n = 15) Dates: N/S Location: Lomas Virreyes, Mexico Length of followup: N/A (no posttreatment followup) | No. of subjects at start: 20 Dropouts: 5 Loss to followup: N/A No. of subjects at end: 15 Setting: Outpatient clinic/physician office Inclusion criteria: Leiomyomata Exclusion criteria: None specified Age: Mean, 35.5 Race: N/S Parity: N/S Baseline uterine size: 375.08 ± 283.16 cc Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Uterine size
  2) | Adverse effects
  1) | Uterine size: Decreased from 375.0 cc (± 283.16 cc) to 242.8 cc (65%) over 3 months
  2) | Adverse effects: Spotting: 40% Headache: 60% Rhinitis: 40% Hot flashes: 80% Nausea: 80% Decreased libido: 80%
  No drug-related abnormalities in liver or kidney function tests, complete blood count, or urinalysis. No orthostatic drop in blood pressure or change in pulse
Benagiano, Morini, Aleandri, et al., 1990 | Design: RCT, method of randomization not described Intervention(s): All patients treated for 6 months with buserelin (1.5 mg SC daily for 1 week, then 1.5 mg IN, 3 times per day, for remainder of 6-month period), then randomized to either: Dates: N/S Location: Rome, Italy Length of followup: N/A (no posttreatment followup) | No. of subjects at start: 48 Dropouts: 12 Loss to followup: N/A No. of subjects at end: 36 Setting: Outpatient clinic/physician office Inclusion criteria: Fibroid with volume > 33 ml, or uterine volume > 90 ml Exclusion criteria: None described Age: N/S Race: N/S Parity: N/S Baseline uterine size: 132 ± 77.2 ml (Provera®); 122 ± 80.3 ml (control) Baseline fibroid size: 25.6 ± 24.8 ml (Provera®); 23.7±21.6 ml (control) Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: − C) Pt selection criteria: + D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: + EXTERNAL VALIDITY H) Age: − I) Race: − J) Pregnancy history: − K) Surgical history: + L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: + S) Standardized measures: − Note: No statistical comparison of uterine regrowth between Provera® and control groups. Incomplete reporting of adverse effects data. Some data on dropouts included in some analyses.
  1) | Medroxyproges­terone acetate (Provera®) for 6 months in tapering dose (200 mg/day for month 1, 100 mg/day for month 2, 50 mg/day for months 3-4, 25 mg/day for months 5-6) (n = 18 at end); or
  2) | No medication (n = 18 at end)
  1) | Uterine volume
  2) | Fibroid volume
  3) | Symptoms
  1) | Uterine volume: During a 6-month lead-in period, all patients were treated with GnRH agonist buserelin, resulting in an average reduction of uterine volume of 46.7% (from 262±147 to 127±85.4 ml [range, 350-42]). Fibroid volume was reduced by 51.8% (from 75.1±74.3 to 24.7±23.3 ml [range, 91-0]). The maximum reduction occurred after 4 months of buserelin therapy.
  Following buserelin therapy, uterine volume increased in the control group from 122±80.3 to 198±77.2 ml (p < 0.001), and uterine volume increased in the Provera® group from 132±77.2 to 170±96.0 ml (p < 0.01)
  2) | Fibroid volume: Fibroid volume increased in the control group from 23.7±21.6 to 47.7±27.5 ml (p < 0.001), but did not change in the Provera® group (25.6±24.8 to 30.6±32.9 ml; p > 0.3)
  3) | Symptoms: Irregular bleeding occurred in 10/18 (55.6%) women in the Provera® group, occurring mainly when the progestogen dosage was decrease
Bianchi, Costantini, Anserini, et al., 1989 | Design: Case series, controls (matched for age and BMI) used for bone density measurement Intervention(s): Buserelin, 3 daily SC injections of 0.5 mg each for first 10 days (during late luteal phase), then 200 mcg IN 4 x per day for 6 months (n = 18) Dates: N/S Location: Genoa, Italy Length of followup: 6 months | No. of subjects at start: 18 Dropouts: 4 Loss to followup: 0 No. of subjects at end: 14 Setting: Outpatient clinic/physician office Inclusion criteria: Uterine fibroids; premenopausal Exclusion criteria: None described Age: Mean, 38.5; range, 28-49 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: + E) Loss to followup: + F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: +
  1) | Fibroid volume
  2) | Bone density
  1) | Fibroid volume: 15/18 patients (83.3%) had a > 30% reduction in fibroid volume after 6 months of treatment
  2) | Bone density: No statistical difference in bone density measured at proximal and distal forearm at 6 months or 1 year. No difference between cases and 18 controls matched for age and BMI
Broekmans, Hompes, Heitbrink, et al., 1996 | Design: RCT, method of randomization not described Intervention(s): All groups received triptorelin 500 mcg SC daily between 6 and 8 pm starting on day 2 of the menstrual cycle for week 1, then 100 mcg daily weeks 2-8. Then randomized to receive either: Dates: N/S Location: Amsterdam, the Netherlands Length of followup: N/A (no posttreatment followup) | No. of subjects at start: 27 Dropouts: 3 Loss to followup: N/A No. of subjects at end: 24 Setting: Outpatient clinic/physician office Inclusion criteria: Leiomyoma by ultrasound; symptoms attributable to leiomyomata Exclusion criteria: Endocrine disorders; history of urolithiasis; disease affecting bone metabolism; abnormal serum creatinine Age: Mean, 34.4 ± 4.9 Race: 62% white; 38% black Parity: N/S Baseline uterine size: Median, 931.2 ml Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: − C) Pt selection criteria: − D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: + EXTERNAL VALIDITY H) Age: + I) Race: + J) Pregnancy history: + K) Surgical history: + L) Fibroid/uterine size: + M) Number of fibroids: + N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: + S) Standardized measures: −
  1) | Triptorelin 100 mcg SC daily for weeks 9 to 26 (n = 9?); or
  2) | Triptorelin 20 mcg SC daily for weeks 9 to 26 (n = 9?); or
  3) | Triptorelin 5 mcg SC daily for weeks 9 to 26 (n = 9?)
  1) | Uterine volume by MRI
  2) | Fibroid volume by MRI
  3) | Adverse effects
  1) | Uterine volume by MRI: Uterine volume (median) decreased from baseline 931.2 ml (range, 318 to 2015) during the standard dose treatment period to 692 ml (range, 178.7 to 1700), or 67% of the baseline value (range, 48% to 90%; p = 0.001) During randomized reduced-dose treatment there was further reduction to 525.1 ml (range, 136 to 1638 ml) or 58% of baseline value. There were no significant differences between the dosage groups, although there was a dose-dependent trend (p = 0.01), with the lowest dose producing the smallest additional decrease
  2) | Fibroid volume by MRI: Fibroid volume decreased to 68.9% of the baseline volume (range, 52% to 100%) during the standard dose treatment period and was further reduced to 63.9% (range, 41% to 110%) of the baseline value during randomized reduced-dose treatment. This reduction was not statistically significant, and there was no dose effect
  3) | Adverse effects: All women experienced hot flashes during standard-dose treatment; 79% continued having flashes during randomized reduced-dose treatments. Amenorrhea occurred in 50%, 75%, and 63% in the 5-, 20-, and 100-mcg dose groups, respectively. Spotting occurred in 50%, 14%, and 0% in the 5-, 20-, and 100-mcg dose groups, respectively. Intermittent, menstruation-like bleeding occurred in 21% of patients, but was more frequent in the lowest dose group (p = 0.037)
Cagnacci, Paoletti, Soldani, et al., 1994 | Design: Case series, no controls Intervention(s): Goserelin depot 3.6 mg SC once per month during follicular phase of menstrual cycle (days 5-7); 22 subjects treated for 6 months, 8 for 1 year Dates: N/S Location: Cagliari, Italy Length of followup: N/S | No. of subjects at start: 30 Dropouts: 0 Loss to followup: 0 No. of subjects at end: 30 Setting: Outpatient clinic/ physician office Inclusion criteria: Ultrasound evidence of uterine fibromatosis and fibroids Exclusion criteria: None specified Age: N/S Race: N/S Parity: N/S Baseline uterine size: 90 ± 10 cc (group treated for 6 months); 130 ± 20 cc (group treated for 1 year) Baseline fibroid size: 33 ± 10 cc (group treated for 6 months); 48 ± 12 cc (group treated for 1 year) Number of fibroids: N/S Baseline Hgb: N/S Baseline Hct: 31 ± 3% (group treated for 6 months); 28±2% (group treated for 1 year) | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: − E) Loss to followup: + F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: − I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: − Note: Although an RCT is described involving an additional set of patients (n = 20), no results from the randomized comparison are reported.
  1) | Uterine volume
  2) | Fibroid volume
  3) | Hematocrit
  1) | Uterine volume: Uterine volume decreased by 50% from 180 ± 10 cc to 90 ± 10 cc (p < 0.05) after 6 months of treatment (n = 22) In 8 subjects who continued treatment for 1 year, maximum shrinkage occurred at 1 year.
  2) | Fibroid volume: Fibroid volume decreased by 50% from 33 ± 10 cc to 15 ± 2 cc (p < 0.05). By 3 months after withdrawal of treatment, these values had increased to 120 ± 10 cc and 22 ± 6 cc In 8 subjects who continued treatment for 1 year, maximum shrinkage occurred at 6 months
  3) | Hematocrit: Hematocrit reached maximal values within 3 months and remained at these maximal levels during continued treatment. All patients became amenorrheic within 2 cycles
Caird, West, Lumsden, et al., 1997 | Design: RCT, centrally prepared randomization scheme held in hospital pharmacy Intervention(s): All patients received goserelin acetate depot (Zoladex®) 3.6 mg SC initiated during days 2-5 of menstrual cycle, then repeated every 28 days through week 48, plus either: Dates: N/S Location: Edinburgh, UK Length of followup: 1 year following treatment | No. of subjects at start: 24 (21 with fibroids, 3 with menorrhagia) Dropouts: 4 Loss to followup: 0 No. of subjects at end: 10 completed treatment; 11 provided data for most outcomes Setting: Outpatient clinic/physician office Inclusion criteria: Premenopausal; symptomatic fibroids (confirmed by ultrasound) or menstrual problems; wish to avoid surgical treatment Exclusion criteria: Conditions affecting bone metabolism; use of any hormonal agent within past 3 months; bone mineral density (Z score) > 1.6 SD below age-matched controls Age: Mean, 42; range, 29-49 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: + C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: + G) Statistical issues: + EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: + L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | MPA 15 mg PO per day, beginning at month 4 (n = 11 with fibroids); or
  2) | Placebo (n = 10 with fibroids)
  1) | Symptoms
  2) | Uterine size
  1) | Symptoms: Bleeding: Most patients had complete relief of bleeding during treatment (8/11 MPA, 6/10 placebo) Dysmenorrhea: "Virtually eliminated in both groups" Hot flashes: The severity of hot flashes was significantly greater in the group treated with placebo compared with those treated with MPA (p < 0.05; weeks 20-40)
  2) | Uterine size: There was no difference in uterine size between placebo and MPA groups at any time point during treatment or followup
Carlson, Miller, and Fowler, 1994 | Design: Cohort study Intervention(s): Dates: Jun 1989-Jan 1992 Location: Multiple sites in state of Maine Length of followup: 1 year | No. of subjects at start: 229 pts with leiomyomas (106 nonsurgical, 123 surgical); part of larger study population of 649 Dropouts: 0 Loss to followup: 0 No. of subjects at end: 229 Setting: Outpatient clinic/physician office Inclusion criteria: Uterine size 8 weeks or greater Exclusion criteria: None specified Age: Mean, 41 (all 649 pts) Race: N/S Parity: 15.5% nulliparous (all 649 pts) Baseline uterine size: > 10 weeks in 49% of fibroid patients Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: 19% of surgical patients and 7% of nonsurgical patients anemic (229 leiomyoma pts only) | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: + G) Statistical issues: + EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: + L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: − S) Standardized measures: + Notes: Hysterectomy techniques not described. Heterogeneous nonsurgical management techniques. Patients with leiomyomas who were managed nonsurgically (in most cases, with observation alone) had no significant change in symptoms or QoL over 1 year. However, these patients had less severe symptoms and better QoL at baseline. Hysterectomy was associated with more improvement in symptoms and QoL than nonsurgical therapy.
  1) | Hysterectomy (n = 123)
  2) | Nonsurgical management (observation alone, 68%; NSAIDs or iron, 18%; hormone therapy, 14%) (n = 106)
  1) | Symptoms
  2) | QoL
  3) | Need for further treatment
  1) | Symptoms: Bleeding: Nonsurgical patients reported a mean of 6 days of bleeding initially, compared with 10 days for surgically managed patients. At 1 year, mean days of bleeding were 7 compared to 0. Initially, 23% of nonsurgical and 55% of surgical patients rated bleeding a "medium" or "big" problem. At 1 year, 19% and 0% rated bleeding a problem. Dysmenorrhea: Initially 5 days and 11 days per month for nonsurgical and surgical patients, respectively, mean days of pain averaged 5 and 2 at 1 year. Pain was a problem for 23% and 61% of patients initially, falling to 12% and 9% at 1 year Global symptom assessment: Initially, 46% and 5% in nonsurgical and surgical groups, respectively, had "positive feelings" about their symptom status. At 1 year these proportions were 67% and 84% (p < 0.001 for comparisons between initial and 1 year)
  2) | Quality of life: Three scales (Mental Health Index, General Health Index, Activity Index) showed similar patterns. Initially, QoL was lower for surgical than nonsurgical patients. There was no change over 1 year in QoL scores for the nonsurgical group. The surgical group showed significant increases in QoL scores over 1 year
  3) | Need for further treatment: Approximately 23% of nonsurgical patients underwent hysterectomy in the 12-month followup period
Carr, Marshburn, Weatherall, et al., 1993 | Design: RCT, method of randomization not described Intervention(s): All patients received leuprolide acetate 1 mg SC per day plus either: Dates: N/S Location: Dallas, TX Length of followup: N/A (no posttreatment followup) | No. of subjects at start: 16 Dropouts: 0 Loss to followup: N/A No. of subjects at end: 16 Setting: Academic medical center, outpatient gynecological clinic Inclusion criteria: Leiomyomata > 12 weeks in size Exclusion criteria: None described Age: Mean, 35.7; range, 29-47 Race: N/S Parity: N/S Baseline uterine size: 1190 ± 185 ml (MPA first); 1278 ± 205 ml (placebo first) Baseline fibroid size: 548 ± 108 ml (MPA first); 345 ± 177 ml (placebo first) Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: − C) Pt selection criteria: − D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: + L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: + S) Standardized measures: − Note: No comments on the effect of MPA on symptoms. Small sample size with no discussion of power in study with negative findings.
  1) | MPA 20 mg/day, given during first 12 weeks of treatment with leuprolide (placebo given during second 12 weeks) (n = 8)
  2) | MPA 20 mg/day, given during second 12 weeks of treatment with leuprolide (placebo given during first 12 weeks) (n = 8)
  1) | Uterine volume
  2) | Fibroid volume
  1) | Uterine volume: 22% to 26% decreases in uterine volume at 24 weeks were not statistically different between protocols. At 12 weeks, even though uterine volume with MPA showed virtually no change and without MPA decreased by 27%, the difference in uterine size was not statistically significant between protocols. Within-group changes were different -- no decrease in first 12 weeks with MPA versus decrease with placebo; effect related to changes in nonmyoma uterine volume.
  2) | Fibroid volume: Although there was a tendency toward a decline in fibroid volume (about 12%-17%) with both protocols, the changes were not statistically significant.
Cirkel, Ochs, Schneider, et al., 1992 | Design: Case series, no controls Intervention(s): Leuprorelin acetate depot 3.75 mg SC on days 1 and 3, then every 4 weeks for 6 months (n = 114) Dates: Oct 1988-Oct 1990 Location: Multiple sites in Germany Length of followup: N/A (no posttreatment followup) | No. of subjects at start: 114 Dropouts: 4 Loss to followup: N/A No. of subjects at end: 110 Setting: Outpatient clinic/ physician office Inclusion criteria: Fibroids by ultrasound or operation Exclusion criteria: None described Age: Mean, 33 Race: N/S Parity: N/S Baseline uterine size: 180.97 ± 18.54 cc Baseline fibroid size: 68.81 ± 10.61 cc Number of fibroids: N/S Baseline Hgb: 13 ± 0.1 g/dl Baseline Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: + L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: − Note: 21% of subjects had previously undergone medical treatment for myomas. This may have biased the study toward a lower incidence of adverse effects and/or greater efficacy. No statistical testing.
  1) | Uterine volume
  2) | Fibroid volume
  3) | Bleeding
  4) | Dysmenorrhea
  5) | Hemoglobin levels
  6) | Adverse effects
  1) | Uterine volume: Decreased with GnRH therapy in 95/110 patients (86%), with average reduction of 67%, from 181±18.5 cc to 104±10.5 cc. After the 16th week of treatment, no further reduction in uterine size was detected.
  2) | Fibroid volume: Decreased in 105/110 patients (92%). In 35 patients, the reduction was more than 80%, and average reduction was 56%, from 68.8 ± 10.6 to 31.6±6.3.
  3) | Bleeding: At 24 weeks, 8 (7%) patients reported uterine bleeding
  4) | Dysmenorrhea: Reduced from 74 women pretreatment to 6 (5.3%) after 24 weeks
  5) | Hemoglobin levels: Increased from 13±0.1 g/dl initially to 13.4±0.1 g/dl at 24 weeks
  6) | Adverse effects: These included hot flashes (82%), sweating (63%), decrease in breast size (46%), sleeplessness (45%), decrease in libido (40%), headache (32%), and mood changes (32%)
Coddington, Brzyski, Hansen, et al., 1992 | Design: Case series, no controls Intervention(s): Prior to myomectomy: Leuprolide acetate depot 3.75 mg IM in follicular phase, repeated after 1 month (n = 27) Dates: N/S Location: Norfolk, VA Length of followup: 1 year postop | No. of subjects at start: 27 (assuming no dropouts and no loss to followup) Dropouts: N/S Loss to followup: N/S No. of subjects at end: 27 Setting: Outpatient clinic/physician office Inclusion criteria: Leiomyomas by exam and ultrasound Exclusion criteria: None specified Age: Mean, N/S; range, 20-40 Race: N/S Parity: N/S Baseline uterine size (mean, with range): 13.6±4.0 weeks (7-30); 474±364 ml (220-1839) Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | At 1 year: 4 (denominator uncertain) | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: + E) Loss to followup: − F) Dropout rates: − G) Statistical issues: − EXTERNAL VALIDITY H) Age: − I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Uterine size by ultrasound
  2) | Improvement in presenting symptoms
  3) | Side effects
  4) | Surgical outcomes
  5) | Regrowth of fibroids
  1) | Uterine size (by ultrasound): Uterine size decreased from 474 ml ± 364 ml pretreatment to 265 ml ± 173 ml after treatment, a decrease of 35% after 1 month and 44% after 2 months
  2) | Improvement in presenting symptoms: All patients reported resolution of initial symptoms. Initial symptoms were menorrhagia (70%), urinary frequency (50%), and tight clothes (50%)
  3) | Side effects: Hot flashes: 96% Insomnia: 73% Mood swings: 57% Urinary symptoms: 54% Dryness of vagina: 27%
  4) | Surgical outcomes: EBL: 243 ml (range, 75-800) Transfusions: 3 (all autologous)
  5) | Regrowth of fibroids: At 6 months: 10 (denominator uncertain)
Costantini, Anserini, Valenzano, et al., 1990 | Design: RCT, method of randomization not described Intervention(s): Dates: Jan 1987-Feb 1988 Location: Genoa, Italy Length of followup: N/A (no posttreatment followup) | No. of subjects at start: 42 Dropouts: 0 Loss to followup: N/A No. of subjects at end: 42 Setting: Outpatient clinic/physician office Inclusion criteria: At least one subserous or intramural uterine fibroid > 5 cm in diameter; premenopausal Exclusion criteria: None specified Age: Means, 39.5 (buserelin), 38.1 (goserelin) Race: N/S Parity: N/S Baseline uterine size: 245 (buserelin); 253 (goserelin) Baseline fibroid size: 205 (buserelin); 192 (goserelin) Number of fibroids: 2.2 ± 1.8, range, 1-4 (buserelin); 1.9±1.5, range, 1-4 (goserelin) Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: − C) Pt selection criteria: − D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: − I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: + N) Location of fibroids: + O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: + S) Standardized measures: +
  1) | Buserelin 500 mcg SC 3 times per day x 10 days, then 200 mcg IN 4 times per day x 6 months (n = 21)
  2) | Goserelin 3.6 mg SC every 28 days x 6 months (n = 21)
  1) | Fibroid volume
  2) | Uterine volume
  3) | Bleeding
  4) | Side effects
  1) | Fibroid volume:
  Number of women | | Buserelin | Goserelin
  < 30% reduction | | 5 | 3
  30-60% reduction | | 7 | 10
  > 60% reduction (p = not significant) | | 9 | 8
  2) | Uterine volume:
  Number of women | | Buserelin | Goserelin
  < 30% reduction | | 4 | 3
  30-60% reduction | | 7 | 8
  > 60% reduction (p = not significant) | | 10 | 10
  3) | Bleeding: All patients were amenorrheic within the second month of treatment, although episodes of spotting were sometimes reported (mostly in the buserelin-treated patients). No p-value reported.
  4) | Side effects: The incidence of hot flashes, vaginal dryness, decreased libido, weight gain, nausea, depression, and headache were similar between groups. Vaginal bleeding was significantly more common in the buserelin-treated group (p < 0.001).
Coutinho, 1990 Also described in Coutinho, 1989 | Design: Case series, no controls Intervention(s): Gestrinone 5 mg PO 3 times per week for 6 months (n = 24; 14 patients had treatment extended to 1 year) Dates: N/S Location: Salvador, Brazil Length of followup: N/A (no posttreatment followup) | No. of subjects at start: 24 Dropouts: 0 Loss to followup: N/A No. of subjects at end: 24 (at 6 months; 14 patients continued to 1 year) Setting: N/S Inclusion criteria: Large myomatous uteri > 200 cc Exclusion criteria: None specified Age: Mean 33.5; range, 23-44 Race: N/S Parity: 23/24 patients (96%) nulliparous Baseline uterine size: 724.9 ± 708 cc Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Uterine size
  2) | Symptoms
  3) | Adverse effects
  1) | Uterine size: Uterine size decreased from 725 to 451 cc at 6 months (p = 0.007) in 24 patients treated for 6 months. Uterine size decreased from 690 to 329 cc at 1 year in 14 patients treated for 1 year.
  2) | Symptoms: All patients reported alleviation of symptoms (pelvic discomfort and pain) at the end of 2 months of treatment.
  3) | Adverse effects: Hypertension requiring treatment (2 pts); acne (21 pts); arthralgia (8 pts); myalgia (8 pts); nervousness (6 pts); headache (6 pts); mild hirsutism (6 pts); increased libido (8 pts); hoarseness (8 pts); hair loss (3 pts); no adverse effects (3 pts). No patients discontinued treatment because of adverse effects.
Coutinho, Boulanger, and Gonçalves, 1986 Also described in Coutinho, 1989 | Design: RCT, method of randomization not described Intervention(s): Dates: N/S Location: Salvador, Bahia, Brazil Length of followup: N/A (no posttreatment followup) | No. of subjects at start: 97 Dropouts: 2 Loss to followup: N/A No. of subjects at end: 95 Setting: N/S Inclusion criteria: Uterine leiomyomas diagnosed by bimanual exam palpation and utrasonography; symptoms of bleeding irregularities, dyspareunia, or pelvic discomfort Exclusion criteria: None specified Age: Mean, 37.4; range, 18-53 Race: N/S Parity: 61 nulliparous Baseline uterine size: 303 cc (group A); 361 cc (group B); 371 cc (group C) Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb: 12.4 Baseline Hct: 36.9% | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: − C) Pt selection criteria: + D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: − Note: Both doses of oral gestrinone resulted in decrease in uterine size, but the vaginal administration was not associated with decrease in uterine size. All groups had similar resolution of symptoms.
  1) | Gestrinone 5 mg PO 3 times per week for 4-13 months (group A; n = 34)
  2) | Gestrinone 2.5 mg PO 3 times per week for 4-13 months (group B; n = 36)
  3) | Gestrinone 2.5 mg intravaginally 3 times per week for 4-13 months (group C; n = 27)
  1) | Uterine size
  2) | Symptoms - bleeding
  3) | Symptoms - pain
  4) | Adverse effects
  5) | Hgb/Hct
  1) | Uterine size: Uterine size decreased at 4 months by 17% in group A and by 26% in group B, but not in group C (increased by 4.3%) (p < 0.05). Uterine size decreased at 10 months by 23% in group A and 15% in group B, but not in group C (increased 11%) (p < 0.05). There was no significant difference between groups A and B.
  2) | Symptoms - bleeding: Among patients who had menorrhagia or metrorrhagia at the beginning of treatment, bleeding ceased in 25/26 (95%) in group A, 28/30 (93%) in group B, and 23/23 (100%) in group C (p = not significant).
  3) | Symptoms - pain: Among patients with chronic (non-coital) pain at the beginning of treatment, 14/15 (93%) in group A, 12/15 (80%) in group B, and 10/11 (91%) in group C had resolution of pain.
  4) | Adverse effects: Hypertension requiring treatment (1 pt); acne (40%); arthralgia (14%); nervousness (4 pts); chloasma (5 pts); curling of hair (3 pts); moderate hirsutism (5 pts); increased libido (4 pts); decreased libido (3 pts); hoarseness (6 pts); hair loss (6 pts); no adverse effects (53 pts).
  5) | Hgb/Hct: Mean Hgb increased to 13.16. Mean Hct increased to 38.4%. (No statistical testing reported)
Coutinho and Gonçalves, 1989 Also described in Coutinho, 1989 | Design: RCT, randomization by computer-generated code Intervention(s): Dates: N/S Location: Salvador, Bahia, Brazil Length of followup: Mean, N/S; range, 6 months-2 years | No. of subjects at start: 100 Dropouts: 4 Loss to followup: 7 No. of subjects at end: 89 Setting: N/S Inclusion criteria: Uterine leiomyoma Exclusion criteria: None specified Age: Mean, 37; range, 23-55 Race: N/S Parity: N/S Baseline uterine size: 245 ± 203 cc (group A); 367 ± 528 (group B); 248 ± 179 (group C) Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: + C) Pt selection criteria: − D) Length of followup: + E) Loss to followup: + F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: − Note: Duration of treatment was not standardized, but determined based on size of uterus by investigators. No ANOVA or repeated measures analysis. Large discrepancy in size of groups, despite computer randomization.
  1) | Gestrinone 2.5 mg PO 3 times per week for 6 months (group A; n = 40)
  2) | Gestrinone 5 mg PO 3 times per week for 6 months (group B; n = 30)
  3) | Gestrinone 5 mg intravaginally 3 times per week for 6 months (group C; n = 26)
  1) | Uterine volume
  2) | Symptoms - bleeding
  3) | Symptoms - pelvic pain
  4) | Adverse effects
  1) | Uterine volume: Uterine volume decreased at 6 months 18% in group A, 29% in group B, and 29% in group C. No statistically significant difference between groups, but each group decreased significantly from baseline (p < 0.02).
  2) | Symptoms - bleeding: At the end of 3 months, 86% of patients in group A, 80% of those in group B, and 76% of group C had ceased to bleed. (Statistical tests not reported)
  3) | Symptoms - pelvic pain: 76% of patients in group A, 88% of patients in group B, and 98% of those in group C who complained of pelvic pain at the beginning of the trial were free of pain by the end of the 3rd month. (Statistical tests not reported)
  4) | Adverse effects: Acne and seborrhea (66% A, 72% B, 66% C; p = not significant); myalgia (10.6%); arthralgia (24.2%; difference between groups p = not significant); hirsutism (13.3% to 26.3%); hoarseness (11%); increased libido (16%)
D'Addato, Repinto, and Andreoli, 1992 | Design: Case series (prospective), no controls Intervention(s): Presurgical treatment with GnRH agonist (various medications) for 3 months (n = 9) or 6 months (n = 16) Dates: Jan 1988-May 1991 Location: Vercelli, Italy Length of followup: N/A (no posttreatment followup) | No. of subjects at start: 25 Dropouts: 1 Loss to followup: N/A No. of subjects at end: 24 Setting: N/S Inclusion criteria: Uterine myomas; nonmenopausal Exclusion criteria: None specified Age: Mean N/S; range, 23-55 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: − S) Standardized measures: − Note: Outcomes not stratified by medication or duration of treatment.
  1) | Change in uterine size
  2) | Side effects
  1) | Change in uterine size: Mean decrease, 40%; range, 25%-68%
  2) | Side effects: Hot flashes: 100% Intermittent vaginal bleeding: 35% Vaginal dryness and dyspareunia: 65%
de Aloysio, Altieri, Penacchioni, et al., 1998 | Design: RCT, method of randomization not described Interventions: Dates: N/S Location: Bologna, Italy Length of followup: N/A (no posttreatment followup) | No. of subjects at start: 50 Dropouts: 3 Loss to followup: N/A No. of subjects at end: 47 Setting: Outpatient clinic/physician office Inclusion criteria: 13-30 months since menopause; 1-4 submucous or intramural asymptomatic fibroids; no coagulation diseases; BMI < 28; no endometrial pathology; no contraindications to hormone replacement therapy Exclusion criteria: None specified Age: Mean, 50.3; range, 46-55 (tibolone); 50.7 (46-56) (CEE/MPA) Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: − C) Pt selection criteria: + D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: + EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: + S) Standardized measures: +
  1) | Tibolone 2.5 mg every day x 12 28-day cycles (n = 25)
  2) | Conjugated equine estrogens 0.625 mg + medroxyprogesterone acetate 5 mg (CEE/MPA) every day x 12 28-day cycles (n = 25)
  1) | Incidence of amenorrhea, irregular bleeding, and spotting
  2) | Change in fibroid size
  3) | Endometrial thickness
  1) | Incidence of amenorrhea, irregular bleeding, and spotting:
  | Tibolone (n = 24) | CEE/MPA (n = 23)
  Cycles | 288 | 276
  Amenorrhea cycles/total p < 0.02 | 75% | 65.6%
  Bleeding cycles/total p = not significant | 22.6% | 29.7%
  Spotting cycles/total p = not significant | 2.4% | 4.7%
  Bleeding + spotting cycles/total p < 0.02 | 25% | 34.4%
  2) | Change in fibroid size: No significant change in fibroid size in either group (by transvaginal ultrasound)
  3) | Endometrial thickness: All patients had endometrial thickness < 4 mm at end of treatment (by transvaginal ultrasound)
de Aloysio, Altieri, Pretolani, et al., 1995 | Design: Case series (prospective), no controls Intervention(s): Leuprolide acetate depot 3.75 mg IM every 28 days for 6 cycles (n = 34), then 6 months with no medication (1st cycle). If uterine size increased during this period (n = 14), patient offered 6 additional months of treatment (2nd cycle). Dates: N/S Location: Bologna, Italy Length of followup: N/A (no posttreatment followup) | No. of subjects at start: 34 Dropouts: 4 during 1st cycle, 4/14 during 2nd cycle Loss to followup: N/A No. of subjects at end: 30 at end of 1st cycle; 12 at end of 2nd cycle (2 new patients added during 2nd cycle) Setting: ? Inclusion criteria: Symptomatic fibroids Exclusion criteria: None specified Age: Mean, 48.6; range, 45-53 Race: N/S Parity: < 3 prior deliveries Baseline uterine size: 301.9 cc ± 97.0 cc Baseline fibroid size: 4.8 cm ± 1.5 cm (diameter) Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: + L) Fibroid/uterine size: + M) Number of fibroids: + N) Location of fibroids: + O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Uterine volume
  2) | Largest fibroid diameter
  3) | Adverse effects
  4) | Symptoms
  1) | Uterine volume: 1st cycle: Uterine volume decreased from a mean 301.9 ± 97 ml to 190.8±98.1 ml after 6 months of treatment (p < 0.001), a 36.8% decrease. During 6 months with no treatment, uterine volume increased 17.5% (p = not significant). 2nd cycle: 33.8% reduction in volume (p < 0.005). Regrowth occurred after stopping treatment in 6/12 patients.
  2) | Largest fibroid diameter: 1st cycle: Largest fibroid diameter decreased from 4.8±1.5 cm to 3.9±0.6 cm after 6 months treatment (p < 0.05), a 17.7% decrease. During 6 months with no treatment, largest fibroid diameter increased 7.4% (p = not significant). 2nd cycle: Decrease in largest fibroid diameter of 15% (p = not significant).
  3) | Adverse effects: All women had hot flashes, severe in 23.6%. Other side effects included insomnia (17.6%), nausea (11.8%), dizziness (8.8%), and vaginal dryness (8.8%).
  4) | Symptoms: Amenorrhea occurred in 85.3% of women throughout the treatment period.
De Leo, la Marca, and Morgante, 1999 | Design: Case series (prospective), no controls Intervention(s): Danazol 400 mg PO per day for 4 months (n = 20) Dates: N/S Location: Siena, Italy Length of followup: 6 months | No. of subjects at start: 20 Dropouts: 0 Loss to followup: 0 No. of subjects at end: 20 Setting: Outpatient clinic/physician office Inclusion criteria: Uterine fibromyomas Exclusion criteria: None specified Age: Mean, N/S; range, 34-42 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: 400 ml Number of fibroids: N/S Baseline Hgb: 10.5 ± 0.7 g/dl Baseline Hct: 33.2 ± 1.6% | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: + E) Loss to followup: + F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: − I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: +
  1) | Fibroid volume
  2) | Hemoglobin
  3) | Hematocrit
  1) | Fibroid volume: Fibroid volume decreased from 400 ml pretreatment to 310 ml, or 76.4% of the pretreatment volume, during 4 months of treatment (p < 0.01). Three and 6 months after the end of treatment uterine volume increased slightly, but not to pretreatment values.
  2) | Hemoglobin: Hemoglobin increased significantly during treatment from 10.5±0.7 g/dl to 11.9±0.5 g/dl.
  3) | Hematocrit Hematocrit increased from 33.2±1.6% to 38.3±0.7% during treatment.
De Leo, Morgante, Lanzetta, et al., 1997 | Design: Case series (prospective), historical controls Intervention(s): Dates: Treatment group, N/S; controls, Nov 1993-Jun 1994 Location: Milan, Italy Length of followup: No posttreatment followup for patients taking danazol (series); 6 months of posttreatment followup for controls | No. of subjects at start: 21 cases, 12 historical controls Dropouts: N/S Loss to followup: N/S No. of subjects at end: N/S Setting: University clinic Inclusion criteria: Uterine leiomyomata (17 symptomatic, 4 asymptomatic) Exclusion criteria: Hormonal medication in past 3 months; prior use of a GnRH agonist Age: Danazol: Mean, 37.64 (range, 31-45); controls: Mean, 38.26 Race: N/S Parity: N/S Baseline uterine size: Approximately 400 ml (both groups) Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: + E) Loss to followup: − F) Dropout rates: − G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: − Note: Most (17/21) women were symptomatic.
  1) | Prospective series: Goserelin or triptorelin, dose N/S, every 28 days for 6 months, followed by danazol 100 mg PO every day for 6 months (n = 21)
  2) | Historical controls: GnRH agonist treatment, as above, but no follow-on danazol (n = 12)
  1) | Uterine size
  2) | Adverse effects
  1) | Uterine size: Regrowth in uterine volume after discontinuation of GnRH agonist was 31.2% less in patients treated with danazol than in historical untreated controls (p < 0.001)
  2) | Adverse effects: With GnRH agonist: Vasomotor symptoms: 75% Vaginal dryness: 30% Headache: 48% With danazol: No adverse effects reported
Donnez, Schrurs, Gillerot, et al., 1989 | Design: Case series (prospective), no controls Intervention(s): Buserelin implant 6.6 mg SC at end of luteal phase (n = 20) Dates: N/S Location: Brussels, Belgium Length of followup: N/A (no posttreatment followup) | No. of subjects at start: 20 Dropouts: 0 Loss to followup: N/A No. of subjects at end: 20 Setting: Outpatient clinic/physician office Inclusion criteria: Symptomatic uterine fibroids Exclusion criteria: None specified Age: Mean, 35; range, 25-42 Race: N/S Parity: N/S Baseline uterine size: 12 ± 5.4 cm2 (uterine cavity size) Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: + O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Uterine cavity area (by hysterosalping-ography)
  2) | Hemoglobin
  3) | Adverse effects
  1) | Uterine cavity area: Uterine cavity area decreased from 12 ± 5.4 cm2 to 7.8 ± 3.3 cm2 at 8 weeks, a decrease to 65% of pretreatment value.
  2) | Hemoglobin: In 9 patients who complained of menorrhagia, Hgb increased from 10.4±0.6 g/dl to 13.6±0.5 gm/dl (p < 0.05) at 8 weeks.
  3) | Adverse effects: Hot flashes: 19/20 (95%) Vaginal dryness: 12/20 (60%)
Fedele, Bianchi, Raffaelli, et al., 2000 | Design: RCT, randomization by computer-generated list Interventions: Dates: N/S Location: Milan, Italy Length of followup: N/A (no posttreatment followup) | No. of subjects at start: 38 Dropouts: 1 Loss to followup: N/A No. of subjects at end: 37 Setting: Outpatient clinic/physician office Inclusion criteria: Postmenopausal women with uterine fibroids who, when premenopausal, received medical treatment for myoma-associated menorrhagia; no GnRH treatment in previous 6 months; FSH > 50; one or more uterine myomas > 3 cm in diameter on ultrasound Exclusion criteria: Hormonal treatment in previous 3 months Age: E/MPA, 50.2 ± 2.3; tibolone, 50.6 ± 2.7 Race: N/S Parity: N/S Baseline uterine size: E/MPA, 103 ± 46 cc; tibolone, 97 ± 42 cc Baseline fibroid size (largest myoma): E/MPA, 26.8±12.5 cc; tibolone, 28.1 +14.1 cc Number of fibroids: E/MPA, 1.75±0.8; tibolone, 1.62±0.8 Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: + C) Pt selection criteria: + D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: + N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Transdermal estradiol 50 mcg per day + medroxyprogesterone acetate 10 mg per day (E/MPA) for 12 days per month x 1 year (n = 20)
  2) | Tibolone 2.5 mg per day x 1 year (n = 18)
  1) | Bleeding pattern
  2) | Vasomotor symptoms
  3) | Side effects
  4) | Volume of uterus
  5) | Number of myomas
  6) | Volume of largest myoma
  7) | Endometrium width
  | | E/MPA | Tibolone
  1) | Bleeding pattern:
  | Amenorrhea | − | 83%
  | Normal | 80% | −
  | Spotting/scant | 20% | 17%
  2) | Vasomotor symptoms: "Almost complete relief from vasomotor symptoms was obtained in all patients of both groups"
  3) | Side effects:
  | Mastodynia | 30% | −
  | Bloating | 20% | 15%
  | Headache | 15% | 15
  4) | Volume of uterus (cc):
  | Baseline | 103±46 | 97 ± 42
  | Month 6 | 119±56 | 101 ± 45
  | Month 12 | 125 ± 60 | 102 ± 49
  5) | Number of myomas:
  | Baseline | 1.75±0.8 | 1.62 ± 0.8
  | Month 6 | 1.95±0.9 | 1.70 ± 0.9
  | Month 12 | 2.15±0.9 | 1.67 ± 0.9
  6) | Volume of largest myoma (cc):
  | Baseline | 26.8±12.5 | 28.1 ± 14.1
  | Month 6 | 32.5±14.2 | 30.2 ± 12.8
  | Month 12 | 35.8±0.2 | 30.6 ± 16.2
  7) | Endometrium width (mm):
  | Baseline | 2.6±0.8 | 2.4 ± 0.8
  | Month 6 | 3.3±0.7 | 2.7 ± 0.7
  | Month 12 | 3.3±0.7 | 2.2 ± 0.6
  No significant differences between groups for outcomes 4 through 7.
Felberbaum, Germer, Ludwig, et al., 1998 | Design: RCT, method of randomization not described Intervention(s): Dates: Aug 1995-? Location: Lübeck, Germany Length of followup: N/A (no posttreatment followup) | No. of subjects at start: 20 Dropouts: 4 Loss to followup: N/A No. of subjects at end: 16 Setting: Outpatient clinic/physician office Inclusion criteria: Premenopausal; symptomatic fibroids; surgery planned Exclusion criteria: None specified Age: Mean, 34.5; range, 23-45 Race: 95% white; 5% black Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: − C) Pt selection criteria: − D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: + J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: + Note: After cetrorelix therapy, all patients underwent surgical procedure: 1 vaginal hysterectomy, 6 abdominal myomectomy, 6 laparoscopic myomectomy, 3 laparoscopic and hysteroscopic ablations, and 3 hysteroscopic myomectomies. No statistical tests described.
  1) | Cetrorelix 60 mg IM x 2 (n = 10)
  2) | Cetrorelix 60 mg IM x 1, then 30 mg IM x 1 (n = 10)
  1) | Uterine volume
  2) | Fibroid volume
  3) | Adverse effects
  1) | Uterine volume, % change: Cetrorelix 60 mg x 2: 30.4±15.2% Cetrorelix 60 mg, 30 mg: 20.5±20%
  2) | Fibroid volume, % change: Cetrorelix 60 mg x 2: 27.1±7.6% Cetrorelix 60 mg, 30 mg: 26.1±9.9%
  3) | Adverse effects: Hot flashes: 50%
Friedman, Barbieri, Benacerraf, et al., 1987 | Design: RCT, method of randomization not described Intervention(s): Treatment initiated (for both groups) during early follicular phase Dates: N/S Location: Boston, MA Length of followup: 4 months posttreatment | No. of subjects at start: 14 Dropouts: 4 Loss to followup: 0 No. of subjects at end: 10 Setting: Outpatient clinic/physician office Inclusion criteria: Leiomyomata uteri (at least one > 2.5 cm in diameter) or uterus twice normal volume with multiple fibroids; premenopausal (FSH < 30 mIU/ml) Exclusion criteria: Pregnant or desirous of future pregnancy; distal radius bone mineral density > 1 SD below mean; hyperplasia or neoplasia on endometrial biopsy; suspicion of ovarian or cervical mALIGNancy on physical exam or ultrasound; increase in uterine size of more than 3 gestational weeks over preceding 6 months Age: Mean, 41.2; range, 32-53 Race: N/S Parity: N/S Baseline uterine size: SC group: 12.9 weeks (range, 5-22); 368.1±60.1 cc; IN group: 14.0 weeks (range, 7-20); 579.1 ± 210.0 cc Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: − C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: + S) Standardized measures: +
  1) | Leuprolide 0.8 mg IN, twice each day for 24 weeks (n = 7)
  2) | Leuprolide 0.5 mg SC daily for 24 weeks (n = 7)
  1) | Uterine volume
  2) | Resolution of presenting symptoms
  3) | Bleeding
  4) | Adverse symptoms
  1) | Uterine volume (cc):
  | SC | IN
  N | 7 | 7
  Pretreatment | 368 | 579
  3 months | 202 | 520.6
  6 months | 172.3 | 635.7
  4 months posttreatment | 296.3 | 789
  2) | Resolution of presenting symptoms: Patients presented with pelvic pain, mass or menorrhagia. All SC patients had resolution of presenting symptoms, while only 1/7 IN patients experienced relief.
  3) | Bleeding: All patients treated with SC leuprolide were amenorrheic after 4 weeks of therapy and did not experience vaginal bleeding throughout the duration of therapy. Three of 7 patients in the IN group experienced amenorrhea after 4 weeks of therapy, while the remaining 4 patients had intermittent and irregular vaginal bleeding throughout the treatment period.
  4) | Adverse symptoms: The most commonly encountered side effect was hot flashes, experienced by all women in the SC group and 4/7 in the IN group.
Friedman, Barbieri, Doubilet, et al., 1988 | Design: RCT, method of randomization not described Intervention(s): Treatment initiated (for both groups) during early follicular phase Dates: N/S Location: Boston, MA Length of followup: N/A (no posttreatment followup) | No. of subjects at start: 16 Dropouts: 0 Loss to followup: N/A No. of subjects at end: 16 Setting: Outpatient clinic/physician office Inclusion criteria: Leiomyomata uteri (at least one > 2.5 cm in diameter) or uterus twice normal volume with multiple fibroids; premenopausal (FSH < 30 mIU/ml) Exclusion criteria: Pregnant or desirous of future pregnancy; distal radius bone mineral density > 1 SD below mean; hyperplasia or neoplasia on endometrial biopsy; suspicion of ovarian or cervical mALIGNancy on physical exam or ultrasound; increase in uterine size of more than 3 gestational weeks over preceding 6 months Age: Mean, 38.5 Race: N/S Parity: N/S Baseline uterine size: 811 ± 174 cc (MPA); 601 ± 62 cc (placebo) Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb: 11.4 g/dl (MPA); 12.7 g/dl (placebo) Baseline Hct: 33.5% (MPA); 36.3% (placebo) | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: − C) Pt selection criteria: + D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: + S) Standardized measures: +
  1) | Leuprolide acetate 0.5 mg SC + MPA 20 mg PO daily for 24 weeks (n = 9)
  2) | Leuprolide acetate 0.5 mg SC + placebo daily for 24 weeks (n = 7)
  1) | Uterine volume
  2) | Hgb
  3) | Hct
  4) | Adverse symptoms
  1) | Uterine volume: There was no significant decrease in uterine volume from baseline for the MPA group; in the placebo group, uterine size decreased significantly from baseline at all time points. No significant difference between groups.
  | MPA | Placebo
  Baseline | 811 | 601
  8 weeks | N/S | 388
  12 weeks | N/S | 307
  24 weeks | 688 | 294
  2) | Hgb (g/dl):
  | MPA | Placebo
  Baseline | 11.4 | 12.7
  24 weeks | 13.3 | 14.1
  3) | Hct (%):
  | MPA | Placebo
  Baseline | 33.5 | 36.3
  24 weeks | 39.1 | 40.7
  2) | Adverse symptoms: The most commonly experienced side effects were hot flashes, experienced by 11% of patients on MPA and 86% of patients on placebo (p < 0.01). Vaginal spotting occurred in 44% of patients on MPA, but no patients on placebo (p = 0.08).
Friedman, Daly, Juneau-Norcross, et al., 1994 and Friedman, Daly, Juneau-Norcross, et al., 1993 | Design: RCT, method of randomization not described Intervention(s): Both groups received leuprolide acetate depot 3.75 mg every 4 weeks for 2 years. After 3 months of this therapy, patients were randomized to receive either: Dates: N/S Location: Boston, MA Length of followup: 6 months posttreatment | No. of subjects at start: 51 Dropouts: 19 Loss to followup: 5 No. of subjects at end: 27 Setting: Outpatient clinic/physician office Inclusion criteria: Premenopausal (FSH < 30 mIU/ml); at least one fibroid > 3 cm in diameter or uterus twice normal size with multiple fibroids Exclusion criteria: Pregnant, lactating, or desirous of future pregnancy; uterine size increase of 3 gestational weeks in previous 6 months Age: Mean, 42.5 Race: N/S Parity: N/S Baseline uterine size: 898 ± 103 cc (E-P group); 738 ± 96 cc (P group) Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb: 11.7 ± 0.6 g/dl (E-P group); 11.2 ± 0.7 g/dl (P group) Baseline Hct: 36.0 ± 1.3% (E-P group); 34.3 ± 2.8% (P group) | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: − C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: +
  1) | Oestropipate 0.75 mg daily + norethindrone 0.7 mg on days 1-14 each month for 21 months (E-P group; n = 26); or
  2) | Norethindrone 10 mg daily for 21 months (P group; n = 25)
  1) | Uterine volume
  2) | Hgb
  3) | Hct
  1) | Uterine volume (cc): During add-back treatment with estrogen-progestin, mean uterine volume did not change significantly. During add-back treatment with progestin, uterine volume increased significantly. After GnRH and add-back treatment was completed, uterine volume returned to baseline levels in both groups.
  | E-P | P
  Baseline | 745 | 683
  3 months | 416 | 440
  Add-back
  1 year | 404 | 591
  2 years | 414 | 647
  Posttreatment
  30 months | 803 | 767
  2) | Hgb: Both treatment groups had significant and parallel increases in mean Hgb concentrations over time.
  3) | Hct: Both treatment groups had significant and parallel increases in mean Hct over time.
Friedman, Harrison-Atlas, Barbieri, et al., 1989 | Design: RCT, method of randomization not described Intervention(s): Dates: N/S Location: Boston, MA Length of followup: N/A (no posttreatment followup) | No. of subjects at start: 38 Dropouts: 5 Loss to followup: N/A No. of subjects at end: 33 Setting: Outpatient clinic/physician office Inclusion criteria: Premenopausal, with FSH < 30 mIU/ml; not pregnant or lactating; one member of couple sterilized or agree to barrier contraception; 1 fibroid 3 cm in diameter, or uterus twice normal size with fibroids on ultrasound; uterus known to have been enlarged for 6 months, with no growth > 3 gestational weeks in 6 months; no suspicion of cancer Exclusion criteria: None specified Age: Mean, 40.5 Race: N/S Parity: N/S Baseline uterine size: 505 ± 93 cc (leuprolide); 426 ± 43 cc (placebo) Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb: 12.3 ± 0.4 g/dl (leuprolide); 12.3 ± 0.3 g/dl (placebo) Baseline Hct: 36.3 ± 1% (leuprolide); 36.3 ± 0.8% (placebo) | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: − C) Pt selection criteria: + D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Leuprolide acetate 3.75 mg IM every 4 weeks x 24 weeks (n = 18)
  2) | Placebo (n = 20)
  1) | Uterine volume
  2) | Hct
  3) | Hgb
  1) | Uterine volume (cc): Leuprolide pre: 505±93 Leuprolide post: 307±57 Placebo pre: 426 ± 43 Placebo post: 429 ± 52
  2) | Hct: Leuprolide pre: 36.3±1% Leuprolide post: 38.1±0.9% Placebo pre: 36.3±0.8% Placebo post: 33.9±1.6%
  3) | Hgb (g/dl): Leuprolide pre: 12.3±0.4 Leuprolide post: 13.0±0.3 Placebo pre: 12.3±0.3 Placebo post: 11.3±0.6
Friedman, Hoffman, Comite, et al., 1991 | Design: RCT, method of randomization not described Intervention(s): Dates: N/S Location: Boston, MA Length of followup: 24 weeks (unclear whether mean or median) | No. of subjects at start: 128 Dropouts: 35 Loss to followup: 1 No. of subjects at end: 92 Setting: Outpatient clinic/physician office Inclusion criteria: Premenopausal; age > 21 yrs; regular cycles; not pregnant or lactating; enlarged uterus on ultrasound or MRI, or > 1 myoma > 3 cm in diameter; no gynecological mALIGNancy; no calcification of pelvic masses; no previous treatment with GnRH analog; no medical/surgical treatment of fibroids in past 3 months; baseline bone density not more than 2 SDs below mean for age-matched controls Exclusion criteria: None specified Age: Mean, 36.4 Race: N/S Parity: N/S Baseline uterine size: 507 cc Baseline fibroid size: 176 cc Number of fibroids: N/S Baseline Hgb: 12.6 g/dl Baseline Hct: 37.5% | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: − C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: − S) Standardized measures: −
  1) | Leuprolide acetate 3.75 mg IM every 4 weeks x 24 weeks (n = 63)
  2) | Placebo (n = 65)
  1) | Uterine volume
  2) | Fibroid volume (largest)
  3) | Hct
  4) | Hgb
  5) | Symptoms
  6) | Side effects
  1) | Uterine volume: Leuprolide pre: 522±52 cc Leuprolide post: 44.6% reduction Placebo pre: 452 ± 51 cc Placebo post: 5% increase
  2) | Fibroid volume (largest): Leuprolide pre: 143±43 cc Leuprolide post: 40.1% reduction Placebo pre: 206 ± 42 cc Placebo post: No change
  3) | Hct: Leuprolide pre: 37.8±0.5% Leuprolide post: 38.6±0.5% Placebo pre: 37.3±0.5% Placebo post: 36.7±0.5%
  4) | Hgb (g/dl): Leuprolide pre: 12.6±0.2 Leuprolide post: 13.1±0.2 Placebo pre: 12.6±0.3 Placebo post: 12.3±0.2
  5) | Symptoms (%) (R = resolve, I = improve, N = no change, W = worse):
    | R | I | N | W
    Bloating:
    Leuprolide | 60 | 9.5 | 19 | 12
    Placebo | 27 | 29 | 39 | 11
    Menorrhagia:
    Leuprolide | 97 | 0 | 3 | 0
    Placebo | 47 | 14 | 22 | 8
    Pelvic pressure:
    Leuprolide | 67 | 26 | 7.5 | 0
    Placebo | 42 | 13 | 38.8 | 65
    Pelvic pain:
    Leuprolide | 83 | 16 | 16 | 0
    Placebo | 65 | 13 | 17 | 4
    Constipation:
    Leuprolide | 61 | 17 | 17 | 14
    Placebo | 44 | 19 | 38 | 0
    Urinary frequency:
    Leuprolide | 78 | 17 | 6 | 0
    Placebo | 36 | 3 | 26 | 14
    Dyspareunia:
    Leuprolide | 69 | 0 | 19 | 13
    Placebo | 56 | 6 | 28 | 11
    Menometrorrhagia:
    Leuprolide | 0 | 0 | 0 | 0
    Placebo | 80 | 20 | 0 | 0
  6) | Side effects:
    | Leuprolide | Placebo
    Vasomotor flushes: | 83% | 8%
    P < 0.0001
    Vaginitis: | 17% | 0%
    P < 0.0005
    Arthralgia/myalgia: | 14% | 0%
    P < 0.005
    Asthenia: | 16% | 5%
    P < 0.05
    Peripheral edema: | 11% | 2%
    P < 0.05
    Insomnia: | 10% | 0%
    P < 0.05
    Nausea: | 10% | 2%
    P < 0.05
    Headache: | 29% | 20%
    Depression: | 11% | 3%
    Emotional lability/nervousness: | 8% | 2%
    Decreased libido: | 3% | 0%
Golan, Bukovsky, Schneider, et al., 1989 | Design: Case series, no controls Intervention(s): D-Trp-6-LHRH 3.2 mg IM every month x 6 months (n = 26) Dates: N/S Location: Zerifin, Israel Length of followup: 3 months after end of treatment | No. of subjects at start: 26 Dropouts: 2 Loss to followup: 1 No. of subjects at end: 23 Setting: N/S Inclusion criteria: Clinically or ultrasonographically diagnosed fibroids; symptoms from fibroids; referral for hysterectomy or myomectomy Exclusion criteria: None specified Age: Mean, 37.8; range, 22-52 Race: N/S Parity: N/S Baseline uterine size: 604 ± 298 ml Baseline fibroid size: 258 ± 124 ml Number of fibroids: N/S Baseline Hgb: N/S Baseline Hct: 63% | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: − Note: "Clinical impression of diminished blood loss and decreased need for transfusion" with treatment.
  1) | Uterine volume
  2) | Fibroid volume
  1) | Uterine volume: Pretreat: 604±298 ml Posttreat (6 months): 289±159 ml Followup: 434±166 ml
  2) | Fibroid volume: Pretreat: 258±124 ml Posttreat (6 months): 95±66 ml Followup: 175± 94 ml
Gregoriou, Vitoratos, Papadias, et al., 1997 | Design: RCT, method of randomization not described Dates: N/S Location: Athens, Greece Length of followup: N/A (no posttreatment followup) | No. of subjects at start: 40 Dropouts: 0 Loss to followup: N/A No. of subjects at end: 40 Setting: Outpatient clinic/physician office Inclusion criteria: Postmenopausal (no menses in previous 1 year); at least one fibroid > 20 mm in diameter Exclusion criteria: Contra-indication to hormone replacement therapy Age: N/S Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: 102.6 cc (tibolone group); 118.4 cc (no-treatment group) Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: − C) Pt selection criteria: + D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: − I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  Intervention(s):
  1) | Tibolone 2.5 mg daily for 1 year (n = 20);
  2) | No treatment (n = 20)
  1) | Fibroid volume
  2) | Adverse effects
  1) | Fibroid volume: Fibroid volume showed no statistically significant change in either group. Tibolone-treated patients had initial volume of 102.6 cc and final volume of 98.2 cc, while control patients began at 118.4 cc and finished at 117.5 cc
  2) | Adverse effects: 3/20 (15%) tibolone-treated patients complained of spotting
Hackenberg, Gesenhues, Deichert, et al., 1992 | Design: Case series (prospective), no controls Intervention(s): Goserelin acetate depot 3.6 mg SC monthly for 3 months (n = 27); started during mid-luteal phase Dates: N/S Location: Marburg, Germany Length of followup: N/A (no posttreatment followup) | No. of subjects at start: 27 Dropouts: 0 Loss to followup: N/A No. of subjects at end: 27 Setting: Outpatient clinic/physician office Inclusion criteria: Symptomatic uterine fibroids Exclusion criteria: None specified Age: Mean, 34; range, 19-40 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: 97 ml (range, 5-267 ml) Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: + S) Standardized measures: − Notes: Ultrasound fibroid size compared with surgical specimens demonstrated fair agreement in 4 specimens. Predictive model was not validated, and cut point selection was suggested by the data distribution. The performance of the prediction in these data certainly overestimates its accuracy if used prospectively.
  1) | Fibroid volume
  2) | Prediction of regression of more than 50% after 3 months based on response at 1 month
  1) | Fibroid volume (by transvaginal ultrasound): Fibroid volume decreased by more than 50% in 15/27 patients (56%); decreased by 11-50% in 7 (26%) patients; showed no significant decrease in 5 (18%). There was no statistically significant correlation between initial fibroid volume and extent of response.
  2) | Prediction of regression of more than 50% after 3 months, based on 1-month response: In a retrospective analysis, the investigators determined that a reduction in fibroid volume of at least 35% after 1 month of treatment was predictive of an ultimate reduction of at least 50% at 3 months. Sensitivity, 86%; specificity, 77%.
Kuhlmann, Gartner, Schindler, et al., 1997 | Design: Case series (retrospective), no controls Dates: 1987-1993 Location: Essen, Germany Length of followup: N/S | No. of subjects at start: 61 Dropouts: N/A Loss to followup: N/S No. of subjects at end: N/S Setting: N/S Inclusion criteria: Series included all patients treated for fibroids with GnRH agonist for 6 months; all patients sterile Exclusion criteria: None specified Age: Mean, 33.3; range, 28-42 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: − E) Loss to followup: − F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: − S) Standardized measures: + Note: Retrospective study with what appear to be posthoc analyses between patients with fibroids alone vs. those with concurrent endometriosis. One of the main outcomes is pregnancy, but 56% of the pregnancies were treated with some assisted reproductive technology.
  Intervention(s):
  1) | GnRH agonists (variety of preparations used) x 6 months (n = 20)
  2) | GnRH agonists (variety of preparations used) x 6 months, followed by myomectomy (n = 41)
  1) | Fibroid volume reduction
  2) | Side effects
  3) | Pregnancy rates
  4) | Abortion rates
  1) | Fibroid volume reduction (%): Fibroids alone (n = 23): 47% Fibroids + endometriosis (n = 38): 54%
  2) | Side effects: Hot flashes: 59% Headache: 40% Insomnia: 20% Vaginal dryness: 16%
  3) | Pregnancy rates: Fibroids alone: GnRH alone: 4% GnRH + myomectomy: 26% Fibroids + endometriosis: GnRH alone: 34% GnRH + myomectomy: 13%
  4) | Abortion rate (% of pregnancies): Fibroids alone: 14% Fibroids + endometriosis: 17%
Maheux and Lemay, 1992 | Design: Nonrandomized concurrent cohort comparison Intervention(s): Goserelin depot 3.6 mg SC every 28 days beginning during days 2-5 of the cycle x 1 year (n = 20). After month 3, low-dose HRT (conjugated equine estrogen 0.3 mg and MPA 5 mg) was given either cyclically or continuously. Dates: May 1987-Jun 1990 Location: Quebec, Canada Length of followup: 3 months | No. of subjects at start: 20 Dropouts: 2 Loss to followup: 0 No. of subjects at end: 18 Setting: Outpatient clinic/physician office Inclusion criteria: Age 39-51; symptomatic uterine leiomyoma; normal ovulatory cycles; normal endometrial biopsy Exclusion criteria: Menopausal; pregnant or breast-feeding; hormonal therapy in previous 6 months; history of thromboembolism; obesity Age: Mean, 45.4; range, 39-51 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: 215.8 ± 73 cc Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Fibroid volume
  2) | Bleeding
  3) | Hemoglobin
  4) | Side effects
  5) | Pelvic pain/pressure
  1) | Fibroid volume: Fibroid volume decreased during the first 3 months (p < 0.001) to 46.5% of pretreatment values. After addition of HRT, mean fibroid volume did not change significantly between months 3 and 12. Three months after treatment ended, fibroid volume increased to pretreatment values (108.7% baseline; p = not significant).
  2) | Bleeding: Better control of bleeding was observed with continuous versus cyclical HRT.
  3) | Hemoglobin: In 5 anemic patients, Hgb increased from 10.5 ± 1.1 g/l to 12.6 ± 0.8 g/l at 1 year.
  4) | Side effects: All patients had hot flashes, severe in 6 patients. Hot flashes decreased with HRT and were less severe in patients receiving continuous HRT.
  5) | Pelvic pain and pressure: These symptoms "almost completely disappeared during treatment."
Murphy, Morales, Kettel, et al., 1995 | Design: Case series (prospective), no controls Intervention(s): RU486 in following doses: Dates: N/S Location: San Diego, CA Length of followup: N/A (no posttreatment outcomes) | No. of subjects at start: 30 Dropouts: 0 Loss to followup: N/A No. of subjects at end: 30 Setting: Outpatient clinic/physician office (university) Inclusion criteria: Normal cycling; age 18-45; symptomatic fibroids Exclusion criteria: None specified Age: N/S Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: + EXTERNAL VALIDITY H) Age: − I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | 50 mg per day x 12 weeks (n = 10)
  2) | 25 mg per day x 12 weeks (n = 11)
  3) | 5 mg per day x 12 weeks (n = 9)
  1) | Uterine volume decrease (estimated from graph)
  2) | Amenorrhea
  1) | Uterine volume decrease: 50 mg per day: 50% 25 mg per day: 55% 5 mg per day: 25% (All p < 0.05)
  2) | Amenorrhea: 100% in all groups
Nakamura, Yoshimura, Yamada, et al., 1991 | Design: Case series (prospective), no controls Intervention(s): Buserelin acetate 300 mcg intranasally 3 times per day x 16 weeks (n = 25) Dates: N/S Location: Tokyo, Japan Length of followup: 3-6 months | No. of subjects at start: 25 (8 of whom had no menses posttreatment; 17 of whom resumed menses within 12 weeks posttreatment) Dropouts: 0 Loss to followup: 0 No. of subjects at end: 25 Setting: Outpatient clinic/physician office Inclusion criteria: Regular menstrual cycles; symptomatic fibroids (pain, menorrhagia, dysmenorrhea, pressure); normal Pap smear; normal endometrial biopsy; no history of major abdominal or pelvic surgery Exclusion criteria: None specified Age: Mean, 48.0; range, 36-54 Race: N/S Parity: N/S Baseline uterine size: 312 ± 48 cc (no-menses group); 311±41 cc (menses group) Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb: 9.5 ± 0.9 mg/dl (both groups) Baseline Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: + G) Statistical issues: + EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: + L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: − S) Standardized measures: − Note: Described as a "randomized retrospective study," but is in fact a case series. The authors reported some results dividing between women who entered menopause directly after treatment versus those who resumed menses. The reason for doing this is unclear.
  1) | Bleeding posttreatment (> 3-month followup)
  2) | Dysmenorrhea
  3) | Pelvic pressure
  4) | Hgb
  5) | Uterine volume
  1) | Bleeding posttreatment: Amenorrhea: 24% Improved: 68% Severe bleeding episode: 8%
  2) | Dysmenorrhea: Resolved: 100%
  3) | Pelvic pressure: Resolved: 100%
  4) | Hgb (mg/dl): No-menses group (includes the severe bleed): Pretreatment: 9.5±0.9 Posttreatment: 12.6±0.7 3-month followup: No significant change (p < 0.02 vs. post− treatment value) Group with resumption of menses: Pretreatment: 9.5±0.9 Posttreatment: 13.0±0.6 (p < 0.001) 3-month followup: 11.8 (p < 0.05 vs. pretreatment value)
  5) | Uterine volume (cc): No-menses group (includes the severe bleed): Pretreatment: 312 ± 48 Posttreatment: 166 ± 45 (p < 0.02) Group with resumption of menses: Pretreatment: 311 ± 41 Posttreatment: 219 ± 63 (p = not significant)
Palomba, Affinito, Di Carlo, et al., 1999 | Design: Case series (prospective), no controls Interventions: Leuprolide acetate 3.75 mg IM every 28 days, plus tibolone 2.5 mg PO daily, for 2 years (n = 25) Dates: N/S Location: Naples, Italy Length of followup: 6 months | No. of subjects at start: 25 Dropouts: 3 Loss to followup: 4 No. of subjects at end: 18 Setting: Outpatient clinic/physician office Inclusion criteria: Symptomatic uterine leiomyomas Exclusion criteria: More than 4 myomas; submucosal fibroids by hysteroscopy; calcific or hypoechoic fibroids Age: Mean, 47.7; range, 41-52 Race: N/S Parity: N/S Baseline uterine size: 987.1 ± 105.4 cc Baseline fibroid size: 295.8 ± 59.1 cc Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: + E) Loss to followup: + F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: + O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Uterine volume
  2) | Fibroid volume
  3) | Symptoms
  1) | Uterine volume: Uterine size decreased from baseline (987.1 ± 105.4 cc) to 6 months (421.6 ± 94.3 cc) (p < 0.01). Between 6 months and 2 years (475.8 ± 106.5 cc), uterine volume did not change significantly. During 6 months after treatment, uterine volume increased significantly (757.2 ± 221.5 cc) from treatment volumes but remained significantly less than baseline volume.
  2) | Fibroid volume: Fibroid size decreased from baseline (295.8 ± 94.3 cc) to 6 months (131.7 ± 29.7 cc) (p < 0.01). Between 6 months and 2 years (159.2 ± 45.3 cc), fibroid volume did not change significantly. During 6 months after treatment, fibroid volume increased significantly (232.7 ± 80.1 cc) from treatment volumes but remained significantly less than baseline volume.
  3) | Symptoms: There was a statistically significant reduction in intensity for all myoma-related symptoms at 6th month of treatment (p < 0.01); this reduction persisted during the entire course of treatment. At followup, there was a significant increase in intensity of myoma-related symptoms compared with during treatment.
Palomba, Affinito, Tommaselli, et al., 1998 | Design: RCT, method of randomization not described Intervention(s): Dates: N/S Location: Naples, Italy Length of followup: N/A (no posttreatment followup) | No. of subjects at start: 50 Dropouts: 1 Loss to followup: N/A No. of subjects at end: 49 Setting: N/S Inclusion criteria: Symptomatic fibroids Exclusion criteria: History of pathologic fractures, renal disease, metabolic disease, endocrine disease, or smoking; use of drugs affecting bone or lipid metabolism; liver disease; ischemic heart disease; alterations in lipid metabolism; diabetes; acute or recent thrombosis; carcinoma of breast or endometrium; previous medical or surgical treatment for fibroids; BMI > 27 kg/m2 Age: Mean, 44.5; range, 38-51 Race: N/S Parity: N/S Baseline uterine size: 995.8 ± 170.4 cc (LA + placebo); 976±114.9 cc (LA + tibolone) Baseline fibroid size: 307.6 ± 64.5 cc (LA + placebo); 295.8 ± 58.7 cc (LA + tibolone) Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: − C) Pt selection criteria: − D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: − S) Standardized measures: −
  1) | Leuprolide acetate (LA) 3.75 mg IM every 28 days plus placebo every day x 6 months (n = 25)
  2) | LA 3.75 mg IM every 28 days plus tibolone 2.5 mg every day x 6 months (n = 25)
  1) | Uterine volume
  2) | Fibroid volume
  3) | Symptoms
  1) | Uterine volume (cc): LA + placebo: Pretreatment: 995.8 ± 170.4 Posttreatment: 386.4 ± 94.6 LA + tibolone: Pretreatment: 976 ± 114.9 Posttreatment: 414.8 ± 98.1 (p = not significant)
  2) | Fibroid volume (cc): LA + placebo: Pretreatment: 307.6 ± 64.5 Posttreatment: 132.8 ± 34.3 LA + tibolone: Pretreatment: 295.8 ± 58.7 Posttreatment: 138.7 ± 29.7 (p = not significant)
  3) | Symptoms: Menorrhagia: LA + placebo (n = 25): Complete relief: 100% Partial relief: 0% LA + tibolone (n = 24): Complete relief: 92% Partial relief: 8% (p = not significant) Pelvic pressure: LA + placebo (n = 24): Complete relief: 94% Partial relief: 6% LA + tibolone (n = 22): Complete relief: 90% Partial relief: 10% (p = not significant) Pelvic pain: LA + placebo (n = 17): Complete relief: 89% Partial relief: 11% LA + tibolone (n = 16): Complete relief: 87.5% Partial relief: 12.5% (p =not significant) Urinary frequency: LA + placebo (n = 19): Complete relief: 84% Partial relief: 16% LA + tibolone (n = 17): Complete relief: 94% Partial relief: 6% (p =not significant) Constipation: LA + placebo (n = 14): Complete relief: 100% Partial relief: 0% LA + tibolone (n = 13): Complete relief: 100% Partial relief: 0% (p =not significant) Number of hot flashes: LA + placebo: 4.5/day LA + tibolone: 1.5/day (p < 0.01)
Rendina and Patrono, 1976 | Design: RCT, method of randomization not described Intervention(s): Dates: N/S Location: Rome, Italy Length of followup: N/A (no posttreatment outcomes) | No. of subjects at start: 58 with fibroids (of total study population of 200) (assuming no dropouts) Dropouts: N/S Loss to followup: N/A No. of subjects at end: 58 Setting: N/S Inclusion criteria: Menorrhagia with uterine fibroids Exclusion criteria: None specified Age: N/S Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: − C) Pt selection criteria: − D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: − G) Statistical issues: − EXTERNAL VALIDITY H) Age: − I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: − Note: "Lysometra" described only as a biologic preparation.
  1) | "Lysometra" 2.5 ml/day x 20 days/month for maximum of 3 months (n = 29)
  2) | Methylandrostendiol 5 mg/day x 20 days/month for maximum of 3 months (n = 29)
  1) | Menstrual bleeding
  1) | Menstrual bleeding: Lysometra: Complete relief: 65% Partial relief: 28% No relief: 7% Methylandrostendiol: Complete relief: 51% Partial relief: 38% No relief: 10%
Sakamoto, Yoshino, Shirahata, et al., 1992 | Design: Case series (prospective), no controls Intervention(s): Kuei-chin-fu-ling-wan, Chinese herbal medication (referred to by Japanese abbreviation KBG), 1.5 g per day x 12 or more weeks Dates: 1985-1989 Location: Tokyo, Japan Length of followup: N/S | No. of subjects at start: 110 Dropouts: N/S Loss to followup: N/S No. of subjects at end: N/S Setting: N/S Inclusion criteria: Premenopausal; symptomatic fibroids Exclusion criteria: > 10-cm diameter uterus Age: Mean, 43.2; range, 27-52 Race: 100% Asian Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: − E) Loss to followup: − F) Dropout rates: − G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: + J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Hypermenorrhea
  2) | Dysmenorrhea
  3) | Anemia improvement
  4) | Fibroid size
  5) | Need for additional treatment
  1) | Hypermenorrhea (57% of patients): Improved: 95% "Reduced to normal": 46%
  2) | Dysmenorrhea (46% of patients): Improved: 94% "Extinguished": 51%
  3) | Anemia (13% of patients): Improved: 43% Improved with study treatment + iron: 57%
  4) | Fibroid size: Complete resolution: 19% Decreased: 43% No change: 34% Increased: 4%
  5) | Need for additional treatment: 15/110 (14%) underwent hysterectomy
Schlaff, Zerhouni, Huth, et al., 1989 | Design: RCT, method of randomization not described Intervention(s): Dates: N/S Location: Baltimore, MD Length of followup: 6 months | No. of subjects at start: 11 Dropouts: 0 Loss to followup: 0 No. of subjects at end: 11 Setting: Academic medical center Inclusion criteria: Symptomatic fibroids; regular monthly menstrual cycles Exclusion criteria: Bone density below mean for age Age: Mean, 36.7 Race: N/S Parity: N/S Baseline uterine size: 654 ± 195 cc (leuprolide); 457 ± 106 cc (placebo) Baseline fibroid size: 402 ± 157 cc (leuprolide); 267 ± 82 cc (placebo) Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: − C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: − Note: Sample size issues not discussed.
  1) | Leuprolide acetate 3.75 mg per month x 6 months (n = 5)
  2) | Placebo x 6 months (n = 6)
  1) | Uterine size
  2) | Fibroid size
  3) | Symptoms
  4) | Side effects/complications
  1) | Uterine size (cc): Placebo: Pretreatment: 457 ± 106 (mean ± SEM); range, 136-924 Posttreatment: 656 ± 208 Leuprolide: Pretreatment: 645±195; range, 266-1383 Posttreatment: 467 ± 182 P < 0.02 compared with placebo
  2) | Fibroid size (cc): Placebo: Pretreatment: 267±82; range, 28-626 Posttreatment: 417 ± 169 Leuprolide: Pretreatment: 402 ± 157; range, 89-1020 Posttreatment: 334 ± 166 P = 0.06 compared with placebo
  3) | Symptoms: Pain: 10/11 resolved at end of treatment; 7/11 persistent response 6 months after cessation Bleeding: 7/7 resolved; 3/7 persistent response Pelvic pressure: 6/8 resolved; 3/8 persistent response Constipation: 4/6 resolved; 3/6 persistent response Dyspareunia: 4/5 resolved; 2/5 persistent response
  4) | Side effects/complications: "All" had hot flashes "Less frequently" reported: Vaginal dryness, fatigue, tenderness at injection site
Scialli and Jestila, 1995 | Design: RCT, randomization by random numbers table (inadequate concealment) Intervention(s): All subjects received LA 3.75 mg per month x 6 months. Then randomized to receive either: Dates: N/S Location: Washington, DC Length of followup: N/A (no posttreatment outcomes) | No. of subjects at start: 41 Dropouts: 20 Loss to followup: N/A No. of subjects at end: 21 Setting: Outpatient clinic/ physician office (university) Inclusion criteria: Abnormal bleeding secondary to fibroids; bleeding > 7 days per month, resulting in anemia or interfering with attendance at work or other customary activities; sonographic confirmation of fibroids Exclusion criteria: Endometrial abnormality Age: Mean, 38.3 Race: N/S Parity: N/S Baseline uterine size: 539 ± 174 cc (MPA); 344 ± 63 cc (placebo) Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb: 10.8 ± 0.7 g/dl (MPA); 11.9 ± 0.4 g/dl (placebo) Baseline Hct: N/S | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: − C) Pt selection criteria: + D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: − Note: Statistical procedures well described; sample size considerations not discussed. High dropout rate due to bleeding; however, this was accounted for in the intention-to-treat analysis.
  1) | MPA 5 mg per day x 6 months (n = 21); or
  2) | Placebo x 6 months (n = 20)
  1) | Uterine size
  2) | Hemoglobin
  3) | Symptoms (prospectively measured by menstrual calendar)
  4) | Side effects/complications
  1) | Uterine size (cc): LA + MPA: Pretreatment: 538 ± 174 After LA: 171±41* After MPA: 473±213 *p < 0.05 compared to pretreatment LA + placebo: Pretreatment: 344 ± 63 After LA: 226 ± 66 After placebo: 510 ± 144 P = not significant
  2) | Hemoglobin (g/dl): LA + MPA: Pretreatment: 12.0 ± 0.3 After LA: 13.0 ± 0.2* After MPA: 12.8 ± 0.2 *p < 0.05 compared to pretreatment LA + placebo: Pretreatment: 10.3 ± 0.8 After LA: 12.4 ± 0.4* After placebo: 11.2 ± 0.6** *p < 0.05 compared to pretreatment **p < 0.05 compared to after LA
  3) | Symptoms: < 7 days/month bleeding or subjective improvement: LA + MPA: 8/21 LA + placebo: 11/20
  4) | Side effects/complications: 7/41 dropped out during LA treatment 3 hot flashes 1 joint pain 1 thyroid enlargement 2 nonmedical reasons
Serra, Panetta, Colosimo, et al., 1992 | Design: Case series (prospective), no controls Intervention(s): Leuprolide acetate 3.75 mg per month x 4 months (n = 110) Dates: N/S Location: Multiple sites in Italy Length of followup: Mean, 8 months; range, 6 months-1 year | No. of subjects at start: 110 Dropouts: 3 Loss to followup: None through 16 weeks; 25 through long-term followup No. of subjects at end: 107 at 16 weeks; 82 at long-term followup Setting: N/S Inclusion criteria: Premenopausal; symptomatic fibroids, confirmed by ultrasound; no possibility of ovarian, uterine, or cervical mALIGNancy on physical or radiographic examination Exclusion criteria: Calcification; prior treatment with GnRH; any other medical/surgical treatment in prior 3 months; pregnant or lactating Age: Mean, 42.1 Race: N/S Parity: N/S Baseline uterine size: 294.5 cc (multiple fibroids); 82.9 cc (single fibroids) | | Results reported separately for patients with single (n = 89) and multiple (n = 88) fibroids; not mutually exclusive groups. | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: − Note: Detailed data provided on subgroups.
  1) | Uterine size
  2) | Symptoms
  3) | Need for surgery
  4) | Side effects/complications
  1) | Uterine size: Single fibroid: Pretreatment: 82.9 cc Posttreatment: Mean reduction in volume, 42.6 P < 0.001 Multiple fibroids: Pretreatment: 294.5 cc Posttreatment: 164.1 cc P < 0.001 Reduction to normal size (< 120 cc) related to pretreatment size:
    Size | % reduced to "Normal"
    121-225 cc (n = 50) | 70%
    236-384 cc (n = 29) | 28%
    401-3063 cc (n = 8) | 8%
  2) | Symptoms: End of 4 months (n = 100): Resolved: 34% Improved: 60% No change: 5.6% 8 months-1 year posttreatment (n = 82): Asymptomatic: 64.5% Recurred: 24.3% Pregnant: 2.4% Menopausal: 1.2% Lost to followup: 7.3%
  3) | Need for surgery: End of 4 months (n = 100): 9/100 (8.4%) 8 months-1 year post treatment (n = 82): 22/76 (26.8%)
  4) | Side effects/complications: "Most" had hot flashes
Ueki, Okamoto, Tsurunaga, et al., 1995 | Design: Case series (prospective), concomitant controls Intervention(s): Dates: N/S Location: Osaka, Japan Length of followup: N/A (no posttreatment followup) | No. of subjects at start: 247? Dropouts: N/S Loss to followup: N/A No. of subjects at end: N/S Setting: Outpatient clinic/physician office Inclusion criteria: Uterine leiomyomas diagnosed by ultrasonography Exclusion criteria: None specified Age: Danazol group: mean, 41.9; range, 24-53. Buserelin group: mean, 42.5; range, 29-54 Race: N/S (likely 100% Asian) Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: − G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Danazol 400 mg PO daily x 4-6 months (n = 164)
  2) | Buserelin 900 mcg IN daily x 4-6 months (n = 83)
  1) | Fibroid volume
  1) | Fibroid volume: Fibroid volume decreased by 27.4% in danazol-treated patients and 51.7% in buserelin-treated patients; 6.7% of danazol-treated patients and 76.1% of buserelin-treated patients had at least a 10% reduction in fibroid size
van Leusden, 1992 | Design: Case series (prospective), no controls Intervention(s): Triptorelin 3.75 mg monthly x 3-6 months Dates: N/S Location: Arnhem, The Netherlands Length of followup: 42 months+ | No. of subjects at start: 28 (22 premenopausal, 6 peri-menopausal) Dropouts: 0 Loss to followup: 0 No. of subjects at end: 28 Setting: N/S Inclusion criteria: Intramural fibroids; symptomatic fibroids Exclusion criteria: None specified Age: Mean, 41; range, 28-54 Race: N/S Parity: N/S Baseline uterine size: 588±561 cc (perimenopausal pts); 444 ± 357.5 cc (premenopausal pts) Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb: 7.4 ± 0.76 g/dl (reported for premenopausal pts only) Baseline Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: − S) Standardized measures: −
  1) | Uterine size
  2) | Hemoglobin
  3) | Need for additional treatment
  1) | Uterine size (cc): Premenopausal (n = 22): Pretreatment: 444 ± 375 Posttreatment: 158 ± 111 P < 0.05 Perimenopausal (n = 6): Pretreatment: 588 ± 561 Posttreatment: 125 ± 76 P = 0.0001
  2) | Hemoglobin (premenopausal only): Pretreatment: 7.4 ± 0.36 g/dl Posttreatment: 8.7 ± 5.3 g/dl P < 0.05
  3) | Need for additional treatment: Premenopausal: 12/22 within 1 year (11 hysterectomies, 1 myomectomy); 1/10 between 2 and 3.5 years (1 hysterectomy) Postmenopausal: 0/6 within 3 years
Vavalà, Lanzone, Monaco, et al., 1997 | Design: Case series, concomitant controls Interventions: Dates: N/S Location: Rome, Italy Length of followup: Up to 40 months (mean N/S) | No. of subjects at start: 65 (assuming no dropouts and no loss to followup) Dropouts: N/S Loss to followup: N/S No. of subjects at end: 65 Setting: Outpatient clinic/physician office Inclusion criteria: Premenopausal patients with uterine myomas; at least 1 myoma > 2 cm in diameter; age < 40 Exclusion criteria: None specified Age: Means, 34 (LA group), 35 (controls) Race: N/S Parity: N/S Baseline uterine size: Approximately 70 cc (LA group); approximately 72 cc (controls) Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: + E) Loss to followup: − F) Dropout rates: − G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: + L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: − S) Standardized measures: −
  1) | LA depot 3.75 mg SC each month for 3 consecutive months each year for 3 years. Treatment was started 4 months after surgery (n = 25)
  2) | Control patients did not accept the above-described treatment after surgery (n = 40)
  1) | Recurrence of myoma > 2 cm in diameter:
  2) | Uterine volume
  1) | Recurrence of myoma > 2 cm in diameter: 1 of 25 leuprolide-treated patients (4%) and 9 of 40 control patients (22.5%) had recurrent myomas over the 40-month followup period (p < 0.05).
  2) | Uterine volume: Patients in the leuprolide-treated group showed a significantly reduced uterine volume (51.7±7 cc) at followup compared with untreated patients (85 0± 17 cc) (p < 0.001).
Vollenhoven, Shekleton, McDonald, et al., 1990 | Design: Case series (prospective), no controls Intervention(s): Dates: N/S Location: Melbourne, Australia Length of followup: 2 weeks to 37 months (mean, 9.6 months) | No. of subjects at start: 40 Dropouts: 4 Loss to followup: 0 No. of subjects at end: 36 Setting: Outpatient clinic/physician office Inclusion criteria: Symptomatic fibroids Exclusion criteria: Smoker Age: Mean, 36.6; range, 19-53 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | Most results were presented in aggregate for both treatment regimens (no significant difference in shrinkage between regimens). | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: − S) Standardized measures: − Note: Sample size issues not discussed.
  1) | Buserelin, 200 mcg IN 6 times per day (n = 21)
  2) | Buserelin, 200 mcg per day by SC pump (n = 19)
  1) | Uterine size
  2) | Symptom relief
  3) | Pregnancy
  4) | Side effects/complications
  5) | Need for subsequent surgery
  1) | Uterine size: IN: 49.4±6.1% of original volume (p < 0.0001) SC: 45.6±5.5% of original volume (p < 0.0001) No difference between regimens Fibroid shrinkage significantly greater for women with larger fibroids
  2) | Symptom relief: "All" patients reported subjective improvement in symptoms
  3) | Pregnancy: Total infertile: 17 Pregnancies within 6 months of treatment in patients with no myomectomy: 3 In patients with myomectomy: 3
  4) | Side effects/complications: Hot flashes: 100% Mood changes: 32.5% Vaginal dryness: 27.5% Vaginal bleeding: 22.5% Joint pain: 22.5% Anorgasmia: 12.5% Transfusions: 5%
  5) | Need for further surgery: 9/40 (22.5%) had myomectomy
Watanabe, Nakamura, Matsuguchi, et al., 1992 | Design: RCT, randomization "by random sampling number" Intervention(s): Dates: N/S Location: Fukuoka, Japan Length of followup: 0-1 year | No. of subjects at start: 41 Dropouts: 2 Loss to followup: 0 No. of subjects at end: 39 Setting: Hospital-based OB/GYN clinic Inclusion criteria: Fibroids presenting as enlarged uterus, hypermenorrhea (83%), dysmenorrhea (22%), and/or infertility; 15% of pts had urinary frequency Exclusion criteria: Cervical or endometrial neoplasia Age: Mean, 42.1 Race: 100% Asian Parity: Prior conception: 65% (1.88-mg group); 76% (3.75-mg group) Baseline uterine size: 553 ± 499 cc (1.88-mg group); 452 ± 224 cc (3.75-mg group) Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: + C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: + J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: + O) Measurement timing: + P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: ? S) Standardized measures: − Note: Sample size issues not discussed.
  1) | LA 1.88 mg SC every month x 6 months
  2) | LA 3.75 mg SC every month x 6 months
  1) | Uterine size
  2) | Symptom relief
  3) | Side effects/complications
  1) | Uterine size (cc): 1.88-mg dose (n = 20): Pretreatment: 553±499 Posttreatment: 295±351 51.5% reduction in volume p < 0.05 compared with pretreatment 3.75-mg dose (n = 21): Pretreatment: 452±224 Posttreatment: 371±314 47.4% reduction in volume p < 0.05 compared with pretreatment Not significant compared with 1.88 mg dose
  2) | Symptom relief: 1.88 mg (n = 20): Partial relief: 4/20 (20%) persistent spotting Amenorrhea: 16/20 3.75 mg (n = 21): Partial relief: 4/21 (19%) persistent spotting Amenorrhea: 16/21 No statistical testing reported
  3) | Side effects/complications:
    | 1.88 mg | 3.75 mg
    Hot flashes | 100% | 76%
    Joint changes | 60% | 57%
    Headache | 50% | 38%
    Insomnia | 20% | 29%
    Injection site | 5% | 14%
    Vertigo | 15% | 0%
    Breast pain | 0% | 10%
West, Lumsden, Hillier, et al., 1992 | Design: Nonrandomized concurrent case series (prospective) Intervention(s): Dates: N/S Location: Edinburgh, UK Length of followup: 2 years | No. of subjects at start: 20 Dropouts: 1 Loss to followup: 0 No. of subjects at end: 19 Setting: Academic hospital-based OB/GYN clinic Inclusion criteria: Premenopausal; symptomatic fibroids, confirmed by ultrasound Exclusion criteria: Ovarian neoplasia Age: Mean, N/S; range, 30-51 Race: N/S Parity: N/S Baseline uterine size: 527 cc (range, 150-1499) Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: − Note: Sample size considerations not discussed.
  1) | Goserelin 3.6 mg per month + medroxy-progesterone acetate (MPA) 15 mg per day for 6 months (COMBINED) (n = 10)
  2) | Goserelin 3.6 mg per month x 3 months, followed by goserelin + MPA 15 mg per day x 3 months (SEQUENTIAL) (n = 10)
  1) | Uterine size
  2) | Patient impression of improvement
  3) | Side effects/complications
  4) | Need for subsequent surgery
  1) | Uterine size: COMBINED: Mean reduction to 82% of pretreatment size (range 36-133%) SEQUENTIAL: Mean reduction to 77% of pretreatment size (range 36-135%)
  2) | Patient impression: COMBINED: 8/9 improved, 1/9 no change SEQUENTIAL: 9/10 improved, 1/10 no change
  3) | Side effects/complications: COMBINED: 70% vasomotor symptoms; 2 with increased libido SEQUENTIAL: 1/10 with decreased libido; 100% vasomotor symptoms, significantly reduced by addition of MPA (p = 0.007)
  4) | Need for subsequent surgery (all hysterectomies): COMBINED: 2/9 first 1 year, 1/7 next 1 year SEQUENTIAL: 0/10 first 1 year, 3/10 next 1 year
Ylikorkala and Pekonen, 1986 | Design: RCT, method of randomization not described Intervention(s): Subjects randomly assigned to 2 months of one drug followed by 2 months of the other Dates: N/S Location: Helsinki, Finland Length of followup: N/A (no posttreatment followup) | No. of subjects at start: 11 pts with fibroids (of total study population of 25) Dropouts: 0 Loss to followup: N/A No. of subjects at end: 11 Setting: N/S Inclusion criteria: Regular menses every 26-30 days; no hormonal therapy in last 6 months; 2 menstrual periods with mean blood loss > 80 cc Exclusion criteria: None specified Age: Mean, 41.7; range, 36-48 Race: N/S Parity: 9/11 pts had had prior pregnancy; 2 no pregnancy Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb: 12.4 ± 0.2 g/dl Baseline Hct: N/S | | Study included women with normal anatomy; results reported here only for patients with fibroids (n = 11). | INTERNAL VALIDITY A) Random: + B) Methods and blinding: − C) Pt selection criteria: + D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: − S) Standardized measures: − Note: Sample size considerations not discussed.
  1) | Naproxen 500 mg twice per day x 5 days during menses
  2) | Placebo twice per day x 5 days during menses
  1) | Mean blood loss, measured by weight of used pads/tampons
  2) | Subject assessment of improvement
  3) | Side effects/complications
  4) | Hemoglobin
  1) | Mean blood loss (ml): Pretreatment: Mean, 239.3 ± 38.4; range, 83-494 Naproxen: Mean, 195.6 ± 32.3; range, 37-435 Placebo: Mean, 220.6 ± 47.2; range, 101-664 Differences not statistically significant
  2) | Subject assessment of improvement: Preferred naproxen: 45% Preferred placebo: 36% No difference: 18%
  3) | Side effects/complications: 3 patients with dyspepsia or headache (all placebo)
  4) | Hemoglobin (g/dl): Pretreatment: 12.4±0.2 Naproxen: 12.7±0.3 Placebo: 12.3±0.2

Evidence Table 3. Preoperative gonadotropin-releasing hormone (GnRH) agonists

Study | Design and interventions | Patient population | Outcomes reported | Results | Notes/Quality score
Audebert, Madenelat, Querleu, et al., 1994 | Design: RCT, method of randomization not described Intervention(s): Dates: N/S Location: Bordeaux, France Length of followup: N/A (on-treatment and in-hospital outcomes only) | No. of subjects at start: 71 Dropouts: 24 Loss to followup: N/A No. of subjects at end: 47 Setting: Hospital Inclusion criteria: Premeno-pausal; age > 25; uterine fibroids confirmed by ultrasound Exclusion criteria: Pregnancy; serious concomitant illness Age: Mean, 41 Race: N/S Parity: N/S Baseline uterine size: 323.8 ± 167.6 ml (GnRH group); 495.1±345.8 ml (no-GnRH group) Baseline fibroid size: 166.3 ± 168.1 ml (GnRH group); 238±190.5 ml (no-GnRH group) Number of fibroids: N/S Baseline Hgb: 12.2 ± 2.1 (GnRH group); 12.5 ± 1.6 (no-GnRH group) Baseline Hct: N/S | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: − C) Pt selection criteria: − D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: + S) Standardized measures: + Note: Results not stratified by surgical procedure performed, only by GnRH or no-GnRH preoperatively.
  1) | GnRH agonist (goserelin) x 3 months, then either: Hysterectomy (n = 15; type not specified) or Abdominal myomectomy (n = 10)
  2) | No GnRH preoperatively (avg. time to surgery 76 days postrandomization), then either: Hysterectomy (n = 23; type not specified) or Abdominal myomectomy (n = 8)
  1) | Uterine volume
  2) | Fibroid volume
  3) | Hemoglobin
  4) | Pain/pressure (composite scale)
  5) | Transfusion rate
  6) | EBL
  | GnRH | No GnRH
  1) | Uterine volume (ml): Pretreat: 323.8±167.6 Preop: 207.5±147.5 % change −40 (p-values not reported) | 495.1 ± 345.8 418 ± 230.8 −15
  2) | Fibroid volume (ml): Pretreat: 166.3±168.1 Preop: 96.8±106.8 % change −42 (p-values not reported) | 238 ± 190.5 252.2 ± 200.8 +6
  3) | Hemoglobin (g/dl): Pretreat:12.2±2.1 Preop:* 12.6±0.3 Postop:**11.5±0.5 (*p = 0.023; **p = 0.052) | 12.5 ± 1.6 11.8 ± 0.2 10.2 ± 0.4
  4) | Pain/pressure score (0-3 scale): Pretreat: 2±1.3 Preop: 0±0.8 (p-values not reported) | 2 ± 1.1 2 ± 1.4
  5) | Transfusion: 0% | 22%
  6) | EBL: (p = not significant [p > 0.05]) | 188 cc
Balasch, Manau, Mimo, et al., 1995 | Design: RCT, method of randomization not described Intervention(s): Dates: N/S Location: Barcelona, Spain Length of followup: N/A (on-treatment and in-hospital outcomes only) | No. of subjects at start: 50 Dropouts: 0 Loss to followup: N/A No. of subjects at end: 50 Setting: University hospital Inclusion criteria: Age 37-52; documented fibroids > 12 weeks in size, with symptoms of menorrhagia or pelvic pain Exclusion criteria: Suspected mALIGNancy, endometriosis, or PID; unstable medical condition Age: Means: GnRH, 43.4±5.1; immediate surgery, 45.4±3.6 Race: N/S Parity: GnRH, 1.9±1.7; immediate surgery, 2.0±1.4 Baseline uterine size: GnRH, 512±267 cc; immediate surgery, 583±349 cc Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb: GnRH, 11.2±1.5 g/dl; immediate surgery, 12.1±1.1 g/dl Baseline Hct: GnRH, 34.8±3.5; immediate surgery, 37.5±3.0 | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: − C) Pt selection criteria: + D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Triptorelin 3.75 mg IM every 4 weeks x 2 injections, followed by abdominal hysterectomy (n = 23);
  2) | Immediate hysterectomy (n = 27)
  1) | Uterine volume
  2) | Type of incision
  3) | Operating time
  4) | Mean decrease in hematocrit
  5) | Need for transfusions
  6) | Complications
  7) | Length of stay
  1) | Uterine volume (cc): GnRH pretreatment: 512±267 GnRH preoperative: 340±180 Immediate surgery baseline: 583±349 Immediate surgery preop: 589±349
  2) | Type of incision (% Pfannenstiel): GnRH: 48% Surgery: 18% (p < 0.05)
  3) | Mean operating time: GnRH: 110 ± 17 minutes Surgery: 107 ± 32 minutes (not significant [p > 0.05])
  4) | Mean hematocrit decrease (%): GnRH: 4.5±2.9 Surgery: 7.8±4.1 (p < 0.01)
  5) | Need for transfusions: GnRH: 0 Surgery: 0
  6) | Complications: GnRH: 17% (3 urinary, 1 abdominal wall infection) Surgery: 40% (2 pelvic hematomas, 1 wound hematoma, 3 abdominal wall, 1 urinary, 1 respiratory, 1 vaginal cuff infections) (p = 0.07)
  7) | Length of stay: GnRH: 7.2±0.6 days Surgery: 9.6 ± 2.6 days (p = 0.08)
Benagiano, Kivinen, Fadini, et al., 1996 | Design: RCT; central randomization scheme Intervention(s): Following treatments given prior to total abdominal hysterectomy: Dates: N/S Location: Multiple sites in Italy, Finland, S. Africa, Denmark, Spain, Norway, Scotland, Portugal, N. Ireland, Ireland Length of followup: N/A (on-treatment and in-hospital outcomes only) | No. of subjects at start: 185 Dropouts: 17 Loss to followup: N/A No. of subjects at end: 168 Setting: Hospital Inclusion criteria: Age > 25 yrs; menorrhagia or metrorrhagia; uterine leiomyomata by manual palpation; Hgb concentration < 12 g/dl; awaiting hysterectomy for leiomyomas Exclusion criteria: Positive cervical cytology in past 1 year; serious renal, hepatic, hemopoietic, or endocrine disorders; history of drug or ethanol abuse; gynecological mALIGNancy; sex hormone therapy in past month; GnRH agonist therapy within past 6 months; blood transfusion within past 12 weeks Age: N/S Race: N/S Parity: N/S Baseline uterine size: 400 ± 304 ml (GA + iron); 383 ± 282 ml (GA alone); 457±523 ml (iron alone) Baseline fibroid size: 153.6 ± 224.2 ml (GA + iron); 113.4 ± 133.0 ml (GA alone); 109.8±126.6 ml (iron alone) Number of fibroids: N/S Baseline Hgb: 10.09 ± 2.04 (GA + iron); 10.05 ± 1.59 (GA alone); 10.91±1.59 (iron alone) Baseline Hct: N/S | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: + C) Pt selection criteria: + D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: + EXTERNAL VALIDITY H) Age: − I) Race: − J) Pregnancy history: − K) Surgical history: + L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: + Notes: Iron treatment improved anemia compared with placebo. The addition of GA resulted in less blood loss, greater improvement in preop anemia, and reduced operative blood loss and postop iron requirements. No variance data for posttreatment measures, including Hgb, uterine size, and fibroid size. No reliability/validity data on symptom score, difficulty-of-surgery score.
  1) | GA 3.6 mg monthly plus iron 600 mg/day for 12 weeks (n = 55 at end of study)
  2) | GA 3.6 mg monthly for 12 weeks (n = 64 at end of study)
  3) | Iron 600 mg/day for 12 weeks (n = 60 at end of study)
  1) | Hemoglobin concentration
  2) | Iron concentration
  3) | Bleeding
  4) | Postoperative iron requirement
  5) | Fibroid volume
  6) | Uterine volume
  7) | Pelvic pain
  8) | Adverse effects
  9) | Difficulty of surgery
  1) | Hemoglobin concentration: Mean hemoglobin concentration increased from entry to preoperative visit by an average of 2.6 g/dl for GA + iron versus GA alone, and 1.6 g/dl for iron alone versus GA alone. These differences were statistically significant (p < 0.0001). The increase in mean hemoglobin concentration was significantly greater for GA + iron than for iron alone (1 g/dl; p < 0.0001).
  2) | Iron concentration: Serum iron concentrations did not differ at preop between the two groups treated with iron.
  3) | Bleeding: More patients on iron only (37; 65%) than on GA only (4; 7%) or GA + iron (7; 13%) reported heavy vaginal bleeding.
  4) | Postoperative iron requirement: This was greatest for GA alone (33%), compared to 16% and 18% for GA + iron and iron only, respectively (p < 0.001).
  5) | Fibroid volume: GA with or without iron treatment resulted in a 44% and 47% reduction in fibroid volume, compared with 7% for iron alone (p < 0.0001).
  6) | Uterine volume: GA with or without iron treatment resulted in a 40% and 37% reduction in uterine size, compared with 7% for iron alone.
  7) | Pelvic pain: Pelvic pain was reduced from entry to preop for both GA-treated groups compared with iron only (p = 0.0073 and p = 0.0012). There was no difference between GA + iron and GA alone.
  8) | Adverse effects: With GA: Hot flashes: 39% Headache: 8-16% With iron: Hot flashes: 13% Abdominal pain: 15% Nausea: 10%
  9) | Difficulty of surgery: "Tendency towards easier surgery for the patients who had received goserelin"; not statistically significant.
Çetin, Vardar, Demir, et al., 1995 | Design: RCT, method of randomization not described Intervention(s): Dates: Oct 1991-Sep 1992 Location: Adana, Turkey Length of followup: N/A (on-treatment and in-hospital outcomes only) | No. of subjects at start: 30 (assuming no dropouts) Dropouts: N/S Loss to followup: N/A No. of subjects at end: 30 Setting: Hospital; outpatient clinic/physician office Inclusion criteria: Symptomatic leiomyomas; negative cervical Pap smear; normal endometrial biopsy; no other cause of infertility Exclusion criteria: None specified Age: N/S Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: 174.3 ± 25.4 cc (buserelin group); 192.2±32.6 cc (myomectomy-only group) Number of fibroids: N/S (reported as outcome measure only) Baseline Hgb: 10.2 ± 0.5 g/dl (n = 10 buserelin pts) Baseline Hct: N/S | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: − C) Pt selection criteria: − D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: − G) Statistical issues: − EXTERNAL VALIDITY H) Age: − I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: + N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: − S) Standardized measures: − Note: Baseline myoma size was smaller in buserelin group; therefore difficult to say what is attributable to the medication concerning the myomectomy procedure.
  1) | Buserelin 900 mcg IN per day x 3 months, followed by myomectomy (n = 15)
  2) | Myomectomy alone (n = 15)
  1) | Uterine size
  2) | Hemoglobin
  3) | EBL
  4) | Number of fibroids removed
  5) | O/R time
  1) | Uterine size (cc): Myomectomy alone: 192.2±32.6 Pre-buserelin: 174.3±25.1 Post-buserelin: 82.4±14.6 (P < 0.05 for post- vs. pre-buserelin; P = not significant for myomectomy alone vs. pre-buserelin)
  2) | Hgb (n = 10 buserelin pts): Pre-buserelin: 10.2±0.5 g/dl Post-buserelin: 13.4±0.6 g/dl (P < 0.05)
  3) | EBL (cc): Myomectomy alone: 292±32 Buserelin: 135 ± 20 (P < 0.05)
  4) | Mean number of fibroids removed: Myomectomy alone: 2.8±2.6 Buserelin: 3.2±2.9
  5) | O/R time (minutes): Myomectomy alone: 102±35 Buserelin: 87 ± 45 (P > 0.05)
Falsetti, Mazzani, Rubessa, et al., 1992 | Design: Case series (prospective), concomitant controls Intervention(s): Dates: N/S Location: Brescia, Italy Length of followup: N/A (on-treatment and in-hospital outcomes only) | No. of subjects at start: 65 Dropouts: 0 Loss to followup: N/A No. of subjects at end: 65 Setting: N/S Inclusion criteria: Symptomatic uterine fibroids; scheduled for myomectomy Exclusion criteria: None specified Age: Means, 32.2 (goserelin group); 35.5 (control) Race: N/S Parity: N/S Baseline uterine size: 550 ± 93 cc (goserelin-treated patients) Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb: 9.8 ± 3.1 g/dl (n = 21 goserelin-treated patients) Baseline Hct: 31.8% (n = 21 goserelin-treated patients) | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: − Note: Control patients did not get baseline measures of uterine volume, hemoglobin, or hematocrit. Comparisons between treated and control groups were provided only for perioperative data.
  1) | Goserelin depot 3.6 mg SC monthly for 4 months prior to myomectomy (n = 30)
  2) | Immediate myomectomy (control) (n = 35)
  1) | Uterine volume
  2) | Hemoglobin
  3) | Hematocrit
  4) | Blood loss
  5) | Fever
  6) | Operative time
  1) | Uterine volume (goserelin-treated patients only): Uterine volume decreased from 550±93 cc to 280 ± 85 cc, a 47.6% decrease over 4 months of treatment.
  2) | Hemoglobin: In 21 anemic patients treated with goserelin, Hgb increased from 9.8 g/dl to 13.5 g/dl (p < 0.01).
  3) | Hematocrit: In 21 anemic patients treated with goserelin, Hct increased from 31.8% to 41% (p < 0.01).
  4) | Blood loss: Total intraoperative blood loss was 205 ± 2.7 ml in goserelin-treated patients, compared with 310 ± 40 ml in control patients (p < 0.001).
  5) | Fever: Postoperative fever occurred in 10% of goserelin-treated patients and 28.6% of control patients.
  6) | Operative time: Operative time was not significantly different between goserelin-treated patients and controls, even controlling for single versus multiple fibroids.
Fedele, Bianchi, Baglioni, et al., 1991 May overlap with patient population described in Fedele, Vercellini, Bianchi, et al., 1990 | Design: RCT, method of randomization not described Intervention(s): Dates: N/S Location: Milan, Italy Length of followup: At least 1 year | No. of subjects at start: 42 Dropouts: 0 Loss to followup: 0 No. of subjects at end: 42 Setting: N/S Inclusion criteria: Symptomatic fibroids, confirmed by ultrasound; candidates for surgery Exclusion criteria: Treatment with sex steroids in previous 6 months Age: Mean, 45.1; range, 25-53 Race: N/S Parity: N/S Baseline uterine size: 465 ± 168 cc (reported for buserelin group only) Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb: 8.7 (reported for 8 buserelin pts only) Baseline Hct: N/S | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: − C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: − Note: Sample size issues not discussed.
  1) | Hysterectomy (n = 15)
  2) | Myomectomy (n = 5)
  3) | Buserelin 400 mcg IN 3 times per day for 6 months, followed by hysterectomy (n = 17) or myomectomy (n = 5)
  1) | Uterine size (buserelin arm only)
  2) | Anemia (buserelin arm only)
  3) | Pregnancy rate (myomectomy candidates only)
  4) | Complications/side effects
  5) | Need for additional treatment
  1) | Uterine size (buserelin only):
    | Mean ± SD (cc)
    Pretreatment | 465±168
    3 months | 308 ± 93
    6 months | 273 ± 88
    3 months after end of treatment | 442±197
  2) | Anemia (8 patients in buserelin arm only): Pretreatment: Mean Hgb 9.7 Posttreatment: Mean Hgb 12.1
  3) | Pregnancy rate (n = 5 buserelin + myomectomy patients, 5 myomectomy-alone patients): Buserelin: 1/5 (20%), c-section at 34 weeks Myomectomy: 3/5 (60%), 2 c-sections, 1 vaginal delivery, all at term
  4) | Complications/side effects: Myomectomy: None reported Hysterectomy: 4/15 transfused Buserelin:
    Hot flashes | 95%
    Headache | 24%
    Vaginal dryness | 18%
    Decreased breast size | 18%
    Decreased libido | 18%
    Insomnia | 13%
    Depression | 13%
  5) | Need for additional treatment: Buserelin ("hysterectomy candidates") 3/15 additional medical treatment (hormonal) 8/15 surgical treatment (hysterectomy)
Fedele, Vercellini, Bianchi, et al., 1990 May overlap with patient population described in Fedele, Bianchi, Baglioni, et al., 1991 | Design: RCT, randomization by "randomization list" Intervention(s): Dates: N/S Location: Milan, Italy Length of followup: 6 months | No. of subjects at start: 24 Dropouts: 0 Loss to followup: 0 No. of subjects at end: 24 Setting: Outpatient clinic/physician office Inclusion criteria: Symptomatic multiple uterine fibroids Exclusion criteria: None specified Age: Mean, 33.6; range, 24-38 Race: N/S Parity: N/S Baseline uterine size: 432.5 ± 165.5 ml (buserelin + myomectomy); 485.8±131.8 ml (myomectomy alone) Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: + C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: − S) Standardized measures: −
  1) | Buserelin 1200 mg IN per day x 3 months, followed by myomectomy (n = 8)
  2) | Myomectomy alone (n = 16)
  1) | Uterine volume (buserelin group only)
  2) | O/R time
  3) | EBL
  4) | Febrile morbidity
  5) | Myoma recurrence at 6 months
  1) | Uterine volume (before/after buserelin; n = 8): Before: 432±165 ml After: 242 ± 83 ml (p < 0.01)
  2) | O/R time (minutes): userelin + myo: 98 (80-127) Myomectomy alone: 92 (83-124)
  3) | EBL: Buserelin + myo: 235±22 ml Myomectomy alone: 275±35 ml
  4) | Febrile morbidity: Buserelin + myo: 25% Myomectomy alone: 22%
  5) | Myoma recurrence at 6 months: Buserelin +myo: 63% Myomectomy alone: 13% (p < 0.05)
Friedman, Daly, Juneau-Norcross, et al., 1992 Followup of study described below in Friedman, Rein, Harrison-Atlas, et al., 1989 | Design: RCT, method of randomization not described Intervention(s): Dates: N/S Location: Boston, MA Length of followup: Mean, 32.3 months (31.9 for LA group; 32.7 for myomectomy-only group); range, 27-38 | No. of subjects at start: 20 Dropouts: 2 Loss to followup: 0 No. of subjects at end: 18 Setting: Outpatient clinic/physician office Inclusion criteria: From original trial report: Age < 42 years; premenopausal (FSH < 30 mIU/ml; not pregnant or lactating; subject or sexual partner sterilized or agree to barrier contraception; one fibroid > 3 cm in diameter or uterine volume > 150 cc with multiple fibroids on ultrasound; no uterine calcification on ultrasound; moderate to severe symptoms due to fibroids (menorrhagia, pelvic pressure, pelvic pain, recurrent pregnancy loss); no suspicion of mALIGNancy; no hyperplasia on endometrial biopsy Exclusion criteria: None specified Age: Mean, 35.5; range, 31-41 Race: N/S Parity: N/S Baseline uterine size: Mean, 678 cc (range, 439-975) (LA group); 654 cc (104-1506) (myomectomy-only group) Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: − C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: + G) Statistical issues: + EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: + N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: − S) Standardized measures: − Note: This is a long-term followup of a group of women who participated in a previous trial (below). No statistical tests were reported for the results of one group vs. the other, but there does not appear to be a difference. The outcomes that had statistical analysis done were case series data. Small series -- may not have had sufficient power to detect a difference in recurrence rates.
  1) | LA 3.75 mg IM every 4 weeks x 12 weeks, followed by myomectomy (n = 9)
  2) | Placebo every 4 weeks x 12 weeks, followed by myomectomy (n = 9)
  1) | Uterine volume
  2) | Number of fibroids (median)
  3) | Fibroid recurrence
  4) | Fibroid number vs. recurrence
  5) | Pretreatment volume vs. followup volume
  6) | Number of myomas resected vs. followup volume
  7) | Symptoms
  1) | Uterine volume: Pre-LA or any treatment: 678 cc Pre-placebo or any treatment: 654 cc 31.9 months posttreatment: 198 cc 32.7 months posttreatment: 263 cc
  2) | Number of fibroids (median): Number of fibroids removed: LA + myomectomy: 4 Placebo + myomectomy: 3 Number of fibroids at followup: LA + myomectomy: 2 Placebo + myomectomy: 1
  3) | Fibroid recurrence: Percentage of patients without fibroids at followup: LA + myomectomy: 34% Placebo + myomectomy: 44% (Not statistically different)
  4) | Fibroid number vs. recurrence: > 3 resected: 90% < 3 resected: 25% (p = 0.015)
  5) | Pretreatment volume vs. followup volume: R = 0.545 (p = 0.023)
  6) | Number of myomas resected vs. followup volume: R = 0.485 (p = 0.048)
  7) | Symptoms overall (includes menorrhagia/hypermenorrhea, pelvic mass, pressure, pain, recurrent pregnancy loss): LA + myomectomy: Resolved: 44% Improved: 33% Unchanged/worse: 22% Placebo + myomectomy: Resolved: 44% Improved: 33% Unchanged/worse: 22% (No statistics reported)
Friedman, Rein, Harrison-Atlas, et al., 1989 Followup described above in Friedman, Daly, Juneau-Norcross, et al., 1992 | Design: RCT, method of randomization not described Intervention(s): Dates: N/S Location: Boston, MA Length of followup: N/A (on-treatment and in-hospital outcomes only) | No. of subjects at start: 20 Dropouts: 2 Loss to followup: N/A No. of subjects at end: 18 Setting: Outpatient clinic/physician office Inclusion criteria: Age < 42 yrs; premenopausal (FSH < 30 mIU/ml; not pregnant or lactating; subject or sexual partner sterilized or agree to barrier contraception; one fibroid > 3 cm in diameter or uterine volume > 150 cc with multiple fibroids on ultrasound; no uterine calcification on ultrasound; moderate to severe symptoms due to fibroids (menorrhagia, pelvic pressure, pelvic pain, recurrent pregnancy loss); no suspicion of mALIGNancy; no hyperplasia on endometrial biopsy Exclusion criteria: None specified Age: Mean, 35.1 Race: N/S Parity: N/S Baseline uterine size: 646 ± 59 cc (leuprolide group); 542 ± 88 cc (placebo group) Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb: 12.7 ± 0.3 gm/dl (leuprolide group); 12.9±0.3 gm/dl (placebo group) Baseline Hct: 37.5 ± 0.7% (leuprolide group); 37.8 ± 0.9% (placebo group) | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: − C) Pt selection criteria: + D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: − Note: All patients donated autologous blood prior to procedure, therefore Hgb/Hct not very useful.
  1) | Leuprolide acetate 3.75 mg IM every 4 weeks x 12 weeks, followed by myomectomy (n = 9)
  2) | Placebo every 4 weeks x 12 weeks, followed by myomectomy (n = 9)
  1) | Uterine volume
  2) | Hemoglobin
  3) | Hematocrit
  4) | O/R time
  5) | EBL
  6) | Transfusion
  7) | Postop fever
  8) | Hospitalization length
  1) | Uterine volume (cc): Leuprolide pre: Overall 646 ± 59 < 600 cc 501 ± 49 > 600 cc 762 ± 60 Leuprolide post: Overall 429 ± 37 cc < 600 cc 388 ± 17 > 600 cc 462 ± 65 Placebo pre (overall): 542 ± 88 Placebo post (overall): 564±122
  2) | Hgb (g/dl): Leuprolide pre (overall): 12.7±0.3 Leuprolide post (overall): 12.2±0.4 Placebo pre (overall): 12.9±0.3 Placebo post (overall): 11.5±0.3
  3) | Hct (%): Leuprolide pre (overall): 37.5±0.7 Leuprolide post (overall): 36.2±1.0 Placebo pre (overall): 37.8±0.9 Placebo post (overall): 34.3±0.8
  4) | O/R time (minutes): Leuprolide: Overall: 99±7 < 600 cc: 88±10 > 600 cc: 110 ± 8 Placebo (overall): 87 ± 5
  5) | EBL (ml): Leuprolide: Overall: 213 ± 44 < 600 cc: 242 ± 89 > 600 cc: 189 ± 44 Placebo: Overall: 302 ± 43 < 600 cc: 193 ± 58 > 600 cc: 390 ± 20
  6) | Transfusion: Leuprolide: 22% Placebo: 22%
  7) | Postop fever: Leuprolide: 44% Placebo: 66%
  8) | Hospitalization length (days): Leuprolide: 4.1± 0.4 Placebo: 4.6±0.5
Gerris, Degueldre, Peters, et al., 1996 | Design: RCT, method of randomization not described Intervention(s): Dates: N/S Location: Multiple sites in Antwerp, Belgium; the Netherlands; Lisbon, Portugal; Malnnö, Sweden; King's Lynn, UK Length of followup: N/A (on-treatment and in-hospital outcomes only) | No. of subjects at start: 247 Dropouts: 32 Loss to followup: N/A No. of subjects at end: 215 (but analyses carried out on intention-to-treat basis) Setting: N/S Inclusion criteria: Premeno-pausal; age > 25 years; uterine fibroids on ultrasound; awaiting hysterectomy; one of the following: symptomatic, Hgb < 12 g/dl; pelvic mass > 12 weeks Exclusion criteria: Pregnancy; breastfeeding; concomitant illness; sex hormone therapy within last 2 months Age: Mean, 43.9 Race: N/S Parity: N/S Baseline uterine size: 498.7 ± 459.4 cc (goserelin); 447.0±355.9 cc (hysterectomy alone) Baseline fibroid size: 162.8 ± 207.2 cc (goserelin); 146.5±166.0 (hysterectomy alone) Number of fibroids: N/S Baseline Hgb: 12.2 ± 1.6 g/dl (goserelin); 12.5 ± 1.6 g/dl (hysterectomy alone) Baseline Hct: N/S | Prehysterectomy outcomes: | Prehysterectomy outcomes: | INTERNAL VALIDITY A) Random: + B) Methods and blinding: − C) Pt selection criteria: + D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: + EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: − Note: Symptom scores for pretreatment included only 22 goserelin patients vs. 121 hysterectomy-alone patients. Validity/reliability of symptom scale not reported.
  1) | Goserelin acetate (Zoladex^®^) 3.6 mg SC per month for 3 months, followed by hysterectomy (n = 123)
  2) | Hysterectomy alone (n = 124)
  1) | Uterine volume
  2) | Fibroid volume
  3) | Total symptom score
  4) | Dysmenorrhea
  5) | Menorrhagia
  6) | Hemoglobin (Hgb)
  7) | Hematocrit (Hct) Surgical outcomes:
  8) | EBL
  9) | Difficulty of operation
  10) | Duration of surgery
  11) | Length of stay
  1) | Uterine volume (cc): Goserelin pre: 498.7±459.4 Goserelin post: 295.1±257.1 (p = 0.0001) Hyst alone pre: 447.0±355.9 Hyst alone post: 457.7±333.2 (p = not significant)
  2) | Fibroid volume (cc): Goserelin pre: 162.8±207.2 Goserelin post: 93.2±160.9 (p = 0.0001) Hyst alone pre: 146.5±166.0 Hyst alone post: 156.3±189.7 (p = not significant)
  3) | Total symptom score (median): Goserelin pre: 2 (0-6) Goserelin post: 0 (0-4) (p = 0.0001) Hyst alone pre: 2 (0-6) Hyst alone post: 2 (0-6) (p = not significant)
  4) | Dysmenorrhea (%):
    | Mild | Mod | Severe
    Goserelin pre: | 11 | 30 | 16
    Goserelin post: | 2 | 2 | 2
    Hyst alone pre: | 21 | 25 | 17
    Hyst alone post: | 22 | 22 | 11
  5) | Menorrhagia (%):
    | Mild | Mod | Severe
    Goserelin pre: | 15 | 29 | 40
    Goserelin post: | 4 | 4 | 4
    (p < 0.0001)
    Hyst alone pre: | 11 | 25 | 40
    Hyst alone post: | 12 | 26 | 32
    (p = not significant)
  6) | Hgb (change): Goserelin: 1.07 g/dl Hysterectomy: 0.33 g/dl (p = 0.01)
  7) | Hct (change): Goserelin: 0.03% Hysterectomy: 0.01% (p = not significant) Surgical outcomes:
  8) | EBL (mean): Goserelin + hysterectomy: 224.2 Hysterectomy alone: 317 (p = 0.01)
  9) | Difficulty of operation (%):
    | None | Mild | Mod | Sev | NA
    Goserelin + hyst: | 50 | 22 | 21 | 7 | 0
    Hyst alone: | 39 | 25 | 29 | 4 | 3
    (p = not significant)
  10) | Duration of surgery (minutes): Goserelin + hysterectomy: 70.2 Hysterectomy alone: 73.9 (p = not significant)
  11) | Length of stay (days): Goserelin + hysterectomy: 6.84 Hysterectomy alone: 7.32 (p = 0.01)
Golan, Bukovsky, Pansky, et al., 1993 | Design: RCT, method of randomization not described Intervention(s): Dates: N/S Location: Zerifin, Israel Length of followup: N/A (on-treatment and in-hospital outcomes only) | No. of subjects at start: 53 Dropouts: 0 Loss to followup: N/A No. of subjects at end: 53 Setting: Hospital Inclusion criteria: Symptoms related to fibroids; uterine size > 12 weeks Exclusion criteria: None specified Age: Mean, 37 Race: N/S Parity: N/S Baseline uterine size: 560 cc (410-680) (D-Trp-6-LHRH group); 528 cc (425-770) (control group) Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb: 11.1 ± 1.8 (D-Trp-6-LHRH + TAH); 11.5±1.6 (D-Trp-6-LHRH + myomectomy); 10.9 ± 1.4 (control + TAH); 11.0 ± 1.6 (control + myomectomy) Baseline Hct: N/S | Outcomes related to treatment with D-Trp-6-LHRH: | All p-values reported below are for between-treatment (D-Trp-6-LHRH vs. no treatment) and within surgery-type comparisons Outcomes related to treatment with D-Trp-6-LHRH: | INTERNAL VALIDITY A) Random: + B) Methods and blinding: − C) Pt selection criteria: + D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: − S) Standardized measures: −
  1) | D-Trp-6-LHRH 3.2 mg IM every month for 2 months, followed by myomectomy or TAH (n = 29)
  2) | No treatment (control) for 2 months, followed by myomectomy or TAH (n = 24)
  1) | Uterine volume
  2) | Hgb Outcomes related to surgery:
  3) | O/R time
  4) | EBL
  5) | Transfusion
  6) | Length of stay
  7) | Postop fever
  8) | Wound infection
  1) | Uterine volume (cc): D-Trp-6-LHRH: Pre: 560 (410-680) Post: 380 (300-400) Control: Pre: 528 (425-770) Post: 496 (370-600)
  2) | Hgb (g/dl): D-Trp-6-LHRH: TAH group: Pre: 11.1±1.8 Post: 12.3±2.1 Myomectomy group: Pre: 11.5±1.6 Post: 12.0±1.9 Control: TAH group: Pre: 10.9±1.4 Post: 10.8±1.0 Myomectomy Group: Pre: 11.0±1.6 Post: 10.9±1.3 (p = not significant) Outcomes related to surgery:
  3) | O/R time (minutes): D-Trp-6-LHRH: TAH group: 49±9 Myomectomy group: 80 ± 42 Control: TAH group: 70±34 Myomectomy group: 96 ± 46 (p < 0.05)
  4) | EBL (ml): D-Trp-6-LHRH: TAH group: 208±64 Myomectomy group: 320 ± 88 Control: TAH group: 309±81 Myomectomy group: 476 ± 86 (p < 0.05)
  5) | Transfusion (%): D-Trp-6-LHRH: TAH group: 6% Myomectomy group: 50% Control: TAH group: 20% Myomectomy group: 56% (p < 0.05)
  6) | Length of stay (days): D-Trp-6-LHRH: TAH group: 6.3 Myomectomy group: 7.9 Control: TAH group: 6.0 Myomectomy group: 7.3 (p = not significant)
  7) | Postop fever: D-Trp-6-LHRH: TAH group: 0 Myomectomy group: 33% Control: TAH group: 20% Myomectomy Group: 44% (p = not significant)
  8) | Wound infection: D-Trp-6-LHRH: TAH group: 6% Myomectomy group: 8% Control: TAH group: 0 Myomectomy group: 0 (p = not significant)
Hutchins, 1992 | Design: Cohort study Intervention(s): Dates: Apr 1988-Dec 1989 Location: Philadelphia, PA Length of followup: N/A (in-hospital outcomes only) | No. of subjects at start: 67 (assuming no dropouts) Dropouts: N/S Loss to followup: N/A No. of subjects at end: 67 Setting: Hospital; outpatient clinic/physician office Inclusion criteria: > 16-week size uterus; scheduled for myomectomy for uterine fibroids Exclusion criteria: None specified Age: Mean, 36.7 Race: N/S Parity: N/S Baseline uterine size: 19.7 weeks (LA + myomectomy); 15.8 weeks (myomectomy alone) (p = 0.003) Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb: 12.5 g/dl (LA + myomectomy); 12.74 g/dl (myomectomy alone) Baseline Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: − G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: − Note: Patients were allowed to choose LA or not. Baseline uterine size in LA group was significantly larger and size unclear at time of procedure itself. Also, almost twice as many fibroids were removed in LA + myomectomy group than in myomectomy-alone group. In general, the control group was inappropriate, and no meaningful comparisons can be made.
  1) | LA for 6-10 weeks, followed by myomectomy (n = 48)
  2) | Myomectomy alone (n = 19)
  1) | EBL
  2) | Transfusion
  3) | Length of stay
  4) | Postoperative infection
  5) | Hgb
  1) | EBL: LA + myomectomy: 300.4 cc Myomectomy alone: 257.4 cc
  2) | Transfusion: LA + myomectomy: 4% Myomectomy alone: 0%
  3) | Length of stay: LA + myomectomy: 4.9 days Myomectomy alone: 4.7 days
  4) | Postoperative infection: LA + myomectomy: 14% Myomectomy alone: 5%
  5) | Hgb (mean): LA + myomectomy: Pre: 12.54 g/dl Post: 9.51 g/dl Myomectomy alone: Pre: 12.74 g/dl Post: 10.48 g/dl P < 0.05 between LA + myomectomy and myomectomy alone for posttreatment values
Kiltz, Rutgers, Phillips, et al., 1994 | Design: Nonrandomized concurrent cohort comparison Intervention(s): Dates: N/S Location: Los Angeles, CA Length of followup: N/A (on-treatment and in-hospital outcomes only) | No. of subjects at start: 28 Dropouts: N/A Loss to followup: N/A No. of subjects at end: 28 Setting: University medical center Inclusion criteria: Uterine leiomyomata requiring myomectomy Exclusion criteria: None specified Age: Means, 30 (7.5-mg group), 28 (3.75-mg group), 31 (controls) Race: N/S Parity: 0.1±0.1 (7.5-mg group); 0.2±0.1 (3.75-mg group); 0.2±0.2 (controls) Baseline uterine size: 7.5-mg group: 16±0.8 weeks, 840±105 ml. 3.75-mg group: 15±1.1 weeks, 963±264 ml. Controls: 17±1.5 weeks; 1342±258 ml. Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb: N/S Baseline Hct: 38.3%±0.7% (7.5-mg group); 36.5%±1.4% (3.75-mg group); 35%±1.8% (controls) | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Leuprolide acetate 7.5 mg IM every 30 days for 3 months (n = 9)
  2) | Leuprolide acetate 3.75 mg IM every 30 days for 3 months (n = 10)
  3) | Control (no treatment) (n = 9)
  1) | Uterine size
  2) | Hematocrit
  3) | Blood loss at myomectomy
  4) | Transfusions
  1) | Uterine volume: Decreased in both leuprolide-treated groups by 34.5% ± 8.5% and 34.6%±0.6% for the 3.75- and 7.5-mg dose groups, respectively. There was no significant difference between these groups.
  2) | Hematocrit (% decrease): Leuprolide acetate 7.5 mg: 11.5% Leuprolide acetate 3.75 mg: 13% No treatment: 9.5%
  3) | Blood loss at myomectomy: There were no significant differences in average estimated blood loss among the three groups.
  4) | Transfusions: 3 control patients, 2 of those treated with 3.5 mg leuprolide, and 1 treated with 7.5 mg leuprolide required blood transfusions.
Lumsden, West, Thomas, et al., 1994 | Design: RCT, method of randomization not described Intervention(s): Dates: N/S Location: Glasgow, UK Length of followup: N/A (on-treatment and in-hospital outcomes only) | No. of subjects at start: 71 Dropouts: 6 Loss to followup: N/A No. of subjects at end: 65 Setting: Hospital Inclusion criteria: Symptomatic uterine fibroids; scheduled for hysterectomy; no contraindication to treatment with GnRH agonist Exclusion criteria: Pregnancy Age: Mean, 43.5 Race: N/S Parity: N/S Baseline uterine size: 295 cc (goserelin group); 444 cc (placebo group) Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb: 12.8 ± 1.6 g/dl (goserelin group); 12.8±1.5 g/dl (placebo group) Baseline Hct: N/S | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: − C) Pt selection criteria: + D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Prehysterectomy goserelin 3.6 mg per month x 3 months (n = 35)
  2) | No prehysterectomy goserelin (placebo injections) (n = 36)
  1) | Uterine volume
  2) | Preoperative Hgb
  3) | Postoperative Hgb
  4) | Estimated blood loss
  5) | Pelvic pain
  6) | Pelvic pressure
  7) | Difficulty of operation
  8) | Duration of operation
  9) | Length of stay
  10) | Type of incision
  11) | Complications
  Prehysterectomy goserelin
  1) | Uterine volume: Pretreatment: 295 cc (115-1310) Posttreatment: 229 cc (77-1392) Percent decrease: 24.4%
  2) | Preoperative Hgb: Pretreatment: 12.8±1.6 Posttreatment: 13.6±1.2
  3) | Postoperative Hgb: 11.8±1.4
  4) | Estimated blood loss: 187 cc (60-600)
  5) | Pelvic pain (scale 0-3): Pretreatment: 2 (0-3) Posttreatment: 0 (0-3)
  6) | Pelvic pressure (scale 0-3): Pretreatment: 1 (0-3) Posttreatment: 0 (0-3)
  7) | Difficulty of operation: None 26% Mild 34% Moderate 40% Severe 0%
  8) | Duration of operation: 61 ± 16 minutes
  9) | Length of stay: 8.6±1.8 days
  10) | Type of incision: Vertical: 31% Transverse: 69%
  11) | Complications: Fever, 26%; wound infection, 17%; UTI, 26%
  No prehysterectomy goserelin (placebo)
  1) | Uterine volume: Pretreatment: 444 cc (97-1235) Posttreatment: 530 cc (127-1626) 3% increase
  2) | Preoperative Hgb: Pretreatment: 12.8±1.5 Posttreatment: 12.7±1.5
  3) | Postoperative Hgb: 11.4±1.7
  4) | Estimated blood loss: 307.5 cc (118-1000)
  5) | Pelvic pain (scale 0-3): Pretreatment: 2 (0-3) Posttreatment: 2 (0-3)
  6) | Pelvic pressure (scale 0-3): Pretreatment: 1 (0-3) Posttreatment: 1 (0-3)
  7) | Difficulty of operation: None 15% Mild 29% Moderate 38% Severe 18%
  8) | Duration of operation: 68±208 minutes
  9) | Length of stay: 8.7±1.8 days
  10) | Type of incision: Vertical: 56% Transverse: 44%
  11) | Complications: Fever, 32%; wound infection, 18%; UTI, 15%
Narayan, Rajat, and Goswamy, 1994 | Design: Case series (prospective), concomitant controls Intervention(s): Dates: N/S Location: London, UK Length of followup: N/S | No. of subjects at start: 100 (27 with submucous fibroids, 73 controls with normal uterine cavity) (assuming no dropouts) Dropouts: N/S Loss to followup: N/S No. of subjects at end: 100 Setting: Private fertility and in vitro fertilization center Inclusion criteria: Infertility after failed in vitro fertilization attempt Exclusion criteria: None specified Age: Mean, 35.1 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: − E) Loss to followup: − F) Dropout rates: − G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: − S) Standardized measures: − Note: Technique of patient selection for various advanced reproductive technologies not described.
  1) | Goserelin 3.6 mg SC every month x 3 months (n = 11)
  2) | Hysteroscopic myomectomy (n = 3)
  3) | Goserelin + hysteroscopic myomectomy (n = 13)
  1) | Pregnancy rate with advanced reproductive techniques (in vitro fertilization, intrauterine insemination, and/or embryo transfer)
  1) | Pregnancy rates: Goserelin only: 55% Hysteroscopic myomectomy: 67% Goserelin + hysteroscopic myomectomy: 46% Control: 26%
Parazzini, Bortolotti, Chiantera, et al., 1999 | Design: RCT, method of randomization not described Interventions: Dates: Jun 1993-Nov 1994 Location: Milan, Naples, and Sondalo, Italy Length of followup: No followup of TAH patients; 3-year followup of patients in goserelin group | No. of subjects at start: 72 Dropouts: 0 Loss to followup: 13 (TAH patients not followed up) No. of subjects at end: 59 Setting: N/S Inclusion criteria: Premeno-pausal; age > 45; one or more uterine fibroids > 10 cm in diameter; symptomatic menorrhagia > 3 months; Hgb > 9 g/dl; candidate for hysterectomy Exclusion criteria: Previous treatment with GnRH agonist; bone mineral density less than 10^th^ percentile for age group; concomitant illness of the genital system requiring surgery Age: Mean (with range): 51 (48-56) (TAH group); 50 (45-56) (goserelin group) Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size (diameter): 8 ± 8 cm (TAH group); 6 ± 3 cm (goserelin group) Number of fibroids: Mean (with range): 2 (1-3) (TAH group); 3 (1-9) (goserelin group) Baseline Hgb: 11 ± 2 g/dl (TAH group); 11 ± 1 g/dl (goserelin group) Baseline Hct: N/S | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: − C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: + G) Statistical issues: + EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: + N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | TAH with bilateral oophorectomy (n = 13)
  2) | Goserelin 3.6 mg every 28 days x 4 months, followed by up to two additional 3-month courses as needed for bleeding (n = 59)
  1) | Cumulative hysterectomy rate in goserelin group
  1) | Cumulative hysterectomy rate in goserelin group (n = 59):* * Indications for hysterectomy included persistent abnormal uterine bleeding, bone mineral density < 10%, or patient desire (distribution not reported).
    Year | Cumulative rate
    1 | 21%
    2 | 32%
    3 | 39% 95% CI, 26-62)
Perino, Chianchiano, Petronio, et al., 1993 | Design: Case series (prospective), concomitant controls Intervention(s): Dates: Jan 1988-Dec 1990 Location: Palermo, Italy Length of followup: 1 year | No. of subjects at start: 58 with fibroids (of larger series of 208) Dropouts: 0 Loss to followup: 0 No. of subjects at end: 58 Setting: Hospital Inclusion criteria: Submucous fibroids < 3 cm; infertility or menstrual disorder Exclusion criteria: Uterus > 12 weeks in size Age: Mean, 35.6; range, 32-40 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: + E) Loss to followup: + F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: + O) Measurement timing: + P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: − S) Standardized measures: −
  1) | Hysteroscopic myomectomy with GnRH preoperatively (n = 33)
  2) | Hysteroscopic myomectomy without GnRH preoperatively (n = 25)
  1) | Operative time
  2) | Intraoperative bleeding
  3) | Operative failure (defined as fibroid not completely removed or continued menstrual abnormality at 1 year postop)
  1) | Operative time (minutes): With preop GnRH: 24.9±6.7 No preop GnRH: 38.4±8.8 (p < 0.001)
  2) | Intraoperative bleeding: With preop GnRH: Severe 0 Moderate 2 Light 31 No preop GnRH: Severe 0 Moderate 8 Light 17 (P < 0.01)
  3) | Operative failure: With preop GnRH: 3% No preop GnRH: 20% (P < 0.05)
Stovall, Muneyyirci-Delale, Summitt, et al., 1995 | Design: RCT, method of randomization not described Intervention(s): Presurgical treatment as follows: All patients received oral iron and calcium. Dates: Jan 1992-Oct 1993 Location: N/S Length of followup: 6 months after surgery | No. of subjects at start: 309 Dropouts: 44 (excluded post-randomization) Loss to followup: 0 No. of subjects at end: 265 Setting: Hospital Inclusion criteria: Hgb < 10.2 g/dl and/or Hct < 30%; fibroids; bleeding x 3 months; not pregnant or lactating; no mALIGNancy; pelvic exam and ultrasound or MRI Exclusion criteria: None specified Age: Mean, 39; range 23-52 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb: 8.2 (both lupron groups); 8.0 (placebo group) Baseline Hct: 28 (7.5-mg group); 28.1 (3.75-mg group); 27.6 (placebo group) | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: − C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: + G) Statistical issues: + EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: + Q) Measurement reliability: + R) Clinical care: + S) Standardized measures: + Patients were stratified by Hct < 28% vs. > 28%, but were not analyzed this way. P-values given, but means not often reported.
  1) | Lupron 7.5 mg every 28 days x 3 months (n = 99)
  2) | Lupron 3.75 mg every 28 days x 3 months (n = 89)
  3) | Placebo every 28 days x 3 months (n = 77)
  1) | Response to therapy (defined as posttreatment Hgb > 12 or Hct > 36%)
  2) | Uterine size
  3) | Fibroid volume
  4) | Hgb/Hct
  5) | Decrease in bleeding
  6) | Pelvic pain
  7) | Adverse events
  8) | Type of surgery
  1) | Response to therapy: 74% of both lupron groups responded to therapy versus 46% in placebo group (no actual numbers given).
  2) | Uterine size (n = 179): Statistically significant decreases in uterine size from baseline to surgery in lupron 7.5-mg (31%) and 3.75-mg (39%) groups. No change in placebo (actual numbers not given)
  3) | Fibroid volume: In lupron 7.5 group, decreased 23%; in lupron 3.75 group, decreased 27%; and in placebo, increased 8%
  4) | Hgb/Hct: Pretreatment Hgb/Hct: Lupron 7.5 mg: 8.2/28 Lupron 3.75 mg: 8.2/28.1 Placebo: 8.0/27.6 Posttreatment Hgb/Hct: Lupron 7.5 mg: 12.7/39.1 Lupron 3.75 mg: 12.6/39.1 Placebo: 11.5/35.7
  5) | Decrease in bleeding: Bleeding decreased 98 to 15% in lupron groups (p < 0.001), compared to placebo decrease of 96 to 64%
  6) | Pelvic pain: Decreased 70 to 38% in lupron groups. No change in placebo group
  7) | Adverse events: Lupron 7.5 mg, 8/99 transfused; lupron 3.75 mg, 2/89 (2%); and placebo, 10/77 (13%)
  8) | Type of surgery: Hysterectomy, 62.8%; myomectomy, 36.7%; one endometrial ablation
Stovall, Summit, Washburn, et al., 1994 Preliminary results for first 50 patients reported in Stovall, Ling, Henry, et al., 1991 | Design: RCT, randomization by computer-generated random number table Intervention(s): Randomized groups were: Group 1A: Uterus 14-18 weeks with immediate TAH (n = 45) Group 1B: Uterus 14-18 weeks with preop GnRH (n = 45) Group 2A: Uterus > 18 weeks with immediate TAH (n = 30) Group 2B: Uterus > 18 weeks with preop GnRH (n = 30) Ferrous sulfate 325 mg 3 times per day from randomization to surgery if Hgb < 11.0 mg/dl Dates: N/S Location: Winston-Salem, NC and Memphis, TN Length of followup: N/S (through postop convalescence period) | No. of subjects at start: 150 Dropouts: 0 Loss to followup: 0 No. of subjects at end: 150 Setting: Hospital Inclusion criteria: FSH < 30 mIU/ml; negative urine pregnancy test; absence of calcification on ultrasound; uterus > 14 weeks by exam; symptoms of bleeding, pain, pressure; benign endometrial histology; normal exam; no ovarian pathology on exam or ultrasound Exclusion criteria: None specified Age: Group 1A: Mean, 41.4 (range, 30-51); group 1B: 40.9 (29-51); group 2A: 40.7 (30-50); group 2B: 41.2 (31-49) Race: N/S Parity: Group 1A: Mean, 2.7 ± 2.0; group 1B: 2.5 ± 2.0; group 2A: 2.4 ± 1.8; group 2B: 2.5 ± 1.6 Baseline uterine size: Group 1A: 15.9±1.4 weeks, 920.2±360 ml; group 1B: 15.8±1.3 weeks, 975.4±400 ml; group 2A: 22.3±2.1 weeks, 2479±362; group 2B: 23.1±2.2 weeks, 2398±486 ml Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb (g/dl): Group 1A, 11.1±2.8; group 1B, 10.5±2.5; group 2A, 11.2±3.1; group 2B, 11.4±3.5 Baseline Hct (%): Group 1A, 33.7 ± 4.9; group 1B, 33.9±5.8; group 2A, 33.7±3.8; group 2B, 34.1±4.0= | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: + C) Pt selection criteria: + D) Length of followup: − E) Loss to followup: + F) Dropout rates: + G) Statistical issues: + EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: +
  1) | Pretreatment GnRH (lupron 0.5 mg SC x 8 weeks or leuprolide 3.75 mg every month x 2 months)
  2) | Immediate surgery
  1) | Uterine size
  2) | Length of stay
  3) | Transfusions
  4) | EBL
  5) | Fever
  6) | Incision type
  7) | Convalescence period
  1) | Uterine size: Pretreatment (mean weeks): 1A: 15.9 ± 1.4 1B: 15.8 ± 1.3 P = not significant) 2A: 22.3 ± 2.1 2B: 23.1 ± 2.2 (P = not significant) Pretreatment (mean ml): 1A: 920.2 ± 360 1B: 975.4 ± 400 (P = not significant) 2A: 2479 ± 362 2B: 2398 ± 486 (P = not significant) Posttreatment (mean weeks): 1A: 15.9 ± 1.4 1B: 11.7 ± 1.7 (P = 0.0001) 2A: 22.3 ± 2.1 2B: 19.6 ± 1.9 (P = 0.001) Posttreatment (mean ml): 1A: 920.2 ± 360 1B: 570 ± 280 (P = 0.0001) 2A: 2879 ± 362 2B: 1175 ± 391 (P = 0.001) Operative weight (in grams): 1A: 710 ± 210 1B: 405 ± 165 (P = 0.01) 2A: 1976 2B: 1250 (P = 0.01)
  2) | Length of stay (days): 1A: 4.7 1B: 2.1 (P = 0.001) 2A: 5.7 2B: 5.6 (P = not significant)
  3) | Transfusions: Preop: 1A: 2/45 patients (4%) 1B: 0/45 (P = not significant) 2A: 3/30 (10%) 2B: None (P = not significant) Intra- or postop: 1A: 1 pt 1B: None (P = not significant) 2A: 1 pt 2B: None (P = not significant)
  4) | EBL (ml): 1A: 576 ± 110 1B: 428 ± 92 (p = 0.001) 2A: 612 ± 130 2B: 590 ± 115 (P = not significant)
  5) | Fever: 1A: 7 pts 1B: 5 pts (P = not significant) 2A: 4 pts 2B: 5 pts (P = not significant)
  6) | Incision type: Vaginal hysterectomy (no. of pts): 1A: 6/45 (13.3%) 1B: 36/45 (80%) 2A: 0% 2B: 2/30 (6.6%)
  7) | Recovery (days): 1A: 28.2 ± 3.9 1B: 19.2 ± 5.8 (P < 0.001) 2A: 36.2 ± 6.5 2B: 37.6±7.1 (P = not significant)
Sudik, Husch, Steller, et al., 1996 | Design: Case series (retrospective), no controls Intervention(s): Myomectomy with (n = 33) or without (n = 34) pretreatment with GnRH (Zoladex^®^ or leuproreline, "usually" for 3 months) Type of myomectomy: 60/67 (89.5%) had abdominal procedures, 7/67 (10.5%) had laparoscopic or hysteroscopic Dates: 1985-1993 Location: Marburg, Germany Length of followup: At least 6 months (through June 1994) | No. of subjects at start: 67 Dropouts: N/A Loss to followup: 0 No. of subjects at end: 67 Setting: Hospital Inclusion criteria: Had myomectomy and desired pregnancy (unexplained infertility) Exclusion criteria: None specified Age: Mean, 34 Race: N/S Parity: N/S Baseline uterine size: N/S Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: + E) Loss to followup: + F) Dropout rates: N/A G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: − M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: − S) Standardized measures: −
  1) | Total pregnancy rate
  2) | Pregnancy rate related to GnRH
  3) | Myoma recurrence
  4) | Number/size of fibroids removed related to pregnancy rate
  5) | Pregnancy outcomes
  1) | Total pregnancy rate: 39/67 = 58.2%. 24/39 (61.5%) conceived in first year, and 33/39 (85%) conceived within 3 years
  2) | Pregnancy rate related to GnRH: No significant difference in pregnancy rates between those treated/not treated with GnRH
  3) | Myoma recurrence by ultrasound examination: 31/67 (46.3%). No statistical difference in pregnancy rates between those with/without (36/67) recurrences; 18/31 (58.1%) with recurrent myomas conceived, 21/36 (58.3%) without recurrent fibroids conceived
  4) | Number/size of fibroids and pregnancy rates: Pregnancy rates lower if > 5 fibroids removed (n = 13, 2/13 pregnant = 15.4%). If 1-5 fibroids removed (n = 37) 65.5% got pregnant (37/54). Size of fibroid impacted pregnancy rates. If volume < 100 ml, 20/43 (46.5%) conceived; if volume > 100 ml, 19/24 (79.2%) conceived
  5) | Pregnancy outcomes: Delivery occurred in 31/51 (60.8%) of conceptions. Spontaneous abortion = 15/51, ectopic pregnancy = 3/51, legal abortion = 2/15
Vercellini, Bocciolone, Colombo, et al., 1993 | Design: Case series, with concomitant controls Intervention(s): Dates: N/S Location: Milan, Italy Length of followup: N/A (on-treatment and in-hospital outcomes only) | No. of subjects at start: 133 Dropouts: 0 Loss to followup: N/A No. of subjects at end: 130 Setting: Hospital (university) Inclusion criteria: Anemic women requiring hysterectomy for myoma-associated menorrhagia; moderate-severe iron deficiency anemia Exclusion criteria: Known pelvic inflammatory disease or endometriosis; urinary stress incontinence; moderate-severe prolapse; adnexal abnormalities at pelvic exam and ultrasound scan; atypia at endometrial biopsy; clotting disorders; unstable general condition Age: Mean, 45.7 Race: N/S Parity: N/S Baseline uterine size: 528±267 ml (goserelin); 555±327 ml (controls) Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb: 8.5 (goserelin); 8.4 (controls) Baseline Hct: 28 (goserelin); 27.2 (controls) | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: − D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: + EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Presurgical treatment with goserelin (Zoladex^®^) 3.6 mg SC every 28 days for a total of 6 months, plus iron for 6 months (n = 41)
  2) | Controls received no GnRH treatment and had immediate surgery (n = 92)
  1) | Type of hysterectomy
  2) | Transfusions
  3) | Operating time
  4) | EBL
  5) | Complications
  6) | Length of stay
  7) | Uterine size
  8) | Hct/Hgb
  9) | Incision type
  1) | Type of hysterectomy: Goserelin: TAH 22/41 = 54%, VH 19/41 = 46% (uterus greater than 12 weeks size considered contraindication to VH) Controls: TAH 74/92 = 80%, VH 18/92 = 20% (p = 0.001)
  2) | Transfusions: Goserelin: None Controls: 47/92 (51%)
  3) | O/R time (minutes): Not significant. In treatment group, TAH = 102±27, VH = 83±19. In controls, TAH = 104±29, VH = 77 ± 16
  4) | EBL (ml): TAH: Goserelin: 186±97 Controls: 351±267 (p < 0.001) VH: Goserelin: 132 ± 53 Controls: 264 ± 179 (p < 0.01)
  5) | Complications: 1 cystotomy in controls Infectious complications: Goserelin, 3/41, controls 14/92
  6) | Length of stay (days): Goserelin TAH 6.6±1.8, control TAH 7.4±1.3 (p = not significant) Goserelin VH 5.5±0.6, control VH 7.0±2.5 (p < 0.05)
  7) | Uterine size: Pretreatment goserelin: 528±267 ml Posttreatment (preop) goserelin: 251 ± 122 ml (median) Controls preop: 555±327 ml Postop weights not recorded
  8) | Hct/Hgb: Pretreatment Hct/Hgb: 8.5/28; controls 8.4/27.2 preop Posttreatment Hct/Hgb: 13.3/40.1 after goserelin and iron
  9) | Incision type: Goserelin: 50% transverse, 50% midline Controls: 45.9% transverse, 54.1% midline
Vercellini, Crosignani, Mangioni, et al., 1998 | Design: RCT, computer-generated randomization, distributed via sealed envelope Intervention(s): Prior to hysterectomy: Dates: May 1995-Oct 1997 Location: Milan and Voghera, Italy Length of followup: 60 days postop | No. of subjects at start: 127 Dropouts: 4 Loss to followup: 0 No. of subjects at end: 123 Setting: Hospital Inclusion criteria: Premeno-pausal (FSH < 30 mIU/ml); symptomatic fibroids (menor-rhagia, pressure) requiring hysterectomy; uterine volume 12-16 weeks; uterine volume, 380-680 ml; no adnexal tumors Exclusion criteria: Uncertain about children; use of GnRH in last 6 months; prior pelvic surgery (except c-section); known pelvic inflammatory disease or endometriosis; stress incontinence; moderate/severe prolapse; clotting disorder; unstable general condition Age: Mean, 46; range, 43-48.5 Race: N/S Parity: N/S Baseline uterine size (median, with range): GnRH group: 14 weeks (12-14), 417 ml (361-513); no-GnRH group: 13 weeks (12-14), 422 ml (374-530) Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb: 11.1 (GnRH group); 11.4 (no-GnRH group) Baseline Hct: 34.3 (GnRH group); 35.7 (no-GnRH group) | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: + C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: + G) Statistical issues: + EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Preoperative GnRH (triptorelin depot [Decapeptyl^®^] 3.75 mg every 28 days x 3) (n = 60)
  2) | No preoperative GnRH (n = 63)
  1) | Type of hysterectomy
  2) | Uterine size
  3) | Preoperative Hgb/Hct
  4) | Morcellation at VH
  5) | Patient satisfaction
  6) | Transfusions
  7) | EBL
  8) | Postoperative complications
  9) | Length of stay
  1) | Type of hysterectomy (vaginal [VH] vs. total abdominal [TAH]): At baseline, VH recommended for 7/60 women randomized to GnRH (12%) and 53/60 (88%) for TAH. VH initially indicated for 10/63 in surgery arm (16%). After GnRH, 25/53 previously recommended for TAH underwent VH. In GnRH group, 32/60 had VH (53%) (p < 0.0001), and 28/60 had TAH. In immediate surgery group, 10/63 had VH, 53/63 had TAH.
  2) | Uterine size (median, with range): GnRH group: Pretreatment, 14 weeks (12-14), 417 (361-513) ml; posttreatment, 11 weeks (10-12), 251 (212-352) ml, 270 (199-330) g Immediate surgery group: Baseline, 13 weeks (12-14), 422 (374-530) ml. At surgery, 396 (302-515) g
  3) | Preoperative Hgb/Hct: GnRH group: Pretreatment = 11.1/34.3, posttreatment = 13.2/39.4 Immediate surgery group: 11.4/35.7
  4) | Morcellation at VH: 21/32 (66%) in GnRH group, 6/10 (60%) in controls
  5) | Patient satisfaction: No between-group difference in patient satisfaction survey (60 day followup)
  6) | Transfusions: None in either group
  7) | EBL: GnRH: 200 ml; surgery group: 225 ml
  8) | Postop complications: GnRH: 7/60; immediate surgery: 3/63
  9) | Length of stay: GnRH = 5 days; surgery = 6 days
Vollenhoven, McCloud, Shekleton, et al., 1993 | Design: Case series, no controls Intervention(s): GnRH agonist±abdominal myomectomy. All patients (n = 20) received one of the following: 13/20 pts (65%) also under-went myomectomy, 11 while on GnRH therapy, and 2 within 6 months of completing GnRH therapy. Dates: N/S Location: Melbourne, Australia Length of followup: 1 year | No. of subjects at start: 20 Dropouts: 1 Loss to followup: 0 No. of subjects at end: 19 Setting: N/S Inclusion criteria: Willing to do 3 hours of weight-bearing exercise per week; infertility; intake of at least 1500 mg of calcium per day Exclusion criteria: Smoking; other causes of infertility Age: Mean, 34; range, 27-42 Race: 100% white Parity: 20% Baseline uterine size: N/S Baseline fibroid size: Mean, 243.9 ml; range, 12-807 ml Number of fibroids: Mean, 2.85; range, 1-6 Baseline Hgb/Hct: N/S | | | INTERNAL VALIDITY A) Random: − B) Methods and blinding: N/A C) Pt selection criteria: + D) Length of followup: + E) Loss to followup: + F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: + J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: + N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Buserelin 200 mcg 6 times per day x 6 months (n = 3)
  2) | Buserelin 200 mcg SC pump per day x 6 months (n = 9)
  3) | Buserelin 200 mcg SC per day x 4 months
  4) | Goserelin 3.6 mg IM per month x 4 months (n = 3)
  5) | Leuprolide 1 mg per day x 6 months (n = 1) (n's given here as reported in article; do not add up correctly)
  1) | Pregnancy rate
  2) | Complications/adverse effects
  1) | Pregnancy rate: GnRH alone: 1/7 (14%) GnRH + myomectomy: 6/12 (50%)
  2) | Complications/adverse effects: Hot flashes: 100%
Ylikorkala, Tiitinen, Hulkko, et al., 1995 | Design: RCT, method of randomization not described Intervention(s): Prior to hysterectomy: Dates: N/S Location: Helsinki, Finland Length of followup: N/A (on-treatment and in-hospital outcomes only) | No. of subjects at start: 188 Dropouts: 22 (5 withdrew; 17 excluded from analysis) Loss to followup: N/A No. of subjects at end: 166 Setting: Hospital Inclusion criteria: Scheduled for hysterectomy Exclusion criteria: Anemia Age: Mean, 43.5 Race: N/S Parity: 9% nulliparous (nafarelin group); 15% nulliparous (placebo group) Baseline uterine size: 301± 204 ml (nafarelin group); 336 ± 264 ml (placebo group) Baseline fibroid size: N/S Number of fibroids: N/S Baseline Hgb: 130.5 ± 10.6 g/l (nafarelin group); 131.9±12.2 g/l (placebo group) Baseline Hct: N/S | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: − C) Pt selection criteria: + D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: + EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: + K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: − N) Location of fibroids: − O) Measurement timing: − P) Measurement methods: − Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | Nafarelin 200 mcg IN twice per day x 3 months (n = 125)
  2) | Placebo nasal spray twice per day x 3 months (n = 63)
  1) | Uterine weight
  2) | Change in uterine size
  3) | Change in fibroid size
  4) | Change in Hgb
  5) | Change in bleeding pattern
  6) | EBL
  7) | O/R time
  8) | Hot flashes
  1) | Uterine weight (posttreatment): Nafarelin: 255.5±12.6 g Placebo: 346.2±35.7 g (p = 0.029)
  2) | Change in uterine size: Nafarelin group decreased by 23.7% in 3 months
  3) | Change in fibroid size: Decrease 31.4% in nafarelin group (p < 0.005)
  4) | Change in Hgb: Increased 5.5 ± 0.9 in nafarelin group. No change in placebo group.
  5) | Change in bleeding pattern: Pretreatment, 91 nafarelin and 48 placebo patients reported severe menstrual blood loss. In nafarelin group, 55% were amenorrheic by 3 months.
  6) | EBL: Nafarelin: 309.6±22.8 ml Placebo: 309.1±22.8 ml (No significant difference)
  7) | O/R time: Nafarelin: 75.6±2.5 minutes Placebo: 74.2±3.3 minutes (No significant difference)
  8) | Hot flashes: 61% in nafarelin, and 35% in placebo
Zullo, Pellicano, De Stefano, et al., 1997 and Zullo, Pellicano, De Stefano, et al., 1998 and Zullo, Pellicano, Di Carlo, et al., 1998 | Design: RCT, computer-generated randomization Interventions: Dates: Sep 1994-Jul 1996 Location: Naples and Catanzaro, Italy Length of followup: N/A (on-treatment and in-hospital outcomes only) | No. of subjects at start: 74 Dropouts: 7 Loss to followup: N/A No. of subjects at end: 67 Setting: Hospital Inclusion criteria: Uterine fibroids; symptoms of increased vaginal bleeding, pelvic pain, or pelvic pressure; main myoma not pedunculated and < 500 cc and > 4 cc on ultrasound; < 4 myomas; absence of submucosal fibroids on hysteroscopy; absence of ultrasound-documented calcification in the main myoma; absence of hyperplasia; normal Pap smear; negative urine pregnancy test; infertility > 3 years or recurrent abortions Exclusion criteria: None specified Age: Mean, 36.8 (LA group); 37.7 (controls) Race: N/S Parity: 1.4±0.7 (LA group); 1.5±0.5 (controls) Baseline uterine size: 473 ± 88 cc (LA group); 458±92 cc (controls) Baseline fibroid size: 62.8±27.7 cc (LA group); 58.5±31.0 cc (controls) Number of fibroids: 2.1±0.4 (LA group); 1.9±0.5 (controls) Baseline Hgb: 13.1 ± 0.8 g/dl (LA group); 12.7 ± 1.0 g/dl (controls) Baseline Hct: N/S | | | INTERNAL VALIDITY A) Random: + B) Methods and blinding: + C) Pt selection criteria: + D) Length of followup: N/A E) Loss to followup: N/A F) Dropout rates: + G) Statistical issues: − EXTERNAL VALIDITY H) Age: + I) Race: − J) Pregnancy history: − K) Surgical history: − L) Fibroid/uterine size: + M) Number of fibroids: + N) Location of fibroids: − O) Measurement timing: + P) Measurement methods: + Q) Measurement reliability: − R) Clinical care: + S) Standardized measures: −
  1) | LA 3.75 mg SC every 28 days x 2 months, followed by laparoscopic myomectomy (n = 35)
  2) | No pretreatment before laparoscopic myomectomy (n = 32)
  1) | Uterine size
  2) | Resistive index of uterine arteries
  3) | Largest diameter of fibroid
  4) | EBL
  5) | O/R time
  6) | Blood loss
  7) | Hemoglobin
  1) | Uterine size: LA: 473 ± 88 cc pretreatment and 396 ± 79 cc posttreatment (presurgery). Controls: 458 ± 92 cc (P < 0.001, LA presurgery vs. controls)
  2) | Resistive index: In LA group: 0.66±0.07 pre- and 0.79±0.08 posttherapy. Change is significant, but no difference between two groups at baseline. Baseline in controls: 0.63±0.08.
  3) | Largest diameter of fibroid: LA group: 4.9±2.1 pretreatment to 4.3±2.3 posttreatment. Controls: baseline 4.8±2.6 (p< 0.001, LA pre- to posttreatment)
  4) | EBL: LA group: 171.8±70.9 Controls: 232.1±68.1 (p < 0.01)
  5) | O/R time: LA group: 98.5±26.1 Controls: 113.3 + 35.1 (p < 0.05)
  6) | Blood loss: Blood loss was significantly lower in the leuprolide-treated group (171.8±70.9 ml) than in the control group (232.1 ± 68.1 ml) (p < 0.01).
  7) | Hemoglobin: Postoperative hemoglobin was significantly higher in the leuprolide-treated patients than in control patients (p < 0.05).