# Abbreviations and Acronyms Used in This Report

Abd: Abdominal

ACOG: American College of Obstetricians and Gynecologists

AHRQ: Agency for Healthcare Research and Quality

BDI: Beck Depression Inventory

BMI: Body mass index

BSO: Bilateral salpingo-oophorectomy

cc: Cubic centimeter

95% CI: 95% Confidence interval

cm: Centimeter

c-section: Cesarean section

D+C: Dilation and curettage

dl: Deciliter

DSFI: Derogatis Sexual Functioning Inventory

DVT: Deep venous thrombosis

EBL: Estimated blood loss

ER: Emergency room

F: Fahrenheit

FDA: Food and Drug Administration

FSH: Follicle-stimulating hormone

F/U: Followup

g: Gram

GA: Goserelin acetate

GHQ: General Health Questionnaire

GnRH: Gonadotropin-releasing hormone

Hct: Hematocrit

HCUP: Healthcare Cost and Utilization Project

HDL: High-density lipoprotein

Hgb: Hemoglobin

HRT: Hormone replacement therapy

H/S: Hysteroscopic

HSE: Hysterosonographic examination

Hyst: Hysterectomy

IBS: Irritable bowel syndrome

ICD-9: International Classification of Diseases, Revision 9

ICSI: Intracytoplasmic sperm injection

IM: Intramuscular

IML: Intramural

IN: Intranasal

IRB: Institutional review board

IVF: In vitro fertilization

KBG: Kuei-chin-fu-ling-wan

kg: Kilogram

KTP/YAG: Potassium-Titanyl-Phosphate/Neodymium:Yttrium-Aluminium-Garnet

LA: Leuprolide acetate

LAM: Laparoscopic-assisted myomectomy

LAVH: Laparoscopically assisted vaginal hysterectomy

LH: Luteinizing hormone

LHRH: Luteinizing hormone-releasing hormone

LITT: Laser-induced interstitial thermotherapy

L/S: Laparoscopic

m: Meter

mcg: Microgram

MD: Medical doctor

MeSH: Medical Subject Headings

mg: Milligram

mIU: Milli-International Unit

ml: Milliliter

mm: Millimeter

mmol: Millimole

MPA: Medroxyprogesterone acetate

MRI: Magnetic resonance imaging

Myo: Myomectomy

n: Number of patients

N/A: Not applicable

Nd:YAG: Neodymium:Yttrium-Aluminium-Garnet

NIS: Nationwide Inpatient Sample

No.: Number

N/S: Not specified

NSAIDs: Nonsteroidal anti-inflammatory drugs

OB/GYN: Obstetrics and gynecology

OCPs: Oral contraceptive pills

O/R: Operating room

OR: Odds ratio

PID: Pelvic inflammatory disease

PO: Per os (orally)

Post-op: Postoperative(ly)

Pre-op: Preoperative(ly)

Pre-treat: Pretreatment

Pt(s): Patient(s)

QoL: Quality of life

RCT: Randomized controlled trial

RR: Relative risk

SAB: Spontaneous abortion

SC: Subcutaneous

SD: Standard deviation

SLL: Second-look laparoscopy

SX: Symptoms

TAB: Therapeutic abortion

TAH: Total abdominal hysterectomy

Temp: Temperature

TEMR: Transcervical endomyometrial resection

Tourn: Tourniquet

TSR: Transcervical electrosurgical resection

TVH: Total vaginal hysterectomy

UTI: Urinary tract infection

Vag: Vaginal

VH: Vaginal hysterectomy

vs.: Versus

WBC: White blood cell

Wk(s): Week(s)

Yr(s): Year(s)