# Bibliography

Abramovici H, Dirnfeld M, Auslander R, et al Pregnancies following treatment by GnRH-a (Decapeptyl) and myomectomy in infertile women with uterine leiomyomata Int J Fertil Menopausal Stud 1994 39(3):150 5 7920751
Abulafia O, Sherer DM Transcatheter uterine artery embolization for the management of symptomatic uterine leiomyomas Obstet Gynecol Surv 1999 54(12):745 53 10596395
Acien P, Quereda F Abdominal myomectomy: results of a simple operative technique Fertil Steril 1996 65(1):41 51 8557153
Adamson GD Treatment of uterine fibroids: current findings with gonadotropin-releasing hormone agonists Am J Obstet Gynecol 1992 166(2):746 51 1531577
Adamson GD. Myomectomy, GnRH analogs, and adhesions. Prog Clin Biol Res. 1993;381:155-85. [pmid: 8316560].
Adamson GD Myoma: Laparoscopic hysterectomy Infertil Reprod Med Clinics North Am 1996 71(1):179 207
Adashi EY Long-term gonadotrophin-releasing hormone agonist therapy: The evolving issue of steroidal ‘add-back’ paradigms Hum Reprod 1994 9(7):1380 97 7962453
Aharoni A, Reiter A, Golan D, et al Patterns of growth of uterine leiomyomas during pregnancy. A prospective longitudinal study Br J Obstet Gynaecol 1988 95(5):510 3 3042016
Akagbosu FT Audit of abdominal hysterectomies at University of Benin Teaching Hospital 1981-1987 J Obstet Gynaecol 1996 16(5):406 8
Akkad AA, Habiba MA, Ismail N, et al Abnormal uterine bleeding on hormone replacement: the importance of intrauterine structural abnormalities Obstet Gynecol 1995 86(3):330 4 7651636
Aleandri V, Benagiano G Report on a conference on developments in the treatment of benign gynecological disorders Gynecol Endocrinol 1992 6(4):301 9 1492588
Aleem FA, Predanic M The hemodynamic effect of GnRH agonist therapy on uterine leiomyoma vascularity: a prospective study using transvaginal color Doppler sonography Gynecol Endocrinol 1995 9(3):253 8 8540296
Alexander DA, Naji AA, Pinion SB, et al Randomised trial comparing hysterectomy with endometrial ablation for dysfunctional uterine bleeding: psychiatric and psychosocial aspects BMJ 1996 312(7026):280 4 8611783
Alexander E Uterine leiomyoma: problems during pregnancy Kansas Med 1988 89(3):77 8
Altchek A Management of fibroids Curr Opin Obstet Gynecol 1992 4(3):463 71 1535799
Surgical alternatives to hysterectomy in the management of leiomyomas. ACOG Pract Bull. 2000;16:1-13.
Amirikia H, Zarewych B, Evans TN Caesarean section: a 15-year review of changing incidence, indications, and risks Am J Obstet Gynecol 1981 140(1):81 90 7223816
Andersen J, Barbieri RL Abnormal gene expression in uterine leiomyomas J Soc Gynecol Invest 1995 2(5):663 72
Anderson RN. United States Life Tables, 1997. National Vital Statistics Reports, Vol. 47, No. 28. Hyattsville, MD: National Center for Health Statistics, 1999.
Andrei B Myomectomy by pelvicoscopy Int Surg 1996 81(3):271 5 9028988
Andrei B, Crovini G, Rosi A Uterine myomas: Pelviscopic treatment Clin Exp Obstet Gynecol 1999 26(1):44 6 10490357
Andreyko JL, Blumenfeld Z, Marshall LA, et al Use of an agonistic analog of gonadotropin-releasing hormone (nafarelin) to treat leiomyomas: assessment by magnetic resonance imaging Am J Obstet Gynecol 1988 158(4):903 10 2966587
Anonymous Goserelin pretreatment eases hysterectomy for the removal of uterine fibroids Hosp Formulary 1991 26(5):
Anonymous Goserelin pretreatment facilitates fibroid surgery Female Patient 1991 16(2):
Anonymous Recurrence of fibroids after myomectomy Lancet 1991 338(8766):
Anonymous Prophylaxis of pelvic sidewall adhesions with Gore-Tex surgical membrane: a multicenter clinical investigation. The Surgical Membrane Study Group Fertil Steril 1992 57(4):921 3 1555708
Anonymous Prevalence and anatomical distribution of endometriosis in women with selected gynaecological conditions: results from a multicentric Italian study. Gruppo italiano per lo studio dell'endometriosi Hum Reprod 1994 9(6):1158 62 7962393
Anonymous Uterine leiomyomata Int J Gynecol Obstet 1994 46(1):73 82
Anonymous Effects of estrogen or estrogen/progestin regimens on heart disease risk factors in postmenopausal women The Postmenopausal Estrogen/Progestin Interventions (PEPI) Trial. The Writing Group for the PEPI Trial [published erratum appears in JAMA 1995 Dec 6;274(21):1676] JAMA 1995 273(3):199 208 7807658
Anonymous Drugs in the peri-operative period: 3-Hormonal contraceptives and hormone replacement therapy Drug Ther Bull 1999 37(10):78 80 10696684
Anteby SO, Yarkoni S, Ever Hadani P The effect of a prostaglandin synthetase inhibitor, indomethacin, on excessive uterine bleeding Clin Exp Obstet Gynecol 1985 12(3-4):60 3 4064305
Arcaini L, Federici D, Muggiasca L, et al Hysteroscopic myomectomy Minim Invasive Ther 1994 3(4):203 5
Arcangeli S, Pasquarette MM Gravid uterine rupture after myolysis Obstet Gynecol 1997 89(5 II Suppl.):
Arieff AI, Ayus JC Endometrial ablation complicated by fatal hyponatremic encephalopathy JAMA 1993 270(10):1230 2 8355387
Ashraf T Management of uterine leiomyomas J Coll Phys Surg Pakistan 1997 7(4):160 2
Aslan P, Brooks A, Drummond M, et al Incidence and management of gynaecological-related ureteric injuries Aust N Z J Obstet Gynaecol 1999 39(2):178 81 10755773
Audebert AJ, Madenelat P, Querleu D, et al Deferred versus immediate surgery for uterine fibroids: clinical trial results Br J Obstet Gynaecol 1994 101(Suppl 10):29 32
Averette HE, Nguyen HN The role of prophylactic oophorectomy in cancer prevention Gynecol Oncol 1994 55(3 Pt 2):S38 41 7835808
Ayala AR, Meza E, Cervera Aguilar R, et al. Effect of insuflated Nafarelin (D-Nal-6-GnRH) upon uterine leiomyomata. Arch Med Res. 1995;26:S23-S26. [pmid: 8845654].
Ayida G, Chamberlain P, Barlow D, et al Uterine cavity assessment prior to in vitro fertilization: comparison of transvaginal scanning, saline contrast hysterosonography and hysteroscopy Ultrasound Obstet Gynecol 1997 10(1):59 62 9263425
Ayida G, Chamberlain P, Barlow D, et al Is routine diagnostic laparoscopy for infertility still justified? A pilot study assessing the use of hysterosalpingo-contrast sonography and magnetic resonance imaging Hum Reprod 1997 12(7):1436 9 9262273
Babaknia A, Rock JA, Jones HW Jr Pregnancy success following abdominal myomectomy for infertility Fertil Steril 1978 30(6):644 7 729825
Baggish MS, Sze EHM, Morgan G Hysteroscopic treatment of symptomatic submucous myomata uteri with the Nd:YAG laser J Gynecol Surg 1989 5(1):27 36
Bakker C, van der Linden S Health related utility measurement: an introduction J Rheumatol 1995 22(6):1197 9 7674256
Balasch J, Manau D, Mimo J, et al Sequential gonadotrophin-releasing hormone agonist/low-dose oral contraceptive treatment for leiomyomata uteri Hum Reprod 1995 10(3):529 32 7782427
Balasch J, Manau D, Mimo J, et al Trial of routine gonadotropin releasing hormone agonist treatment before abdominal hysterectomy for leiomyoma Acta Obstet Gynecol Scand 1995 74(7):562 5 7618457
Ballard LA, Walters MD Transvaginal mobilization and removal of ovaries and fallopian tubes after vaginal hysterectomy Obstet Gynecol 1996 87(1):35 9 8532262
Barbieri RL Abdominal myomectomy is a safe and effective treatment for uterine leiomyomata J Gynecol Tech 1998 4(3):85 7
Barbieri RL Ambulatory management of uterine leiomyomata Clin Obstet Gynecol 1999 42(2):196 205 10370841
Barbieri RL, Dilena M, Chumas J, et al Leuprolide acetate depot decreases the number of nucleolar organizer regions in uterine leiomyomata Fertil Steril 1993 60(3):569 70 8375543
Bassaw K, Gangar K, Lumbiganon P, et al Protective effect of depot-medroxyprogesterone acetate on surgically treated uterine leiomyomas: a multicentre case-control study (multiple letters) Br J Obstet Gynaecol 1997 104(6):758 9
Benagiano G, Kivinen ST, Fadini R, et al Zoladex (goserelin acetate) and the anemic patient: results of a multicenter fibroid study Fertil Steril 1996 66(2):223 9 8690106
Benagiano G, Morini A, Aleandri V, et al Sequential Gn-RH superagonist and medroxyprogesterone acetate treatment of uterine leiomyomata Int J Gynaecol Obstet 1990 33(4):333 43 1979288
Benagiano G, Morini A, Primiero FM Fibroids: Overview of current and future treatment options Br J Obstet Gynaecol 1992(Suppl. 7):18 22
Ben-Baruch G, Schiff E, Menashe Y, et al. Immediate and late outcome of vaginal myomectomy for prolapsed pedunculated submucous myoma. Obstet Gynecol. 1988;72:858-61. [pmid: 3186093].
Bennett KL, Ohrmundt C, Maloni JA Preventing intravasation in women undergoing hysteroscopic procedures AORN J 1996 64(5):792 9 8922218
Berkeley AS, DeCherney AH, Polan ML Abdominal myomectomy and subsequent fertility Surg Gynecol Obstet 1983 156(3):319 22 6828976
Bernard G, Darai E, Poncelet C, et al Fertility after hysteroscopic myomectomy: effect of intramural myomas associated Eur J Obstet Gynecol Reprod Biol 2000 88(1):85 90 10659923
Bernhard LA Consequences of hysterectomy in the lives of women Health Care Women Internat 1992 13(3):281 91
Beyth Y Gonadotropin-releasing hormone analog treatment should not precede conservative myomectomy Fertil Steril 1990 53(1):187 8 2403936
Bhattacharya S, Mollison J, Pinion S, et al A comparison of bladder and ovarian function two years following hysterectomy or endometrial ablation [published erratum appears in Br J Obstet Gynaecol 1996 Dec;103(12):1273] Br J Obstet Gynaecol 1996 103(9):898 903 8813310
Bianchi G, Costantini S, Anserini P, et al Effects of gonadotrophin-releasing hormone agonist on uterine fibroids and bone density Maturitas 1989 11(3):179 85 2512467
Bianchi S, Fedele L, Vignali M, et al Effects on bone mineral density of 12-month goserelin treatment in over 40-year-old women with uterine myomas Calcif Tissue Int 1995 57(1):78 80 7671171
Biberoglu K, Gursoy R, Yildiz A Treatment of estrogen-dependent gynecological disorders with the gonadotropin releasing hormone agonist buserelin Gynecol Endocrinol 1991 5(2):109 22 1833953
Bischof P, Galfetti MA, Seydoux J, et al Peripheral CA 125 levels in patients with uterine fibroids Hum Reprod 1992 7(1):35 8 1532397
Borgfeldt C, Andolf E Transvaginal ultrasonographic findings in the uterus and the endometrium: low prevalence of leiomyoma in a random sample of women age 25-40 years Acta Obstet Gynecol Scand 2000 79(3):202 7 10716301
Botsis D, Kassanos D, Antoniou G, et al Adenomyoma and leiomyoma: Differential diagnosis with transvaginal sonography J Clin Ultrasound 1997 26(1):21 5
Botvin MA, Pobedinskii NM, Zuev VM, et al Biocompatible polymer materials for conservative uterine plastic surgery Bio-Med Engineering 1994 28(3):165 7
Boyd ME Myomectomy Can J Surg 1986 29(3):161 3 3518894
Bradham DD, Stovall TG, Thompson CD Use of GnRH agonist before hysterectomy: a cost simulation Obstet Gynecol 1995 85(3):401 6 7862380
Breuiller-Fouche M, Vacher-Lavenu MC, Fournier T, et al Endothelin(A) receptors in human uterine leiomyomas Obstet Gynecol 1997 90(5):727 30 9351753
Brill AI What is the role of hysteroscopy in the management of abnormal uterine bleeding? Clin Obstet Gynecol 1995 38(2):319 45 7554600
Broder MS, Kanouse DE, Mittman BS, et al. The appropriateness of recommendations for hysterectomy. Obstet Gynecol. 2000;95:199-205. [pmid: 10674580].
Broekmans FJ GnRH agonists and uterine leiomyomas Hum Reprod 1996 11(Suppl 3):3 25 9147098
Broekmans FJ, Heitbrink MA, Hompes PG, et al Quantitative MRI of uterine leiomyomas during triptorelin treatment: reproducibility of volume assessment and predictability of treatment response Magn Reson Imaging 1996 14(10):1127 35 9065902
Broekmans FJ, Hompes PG, Heitbrink MA, et al Two-step gonadotropin-releasing hormone agonist treatment of uterine leiomyomas: standard-dose therapy followed by reduced-dose therapy Am J Obstet Gynecol 1996 175(5):1208 16 8942490
Brooks PG Resectoscopic myoma vaporizer J Reprod Med 1995 40(11):791 5 8592315
Brooks PG, Loffer FD, Serden SP Resectoscopic removal of symptomatic intrauterine lesions J Reprod Med 1989 34(7):435 7
Brosens I, Deprest J, Dal Cin P, et al Clinical significance of cytogenetic abnormalities in uterine myomas Fertil Steril 1998 69(2):232 5 9496334
Brosens I, Johannisson E, Dal Cin P, et al Analysis of the karyotype and desoxyribonucleic acid content of uterine myomas in premenopausal, menopausal, and gonadotropin-releasing hormone agonist-treated females Fertil Steril 1996 66(3):376 9 8751732
Brown D, Fletcher HM, Myrie MO, et al Caesarean myomectomy -- A safe procedure. A retrospective case controlled study J Obstet Gynaecol 1999 19(2):139 41 15512253
Brown JS, Seeley DG, Fong J, et al Urinary incontinence in older women: who is at risk? Study of Osteoporotic Fractures Research Group Obstet Gynecol 1996 87(5 Pt 1):715 21 8677073
Bulletti C, Polli V, Negrini V, et al Adhesion formation after laparoscopic myomectomy J Am Assoc Gynecol Laparosc 1996 3(4):533 6 9050684
Burn P, McCall J, Chinn R, et al Embolization of uterine fibroids Br J Radiol 1999 72(854):159 61 10365066
Burton CA, Grimes DA, March CM Surgical management of leiomyomata during pregnancy Obstet Gynecol 1989 74(5):707 9 2812645
Bush TL, Barrett-Connor E, Cowan LD, et al Cardiovascular mortality and noncontraceptive use of estrogen in women: results from the Lipid Research Clinics Program Follow-up Study Circulation 1987 75(6):1102 9 3568321
Buttram VC Jr, Reiter RC Uterine leiomyomata: Etiology, symptomatology, and management Fertil Steril 1981 36(4):433 45 7026295
Cagnacci A, Paoletti AM, Soldani R, et al Role of goserelin-depot in the clinical management of uterine fibroids Clin Exp Obstet Gynecol 1994 21(4):263 5 7994879
Caird LE, West CP, Lumsden MA, et al Medroxyprogesterone acetate with Zoladex for long-term treatment of fibroids: effects on bone density and patient acceptability Hum Reprod 1997 12(3):436 40 9130735
Candiani GB, Fedele L, Parazzini F, et al Risk of recurrence after myomectomy Br J Obstet Gynaecol 1991 98(4):385 9 2031897
Candiani GB, Vercellini P, Fedele L, et al Use of goserelin depot, a gonadotropin-releasing hormone agonist, for the treatment of menorrhagia and severe anemia in women with leiomyomata uteri Acta Obstet Gynecol Scand 1990 69(5):413 5 2148663
Cano A, Aliaga R, Puertolas C, et al Influence of the ovary on parameters of LH secretion during the recovery from buserelin-induced desensitization Eur J Obstet Gynecol Reprod Biol 1994 55(3):187 92 7958164
Cantuaria GH, Angioli R, Frost L, et al Comparison of bimanual examination with ultrasound examination before hysterectomy for uterine leiomyoma Obstet Gynecol 1998 92(1):109 12 9649104
Carlson KJ, Miller BA, Fowler FJ Jr. The Maine Women's Health Study: I. Outcomes of hysterectomy. Obstet Gynecol 1994a;83(4):556-65.
Carlson KJ, Miller BA, Fowler FJ Jr The Maine Women's Health Study: II. Outcomes of nonsurgical management of leiomyomas, abnormal bleeding, and chronic pelvic pain Obstet Gynecol 1994b 83(4):566 72 8134067
Carlsson S, Kullander S In vivo localization and turnover of radio-iodinated HCG in women with myomas and in nude mice with ovarian tumor heterografts Acta Obstet Gynecol Scand 1981 60(3):287 90 7270098
Carr BR, Marshburn PB, Weatherall PT, et al An evaluation of the effect of gonadotropin-releasing hormone analogs and medroxyprogesterone acetate on uterine leiomyomata volume by magnetic resonance imaging: a prospective, randomized, double blind, placebo-controlled, crossover trial J Clin Endocrinol Metab 1993 76(5):1217 23 8496313
Carter JE Combined hysteroscopic and laparoscopic findings in patients with chronic pelvic pain J Am Assoc Gynecol Laparosc 1994 2(1):43 7 9050532
Carter JE, McCarus SD Laparoscopic myomectomy: time and cost analysis of power vs. manual morcellation J Reprod Med 1997 42(7):383 8 9252927
Cerny E, Bucek J Inflammatory changes in uterine leiomyomas Scripta Medica Facultatis Medicae Universitatis Brunensis Masarykianae 1996 69(7):361 5
Cetin MT, Vardar MA, Demir SC, et al Administration of preoperative gonadotropin releasing hormone agonist (buserelin) for uterine leiomyomas Ann Med Sci 1995 4(2):102 8
Challener RC, Kaufman B Fatal venous air embolism following sequential unsheathed (bare) and sheathed quartz fiber Nd:YAG laser endometrial ablation Anesthesiology 1990 73(3):548 51 2393141
Chang FH, Soong YK, Cheng PJ, et al Laparoscopic myomectomy of large symptomatic leiomyoma using airlift gasless laparoscopy: a preliminary report Hum Reprod 1996 11(7):1427 32 8671480
Chapman R Treatment of uterine myomas by interstitial hyperthermia Gynaecol Endoscopy 1993 2(4):227 34
Chapman R Low power interstitial photocoagulation of uterine leiomyomas by KTP/NAG laser Lasers Med Sci 1994 9(1):37 46
Chapman R Treatment of large uterine fibroids Br J Obstet Gynaecol 1997 104(7):867 8 9236659
Chapman R New therapeutic technique for treatment of uterine leiomyomas using laser-induced interstitial thermotherapy (LITT) by a minimally invasive method Lasers Surg Med 1998 22(3):171 8 9510102
Chapman R Successful pregnancies following laser-induced interstitial thermotherapy (LITT) for treatment of large uterine leiomyomas by a minimally invasive method Acta Obstet Gynecol Scand 1998 77(10):1024 5 9849850
Chiaffarino F, Parazzini F, La Vecchia C, et al Diet and uterine myomas Obstet Gynecol 1999 94(3):395 8 10472866
Chiaffarino F, Parazzini F, La Vecchia C, et al Use of oral contraceptives and uterine fibroids: Results from a case-control study Br J Obstet Gynaecol 1999 106(8):857 60 10453838
Chiang CH, Chang MY, Hsu JJ, et al Tumor vascular pattern and blood flow impedance in the differential diagnosis of leiomyoma and adenomyosis by color Doppler sonography J Assist Reprod Genet 1999 16(5):268 75 10335475
Chong RK, Thong PH, Tan SL, et al Myomectomy: indications, results of surgery and relation to fertility Singapore Med J 1988 29(1):35 7 3406762
Chrisp P, Goa KL Goserelin. A review of its pharmacodynamic and pharmacokinetic properties, and clinical use in sex hormone-related conditions Drugs 1991 41(2):254 88 1709853
Christiansen JK The facts about fibroids: Presentation and latest management options Postgrad Med 1993 94(3):129 32, 134, 137 8361939
Chung TKH, Chan MYM, Stock AI Myomectomy in the treatment of postpartum haemorrhage Br J Obstet Gynaecol 1994 191(1):73 4
Cicinelli E, Romano F, Anastasio PS, et al Transabdominal sonohysterography, transvaginal sonography, and hysteroscopy in the evaluation of submucous myomas Obstet Gynecol 1995 85(1):42 7 7800322
Cirkel U, Ochs H, Roehl A, et al Estrogen and progesterone receptor content of enucleated uterine myomata after luteinizing hormone-releasing hormone. Analogue depot therapy Acta Obstet Gynecol Scand 1994 73(4):328 32 8160541
Cirkel U, Ochs H, Schneider HP, et al Experience with leuprorelin acetate depot in the treatment of fibroids: a German multicentre study Clin Ther 1992 14(Suppl A):37 50 1606593
Cittadini E Laparoscopic myomectomy: The Italian experience J Am Assoc Gynecol Laparosc 1998 5(1):7 9 9454869
Clarke A, Black N, Rowe P, et al Indications for and outcome of total abdominal hysterectomy for benign disease: a prospective cohort study Br J Obstet Gynaecol 1995 102(8):611 20 7654638
Coddington CC, Brzyski R, Hansen KA, et al Short term treatment with leuprolide acetate is a successful adjunct to surgical therapy of leiomyomas of the uterus Surg Gynecol Obstet 1992 175(1):57 63 1621201
Cohen D, Mazur MT, Jozefczyk MA, et al Hyalinization and cellular changes in uterine leiomyomata after gonadotropin releasing hormone agonist therapy J Reprod Med 1994 39(5):377 80 7520497
Cohen LS, Valle RF Role of vaginal sonography and hysterosonography in the endoscopic treatment of uterine myomas Fertil Steril 2000 73(2):197 204 10685515
Cohen O, Schindel B, Homburg R Uterine leiomyomata -- A feature of acromegaly Hum Reprod 1998 13(7):1945 6 9740454
Colacurci N, DeFranciscis P, Cobellis L, et al. Effects of hormone replacement therapy on postmenopausal uterine myoma. Maturitas. 2000;35:167-73. [pmid: 10924843].
Colditz GA, Willett WC, Stampfer MJ, et al Menopause and the risk of coronary heart disease in women N Engl J Med 1987 316(18):1105 10 3574358
Colgan TJ, Pendergast S, LeBlanc M The histopathology of uterine leiomyomas following treatment with gonadotropin-releasing hormone analogues Hum Pathol 1993 24(10):1073 7 8406417
Connelly CS, Panush RS Should nonsteroidal anti-inflammatory drugs be stopped before elective surgery? Arch Intern Med 1991 151(10):1963 6 1929684
Coppen A, Bishop M, Beard RJ, et al Hysterectomy, hormones, and behaviour. A prospective study Lancet 1981 1(8212):126 8 6109801
Cornelison TL, Natarajan N, Piver MS, et al. Tubal ligation and the risk of ovarian carcinoma. Cancer Detect Prev. 1997;21:1-6. [pmid: 9043756].
Coronado GD, Marshall LM, Schwartz SM. Complications in pregnancy, labor, and delivery with uterine leiomyomas: a population-based study. Obstet Gynecol. 2000;95:764-9. [pmid: 10775744].
Corson SL Hysteroscopic diagnosis and operative therapy of submucous myoma Obstet Gynecol Clin North Am 1995 22(4):739 55 8786879
Corson SL, Brooks PG Resectoscopic myomectomy Fertil Steril 1991 55(6):1041 4 2037101
Costantini S, Anserini P, Valenzano M, et al Luteinizing hormone-releasing hormone analog therapy of uterine fibroid: analysis of results obtained with buserelin administered intranasally and goserelin administered subcutaneously as a monthly depot Eur J Obstet Gynecol Reprod Biol 1990 37(1):63 9 2142921
Coulam CB, Adamson SC, Annegers JF Incidence of premature ovarian failure Obstet Gynecol 1986 67(4):604 6 3960433
Councell RB, Thorp JM Jr, Sandridge DA, et al Assessments of laparoscopic-assisted vaginal hysterectomy J Am Assoc Gynecol Laparosc 1994 2(1):49 56 9147858
Courban D, Blank S, Harris MA, et al Acute renal failure in the first trimester resulting from uterine leiomyomas Am J Obstet Gynecol 1997 177(2):472 3 9290476
Coutinho EM. Gestrinone in the treatment of myomas. Acta Obstet Gynecol Scand Suppl. 1989;150:39-46. [pmid: 2694740].
Coutinho EM Treatment of large fibroids with high doses of gestrinone Gynecol Obstet Invest 1990 30(1):44 7 2227612
Coutinho EM, Boulanger GA, Goncalves MT Regression of uterine leiomyomas after treatment with gestrinone, an antiestrogen, antiprogesterone Am J Obstet Gynecol 1986 155(4):761 7 3532799
Coutinho EM, Goncalves MT Long-term treatment of leiomyomas with gestrinone Fertil Steril 1989 51(6):939 46 2656310
Cramer SF, Horiszny JA, Leppert P Epidemiology of uterine leiomyomas. With an etiologic hypothesis J Reprod Med 1995 40(8):595 600 7473458
Cramer SF, Patel A The frequency of uterine leiomyomas Am J Clin Pathol 1990 94(4):435 8 2220671
Cramer SF, Patel A Myometrial hyperplasia: proposed criteria for a discrete morphological entity Modern Pathology 1995 8(1):71 7 7731945
Cravello L, D'Ercole C, Boubli L, et al Hysteroscopic treatment of uterine fibroids J Gynecol Surg 1995 11(4):227 32
Cravello L, Farnarier J, De Montgolfier R, et al Hysteroscopic resection of fibroids: results with a 6-year follow-up period J Gynecol Surg 1999 15(1):1 5
Criqui MH, Suarez L, Barrett-Connor E, et al Postmenopausal estrogen use and mortality. Results from a prospective study in a defined, homogeneous community Am J Epidemiol 1988 128(3):606 14 3414664
Crosignani PG, Vercellini P, Apolone G, et al Endometrial resection versus vaginal hysterectomy for menorrhagia: long-term clinical and quality-of-life outcomes Am J Obstet Gynecol 1997 177(1):95 101 9240590
Crosignani PG, Vercellini P, Meschia M, et al GnRH agonists before surgery for uterine leiomyomas: A review J Reprod Med 1996 41(6):415 21 8799917
Crow J, Gardner RL, McSweeney G, et al Morphological changes in uterine leiomyomas treated by GnRH agonist goserelin Int J Gynecol Pathol 1995 14(3):235 42 8600075
Cruikshank SH, Kovac SR Randomized comparison of three surgical methods used at the time of vaginal hysterectomy to prevent posterior enterocele Am J Obstet Gynecol 1999 180(4):859 65 10203653
D'Addato F, Repinto A, Andreoli C Pre-surgical treatment of uterine myomas with LH-RH agonists Clin Exp Obstet Gynecol 1992 19(1):45 50 1535032
Daly JW, Higgins KA Injury to the ureter during gynecologic surgical procedures Surg Gynecol Obstet 1988 167(1):19 22 3381180
Daniell J Argon beam coagulator for laparoscopic myomectomy Gynaecol Endoscopy 1995 4(3):219 22
Daniell JF, Gurley LD Laparoscopic treatment of clinically significant symptomatic uterine fibroids J Gynecol Surg 1991 7(1):37 40
Darai E, Dechaud H, Benifla JL, et al Fertility after laparoscopic myomectomy: preliminary results Hum Reprod 1997 12(9):1931 4 9363709
Davies A Treatment with a gonadotrophin releasing hormone agonist before hysterectomy for leiomyomas: results of a multicentre, randomised controlled trial [letter] Br J Obstet Gynaecol 1999 106(7):751 2 10428541
Davies A, Hart R, Magos AL The excision of uterine fibroids by vaginal myomectomy: a prospective study Fertil Steril 1999 71(5):961 4 10231066
Davies A, O'Connor H, Magos AL A prospective study to evaluate oophorectomy at the time of vaginal hysterectomy Br J Obstet Gynaecol 1996 103(9):915 20 8813313
Davies A, Vizza E, Bournas N, et al How to increase the proportion of hysterectomies performed vaginally Am J Obstet Gynecol 1998 179(4):1008 12 9790389
Davis JL, Ray-Mazumder S, Hobel CJ, et al Uterine leiomyomas in pregnancy: a prospective study Obstet Gynecol 1990 75(1):41 4 2296420
Davis KM, Schlaff WD Medical management of uterine fibromyomata Obstet Gynecol Clin North Am 1995 22(4):727 38 8786878
Dawood MY Dysmenorrhea J Reprod Med 1985 30(3):154 67 3158737
de Aloysio D, Altieri P, Penacchioni P, et al Bleeding patterns in recent postmenopausal outpatients with uterine myomas: Comparison between two regimens of HRT Maturitas 1998 29(3):261 4 9699198
de Aloysio D, Altieri P, Pretolani G, et al The combined effect of a GnRH analog in premenopause plus postmenopausal estrogen deficiency for the treatment of uterine leiomyomas in perimenopausal women Gynecol Obstet Invest 1995 39(2):115 9 7737580
De Blok S, Dijkman AB, Hemrika DJ Transcervical resection of fibroids (TCRM): results related to hysteroscopic classification Gynaecol Endoscopy 1996 4(4):243 6
De Blok S, Wamsteker K Hysteroscopic surgery: possibilities, limitations and future Reprod Med Rev 1995 4(2):101 13
De Leo V, la Marca A, Morgante G Short-term treatment of uterine fibromyomas with danazol Gynecol Obstet Invest 1999 47(4):258 62 10352389
De Leo V, Morgante G, Lanzetta D, et al Danazol administration after gonadotrophin-releasing hormone analogue reduces rebound of uterine myomas [published erratum appears in Hum Reprod 1998 Mar; 13(3):780] Hum Reprod 1997 12(2):357 60 9070725
De Lia JE, Michelin DP, Johnson SC, et al Cherney versus midline vertical incision for myomectomy or hysterectomy of a significantly enlarged uterus Am J Obstet Gynecol 1995 173(6):1714 8 8610750
De Salvia D, Bertasi M, Fiscon D Myomas in pregnancy J Gynaecol Endocrinol 1988 4(1-4):42 4
de Souza NM, Brosens JJ, Schwieso JE, et al The potential value of magnetic resonance imaging in infertility Clin Radiol 1995 50(2):75 9 7867272
Dekel A, Farhi J, Levy T, et al Pre-operative ultrasonographic evaluation of nongravid, enlarged uteri -- Correlation with bimanual examination Eur J Obstet Gynecol Reprod Biol 1998 80(2):205 7 9846670
DeLancey JOL A modified technique for hemostasis during myomectomy Surg Gynecol Obstet 1992 174(2):153 4 1734575
Deligdisch L, Hirschmann S, Altchek A Pathologic changes in gonadotropin releasing hormone agonist analogue treated uterine leiomyomata Fertil Steril 1997 67(5):837 41 9130887
Demopoulos RI, Jones KY, Mittal KR, et al Histology of leiomyomata in patients treated with leuprolide acetate Int J Gynecol Pathol 1997 16(2):131 7 9100066
Deprest JA, Munro MG, Koninckx PR Review on laparoscopic hysterectomy Zentralbl Gynakol 1995 117(12):641 51 8585359
Dequesne J, Schmidt N Laser hysteroscopic treatment of uterine fibroids References En Gynecologie Obstetrique 1996 4(3):251 6
Derman SG, Rehnstrom J, Neuwirth RS The long-term effectiveness of hysteroscopic treatment of menorrhagia and leiomyomas Obstet Gynecol 1991 77(4):591 4 2002983
Dgani R, Piura B, Ben-Baruch G, et al Clinical-pathological study of uterine leiomyomas with high mitotic activity Acta Obstet Gynecol Scand 1998 77(1):74 7 9492723
Diamond MP, Bieber E, Coddington C, et al Reduction of adhesions after uterine myomectomy by Seprafilm membrane (HAL-F): A blinded, prospective, randomized, multicenter clinical study Fertil Steril 1996 66(6):904 10 8941053
Dicker D, Dekel A, Orvieto R, et al The controversy of laparoscopic myomectomy Hum Reprod 1996 11(5):935 7 8815068
Dicker D, Feldberg D, Dekel A, et al The management of prolapsed submucous fibroids Aust N Z J Obstet Gynaecol 1986 26(4):308 11 3470001
Dicker RC, Scally MJ, Greenspan JR, et al Hysterectomy among women of reproductive age. Trends in the United States, 1970-1978 JAMA 1982 248(3):323 7 7087126
Dickersin K, Scherer R, Lefebvre C Identifying relevant studies for systematic reviews. [Review] BMJ 1994 309(6964):1286 91 7718048
Dildy GA 3d, Moise KJ Jr, Smith LG Jr, et al Indomethacin for the treatment of symptomatic leiomyoma uteri during pregnancy Am J Perinatol 1992 9(3):185 9 1374254
Diokno AC, Brock BM, Herzog AR, et al Medical correlates of urinary incontinence in the elderly Urology 1990 36(2):129 38 2385880
Dodson MG Use of transvaginal ultrasound in diagnosing the etiology of menometrorrhagia J Reprod Med 1994 39(5):362 72 8064703
Donnez J, Gillerot S, Bourgonjon D, et al Neodymium: YAG laser hysteroscopy in large submucous fibroids Fertil Steril 1990 54(6):999 1003 2245860
Donnez J, Mathieu PE, Bassil S, et al Fibroids: management and treatment: the state of the art Hum Reprod 1996 11(9):1837 40 8921049
Donnez J, Nisolle M, Clerckx F, et al Advanced endoscopic techniques used in dysfunctional bleeding, fibroids and endometriosis, and the role of gonadotrophin-releasing hormone agonist treatment Br J Obstet Gynaecol 1994 101(Suppl 10):2 9 8199099
Donnez J, Nisolle M, Grandjean P, et al The place of GnRH agonists in the treatment of endometriosis and fibroids by advanced endoscopic techniques Br J Obstet Gynaecol 1992 99(Suppl 7):31 3 1532508
Donnez J, Polet R, Smets M, et al Hysteroscopic myomectomy Curr Opin Obstet Gynecol 1995 7(4):311 6 7578973
Donnez J, Schrurs B, Gillerot S, et al Treatment of uterine fibroids with implants of gonadotropin-releasing hormone agonist: assessment by hysterography Fertil Steril 1989 51(6):947 50 2498131
Dover RW, Powell MC Imaging leiomyomas prior to endoscopic surgery: the role of magnetic resonance imaging Gynaecol Endoscopy 1999 8(4):197 203
Downes KA, Hart WR Bizarre leiomyomas of the uterus: a comprehensive pathologic study of 24 cases with long-term follow-up Am J Surg Pathol 1997 21(11):1261 70 9351564
Dubinsky TJ, Parvey HR, Maklad N The role of transvaginal sonography and endometrial biopsy in the evaluation of peri- and postmenopausal bleeding Am J Roentgenol 1997 169(1):145 9 9207515
Dubuisson JB, Chapron C. Laparoscopic myomectomy. Operative procedure and results. Ann N Y Acad Sci. 1994;734:450-4. [pmid: 7978947].
Dubuisson JB, Chapron C Laparoscopic myomectomy and myolysis Baillieres Clin Obstet Gynaecol 1995 9(4):717 28 8821250
Dubuisson JB, Chapron C Laparoscopic myomectomy today. A good technique when correctly indicated Hum Reprod 1996 11(5):934 5 8815067
Dubuisson JB, Chapron C Uterine fibroids: place and modalities of laparoscopic treatment Eur J Obstet Gynecol Reprod Biol 1996 65(1):91 4 8706965
Dubuisson JB, Chapron C, Chavet X, et al Fertility after laparoscopic myomectomy of large intramural myomas: preliminary results Hum Reprod 1996 11(3):518 22 8671257
Dubuisson JB, Chapron C, Fauconnier A. Laparoscopic myomectomy: operative technique and results. Ann NY Acad Sci. 1997;828:326-31. [pmid: 9329853].
Dubuisson JB, Chapron C, Fauconnier A, et al Laparoscopic myomectomy and myolysis Curr Opin Obstet Gynecol 1997 9(4):233 8 9263713
Dubuisson JB, Chapron C, Levy L Difficulties and complications of laparoscopic myomectomy J Gynecol Surg 1996 12(3):159 65
Dubuisson JB, Fauconnier A, Chapron C, et al Second look after laparoscopic myomectomy Hum Reprod 1998 13(8):2102 6 9756277
Dubuisson JB, Lecuru F, Foulot H, et al Myomectomy by laparoscopy: a preliminary report of 43 cases Fertil Steril 1991 56(5):827 30 1834484
Dubuisson JB, Lecuru F, Foulot H, et al Gonadotrophin-releasing hormone agonist and laparoscopic myomectomy Clin Ther 1992 14(Suppl. A):51 6 1535022
Dudiak CM, Turner DA, Patel SK, et al Uterine leiomyomas in the infertile patient: preoperative localization with MR imaging versus US and hysterosalpingography Radiology 1988 167(3):627 30 3283833
Dueholm M, Forman A, Ingerslev J Regression of residual tissue after incomplete resection of submucous myomas Gynaecol Endoscopy 1998 7(6):309 14
Duleba AJ, Spaczynski RZ Laparoscopic myomectomy Infertil Reprod Med Clinics North Am 1997 8(3):399 415
Dunn TS, Stamm C, Delorit M, et al A key clinical pathway for the evaluation of women with abnormal uterine bleeding Obstet Gynecol 2000 95(4 Suppl 1):
Dwyer N, Hutton J, Stirrat GM Randomised controlled trial comparing endometrial resection with abdominal hysterectomy for the surgical treatment of menorrhagia Br J Obstet Gynaecol 1993 100(3):237 43 8476829
Ecker JL, Foster JT, Friedman AJ. Abdominal hysterectomy or abdominal myomectomy for symptomatic leiomyoma: a comparison of preoperative demography and postoperative morbidity. J Gynecol Surg. 1995;11:11-8.
Egwuatu VE Fertility and fetal salvage among women with uterine leiomyomas in a Nigerian Teaching Hospital Int J Fertil 1989 34(5):341 6 2571594
El Dosoky M, Dagestani M Laparoscopic assisted vaginal hysterectomy in obese women J Obstet Gynaecol 1997 17(2):186 7 15511818
Eldar-Geva T, Meagher S, Healy DL, et al Effect of intramural, subserosal, and submucosal uterine fibroids on the outcome of assisted reproductive technology treatment Fertil Steril 1998 70(4):687 91 9797099
Ellis PK, Kidney DD, Deutsch LS Uterine arterial embolization in the management of symptomatic leiomyomata J Intervent Radiol 1998 13(1):16 9
Emanuel MH, Wamsteker K, Hart AAM, et al Long-term results of hysteroscopic myomectomy for abnormal uterine bleeding Obstet Gynecol 1999 93(5):743 8 10912978
Emembolu JO Uterine fibromyomata: Presentation and management in northern Nigeria Int J Gynaecol Obstet 1987 25(5):413 6 2889637
Englund K, Blanck A, Gustavsson I, et al Sex steroid receptors in human myometrium and fibroids: changes during the menstrual cycle and gonadotropin-releasing hormone treatment J Clin Endocrinol Metab 1998 83(11):4092 6 9814497
Ettinger B, Genant HK, Cann CE Postmenopausal bone loss is prevented by treatment with low-dosage estrogen with calcium Ann Intern Med 1987 106(1):40 5 3789576
Everson SA, Matthews KA, Guzick DS, et al Effects of surgical menopause on psychological characteristics and lipid levels: the Healthy Women Study Health Psychol 1995 14(5):435 43 7498115
Exacoustos C, Rosati P Ultrasound diagnosis of uterine myomas and complications in pregnancy Obstet Gynecol 1993 82(1):97 101 8515934
Falsetti L, Mazzani MD, Rubessa S, et al Presurgical treatment of uterine fibroids by using gonadotropin-releasing hormone agonists Acta Eur Fertil 1992 23(1):29 32 1293897
Farghaly SA, Hindmarsh JR, Worth PH Post-hysterectomy urethral dysfunction: evaluation and management Br J Urol 1986 58(3):299 302 3719250
Farhi J, Ashkenazi J, Feldberg D, et al Effect of uterine leiomyomata on the results of in-vitro fertilization treatment Hum Reprod 1995 10(10):2576 8 8567773
Farmakides G, Stefanidis K, Paschopoulos M, et al Uterine artery Doppler velocimetry with leiomyomas Arch Gynecol Obstet 1998 262(1-2):53 7 9836000
Farquhar CM, Lethaby A, Sowter M, et al An evaluation of risk factors for endometrial hyperplasia in premenopausal women with abnormal menstrual bleeding Am J Obstet Gynecol 1999 181(3):525 9 10486458
Farquhar CM, Vandekerckhove P, Watson A, et al. Barrier agents for preventing adhesions after surgery for subfertility [systematic review]. Cochrane Database of Systematic Reviews. The Cochrane Library: Oxford, UK, 2000, Issue 1. 2000; (Update Software, online or CD-ROM, updated quarterly).
Fauconnier A, Dubuisson J-B, Ancel P-Y, et al Prognostic factors of reproductive outcome after myomectomy in infertile patients Hum Reprod 2000 15(8):1751 7 10920098
Febo G, Tessarolo M, Leo L, et al Surgical management of leiomyomata in pregnancy Clin Exp Obstet Gynecol 1997 24(2):76 8 9342467
Fedele L, Bianchi S, Baglioni A, et al Intranasal buserelin versus surgery in the treatment of uterine leiomyomata: long-term follow-up Eur J Obstet Gynecol Reprod Biol 1991 38(1):53 7 1899079
Fedele L, Bianchi S, Dorta M, et al Transvaginal ultrasonography versus hysteroscopy in the diagnosis of uterine submucous myomas Obstet Gynecol 1991 77(5):745 8 2014089
Fedele L, Bianchi S, Raffaelli R, et al A randomized study of the effects of tibolone and transdermal estrogen replacement therapy in postmenopausal women with uterine myomas Eur J Obstet Gynecol Reprod Biol 2000 88(1):91 4 10659924
Fedele L, Parazzini F, Luchini L, et al Recurrence of fibroids after myomectomy: a transvaginal ultrasonographic study Hum Reprod 1995 10(7):1795 6 8582982
Fedele L, Vercellini P, Bianchi S, et al Treatment with GnRH agonists before myomectomy and the risk of short-term myoma recurrence Br J Obstet Gynaecol 1990 97(5):393 6 2115379
Schoenberg Fejzo MS, Ashar HR, Krauter KS, et al Translocation breakpoints upstream of the HMGIC gene in uterine leiomyomata suggest dysregulation of this gene by a mechanism different from that in lipomas Genes Chromosomes Cancer 1996 17(1):1 6 8889500
Fejzo MS, Yoon SJ, Montgomery KT, et al Identification of a YAC spanning the translocation breakpoints in uterine leiomyomata, pulmonary chondroid hamartoma, and lipoma: physical mapping of the 12q14-q15 breakpoint region in uterine leiomyomata Genomics 1995 26(2):265 71 7601452
Felberbaum RE, Germer U, Ludwig M, et al Treatment of uterine fibroids with a slow-release formulation of the gonadotrophin releasing hormone antagonist Cetrorelix Hum Reprod 1998 13(6):1660 8 9688409
Felice R, Bianco V, Magro B, et al Pattern of uterine fibroid volume response to a GnRH agonist during treatment and in a 12 months follow-up Ital J Gynaecol Obstet 1993 5(4):165 70
Fenwick DK, Divers MJ Medical pregnancy termination in the presence of a massive uterine fibroid Br J Clin Pract 1995 49(6):332 3 8554964
Fernandez-Montoli ME, Diez-Gibert O, Samaniego JM, et al Total and unbound cytosolic estrogen and progesterone receptors in myometrium and fibroid after gonadotropin-releasing hormone agonist treatment Fertil Steril 1995 63(3):522 7 7851581
Fields KR, Neinstein LS Uterine myomas in adolescents: case reports and a review of the literature J Pediatr Adolesc Gynecol 1996 9(4):195 8 8957774
Finikiotis G Hysteroscopy in infertility Clin Reprod Fertil 1986 4(4):241 51 3779580
Fiscella K, Franks P, Gold MR, et al Inequality in quality: addressing socioeconomic, racial, and ethnic disparities in health care JAMA 2000 283(19):2579 84 10815125
Fletcher H, Frederick J, Hardie M, et al A randomized comparison of vasopressin and tourniquet as hemostatic agents during myomectomy Obstet Gynecol 1996 87(6):1014 8 8649682
Franklin R, Haney A, Kettel LM, et al An expanded polytetrafluoroethylene barrier (Gore-Tex surgical membrane) reduces post-myomectomy adhesion formation Fertil Steril 1995 63(3):491 3 7851575
Franssen AM, Willemsen WN, Corbey RS, et al Subcutaneous injection or infusion of gonadotropin releasing-hormone agonist buserelin in the treatment of enlarged uteri harboring leiomyomata Eur J Obstet Gynecol Reprod Biol 1991 40(3):221 8 1908799
Fraser IS, Pearse C, Shearman RP, et al Efficacy of mefenamic acid in patients with a complaint of menorrhagia Obstet Gynecol 1981 58(5):543 51 7029369
Frederick J, Fletcher H, Simeon D, et al Intramyometrial vasopressin as a haemostatic agent during myomectomy Br J Obstet Gynaecol 1994 101(5):435 7 8018617
Friedman AJ Treatment of leiomyomata uteri with short-term leuprolide followed by leuprolide plus estrogen-progestin hormone replacement therapy for 2 years: a pilot study Fertil Steril 1989 51(3):526 8 2537769
Friedman AJ Leuprolide depot before myomectomy Fertil Steril 1990 53(6):1109 10 2112497
Friedman AJ Treatment of uterine myomas with GnRH agonists Semin Reprod Endocrinol 1993 11(2):154 61
Friedman AJ Use of gonadotropin-releasing hormone agonists before myomectomy Clin Obstet Gynecol 1993 36(3):650 9 8403611
Friedman AJ Treatment of uterine leiomyomas with gonadotropin-releasing hormone agonists Endocrinologist 1995 5(1):61 7
Friedman AJ, Barbieri RL, Benacerraf BR, et al Treatment of leiomyomata with intranasal or subcutaneous leuprolide, a gonadotropin-releasing hormone agonist Fertil Steril 1987 48(4):560 4 3115833
Friedman AJ, Barbieri RL, Doubilet PM, et al A randomized, double-blind trial of a gonadotropin releasing-hormone agonist (leuprolide) with or without medroxyprogesterone acetate in the treatment of leiomyomata uteri Fertil Steril 1988 49(3):404 9 2963759
Friedman AJ, Daly M, Juneau-Norcross M, et al Recurrence of myomas after myomectomy in women pretreated with leuprolide acetate depot or placebo Fertil Steril 1992 58(1):205 8 1624009
Friedman AJ, Daly M, Juneau-Norcross M, et al A prospective, randomized trial of gonadotropin-releasing hormone agonist plus estrogen-progestin or progestin "add-back" regimens for women with leiomyomata uteri J Clin Endocrinol Metab 1993 76(6):1439 45 8501148
Friedman AJ, Daly M, Juneau-Norcross M, et al Long-term medical therapy for leiomyomata uteri: a prospective, randomized study of leuprolide acetate depot plus either oestrogen-progestin or progestin "add-back" for 2 years Hum Reprod 1994 9(9):1618 25 7836510
Friedman AJ, Haas ST Should uterine size be an indication for surgical intervention in women with myomas? Am J Obstet Gynecol 1993 168(31):751 5 8456874
Friedman AJ, Harrison-Atlas D, Barbieri RL, et al A randomized, placebo-controlled, double-blind study evaluating the efficacy of leuprolide acetate depot in the treatment of uterine leiomyomata Fertil Steril 1989 51(2):251 6 2492232
Friedman AJ, Harrison-Atlas D, Barbieri RL, et al Gonadotropin-releasing hormone analog treatment should not precede conservative myomectomy Fertil Steril 1990 53(1):188 9
Friedman AJ, Hoffman DI, Comite F, et al Treatment of leiomyomata uteri with leuprolide acetate depot: a double-blind, placebo-controlled, multicenter study. The Leuprolide Study Group Obstet Gynecol 1991 77(5):720 5 1901638
Friedman AJ, Lobel SM, Rein MS, et al Efficacy and safety considerations in women with uterine leiomyomas treated with gonadotropin-releasing hormone agonists: the estrogen threshold hypothesis Am J Obstet Gynecol 1990 163(4 Pt 1):1114 9 2145765
Friedman AJ, Rein MS, Harrison-Atlas D, et al A randomized, placebo-controlled, double-blind study evaluating leuprolide acetate depot treatment before myomectomy [published erratum appears in Fertil Steril 1990 Oct;54(4):749] Fertil Steril 1989 52(5):728 33 2509250
Friedman AJ, Rein MS, Pandian MR, et al Fasting serum growth hormone and insulin-like growth factor-I and -II concentrations in women with leiomyomata uteri treated with leuprolide acetate or placebo Fertil Steril 1990 53(2):250 3 2105242
Friedman AJ, Thomas PP Does low-dose combination oral contraceptive use affect uterine size or menstrual flow in premenopausal women with leiomyomas? Obstet Gynecol 1995 85(4):631 5 7898846
Fruchter O, Friedman AJ, Haas ST Uterine size as indication for early hysterectomy Am J Obstet Gynecol 1994 170(11):258 69
Garcia CR Management of the symptomatic fibroid in women older than 40 years of age: Hysterectomy or myomectomy? Obstet Gynecol Clin North Am 1993 20(2):337 48 8367136
Garcia CR, Tureck RW Submucosal leiomyomas and infertility Fertil Steril 1984 42(1):16 9 6724011
Garnet JD. Uterine rupture during pregnancy. Obstet Gynecol. 1964;23:898-905. [pmid: 14170210].
Gath D, Cooper P Psychiatric disorder after hysterectomy J Psychosom Res 1981 25(5):347 55 7328503
Gath D, Cooper P, Day A. Hysterectomy and psychiatric disorder: I. Levels of psychiatric morbidity before and after hysterectomy. Br J Psychiatry. 1982;140:335-42. [pmid: 7093609].
Gatti D, Falsetti L, Viani A, et al Uterine fibromyoma and sterility: role of myomectomy Acta Eur Fertil 1989 20(1):11 3 2781982
Gaucherand P, Piacenza JM, Salle B, et al Sonohysterography of the uterine cavity: Preliminary investigations J Clin Ultrasound 1995 23(6):339 48 7673449
Gehlbach DL, Sousa RC, Carpenter SE, et al Abdominal myomectomy in the treatment of infertility Int J Gynecol Obstet 1993 40(1):45 50
Gerris J, Degueldre M, Peters AA, et al The place of Zoladex in deferred surgery for uterine fibroids. Zoladex Myoma Study Group Horm Res 1996 45(6):279 84 8793522
Giatras K, Berkeley AS, Noyes N, et al Fertility after hysteroscopic resection of submucous myomas J Am Assoc Gynecol Laparosc 1999 6(2):155 8 10226124
Ginsburg ES, Benson CB, Garfield JM, et al The effect of operative technique and uterine size on blood loss during myomectomy: a prospective randomized study Fertil Steril 1993 60(6):956 62 8243699
Gitsch G, Berger E, Tatra G Trends in thirty years of vaginal hysterectomy Surg Gynecol Obstet 1991 172(3):207 10 1994496
Glavind K, Palvio DHB, Lauritsen JG Uterine myoma in pregnancy Acta Obstet Gynecol Scand 1990 69(7-8):617 9 2094144
Gleeson NC, Onwude JL Uterine leiomyoma causing retained placenta Br J Clin Pract 1990 44(12):689 90 2102195
Gleich P Transcervical resection of uterine myomas with a resectoscope Urol Clin North Am 1990 17(1):59 62 2305522
Golan A GnRH analogues in the treatment of uterine fibroids Hum Reprod 1996 11(Suppl 3):33 41 9147100
Golan A, Aharoni A, Gonen R, et al Early spontaneous rupture of the post-myomectomy gravid uterus Int J Gynaecol Obstet 1990 31(2):167 70 1968865
Golan A, Bukovsky I, Pansky M, et al Pre-operative gonadotrophin-releasing hormone agonist treatment in surgery for uterine leiomyomata Hum Reprod 1993 8(3):450 2 8473466
Golan A, Bukovsky I, Schneider D, et al D-Trp-6-luteinizing hormone-releasing hormone microcapsules in the treatment of uterine leiomyomas Fertil Steril 1989 52(3):406 11 2528476
Goldfarb HA A review of 35 endometrial ablations using the Nd:YAG laser for recurrent menometrorrhagia Obstet Gynecol 1990 76(5 Pt 1):833 5 2120643
Goldfarb HA Bipolar laparoscopic needles for myoma coagulation J Am Assoc Gynecol Laparosc 1995 2(2):175 9 9050553
Goldfarb HA Laparoscopic coagulation of myoma (myolysis) Obstet Gynecol Clin North Am 1995 22(4):807 19 8786884
Goldfarb HA Laparoscopic coagulation of myoma (myolysis) Infertil Reprod Med Clinics North Am 1996 7(1):129 41
Goldstein SR Use of ultrasonohysterography for triage of perimenopausal patients with unexplained uterine bleeding Am J Obstet Gynecol 1994 170(2):565 70 8116714
Gomel V, Taylor PJ Laparoscopic myomectomy and tubal reconstructive surgery in the infertile patient Baillieres Clin Obstet Gynaecol 1994 8(4):773 88 7882625
Goodkin K, Antoni MH, Blaney PH Stress and hopelessness in the promotion of cervical intraepithelial neoplasia to invasive squamous cell carcinoma of the cervix [published erratum appears in J Psychosom Res 1987;31(5):659] J Psychosom Res 1986 30(1):67 76 3701669
Goodwin SC, Chen G Uterine artery embolization for uterine fibroids Contemp Rev Obstet Gynaecol 1998 10(3):217 21
Goodwin SC, McLucas B, Lee M, et al Uterine artery embolization for the treatment of uterine leiomyomata midterm results J Vasc Interv Radiol 1999 10(9):1159 65 10527191
Goodwin SC, Walker WJ Uterine artery embolization for the treatment of uterine fibroids Curr Opin Obstet Gynecol 1998 10(4):315 20 9719883
Gordon SJ, Westgate J The incidence and management of failed Pipelle sampling in a general outpatient clinic Aust N Z J Obstet Gynaecol 1999 39(1):115 8 10099766
Gordon T, Kannel WB, Hjortland MC, et al Menopause and coronary heart disease. The Framingham Study Ann Intern Med 1978 89(2):157 61 677576
Gorodeski IG, Bahary CM, Beery R, et al Decreased induced retention of the progesterone receptor in the nuclear extract in human uterine leiomyoma in vivo Gynecol Obstet Invest 1987 23(4):241 6 3609907
Grau E, Torrecilla T, Real E, et al Leukopenia induced by leuprolide acetate depot Ann Pharmacother 1994 28(2):283 4 8173155
Greenberg MD, Kazamel TIG Medical and socioeconomic impact of uterine fibroids Obstet Gynecol Clin North Am 1995 22(4):625 36 8786874
Greenwood SM The relation of adenomyosis uteri to coexistent endometrial carcinoma and endometrial hyperplasia Obstet Gynecol 1976 48(1):68 72 934577
Gregoriou O, Vitoratos N, Papadias C, et al Effect of tibolone on postmenopausal woman with myomas Maturitas 1997 27(2):187 91 9255754
Griffith-Jones MD, Jarvis GJ, McNamara HM Adverse urinary symptoms after total abdominal hysterectomy -- fact or fiction? Br J Urol 1991 67(3):295 7 2021819
Grignon DJ, Carey MR, Kirk ME, et al Diffuse uterine leiomyomatosis: a case study with pregnancy complicated by intrapartum hemorrhage Obstet Gynecol 1987 69(3 Pt 2):477 80 3492695
Gronlund L, Hertz J, Helm P, et al Transvaginal sonohysterography and hysteroscopy in the evaluation of female infertility, habitual abortion or metrorrhagia. A comparative study Acta Obstet Gynecol Scand 1999 78(5):415 8 10326887
Gross CP, Nicholson W, Powe NR Factors affecting prophylactic oophorectomy in postmenopausal women Obstet Gynecol 1999 94(6):962 8 10576183
Grover SR, Quinn MA Is there any value in bimanual pelvic examination as a screening test Med J Austr 1995 162(8):408 10
Guillaume AJ, Benjamin F, Spitzer M Myomectomy performed concurrently with tuboplasty J Reprod Med 1998 43(6):483 6 9653693
Gutmann JN, Thornton KL, Diamond MP, et al Evaluation of leuprolide acetate treatment on histopathology of uterine myomata Fertil Steril 1994 61(4):622 6 8150102
Haas S, Spies JB Toward optimal health: The experts respond to fibroids J Womens Health Gender Med 1999 8(7):879 83
Hackenberg R, Gesenhues T, Deichert U, et al The response of uterine fibroids to GnRH-agonist treatment can be predicted in most cases after one month Eur J Obstet Gynecol Reprod Biol 1992 45(2):125 9 1386817
Halila H, Suikkari AM, Seppala M The effect of hysterectomy on serum CA 125 levels in patients with adenomyosis and uterine fibroids Hum Reprod 1987 2(3):265 6 3474239
Hallez JP Single-stage total hysteroscopic myomectomies: indications, techniques, and results Fertil Steril 1995 63(4):703 8 7890051
Hallez JP Myomectomies by endo-uterine resection Curr Opin Obstet Gynecol 1996 8(4):250 8 8875035
Hallez JP, Netter A, Cartier R Methodical intrauterine resection Am J Obstet Gynecol 1987 156(5):1080 4 3578415
Hamasaki K, Doi Y, Sakamoto Y, et al The contraction of small arteries in the perimetrium by presurgical medication with the luteinizing hormone-releasing hormone agonist to patients with leiomyomas: An electron and immunoelectron microscopy Fukuoka Igaku Zasshi 1995 86(10):389 97 8529993
Han GS Assessing the role of laparoscopically assisted vaginal hysterectomy in the everyday practice of gynecology J Reprod Med 1996 41(7):521 8 8829066
Han ML, Wang YF, Tang MY, et al. Gossypol in the treatment of endometriosis and uterine myoma. Contrib Gynecol Obstet. 1987;16:268-70. [pmid: 3121251].
Haney AF Removal of surgical barriers of expanded polytetrafluoroethylene at second-look laparoscopy was not associated with adhesion formation Fertil Steril 1997 68(4):721 3 9341618
Harkki-Siren P, Sjoberg J Evaluation and the learning curve of the first one hundred laparoscopic hysterectomies Acta Obstet Gynecol Scand 1995 74(8):638 41 7660772
Harkki-Siren P, Sjoberg J, Makinen J, et al Finnish national register of laparoscopic hysterectomies: a review and complications of 1165 operations Am J Obstet Gynecol 1997 176(1 Pt 1):118 22 9024101
Harkki-Siren P, Sjoberg J, Tiitinen A Urinary tract injuries after hysterectomy Obstet Gynecol 1998 92(1):113 8 9649105
Harmon JW, Tang DG, Gordon TA, et al Hospital volume can serve as a surrogate for surgeon volume for achieving excellent outcomes in colorectal resection Ann Surg 1999 230(3):404 11 discussion 411-3 10493487 1420885
Harris WJ Uterine dehiscence following laparoscopic myomectomy Obstet Gynecol 1992 80(3 Pt 2):545 6 1386666
Harrison-Woolrych ML, Charnock-Jones DS, Smith SK Quantification of messenger ribonucleic acid for epidermal growth factor in human myometrium and leiomyomata using reverse transcriptase polymerase chain reaction J Clin Endocrinol Metab 1994 78(5):1179 84 8175976
Hart R, Molnar BG, Magos A Long term follow up of hysteroscopic myomectomy assessed by survival analysis Br J Obstet Gynaecol 1999 106(7):700 5 10428527
Hasan F, Arumugam K, Sivanesaratnam V Uterine leiomyomata in pregnancy Int J Gynaecol Obstet 1991 34(1):45 8 1671020
Hasson HM Cervical removal at hysterectomy for benign disease. Risks and benefits J Reprod Med 1993 38(10):781 90 8263867
Hasson HM Laparoscopic myomectomy Infertil Reprod Med Clinics North Am 1996 7(1):143 59
Hasson HM The role of laparoscopy in myomectomy Int J Fertil Menopausal Stud 1996 41(3):276 9 8799755
Hasson HM, Rotman C, Rana N, et al Laparoscopic myomectomy Obstet Gynecol 1992 80(5):884 8 1407934
Heaton KW, Parker D, Cripps H Bowel function and irritable bowel symptoms after hysterectomy and cholecystectomy -- a population based study Gut 1993 34(8):1108 11 8174964 1374364
Heffernan LP, Fraser RC, Purdy RA L-5 radiculopathy secondary to a uterine leiomyoma in a primigravid patient Am J Obstet Gynecol 1980 138(4):460 1 7425005
Helstrom L, Lundberg PO, Sorbom D, et al Sexuality after hysterectomy: a factor analysis of women's sexual lives before and after subtotal hysterectomy Obstet Gynecol 1993 81(3):357 62 8437786
Helstrom L, Sorbom D, Backstrom T Influence of partner relationship on sexuality after subtotal hysterectomy Acta Obstet Gynecol Scand 1995 74(2):142 6 7900511
Helstrom L, Weiner E, Sorbom D, et al Predictive value of psychiatric history, genital pain and menstrual symptoms for sexuality after hysterectomy Acta Obstet Gynecol Scand 1994 73(7):575 80 8079610
Higashijima T, Kataoka A, Nishida T, et al Gonadotropin-releasing hormone agonist therapy induces apoptosis in uterine leiomyoma Eur J Obstet Gynecol Reprod Biol 1996 68(1-2):169 73 8886702
Hillis SD, Marchbanks PA, Peterson HB Uterine size and risk of complications among women undergoing abdominal hysterectomy for leiomyomas Obstet Gynecol 1996 87(4):539 43 8602305
Ho V Evolution of the volume-outcome relation for hospitals performing coronary angioplasty Circulation 2000 101(15):1806 11 10769281
Hoffman MS, DeCesare S, Kalter C Abdominal hysterectomy versus transvaginal morcellation for the removal of enlarged uteri Am J Obstet Gynecol 1994 171(2):309 15 8059807
Hording U, Pedersen KH, Sidenius K, et al Urinary incontinence in 45-year-old women. An epidemiological survey Scand J Urol Nephrol 1986 20(3):183 6 3787195
Hreshchyshyn MM, Hopkins A, Zylstra S, et al Effects of natural menopause, hysterectomy, and oophorectomy on lumbar spine and femoral neck bone densities Obstet Gynecol 1988 72(4):631 8 3419740
Huang RT, Chou CY, Chang CH, et al Differentiation between adenomyoma and leiomyoma with transvaginal ultrasonography Ultrasound Obstet Gynecol 1995 5(1):47 50 7850590
Huang SC, Chou CY, Lin YS, et al Enhanced deoxyribonucleic acid damage and repair but unchanged apoptosis in uterine leiomyomas treated with gonadotropin-releasing hormone agonist Am J Obstet Gynecol 1997 177(2):417 24 9290461
Huang SC, Yu CH, Huang RT, et al Intratumoral blood flow in uterine myoma correlated with a lower tumor size and volume, but not correlated with cell proliferation or angiogenesis Obstet Gynecol 1996 87(6):1019 24 8649683
Hulley S, Grady D, Bush T, et al Randomized trial of estrogen plus progestin for secondary prevention of coronary heart disease in postmenopausal women. Heart and Estrogen/progestin Replacement Study (HERS) Research Group JAMA 1998 280(7):605 13 9718051
Hutchins FL Jr Myomectomy after selective preoperative treatment with a gonadotropin releasing hormone analog J Reprod Med 1992 37(8):699 702 1432986
Hutchins FL Jr Abdominal myomectomy as a treatment for symptomatic uterine fibroids Obstet Gynecol Clin North Am 1995 22(4):781 9 8786881
Hutchins FL Jr Uterine fibroids: Diagnosis and indications for treatment Obstet Gynecol Clin North Am 1995 22(4):659 65 8786876
Hutchins FL Jr A randomized comparison of vasopressin and tourniquet as hemostatic agents during myomectomy [letter] Obstet Gynecol 1996 88(4 Pt 1):639 40 8841235
Hutchins FL Jr, Worthington-Kirsch R, Berkowitz RP Selective uterine artery embolization as primary treatment for symptomatic leiomyomata uteri J Am Assoc Gynecol Laparosc 1999 6(3):279 84 10459027
Igarashi M, Paulson RJ, Verkauf BS Value of myomectomy in the treatment of infertility Fertil Steril 1993 59(6):1331 3 8495789
Ikpeze OC, Nwosu OB Features of uterine fibroids treated by abdominal myomectomy at Nnewi, Nigeria J Obstet Gynaecol 1998 18(6):569 71 15512182
Indman PD Hysteroscopic treatment of menorrhagia associated with uterine leiomyomas Obstet Gynecol 1993 81(51):716 20 8469459
Iosif CS, Bekassy Z, Rydhstrom H Prevalence of urinary incontinence in middle-aged women Int J Gynaecol Obstet 1988 26(2):255 9 2898402
Istre O Transcervical resection of endometrium and fibroids: the outcome of 412 operations performed over 5 years Acta Obstet Gynecol Scand 1996 75(6):567 74 8693935
Itzkowic D Submucous fibroids: Clinical profile and hysteroscopic management Aust N Z J Obstet Gynaecol 1993 33(1):63 7 8498943
Iverson RE Jr, Chelmow D, Strohbehn K, et al Relative morbidity of abdominal hysterectomy and myomectomy for management of uterine leiomyomas Obstet Gynecol 1996 88(3):415 9 8752251
Iverson RE Jr, Chelmow D, Strohbehn K, et al Myomectomy fever: testing the dogma Fertil Steril 1999 72(1):104 8 10428156
Iyer V, Farquhar C, Jepson R. Oral contraceptive pills for heavy menstrual bleeding [systematic review]. Cochrane Database of Systematic Reviews. The Cochrane Library: Oxford, UK. 2000, Issue 1. 2000;(Update Software, online or CD-ROM, updated quarterly).
Jequier AM Urinary symptoms and total hysterectomy Br J Urol 1976 48(6):437 41 1009326
Johansson BW, Kaij L, Kullander S, et al On some late effects of bilateral oophorectomy in the age range 15-30 years Acta Obstet Gynecol Scand 1975 54(5):449 61 1202905
Jourdain O, Descamps P, Abusada N, et al Treatment of fibromas Eur J Obstet Gynecol Reprod Biol 1996 66(2):99 107 8735729
Jourdain O, Joyeux P, Lajus C, et al Endometrial Nd-YAG laser ablation by hysterofibroscopy: long-term results of 137 cases Eur J Obstet Gynecol Reprod Biol 1996 69(2):103 7 8902441
Juni P, Witschi A, Bloch R, et al The hazards of scoring the quality of clinical trials for meta-analysis JAMA 1999 282(11):1054 60 10493204
Kadar N Extraperitoneal laparoscopic hyoterectomy for the large uterus Gynaecol Endoscopy 1996 5(5):271 6
Kaiser R, Kusche M, Wurz H Hormone levels in women after hysterectomy Arch Gynecol Obstet 1989 244(3):169 73 2500073
Kalir T, Goldstein M, Dottino P, et al Morphometric and electron-microscopic analyses of the effects of gonadotropin-releasing hormone agonists on uterine leiomyomas Arch Pathol Lab Med 1998 122(5):442 6 9593346
Kaminski BT, Rzempoluch J, Wiczkowski A, et al Some parameters of lipid metabolism in women 6 years after surgery on account of uterine leiomyoma Ceska Gynekol 1994 59(5):247 50 7804565
Karlsson B, Granberg S, Hellberg P, et al Comparative study of transvaginal sonography and hysteroscopy for the detection of pathologic endometrial lesions in women with postmenopausal bleeding J Ultrasound Med 1994 13(10):757 62 7823337
Katz VL, Dotters DJ, Droegemeuller W Complications of uterine leiomyomas in pregnancy Obstet Gynecol 1989 73(4):593 6 2927854
Kawaguchi K, Fujii S, Konishi I, et al Immunohistochemical analysis of oestrogen receptors, progesterone receptors and Ki-67 in leiomyoma and myometrium during the menstrual cycle and pregnancy Virchows Archiv 1991 419(4):309 15 1949613
Kawamura N, Ito F, Ichimura T, et al Correlation between shrinkage of uterine leiomyoma treated with buserelin acetate and histopathologic findings of biopsy specimen before treatment Fertil Steril 1997 68(4):632 6 9341601
Keckstein J, Sasse V, Roth A, et al Laser techniques in gynaecology Endosc Surg Allied Technol 1994 2(3-4):176 80 8000881
Kettel LM Clinical applications of the antiprogestins Clin Obstet Gynecol 1995 38(4):921 34 8616987
Kettel LM, Murphy AA, Morales AJ, et al Rapid regression of uterine leiomyomas in response to daily administration of gonadotropin-releasing hormone antagonist Fertil Steril 1993 60(4):642 6 8405517
Kettel LM, Murphy AA, Morales AJ, et al Clinical efficacy of the antiprogesterone RU486 in the treatment of endometriosis and uterine fibroids Hum Reprod 1994 9(Suppl 1):116 20 7962456
Khurana KK, Singh SB, Tatum AH, et al Maintenance of increased Bcl-2 expression in uterine leiomyomas after GnRH agonist therapy J Reprod Med 1999 44(6):487 92 10394541
Kiesel L, Schweppe KW, Sillem M, et al Should add-back therapy for endometriosis be deferred for optimal results? Br J Obstet Gynaecol 1996 103(Suppl 14):15 7 8916982
Kilkku P Supravaginal uterine amputation vs. hysterectomy. Effects on coital frequency and dyspareunia Acta Obstet Gynecol Scand 1983 62(2):141 5 6868962
Kilkku P Supravaginal uterine amputation versus hysterectomy with reference to subjective bladder symptoms and incontinence Acta Obstet Gynecol Scand 1985 64(5):375 9 4061057
Kilkku P, Gronroos M, Hirvonen T, et al Supravaginal uterine amputation vs. hysterectomy. Effects on libido and orgasm Acta Obstet Gynecol Scand 1983 62(2):147 52 6868963
Kilkku P, Hirvonen T, Gronroos M Supra-vaginal uterine amputation vs. abdominal hysterectomy: the effects on urinary symptoms with special reference to pollakisuria, nocturia and dysuria Maturitas 1981 3(3-4):197 204 7334931
Kiltz RJ, Rutgers J, Phillips J, et al Absence of a dose-response effect of leuprolide acetate on leiomyomata uteri size Fertil Steril 1994 61(6):1021 6 8194611
Kim AH, Keltz MD, Arici A, et al Dilutional hyponatremia during hysteroscopic myomectomy with sorbitol-mannitol distention medium J Am Assoc Gynecol Laparosc 1995 2(2):237 42 9050566
Kivnick S, Kanter MH Bowel injury from rollerball ablation of the endometrium Obstet Gynecol 1992 79(5 Pt 2):833 5 1565382
Kjerulff KH, Guzinski GM, Langenberg PW, et al Hysterectomy and race Obstet Gynecol 1993 82(5):757 64 8414322
Kjerulff KH, Langenberg PW, Rhodes JC, et al Effectiveness of hysterectomy Obstet Gynecol 2000 95(3):319 26 10711536
Kjerulff KH, Langenberg PW, Seidman JD, et al Uterine leiomyomas: Racial differences in severity, symptoms and age at diagnosis J Reprod Med 1996 41(7):483 90 8829060
Kliewer MA, Hertzberg BS, George PY, et al Acoustic shadowing from uterine leiomyomas: sonographic-pathologic correlation Radiology 1995 196(1):99 102 7784598
Klitsch M Hysterectomy, nonsurgical management both lessen fibroids, pain and bleeding Family Plann Perspectiv 1994 26(4):190 1
Klotzbucher M, Wasserfall A, Fuhrmann U Misexpression of wild-type and truncated isoforms of the high-mobility group I proteins HMGI-C and HMGI(Y) in uterine leiomyomas Am J Pathol 1999 155(5):1535 42 10550310 1866973
Koide SS Mifepristone. Auxiliary therapeutic use in cancer and related disorders J Reprod Med 1998 43(7):551 60 9693404
Koong DK, McKenna KM Is the fibroid a uterus? Aust N Z J Obstet Gynaecol 1995 35(3):332 4 8546659
Kovac SR Hysterectomy outcomes in patients with similar indications Obstet Gynecol 2000 95(6):787 93 10831967
Kuhlmann M, Gartner A, Schindler EM, et al Uterine leiomyomata and sterility: therapy with gonadotropin-releasing hormone agonists and leiomyomectomy Gynecol Endocrinol 1997 11(3):169 74 9209897
Kuhn R, Mitchell P Embolic occlusion of the blood supply to uterine myomas: Report of 2 cases Aust N Z J Obstet Gynaecol 1999 39(1):120 2 10099768
Kukuvitis A, Bildiris J, Prapas Y, et al Effect of treatment with GnRH agonists on new markers of bone metabolism Gynecol Obstet Invest 1999 47(3):194 6 10087416
La Torre R, Scarpellini F, Fusaro P, et al Transvaginal ultrasonographic diagnosis of adenomyosis in female patients suffering from uterine fibromatosis Clin Exp Obstet Gynecol 1996 23(4):195 7 9001778
La Vecchia C, Franceschi S Oral contraceptives and ovarian cancer Eur J Cancer Prev 1999 8(4):297 304 10493304
Lakhani KP, Marsh MS, Purcell W, et al Uterine artery blood flow parameters in women with dysfunctional uterine bleeding and uterine fibroids: the effects of tranexamic acid Ultrasound Obstet Gynecol 1998 11(4):283 5 9618854
Lalos O, Bjerle P Bladder wall mechanics and micturition before and after subtotal and total hysterectomy Eur J Obstet Gynecol Reprod Biol 1986 21(3):143 50 3956833
Lambden MP, Bellamy G, Ogburn-Russell L, et al Women's sense of well-being before and after hysterectomy J Obstet Gynecol Neonatal Nurs 1997 26(5):540 8
Lamminen S, Pyykko K, Rorarius M, et al Cytochrome P450IA1 activity in human myometrium and uterine leiomyoma: Influence of smoking Toxicology 1993 83(1-3):41 8 8248949
LaMorte AI, Lalwani S, Diamond MP Morbidity associated with abdominal myomectomy Obstet Gynecol 1993 82(6):897 900 8233261
Lamping DL, Rowe P, Clarke A, et al Development and validation of the Menorrhagia Outcomes Questionnaire Br J Obstet Gynaecol 1998 105(7):766 79 9692419
Langer R, Golan A, Neuman M, et al The effect of large uterine fibroids on urinary bladder function and symptoms Am J Obstet Gynecol 1990 163(4 Pt 1):1139 41 2145766
Langer R, Neuman M, Ron-el R, et al The effect of total abdominal hysterectomy on bladder function in asymptomatic women Obstet Gynecol 1989 74(2):205 7 2748057
Lanouette JM, Diamond MP Pregnancy in women with myoma uteri Infertil Reprod Med Clinics North Am 1996 7(1):19 32
Laughead MK, Stones LM Clinical utility of saline solution infusion sonohysterography in a primary care obstetric-gynecologic practice Am J Obstet Gynecol 1997 176(6):1313 6 discussion 1316-8 9215190
Law P, Gedroyc WMW, Regan L Magnetic-resonance-guided percutaneous laser ablation of uterine fibroids Lancet 1999 354(9195):2049 50 10636374
Lee BS, Stewart EA, Sahakian M, et al Interferon-alpha is a potent inhibitor of basic fibroblast growth factor-stimulated cell proliferation in human uterine cells Am J Reprod Immunol 1998 40(1):19 25 9689356
Lee CL, Soong YK Laparoscopic hysterectomy: is dissecting the ureter necessary? Int Surg 1995 80(2):167 9 8530236
Lee WY, Tzeng CC, Chou CY Uterine leiomyosarcomas coexistent with cellular and atypical leiomyomata in a young woman during the treatment with luteinizing hormone-releasing hormone agonist Gynecol Oncol 1994 52(1):74 9 8307505
Leibsohn S, d'Ablaing G, Mishell DR Jr, et al Leiomyosarcoma in a series of hysterectomies performed for presumed uterine leiomyomas Am J Obstet Gynecol 1990 162(4):968 74 discussion 974-6 2327466
Lemay A, Maheux R GnRH agonists in the management of uterine leiomyoma Infertil Reprod Med Clinics North Am 1996 7(1):33 55
Leone M, Cucuccio S, Venturini PL, et al Immunohistochemical localization of epidermal growth factor receptor in leiomyomas from women treated with goserelin depot Horm Metab Res 1991 23(9):442 5 1835956
Lepine LA, Hillis SD, Marchbanks PA, et al Hysterectomy surveillance -- United States, 1980-1993 MMWR 1997 46(4):1 15
Lethaby A, Augood C, Duckitt K. Nonsteroidal anti-inflammatory drugs for heavy menstrual bleeding. [systematic review]. Cochrane Database of Systematic Reviews. The Cochrane Library: Oxford, UK. 2000, Issue 1. 2000;(Update Software, online or CD-ROM, updated quarterly).
Lethaby A, Irvine G, Cameron I. Cyclical progestogens for heavy menstrual bleeding [systematic review]. Cochrane Database of Systematic Reviews. The Cochrane Library: Oxford, UK. 2000, Issue 1. 2000;(Update Software, online or CD-ROM, updated quarterly).
Lethaby A, Vollenhoven B, Sowter M. Pre-operative gonadotropin-releasing hormone analogue before hysterectomy or myomectomy for uterine fibroids. The Cochrane Library: Oxford, UK. 1999, Issue 3. 1999 (Update Software, Online or CD-ROM, Updated Quarterly).
Letterie GS, Coddington CC, Winkel CA, et al Efficacy of a gonadotropin-releasing hormone agonist in the treatment of uterine leiomyomata: long-term follow-up Fertil Steril 1989 51(6):951 6 2498132
LevGur M The enlarged uterus. Relation of uterine size to symptoms and histopathologic findings J Reprod Med 1996 41(3):166 70 8778414
Levine RL, Reich H Advances in gynecologic laparoscopic procedures World J Surg 1993 17(1):63 9 8447142
Lev-Toaff AS, Coleman BG, Arger PH, et al Leiomyomas in pregnancy: sonographic study Radiology 1987 164(2):375 80 3299488
Lev-Toaff AS, Karasick S, Toaff ME Hysterosalpingography before and after myomectomy: Clinical value and imaging findings Am J Roentgenol 1993 160(4):803 7 8456668
Li TC, Mortimer R, Cooke ID Myomectomy: a retrospective study to examine reproductive performance before and after surgery Hum Reprod 1999 14(7):1735 40 10402378
Lin BL, Iwata Y, Liu KH Removing a large submucous fibroid hysteroscopically with the two-resectoscope method J Am Assoc Gynecol Laparosc 1994 1(3):259 63 9050497
Lindegard B Breast cancer among women from Gothenburg with regard to age, mortality and coexisting benign breast disease or leiomyoma uteri Oncology 1990 47(5):369 75 2216291
Lindsay PC, Shaw RW, Bennink HJ, et al The effect of add-back treatment with tibolone (Livial) on patients treated with the gonadotropin-releasing hormone agonist triptorelin (Decapeptyl) Fertil Steril 1996 65(2):342 8 8566259
Lindsay R, Hart DM, Clark DM The minimum effective dose of estrogen for prevention of postmenopausal bone loss Obstet Gynecol 1984 63(6):759 63 6374537
Liu CH, Lin YS, Lin CC, et al Medical treatment of uterine myoma with long-acting gonadotropin-releasing hormone agonist prior to myomectomy J Formosan Med Assoc 1993 92(6):536 9 8106041
Loffer FD Hysteroscopy with selective endometrial sampling compared with D&C for abnormal uterine bleeding: the value of a negative hysteroscopic view Obstet Gynecol 1989 73(1):16 20 2909040
Loffer FD Removal of large symptomatic intrauterine growths by the hysteroscopic resectoscope Obstet Gynecol 1990 76(5 Pt 1):836 40 2216235
Lomano J Endometrial ablation for the treatment of menorrhagia: a comparison of patients with normal, enlarged, and fibroid uteri Lasers Surg Med 1991 11(1):8 12 1825511
Loverro G, Nicolardi V, Selvaggi L Depot GnRH analog treatment of uterine fibroids Int J Gynecol Obstet 1993 43(2):199 201
Lumbiganon P, Rugpao S, Phandhu-fung S, et al Protective effect of depot-medroxyprogesterone acetate on surgically treated uterine leiomyomas: a multicentre case -- control study Br J Obstet Gynaecol 1996 103(9):909 14 8813312
Lumsden MA, Wallace EM Clinical presentation of uterine fibroids Baillieres Clin Obstet Gynaecol 1998 12(2):177 95 10023417
Lumsden MA, West CP, Hawkins RA, et al The binding of steroids to myometrium and leiomyomata (fibroids) in women treated with the gonadotrophin-releasing hormone agonist Zoladex (ICI 118630) J Endocrinol 1989 121(2):389 96 2526844
Lumsden MA, West CP, Thomas E, et al Treatment with the gonadotrophin releasing hormone-agonist goserelin before hysterectomy for uterine fibroids Br J Obstet Gynaecol 1994 101(5):438 42 8018618
Magos AL, Bournas N, Sinha R, et al Vaginal myomectomy Br J Obstet Gynaecol 1994 101(12):1092 4 7826970
Magos AL, Bournas N, Sinha R, et al Vaginal hysterectomy for the large uterus Br J Obstet Gynaecol 1996 103(3):246 51 8630309
Maheux R Treatment of uterine leiomyomata: Past, present and future Horm Res 1989 32(Suppl. 1):125 33 2693323
Maheux R GnRH agonists: an alternative to surgery? Hum Reprod 1996 11(Suppl 3):43 50 9147101
Maheux R, Lemay A Treatment of peri-menopausal women: potential long-term therapy with a depot GnRH agonist combined with hormonal replacement therapy Br J Obstet Gynaecol 1992 99(Suppl 7):13 7
Maheux R, Lemay A, Blanchet P, et al Maintained reduction of uterine leiomyoma following addition of hormonal replacement therapy to a monthly luteinizing hormone-releasing hormone agonist implant: a pilot study Hum Reprod 1991 6(4):500 5 1655823
Mais V, Ajossa S, Guerriero S, et al Laparoscopic versus abdominal myomectomy: a prospective, randomized trial to evaluate benefits in early outcome Am J Obstet Gynecol 1996 174(2):654 8 8623802
Mais V, Ajossa S, Piras B, et al Prevention of de-novo adhesion formation after laparoscopic myomectomy: a randomized trial to evaluate the effectiveness of an oxidized regenerated cellulose absorbable barrier Hum Reprod 1995 10(12):3133 5 8822429
Makarainen L, Ylikorkala O Primary and myoma-associated menorrhagia: role of prostaglandins and effects of ibuprofen Br J Obstet Gynaecol 1986 93(9):974 8 3533137
Malhotra N, Sood M Role of hysteroscopy in infertile women J Indian Med Assoc 1997 95(9):
Malone LJ Myomectomy: recurrence after removal of solitary and multiple myomas Obstet Gynecol 1969 34(2):200 3 5816311
Mant J, Painter R, Vessey M Epidemiology of genital prolapse: observations from the Oxford Family Planning Association Study Br J Obstet Gynaecol 1997 104(5):579 85 9166201
Mao X, Barfoot R, Hamoudi RA, et al Allelotype of uterine leiomyomas Cancer Genet Cytogenet 1999 114(2):89 95 10549262
March CM, Boyers S, Franklin R, et al. Prevention of adhesion formation/reformation with the Gore-Tex Surgical Membrane. Prog Clin Biol Res. 1993;381:253-9. [pmid: 8316567].
Marshall LA, Cain DF, Dmowski WP, et al Urinary N-telopeptides to monitor bone resorption while on GnRH agonist therapy Obstet Gynecol 1996 87(3):350 4 8598953
Marshall LM, Spiegelman D, Barbieri RL, et al Variation in the incidence of uterine leiomyoma among premenopausal women by age and race Obstet Gynecol 1997 90(6):967 73 9397113
Marshall LM, Spiegelman D, Goldman MB, et al A prospective study of reproductive factors and oral contraceptive use in relation to the risk of uterine leiomyomata Fertil Steril 1998 70(3):432 9 9757871
Marshall LM, Spiegelman D, Manson JE, et al Risk of uterine leiomyomata among premenopausal women in relation to body size and cigarette smoking Epidemiology 1998 9(5):511 7 9730029
Martin LC, Puente I, Sosa JL, et al Open versus laparoscopic appendectomy. A prospective randomized comparison Ann Surg 1995 222(3):256 62 7677456 1234801
Martyn P, Allan B Long-term follow-up of endometrial ablation J Am Assoc Gynecol Laparosc 1998 5(2):115 8 9564056
Matchar DB, Samsa GP, Matthews JR, et al The stroke prevention policy model: linking evidence and clinical decisions Ann Intern Med 1997 127(8 Pt 2):704 11 9382384
Matorras R, Rodriguez F, Perez C, et al Infertile women with and without endometriosis: a case control study of luteal phase and other infertility conditions Acta Obstet Gynecol Scand 1996 75(9):826 31 8931507
Matsunaga E, Shiota K Ectopic pregnancy and myoma uteri: teratogenic effects and maternal characteristics Teratology 1980 21(1):61 9 7385056
Matta WH, Stabile I, Shaw RW, et al Doppler assessment of uterine blood flow changes in patients with fibroids receiving the gonadotropin-releasing hormone agonist Buserelin Fertil Steril 1988 49(6):1083 5 2967195
Mayer DP, Shipilov V Ultrasonography and magnetic resonance imaging of uterine fibroids Obstet Gynecol Clin North Am 1995 22(4):667 725 8786877
Mazdisnian F, Kurzel RB, Coe S, et al Vaginal hysterectomy by uterine morcellation: an efficient, non-morbid procedure Obstet Gynecol 1995 86(1):60 4 7784024
McCarthy S Magnetic resonance imaging in the evaluation of infertile women Magn Reson Q 1990 6(4):239 49 2288867
McCausland AM Hysteroscopic myometrial biopsy: its use in diagnosing adenomyosis and its clinical application Am J Obstet Gynecol 1992 166(6 Pt 1):1619 26 discussion 1626-8 1615969
McClelland HR, Quinn AJ Shrinkage of uterine fibroids by preoperative LHRH analogue injection Ulster Med J 1992 61(1):51 5 1535743
McCrory DC, Matchar D, Bastian L, et al. Evaluation of Cervical Cytology. Evidence Report/Technology Assessment No. 5 (Prepared by Duke University under Contract No. 290-97-0014). AHCPR Publication No. 99-E010. Rockville, MD: Agency for Health Care Policy and Research. February 1998.
McKinlay SM The normal menopause transition: an overview Maturitas 1996 23(2):137 45 8735352
McKinlay SM, Brambilla DJ, Posner JG The normal menopause transition Maturitas 1992 14(2):103 15 1565019
McLachlan RI, Healy DL, Burger HG Clinical aspects of LHRH analogues in gynaecology: a review Br J Obstet Gynaecol 1986 93(5):431 54 3085705
McLaughlin DS Micro-laser myomectomy technique to enhance reproductive potential: a preliminary report Lasers Surg Med 1982 2(2):107 27 7176798
McNaughton Collins M, Ransohoff DF, Barry MJ Early detection of prostate cancer. Serendipity strikes again JAMA 1997 278(18):1516 9 9363972
Drug Topics Red Book. Oradell, NJ: Medical Economics Co.: 2000.
Megafu U Surgical causes and management of female infertility in Nigeria Int Surg 1988 73(3):144 7 3229919
Meilahn EN, Matthews KA, Egeland G, et al Characteristics of women with hysterectomy Maturitas 1989 11(4):319 29 2615667
Meldrum DR, Erlik Y, Lu JK, et al Objectively recorded hot flushes in patients with pituitary insufficiency J Clin Endocrinol Metab 1981 52(4):684 8 6782116
Mencaglia L Preparation of the endometrium prior to hysteroscopic surgery Eur J Obstet Gynecol Reprod Biol 1996 65(1):107 8
Mencaglia L, Colafranceschi M, Gordon AG, et al Is hysteroscopy of value in the investigation of female infertility? Acta Eur Fertil 1988 19(4):239 41 3067483
Merchant S, Panjwani M, Sarvagod T, et al Asymmetric uterine enlargement: a reliable sign of leiomyomas Am J Roentgenol 1993 161(3):
Mettler L, Alvarez-Rodas E, Lehmann-Willenbrock E, et al Intrafascial supracervical hysterectomy without colpotomy and transuterine mucosal resection by pelviscopy and laparotomy Diagn Therap Endoscopy 1995 1(4):201 7
Mettler L, Alvarez-Rodas E, Semm K Myomectomy by laparoscopy: a report of 482 cases Gynaecol Endoscopy 1995 4(4):259 64
Mikamo H, Izumi K, Ito K, et al Bacterial flora detected of the uterine endometrial cavity of diabetic patients with myoma uteri Kansenshogaku Zasshi 1993 67(7):654 8 8360520
Miller CE Are fibroids a cause of infertility? Infertil Reprod Med Clinics North Am 1997 8(4):639 47
Miller CE, Johnston M, Rundell M Laparoscopic myomectomy in the infertile woman J Am Assoc Gynecol Laparosc 1996 3(4):525 32 9050683
Miller DK, Homan SM Determining transition probabilities: confusion and suggestions Med Decis Making 1994 14(1):52 8 8152357
Milsom I, Ekelund P, Molander U, et al The influence of age, parity, oral contraception, hysterectomy and menopause on the prevalence of urinary incontinence in women J Urol 1993 149(6):1459 62 8501788
Mints M, Radestad A, Rylander E Follow up of hysteroscopic surgery for menorrhagia Acta Obstet Gynecol Scand 1998 77(4):435 8 9598954
Misciagna G, Mangini V, Messa C, et al Gallstones and uterine fibroids Surg Gynecol Obstet 1987 165(5):429 34 3672302
Mizutani T, Sugihara A, Nakamuro K, et al Suppression of cell proliferation and induction of apoptosis in uterine leiomyoma by gonadotropin-releasing hormone agonist (leuprolide acetate) J Clin Endocrinol Metab 1998 83(4):1253 5 9543151
Moghissi KS Hormonal therapy before surgical treatment for uterine leiomyomas Surg Gynecol Obstet 1991 172(6):497 502 1827931
Moher D, Jadad AR, Tugwell P Assessing the quality of randomized controlled trials. Current issues and future directions Inter J Tech Assess Health Care 1996 12(2):195 208
Moller LMA, Berget A Prehysterectomy curettage in women with uterine fibromyomata is not worthwhile Acta Obstet Gynecol Scand 1993 72(5):374 6 8392269
Mollica G, Pittini L, Minganti E, et al Elective uterine myomectomy in pregnant women Clin Exp Obstet Gynecol 1996 23(3):168 72 8894327
Mommsen S, Foldspang A, Elving L, et al Association between urinary incontinence in women and a previous history of surgery Br J Urol 1993 72(1):30 7 8149175
Monga AK, Woodhouse CR, Stanton SL Pregnancy and fibroids causing simultaneous urinary retention and ureteric obstruction Br J Urol 1996 77(4):606 7 8777631
Montemagno U, De Placido G, Colacurci N, et al Uterine fibroids: Protocols of integrated medical/surgical treatment Clin Exp Obstet Gynecol 1993 20(3):167 72 8403425
Morton CC Many tumors and many genes: Genetics of uterine leiomyomata Am J Pathol 1998 153(4):1015 20 9777932 1853042
Motashaw ND, Dave S, Paghdiwalla K Hysteroscopic management of submucous uterine myomata Gynaecol Endoscopy 1995 4(3):207 12
Mroueh J, Margono F, Feinkind L Tubal pregnancy associated with ampullary tubal leiomyoma Obstet Gynecol 1993 81(5 Pt 2):880 2 8469506
Mukherjee T, Abadi M, Copperman AB, et al The effect of extended gonadotropin-releasing hormone agonist administration on uterine leiomyoma histopathology J Gynecol Surg 1996 12(4):251 6
Mukherjee T, Barad D, Turk R, et al A randomized, placebo-controlled study on the effect of cyclic intermittent etidronate therapy on the bone mineral density changes associated with six months of gonadotropin-releasing hormone agonist treatment Am J Obstet Gynecol 1996 175(1):105 9 8694034
Mulvany NJ, Slavin JL, Ostor AG, et al Intravenous leiomyomatosis of the uterus: a clinicopathologic study of 22 cases Int J Gynecol Pathol 1994 13(1):1 9 8112951
Murphy AA RU486 in the treatment of leiomyomata uteri Infertil Reprod Med Clinics North Am 1996 7(1):57 68
Murphy AA, Castellano PZ RU486: Pharmacology and potential use in the treatment of endometriosis and leiomyomata uteri Curr Opin Obstet Gynecol 1994 6(3):269 78 8038415
Murphy AA, Morales AJ, Kettel LM, et al Regression of uterine leiomyomata to the antiprogesterone RU486: dose-response effect Fertil Steril 1995 64(1):187 90 7789557
Murray C, Tulandi T Prevention of postmyomectomy adhesions Infertil Reprod Med Clinics North Am 1996 7(1):169 77
Myers ER, Steege JF Risk adjustment for complications of hysterectomy: limitations of routinely collected administrative data Am J Obstet Gynecol 1999 181(3):567 75 10486465
Nachtigall LE, Nachtigall RH, Nachtigall RD, et al Estrogen replacement therapy I: a 10-year prospective study in the relationship to osteoporosis Obstet Gynecol 1979 53(3):277 81 218151
Nagamani M, Stuart CA Specific binding sites for insulin in the human myometrium and leiomyomas of the uterus Fertil Steril 1992 58(1):120 3 1623992
Nakamura Y, Yoshimura Y Treatment of uterine leiomyomas in perimenopausal women with gonadotropin-releasing hormone agonists Clin Obstet Gynecol 1993 36(3):660 7 8403612
Nakamura Y, Yoshimura Y, Yamada H, et al Treatment of uterine leiomyomata with a luteinizing hormone-releasing hormone agonist: the possibility of nonsurgical management in selected perimenopausal women Fertil Steril 1991 55(5):900 5 1902420
Narayan R, Rajat, Goswamy K Treatment of submucous fibroids, and outcome of assisted conception J Am Assoc Gynecol Laparosc 1994 1(4 Pt 1):307 11 9138869
Narayansingh GV, Ramsewak S, Kissoon W Elective cesarean hysterectomy for uterine fibroids Int J Gynecol Obstet 1992 38(2):125 6
Nathorst-Boos J, von Schoultz B Psychological reactions and sexual life after hysterectomy with and without oophorectomy Gynecol Obstet Invest 1992 34(2):97 101 1398273
[electronic database]. Release 6; 1997 data. Agency for Healthcare Research and Quality: Rockville, MD. Available from: http://www.ntis.gov/fcpc/cpn8834.htm. 1997.
Nencioni T, Penotti M, Barbieri-Carones M, et al Gonadotropin releasing hormone agonist therapy and its effect on bone mass Gynecol Endocrinol 1991 5(1):49 56 1910246
Neuwirth RS Hysteroscopic resection of submucous myomas Cervix & the Lower Female Genital Tract 1988 6(4):325 31
Neuwirth RS Hysteroscopic submucous myomectomy Infertil Reprod Med Clinics North Am 1996 7(1):91 108
Nezhat C The "cons" of laparoscopic myomectomy in women who may reproduce in the future Int J Fertil Menopausal Stud 1996 41(3):280 3 8799756
Nezhat C, Nezhat F, Bess O, et al Laparoscopically assisted myomectomy: a report of a new technique in 57 cases Int J Fertil 1994 39(1):39 44
Nezhat C, Nezhat F, Silfen SL, et al Laparoscopic myomectomy Int J Fertil 1991 36(5):275 80 1683655
Nezhat FR, Roemisch M, Nezhat CH, et al Recurrence rate after laparoscopic myomectomy J Am Assoc Gynecol Laparosc 1998 5(3):237 40 9668143
Nezhat FR, Seidman DS, Nezhat C, et al Laparoscopic myomectomy today. Why, when and for whom? Hum Reprod 1996 11(5):933 4 8671365
Nikolic B, Spies JB, Lundsten MJ, et al Patient radiation dose associated with uterine artery embolization Radiology 2000 214(1):121 5 10644110
Nimaroff ML, Dimino M, Maloney S Laparoscopic-assisted vaginal hysterectomy of large myomatous uteri with supracervical amputation followed by trachelectomy J Am Assoc Gynecol Laparosc 1996 3(4):585 7 9050693
Nisolle M, Smets M, Malvaux V, et al Laparoscopic myolysis with the Nd:YAG laser J Gynecol Surg 1993 9(2):95 9 10171973
Niu H, Simari RD, Zimmermann EM, et al Nonviral vector-mediated thymidine kinase gene transfer and ganciclovir treatment in leiomyoma cells Obstet Gynecol 1998 91(5 Pt 1):735 40 9572221
Norris HJ, Hilliard GD, Irey NS Hemorrhagic cellular leiomyomas ("apoplectic leiomyoma") of the uterus associated with pregnancy and oral contraceptives Int J Gynecol Pathol 1988 7(3):212 24 3182168
Nowak RA Fibroids: Pathophysiology and current medical treatment Baillieres Clin Obstet Gynaecol 1999 13(2):223 38
O'Connor DM, Norris HJ. Mitotically active leiomyomas of the uterus. Hum Pathol. 1990;21:223-7. [pmid: 2307449].
Oguchi O, Mori A, Kobayashi Y, et al Prediction of histopathologic features and proliferative activity of uterine leiomyoma by magnetic resonance imaging prior to GnRH analogue therapy: Correlation between T2-Weighted images and effect of GnRH analogue J Obstet Gynaecol 1995 21(2):107 17 8556572
Ojeda VJ The pathology of hysterectomy specimens N Z Med J 1979 89(631):169 71 287933
Okizuka H, Sugimura K, Takemori M, et al MR detection of degenerating uterine leiomyomas J Comput Assist Tomogr 1993 17(5):760 6 8370831
Olah KS, Dunn JA, Gee H Leiomyosarcomas have a poorer prognosis than mixed mesodermal tumours when adjusting for known prognostic factors: The result of a retrospective study of 423 cases of uterine sarcoma Br J Obstet Gynaecol 1992 99(7):590 4 1326319
Oldenhave A, Jaszmann LJ, Everaerd WT, et al Hysterectomized women with ovarian conservation report more severe climacteric complaints than do normal climacteric women of similar age Am J Obstet Gynecol 1993 168(3 Pt 1):765 71 8456877
Olsen AL, Smith VJ, Bergstrom JO, et al Epidemiology of surgically managed pelvic organ prolapse and urinary incontinence Obstet Gynecol 1997 89(4):501 6 9083302
Oyawoye OA Elective hysterectomy at Ilorin, Nigeria -- 4 year review J Obstet Gynaecol 1998 18(1):72 5 15512009
Ozeren M, Ulusoy M, Uyanik E First-trimester spontaneous uterine rupture after traditional myomectomy: case report Isr J Med Sci 1997 33(11):752 3 9434814
Packenham JP, du Manoir S, Schrock E, et al Analysis of genetic alterations in uterine leiomyomas and leiomyosarcomas by comparative genomic hybridization Mol Carcinog 1997 19(4):273 9 9290705
Paganini-Hill A, Ross RK, Gerkins VR, et al Menopausal estrogen therapy and hip fractures Ann Intern Med 1981 95(1):28 31 7247123
Pairwuti S Pap smear examination of patients with leiomyoma J Med Assoc Thai 1991 74(10):471 4 1797958
Palan PR, Goldberg GL, Basu J, et al Lipid-soluble antioxidants: beta-carotene and alpha-tocopherol levels in breast and gynecologic cancers Gynecol Oncol 1994 55(1):72 7 7959271
Palan PR, Mikhail M, Romney SL Decreased beta-carotene tissue levels in uterine leiomyomas and cancers of reproductive and nonreproductive organs Am J Obstet Gynecol 1989 161(61):1649 52 2603922
Palomba S, Affinito P, Di Carlo C, et al Long-term administration of tibolone plus gonadotropin-releasing hormone agonist for the treatment of uterine leiomyomas: Effectiveness and effects on vasomotor symptoms, bone mass, and lipid profiles Fertil Steril 1999 72(5):889 95 10560995
Palomba S, Affinito P, Tommaselli GA, et al A clinical trial of the effects of tibolone administered with gonadotropin-releasing hormone analogues for the treatment of uterine leiomyomata Fertil Steril 1998 70(1):111 8 9660431
Parazzini F, Bortolotti A, Chiantera V, et al Goserelin acetate to avoid hysterectomy in pre-menopausal women with fibroids requiring surgery Eur J Obstet Gynecol Reprod Biol 1999 87(1):31 3 10579613
Parazzini F, Moroni S, La Vecchia C, et al Ovarian cancer risk and history of selected medical conditions linked with female hormones Eur J Cancer 1997 33(10):1634 7 9389926
Parazzini F, Negri E, La Vecchia C, et al Oral contraceptive use and risk of uterine fibroids Obstet Gynecol 1992 79(3):430 3 1738528
Parazzini F, Negri E, La Vecchia C, et al Reproductive factors and risk of uterine fibroids Epidemiology 1996 7(4):440 2 8793374
Parker WH Myomectomy: Laparoscopy or laparotomy? Clin Obstet Gynecol 1995 38(2):392 400 7554606
Parker WH, Fu YS, Berek JS Uterine sarcoma in patients operated on for presumed leiomyoma and rapidly growing leiomyoma Obstet Gynecol 1994 83(3):414 8 8127535
Parker WH, Rodi IA Patient selection for laparoscopic myomectomy J Am Assoc Gynecol Laparosc 1994 2(1):23 6 9050528
Parys BT, Haylen BT, Hutton JL, et al The effects of simple hysterectomy on vesicourethral function Br J Urol 1989 64(6):594 9 2627634
Parys BT, Haylen BT, Hutton JL, et al Urodynamic evaluation of lower urinary tract function in relation to total hysterectomy Aust N Z J Obstet Gynaecol 1990 30(2):161 5 2400362
Parys BT, Woolfenden KA, Parsons KF Bladder dysfunction after simple hysterectomy: urodynamic and neurological evaluation Eur Urol 1990 17(2):129 33 2311638
Patterson-Keels LM, Selvaggi SM, Haefner HK, et al Morphologic assessment of endometrium overlying submucosal leiomyomas J Reprod Med 1994 39(8):579 84 7996520
Peacock LM, Rock JA Indications for and technique of myomectomy Infertil Reprod Med Clinics North Am 1996 7(1):109 27
Pelage JP, Le Dref O, Soyer P, et al Fibroid-related menorrhagia: treatment with superselective embolization of the uterine arteries and midterm follow-up Radiology 2000 215(2):428 31 10796920
Pelosi MA 3rd, Pelosi MA Laparoscopic-assisted transvaginal myomectomy J Am Assoc Gynecol Laparosc 1997 4(2):241 6 9050735
Pelosi MA 3rd, Pelosi MA, Cantuaria GHC, et al Comparison of bimanual examination with ultrasound examination before hysterectomy for uterine leiomyoma (multiple letters) Obstet Gynecol 1998 92(5):
Negrin Perez MC, De La Torre Fdz P, Ramirez A Ureteral complications after gasless laparoscopic hysterectomy Surg Laparosc Endosc Percutaneous Tech 1999 9(4):300 2
Perino A, Chianchiano N, Petronio M, et al Role of leuprolide acetate depot in hysteroscopic surgery: a controlled study Fertil Steril 1993 59(3):507 10 8458448
Perry CM, Brogden RN Goserelin. A review of its pharmacodynamic and pharmacokinetic properties, and therapeutic use in benign gynaecological disorders Drugs 1996 51(2):319 46 8808170
Phelan JP Myomas and pregnancy Obstet Gynecol Clin North Am 1995 22(4):801 5 8786883
Phillips DR Laparoscopic leiomyoma coagulation (myolysis) Gynaecol Endoscopy 1995 4(1):3 4
Phillips DR, Milim SJ, Nathanson HG, et al Experience with laparoscopic leiomyoma coagulation and concomitant operative hysteroscopy J Am Assoc Gynecol Laparosc 1997 4(4):425 33 9224575
Phillips DR, Nathanson HG, Meltzer SM, et al Transcervical electrosurgical resection of submucous leiomyomas for chronic menorrhagia [published erratum appears in J Am Assoc Gynecol Laparosc 1995 Aug;2(4):496] J Am Assoc Gynecol Laparosc 1995 2(2):147 53 9050549
Phillips DR, Nathanson HG, Milim SJ, et al 100 laparoscopic hysterectomies in private practice and visiting professorship programs J Am Assoc Gynecol Laparosc 1995 3(1):47 53 9050616
Phillips DR, Nathanson HG, Milim SJ, et al The effect of dilute vasopressin solution on blood loss during operative hysteroscopy: a randomized controlled trial Obstet Gynecol 1996 88(5):761 6 8885909
Phillips SM, Sherwin BB Effects of estrogen on memory function in surgically menopausal women Psychoneuroendocrinology 1992 17(5):485 95 1484915
Piazze Garnica J, Gallo G, Marzano PF, et al Clinical and ultrasonographic implications of uterine leiomyomatosis in pregnancy Clin Exp Obstet Gynecol 1995 22(4):293 7 8777782
Pinto S, Coppo M, Bruni V, et al Changes in thromboxane A2 generation and plasma lipid pattern in pseudomenopause induced by gonadotropin releasing hormone (GnRH) analogue buserelin Prostaglandins Leukot Essent Fatty Acids 1991 43(3):203 7 1908102
Piscitelli JT, Simel DL, Addison WA Who should have intravenous pyelograms before hysterectomy for benign disease? Obstet Gynecol 1987 69(4):541 5 3822294
Pitkin RM Abdominal hysterectomy in obese women Surg Gynecol Obstet 1976 142(4):532 36 769202
Pitkin RM Does low-dose combination oral contraceptive use affect uterine size or menstrual flow in premenopausal women with leiomyomas? [retraction of Friedman AJ, Thomas PP. RL>In: Obstet Gynecol 1995;85(4):631-5] Obstet Gynecol 1995 86(5):
Piver MS, Jishi MF, Tsukada Y, et al Primary peritoneal carcinoma after prophylactic oophorectomy in women with a family history of ovarian cancer. A report of the Gilda Radner Familial Ovarian Cancer Registry Cancer 1993 71(9):2751 5 8467455
Plockinger B, Kolbl H Development of ovarian pathology after hysterectomy without oophorectomy J Am Coll Surg 1994 178(6):581 5 8193751
Plosker GL, Brogden RN Leuprorelin. A review of its pharmacology and therapeutic use in prostatic cancer, endometriosis and other sex hormone-related disorders Drugs 1994 48(6):930 67 7533699
Poad D, Arnold EP Sexual function after pelvic surgery in women Aust N Z J Obstet Gynaecol 1994 34(4):471 4 7848244
Pokras R, Hufnagel VG Hysterectomy in the United States, 1965-84 Am J Public Health 1988 78(7):852 3 3381968 1350353
Polet R, de Jong P, van der Spuy ZM, et al Laparoscopically assisted vaginal hysterectomy (LAVH) -- an alternative to total abdominal hysterectomy S Afr Med J 1996 86(9 Suppl):1190 4 9180782
Pooley AS, Ewen SP, Sutton CJG Does transcervical resection of the endometrium for menorrhagia really avoid hysterectomy? Life table analysis of a large series J Am Assoc Gynecol Laparosc 1998 5(3):229 35 9668142
Prayson RA, Hart WR Mitotically active leiomyomas of the uterus Am J Clin Pathol 1992 97(1):14 20 1728856
Preutthipan S Clinical applications of GnRH agonists in gynaecology J Med Assoc Thai 1993 76(Suppl. 1):11 8 8113648
Prior A, Stanley KM, Smith AR, et al Relation between hysterectomy and the irritable bowel: a prospective study Gut 1992 33(6):814 7 1624165 1379342
Puzigaca Z, Prelevic GM, Sretenovic Z Differential reduction in the volume of leiomyoma and uterus during buserelin treatment Gynecol Endocrinol 1994 8(1):39 43 8059616
Qazi F, McGuire WP The treatment of epithelial ovarian cancer CA: a Cancer Journal for Clinicians 1995 45(2):88 101 7889393
Ramzy AM, Sattar M, Amin Y, et al Uterine myomata and outcome of assisted reproduction Hum Reprod 1998 13(1):198 202 9512257
Ransohoff DF, Lang CA Small adenomas detected during fecal occult blood test screening for colorectal cancer. The impact of serendipity JAMA 1990 264(1):76 8 2192093
Ravina JH, Vigneron NC, Aymard A, et al Pregnancy after embolization of uterine myoma: report of 12 cases Fertil Steril 2000 73(6):1241 3 10856491
Ravn P, Lind C, Nilas L Lack of influence of simple premenopausal hysterectomy on bone mass and bone metabolism Am J Obstet Gynecol 1995 172(3):891 5 7892881
Ravnikar VA Compliance with hormone therapy Am J Obstet Gynecol 1987 156(5):1332 4 3578453
Ravnikar VA, Chen E Hysterectomies: where are the indications? Obstet Gynecol Clin North Am 1994 21(2):405 11 7936552
Regidor PA, Schmidt M, Callies R, et al Estrogen and progesterone receptor content of GnRH analogue pretreated and untreated uterine leiomyomata Eur J Obstet Gynecol Reprod Biol 1995 63(1):69 73 8674569
Reich H Laparoscopic myomectomy Obstet Gynecol Clin North Am 1995 22(4):757 80 8786880
Reich H, McGlynn F, Sekel L Total laparoscopic hysterectomy Gynaecol Endoscopy 1993 2(2):59 63
Reidy JF, Bradley EA Uterine artery embolization for fibroid disease Cardiovasc Intervent Radiol 1998 21(5):357 60 9853139
Reilly RJ, Nour N Abdominal myomectomy is associated with few surgical complications J Gynecol Tech 1998 4(3):107 12
Rein MS, Barbieri RL, Friedman AJ Progesterone: a critical role in the pathogenesis of uterine myomas Am J Obstet Gynecol 1995 172(1 Pt 1):14 8 7847524
Rein MS, Barbieri RL, Welch W, et al The concentrations of collagen-associated amino acids are higher in GnRH agonist-treated uterine myomas Obstet Gynecol 1993 82(6):901 5 8233262
Rein MS, Friedman AJ, Heffner LJ Decreased prolactin secretion by explant cultures of fibroids from women treated with a gonadotropin-releasing hormone agonist J Clin Endocrinol Metab 1990 70(6):1554 8 2112150
Rein MS, Friedman AJ, Pandian MR, et al The secretion of insulin-like growth factors I and II by explant cultures of fibroids and myometrium from women treated with a gonadotropin-releasing hormone agonist Obstet Gynecol 1990 76(3 Pt 1):388 94 2116610
Rein MS, Friedman AJ, Stuart JM, et al Fibroid and myometrial steroid receptors in women treated with gonadotropin-releasing hormone agonist leuprolide acetate Fertil Steril 1990 53(6):1018 23 2112489
Rein MS, Powell WL, Walters FC, et al Cytogenetic abnormalities in uterine myomas are associated with myoma size Mol Hum Reprod 1998 4(1):83 6 9510016
Reinsch RC, Murphy AA, Morales AJ, et al The effects of RU486 and leuprolide acetate on uterine artery blood flow in the fibroid uterus: a prospective, randomized study Am J Obstet Gynecol 1994 170(6):1623 7 discussion 1627-8 8203418
Reiter RC, Wagner PL, Gambone JC Routine hysterectomy for large asymptomatic uterine leiomyomata: a reappraisal Obstet Gynecol 1992 79(4):481 4 1553162
Rekers H, Drogendijk AC, Valkenburg HA, et al The menopause, urinary incontinence and other symptoms of the genito-urinary tract Maturitas 1992 15(2):101 11 1470043
Rendina GM, Patrono D The use of a biological preparation in the treatment of some gynaecological diseases Curr Med Res Opin 1976 4(2):151 7 776538
Rhodes JC, Kjerulff KH, Langenberg PW, et al Hysterectomy and sexual functioning JAMA 1999 282(20):1934 41 10580459
Ribeiro SC, Reich H, Rosenberg J, et al Laparoscopic myomectomy and pregnancy outcome in infertile patients Fertil Steril 1999 71(3):571 4 10065802
Rice JP, Kay HH, Mahony BS The clinical significance of uterine leiomyomas in pregnancy Am J Obstet Gynecol 1989 160(5 Pt 1):1212 6 2658611
Richardson RE, Bournas N, Magos AL Is laparoscopic hysterectomy a waste of time? Lancet 1995 345(8941):36 41 7799707
Riley P Treatment of prolapsed submucous fibroids S Afr Med J 1982 62(1):22 4 7089775
Rinehart JS Myomas and infertility: small intramural myomas do not reduce pregnancy rate in in vitro fertilization Assisted Reprod 1999 9(2):87 94
Rintala S, Kujansuu E, Teisala K, et al GnRH analogues and uterine leiomyomas. Effect of hormone replacement therapy on cell proliferation Gynecol Obstet Invest 1999 48(4):276 9 10592433
Rivlin ME, Patel RB, Hess LW, et al Leuprolide acetate depot for the treatment of uterine leiomyomas. Changes in bone density, uterine volume and uterine vascular resistive index J Reprod Med 1994 39(9):663 6 7807474
Roberts WE, Fulp KS, Morrison JC, et al The impact of leiomyomas on pregnancy Aust N Z J Obstet Gynaecol 1999 39(1):43 7 10099748
Roman JD, Trivedi AN Implementation of an outpatient hysteroscopy clinic at Waikato Women's Hospital report of the first 60 cases N Z Med J 1999 112(1091):253 5 10448983
Romero R, Chervenak FA, DeVore G, et al Fetal head deformation and congenital torticollis associated with a uterine tumor Am J Obstet Gynecol 1981 141(7):839 40 7198386
Roos NP Hysterectomies in one Canadian province: a new look at risks and benefits Am J Public Health 1984 74(1):39 46 6689840 1651382
Rosati P, Bellati U, Exacoustos C, et al Uterine myoma in pregnancy: ultrasound study Int J Gynaecol Obstet 1989 28(2):109 17 2563696
Rosenfeld DL Abdominal myomectomy for otherwise unexplained infertility Fertil Steril 1986 46(2):328 30 3732540
Rossetti A, Paccosi M, Sizzi O, et al Dilute ornitin vasopressin and a myoma drill for laparoscopic myomectomy J Am Assoc Gynecol Laparosc 1999 6(2):189 93 10226131
Rowe MK, Kanouse DE, Mittman BS, et al Quality of life among women undergoing hysterectomies Obstet Gynecol 1999 93(6):915 21 10362154
Rutgers JL, Spong CY, Sinow R, et al Leuprolide acetate treatment and myoma arterial size Obstet Gynecol 1995 86(3):386 8 7651647
Rzempoluch J, Kaminski BT, Wawryk R, et al Postoperative serum levels of some fat metabolism parameters in women with uterine leiomyoma, depending on the extent of surgery Zentralbl Gynakol 1989 111(14):960 6 2800780
Sadik S, Uran B, Ozaydin T Laparoscopic-assisted vaginal hysterectomy and bilateral salpingo-oophorectomy with suturing technique J Am Assoc Gynecol Laparosc 1995 2(4):437 40 9050599
Sakamoto S, Kudo H, Kawasaki T, et al Effects of a Chinese herbal medicine, keishi-bukuryo-gan, on the gonadal system of rats Ethnopharmacology 1988 23(2-3):151 8 3143030
Sakamoto S, Yoshino H, Shirahata Y, et al Pharmacotherapeutic effects of kuei-chih-fu-ling-wan (keishi-bukuryo-gan) on human uterine myomas Am J Chin Med 1992 20(3-4):313 7 1471615
Saltiel E Potential cost savings using GnRH agonists as preoperative therapy for uterine leiomyomas Hosp Formulary 1995 30(9):532 42
Samuelsson EC, Arne Victor FT, Tibblin G, et al Signs of genital prolapse in a Swedish population of women 20 to 59 years of age and possible related factors Am J Obstet Gynecol 1999 180(2 Pt 1):299 305 9988790
Sandy II EA The combined use of leuprolide acetate depot and laparoscopically assisted vaginal hysterectomy in the treatment of symptomatic uterine leiomyomas J Gynecol Surg 1993 9(3):183 4
Sato F, Nishi M, Kudo R, et al Body fat distribution and uterine leiomyomas J Epidemiol 1998 8(3):176 80 9782674
Schairer C, Persson I, Falkeborn M, et al Breast cancer risk associated with gynecologic surgery and indications for such surgery Int J Cancer 1997 70(2):150 4 9009152
Scher KS Unplanned reoperation for bleeding Am Surg 1996 62(1):52 5 8540646
Schlaff WD, Zerhouni EA, Huth JA, et al A placebo-controlled trial of a depot gonadotropin-releasing hormone analogue (leuprolide) in the treatment of uterine leiomyomata Obstet Gynecol 1989 74(6):856 62 2511532
Schneider A, Merker A, Martin C, et al Laparoscopically assisted vaginal hysterectomy as an alternative to abdominal hysterectomy in patients with fibroids Arch Gynecol Obstet 1997 259(2):79 85 9059748
Schofield MJ, Bennett A, Redman S, et al Self-reported long-term outcomes of hysterectomy Br J Obstet Gynaecol 1991 98(11):1129 36 1760425
Schricker T, Berroth A, Pfeiffer U, et al Assessment of perioperative glycerol metabolism by stable isotope tracer technique Nutrition 1997 13(3):191 5 9131677
Schricker T, Carli F, Schreiber M, et al Time of peritoneal cavity exposure influences postoperative glucose production Can J Anaesth 1999 46(4):352 8 10232719
Schulz KF, Chalmers I, Grimes DA, et al Assessing the quality of randomization from reports of controlled trials published in obstetrics and gynecology journals JAMA 1994 272(2):125 8 8015122
Schulz KF, Chalmers I, Hayes RJ, et al Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials JAMA 1995 273(5):408 12 7823387
Schust DJ, Friedman AJ Treatment of uterine leiomyomas in the perimenopause Infertil Reprod Med Clinics North Am 1995 6(4):739 56
Schutter EM, Kenemans P, Sohn C, et al Diagnostic value of pelvic examination, ultrasound, and serum CA 125 in postmenopausal women with a pelvic mass. An international multicenter study Cancer 1994 74(4):1398 406 8055463
Schwartz LB, Diamond MP, Schwartz PE Leiomyosarcomas: clinical presentation Am J Obstet Gynecol 1993 168(1 Pt 1):180 3 8420323
Schwartz LB, Rutkowski N, Horan C, et al Use of transvaginal ultrasonography to monitor the effects of tamoxifen on uterine leiomyoma size and ovarian cyst formation J Ultrasound Med 1998 17(11):699 703 9805306
Schwartz LB, Zawin M, Carcangiu ML, et al Does pelvic magnetic resonance imaging differentiate among the histologic subtypes of uterine leiomyomata? Fertil Steril 1998 70(3):580 7 9757898
Schwartz Z, Dgani R, Katz Z, et al Urinary retention caused by impaction of leiomyoma in pregnancy Acta Obstet Gynecol Scand 1986 65(5):525 6 3776497
Schwarzler P, Concin H, Bosch H, et al An evaluation of sonohysterography and diagnostic hysteroscopy for the assessment of intrauterine pathology Ultrasound Obstet Gynecol 1998 11(5):337 42 9644773
Schwarzler P, Senat MV, Holden D, et al Feasibility of the second-trimester fetal ultrasound examination in an unselected population at 18, 20 or 22 weeks of pregnancy: a randomized trial Ultrasound Obstet Gynecol 1999 14(2):92 7 10492867
Schweppe KW, Beller FK [Prophylactic oophorectomy (author's transl)] Geburtshilfe Und Frauenheilkunde 1979 39(12):1024 32 [German] 520781
Scialli AR Alternatives to hysterectomy for benign conditions Int J Fertil Womens Med 1998 43(4):186 91 9726846
Scialli AR, Jestila KJ Sustained benefits of leuprolide acetate with or without subsequent medroxyprogesterone acetate in the nonsurgical management of leiomyomata uteri Fertil Steril 1995 64(2):313 20 7615109
Seidman DS, Nezhat CH, Nezhat F, et al Laparoscopic-assisted myomectomy Infertil Reprod Med Clinics North Am 1996 7(1):161 7
Seinera P, Arisio R, Decko A, et al Laparoscopic myomectomy: Indications, surgical technique and complications Hum Reprod 1997 12(9):1927 30 9363708
Seinera P, Gaglioti P, Volpi E, et al Ultrasound evaluation of uterine wound heALIGN following laparoscopic myomectomy: preliminary results Hum Reprod 1999 14(10):2460 3 10527969
Sener AB, Seckin NC, Ozmen S, et al The effects of hormone replacement therapy on uterine fibroids in postmenopausal women Fertil Steril 1996 65(2):354 7 8566261
Seoud MA-F, Patterson R, Muasher SJ, et al Effects of myomas or prior myomectomy on in vitro fertilization (IVF) performance J Assist Reprod Genet 1992 9(3):217 21 1525449
Serra GB, Panetta V, Colosimo M, et al Efficacy of leuprorelin acetate depot in symptomatic fibromatous uteri: the Italian multicentre trial Clin Ther 1992 14(Suppl A):57 73 1606594
Servy EJ, Tzingounis VA Tubal patency: hysterosalpingography compared with laparoscopy Southern Med J 1978 71(12):1511 2 152979
Settnes A, Jorgensen T Hysterectomy in a Danish cohort. Prevalence, incidence and socio-demographic characteristics Acta Obstet Gynecol Scand 1996 75(3):274 80 8607343
Shaw RW Mechanism of LHRH analogue action in uterine fibroids Horm Res 1989 32Suppl 1:150 3 2533145
Shaw RW Blood flow changes in the uterus induced by treatment with GnRH analogues Hum Reprod 1996 11(Suppl. 3):27 32 9147099
Shaw RW Gonadotrophin hormone-releasing hormone analogue treatment of fibroids Baillieres Clin Obstet Gynaecol 1998 12(2):245 68 10023421
Shekelle PG, Kahan JP, Bernstein SJ, et al The reproducibility of a method to identify the overuse and underuse of medical procedures N Engl J Med 1998 338(26):1888 95 9637810
Sherwin BB, Tulandi T "Add-back" estrogen reverses cognitive deficits induced by a gonadotropin-releasing hormone agonist in women with leiomyomata uteri J Clin Endocrinol Metab 1996 81(7):2545 9 8675575
Shushan A, Mohamed H, Magos AL A case-control study to compare the variability of operating time in laparoscopic and open surgery Hum Reprod 1999 14(6):1467 9 10357960
Siddle N, Sarrel P, Whitehead M The effect of hysterectomy on the age at ovarian failure: identification of a subgroup of women with premature loss of ovarian function and literature review Fertil Steril 1987 47(1):94 100 3539646
Simon FA Jr Leiomyomas in pregnancy Am Fam Physician 1988 37(2):163 6 3278562
Sirjusingh A, Bassaw B, Roopnarinesingh S The results of abdominal myomectomy West Indian Med J 1994 43(4):138 9 7900378
Siskin GP, Eaton LA Jr, Stainken BF, et al Pathologic findings in a uterine leiomyoma after bilateral uterine artery embolization J Vasc Interv Radiol 1999 10(7):891 4 10435706
Siskin GP, Stainken BF, Dowling K, et al. Outpatient uterine artery embolization for symptomatic uterine fibroids: experience in 49 patients. J Vasc Interv Radiol. 2000;11:305-11. [pmid: 10735424].
Sivin I, Stern J Health during prolonged use of levonorgestrel 20 micrograms/d and the copper TCu 380Ag intrauterine contraceptive devices: a multicenter study. International Committee for Contraception Research (ICCR) Fertil Steril 1994 61(1):70 7 8293847
Skoner MM, Thompson WD, Caron VA Factors associated with risk of stress urinary incontinence in women Nurs Res 1994 43(5):301 6 7937177
Slade RJ, McCallum KA, Ellis JD Endometrial resection after GnRH analogue therapy -- a possible new treatment for fibromyomata J Obstet Gynaecol 1993 13(1):69 71
Smith DC, Uhlir JK Myomectomy as a reproductive procedure Am J Obstet Gynecol 1990 162(6):1476 9 discussion 1479-82 2360579
Smoot JS, Zaloudek C Myometrial and stromal lesions of the uterus Clin Lab Med 1995 15(3):545 73 8542723
25th Annual Scientific Meeting; March 25-30, 2000; San Diego, CA J Vasc Interven Radiol 2000 11(2, Part 2: Supplement).
Soderstrom RM, Hardiman MK, Reiter RC, et al Routine hysterectomy for large asymptomatic uterine leiomyomata: A reappraisal Obstet Gynecol 1992 80(3 I):474 6 1495710
Sofer T, Roos NP, Nelson N Hysterectomy in Manitoba -- 1970-1978: patterns of practice and changes over time Can J Public Health 1983 74(2):100 5 6682693
Sorensen SS, Colov NP, Vejerslev LO Pre- and postoperative therapy with GnRH agonist for endometrial resection. A prospective, randomized study Acta Obstet Gynecol Scand 1997 76(4):340 4 9174428
Sosa JL, Sleeman D, McKenney MG, et al A comparison of laparoscopic and traditional appendectomy J Laparoendosc Surg 1993 3(2):129 31 8518464
Sosic A, Skupski DW, Streltzoff J, et al Vascularity of uterine myomas: Assessment by color and pulsed Doppler ultrasound Int J Gynecol Obstet 1996 54(3):245 50
Sourla A, Polychronakos C, Zeng WR, et al Plasminogen activator inhibitor 1 messenger RNA expression and molecular evidence for del(7)(q22) in uterine leiomyomas Cancer Res 1996 56(13):3123 8 8674071
Spaulding LB Endometrial ablation for refractory postmenopausal bleeding with continuous hormone replacement therapy Fertil Steril 1994 62(6):1181 5 7957981
Speroff L, Glass RH, Kase NG. Clinical gynecologic endocrinology and infertility. 5th edition. Baltimore, MD: Williams & Wilkins, 1994: pp. 745-7.
Speroff L, Glass RH, Kase NG. Clinical gynecologic endocrinology and infertility. 6th edition. Philadelphia, PA: Lippincott Williams & Wilkins, 1999: pp. 149-53.
Speroff T, Dawson NV, Speroff L, et al A risk-benefit analysis of elective bilateral oophorectomy: effect of changes in compliance with estrogen therapy on outcome Am J Obstet Gynecol 1991 164(1 Pt 1):165 74 1986605
Spies JB, Scialli AR, Jha RC, et al Initial results from uterine fibroid embolization for symptomatic leiomyomata J Vasc Interv Radiol 1999 10(9):1149 57 10527190
Spies JB, Warren EH, Mathias SD, et al Uterine fibroid embolization: measurement of health-related quality of life before and after therapy J Vasc Interv Radiol 1999 10(10):1293 303 10584643
Spong CY, Sinow R, Renslo R, et al Induced hypoestrogenism increases the arterial resistance index of leiomyomata without affecting uterine or carotid arteries J Assist Reprod Genet 1995 12(5):338 41 8520200
Sreenan JJ, Prayson RA, Biscotti CV, et al Histopathologic findings in 107 uterine leiomyomas treated with leuprolide acetate compared with 126 controls [published erratum appears in Am J Surg Pathol 1996 Sep;20(9):1160] Am J Surg Pathol 1996 20(4):427 32 8604809
Stanton SL, Hilton P, Norton C, et al Clinical and urodynamic effects of anterior colporrhaphy and vaginal hysterectomy for prolapse with and without incontinence Br J Obstet Gynaecol 1982 89(6):459 63 7082603
Starks GC CO2 laser myomectomy in an infertile population J Reprod Med 1988 33(2):184 6 3351816
Stewart EA, Friedman AJ Steroidal treatment of myomas: preoperative and long-term medical therapy Semin Reprod Endocrinol 1992 10(4):344 57
Stewart EA, Nowak RA Leiomyoma-related bleeding: a classic hypothesis updated for the molecular era Hum Reprod Update 1996 2(4):295 306 9080227
Stewart EA, Nowak RA New concepts in the treatment of uterine leiomyomas Obstet Gynecol 1998 92(4 I):624 7 9764641
Stjernquist M Treatment of uterine fibroids with GnRH-analogues prior to hysterectomy Acta Obstet Gynecol Scand 1997Suppl 76(164) 94 7
Stovall DW, Parrish SB, Van Voorhis BJ, et al Uterine leiomyomas reduce the efficacy of assisted reproduction cycles: results of a matched follow-up study Hum Reprod 1998 13(1):192 7 9512256
Stovall TG Rationale for the short-term use of luteinising hormone-releasing hormone analogues in the treatment of uterine myomata Horm Res 1989 32(Suppl. 1):134 6 2693324
Stovall TG Gonadotropin-releasing hormone agonists: utilization before hysterectomy Clin Obstet Gynecol 1993 36(3):642 9 8403610
Stovall TG, Ling FW, Crawford DA Hysterectomy for chronic pelvic pain of presumed uterine etiology Obstet Gynecol 1990 75(4):676 9 2248635
Stovall TG, Ling FW, Henry LC, et al A randomized trial evaluating leuprolide acetate before hysterectomy as treatment for leiomyomas Am J Obstet Gynecol 1991 164(6 Pt 1):1420 3 discussion 1423-5 1904681
Stovall TG, Muneyyirci-Delale O, Summitt RL Jr, et al GnRH agonist and iron versus placebo and iron in the anemic patient before surgery for leiomyomas: a randomized controlled trial. Leuprolide Acetate Study Group Obstet Gynecol 1995 86(1):65 71 7784025
Stovall TG, Summit RL Jr, Washburn SA, et al Gonadotropin-releasing hormone agonist use before hysterectomy Am J Obstet Gynecol 1994 170(6):1744 8 discussion 1748-51 8203435
Stringer NH Laparoscopic myomectomy in African-American women J Am Assoc Gynecol Laparosc 1996 3(3):375 81 9050659
Stringer NH One hundred laparoscopic myomectomies with ultrasonic energy: Surgical evaluation of a new energy source Gynaecol Endoscopy 1998 7(2):85 93
Stringer NH, McMillen MA, Jones RL, et al Uterine closure with the endo stitch 10-mm laparoscopic suturing device -- a review of 50 laparoscopic myomectomies Int J Fertil Womens Med 1997 42(5):288 96 9406833
Stringer NH, Walker JC, Meyer PM Comparison of 49 laparoscopic myomectomies with 49 open myomectomies J Am Assoc Gynecol Laparosc 1997 4(4):457 64 9224580
Strobelt N, Ghidini A, Cavallone M, et al Natural history of uterine leiomyomas in pregnancy J Ultrasound Med 1994 13(5):399 401 8015049
Stroup DF, Berlin JA, Morton SC, et al. Meta-analysis of observational studies in epidemiology: a proposal for reporting. JAMA. 2000;283:2008-12. [pmid: 10789670].
Studd J, Leather AT The need for add-back with gonadotrophin-releasing hormone agonist therapy Br J Obstet Gynaecol 1996 103(Suppl 14):1 4
Sudik R, Husch K, Steller J, et al Fertility and pregnancy outcome after myomectomy in sterility patients Eur J Obstet Gynecol Reprod Biol 1996 65(2):209 14 8730626
Sutton CJG Treatment of large utrine fibroids Br J Obstet Gynaecol 1996 103(6):494 6 8645637
Swe TT, Onitsuka H, Kawamoto K, et al Uterine leiomyoma: Correlation between signal intensity on magnetic resonance imaging and pathologic characteristics Radiat Med 1992 10(6):235 42 1287735
Szafranko K, Powolny M Comparative analysis of surgical procedures for uterine myomas in the year 1986-1995 in the Department of Gynaecology and Obstetrics of the Ministry of Home Affairs Hospital in Warsaw Med Sci Monitor 1997 3(1):76 80
Szamatowicz J, Laudanski T, Bulkszas B, et al Fibromyomas and uterine contractions Acta Obstet Gynecol Scand 1997 76(10):973 6 9435739
Tahir MM, Bigrigg MA, Browning JJ, et al A randomised controlled trial comparing transvaginal ultrasound, outpatient hysteroscopy and endometrial biopsy with inpatient hysteroscopy and curettage Br J Obstet Gynaecol 1999 106(12):1259 64 10609719
Takamizawa S, Minakami H, Usui R, et al Risk of complications and uterine mALIGNancies in women undergoing hysterectomy for presumed benign leiomyomas Gynecol Obstet Invest 1999 48(3):193 6 10545745
Taylor CV, Letarte M, Lye SJ The expression of integrins and cadherins in normal human uterus and uterine leiomyomas Am J Obstet Gynecol 1996 175(2):411 9 8765262
Taylor T, Smith AN, Fulton PM Effect of hysterectomy on bowel function BMJ 1989 299(6694):300 1 2504409 1837168
Tepper R, Beyth Y, Altaras MM, et al Value of sonohysterography in asymptomatic postmenopausal tamoxifen-treated patients Gynecol Oncol 1997 64(3):386 91 9062139
Thom DH, van den Eeden SK, Brown JS Evaluation of parturition and other reproductive variables as risk factors for urinary incontinence in later life Obstet Gynecol 1997 90(6):983 9 9397116
Thomas EJ Add-back therapy for long-term use in dysfunctional uterine bleeding and uterine fibroids Br J Obstet Gynaecol 1996 103(Suppl 14):18 21 8916983
Thorsen P, Moller BR, Ahrons S GnRH-agonist in the treatment of fibromyomata of the uterus J Obstet Gynaecol 1993 13(1):68 9
Tiltman AJ The effect of progestins on the mitotic activity of uterine fibromyomas Int J Gynecol Pathol 1985 4(2):89 96 3926664
Togashi K, Ozasa H, Konishi I, et al Enlarged uterus: differentiation between adenomyosis and leiomyoma with MR imaging Radiology 1989 171(2):531 4 2704819
Tomas E, Kauppila A, Blanco G, et al Comparison between the effects of tamoxifen and toremifene on the uterus in postmenopausal breast cancer patients Gynecol Oncol 1995 59(2):261 6 7590484
Torrance GW Preferences for health outcomes and cost-utility analysis Am J Managed Care 1997 3(Suppl):S8 20
Treissman DA, Bate JT, Randall PT Epidural use of morphine in managing the pain of carneous degeneration of a uterine leiomyoma during pregnancy CMAJ 1982 126(5):505 6 7066809 1863056
Tuck SM, Yudkin PL, Turnbull AC Pregnancy outcome in elderly primigravidae with and without a history of infertility Br J Obstet Gynaecol 1988 95(3):230 7 3370195
Tulandi T, Murray C, Guralnick M Adhesion formation and reproductive outcome after myomectomy and second-look laparoscopy Obstet Gynecol 1993 82(2):213 5 8336866
Tulandi T, Popkin D. Infertility surgery with the laser beam. Obstet Gynecol Annual. 1985;14:266-76.
Tulandi T, Youseff H Laparoscopy-assisted myomectomy of large uterine myomas Gynaecol Endoscopy 1997 6(2):105 8
Tuppurainen M, Honkanen R, Kroger H, et al Osteoporosis risk factors, gynaecological history and fractures in perimenopausal women -- the results of the baseline postal enquiry of the Kuopio Osteoporosis Risk Factor and Prevention Study Maturitas 1993 17(2):89 100 8231907
Tuppurainen M, Kroger H, Saarikoski S, et al The effect of gynecological risk factors on lumbar and femoral bone mineral density in peri- and postmenopausal women Maturitas 1995 21(2):137 45 7752951
Turner RT, Berman AM, Topel HC Improved demonstration of endometrial polyps and submucous myomas using saline-enhanced vaginal sonohysterography J Am Assoc Gynecol Laparosc 1995 2(4):421 5 9050596
Ubaldi F, Tournaye H, Camus M, et al Fertility after hysteroscopic myomectomy Hum Reprod Update 1995 1(1):81 90 9080209
Ueki M, Okamoto Y, Tsurunaga T, et al Endocrinological and histological changes after treatment of uterine leiomyomas with danazol or buserelin J Obstet Gynaecol 1995 21(1):1 7 8591104
Uemura T, Mori J, Yoshimura Y, et al Treatment effects of GnRH agonist on the binding of estrogen and progesterone, and the histological findings of uterine leiomyomas Asia Oceania J Obstet Gynaecol 1991 17(4):315 20 1724899
Ugur M, Turan C, Mungan T, et al Laparoscopy for adhesion prevention following myomectomy Int J Gynaecol Obstet 1996 53(2):145 9 8735295
Ugwumadu AH, Harding K Uterine leiomyomata and endometrial proliferation in postmenopausal women treated with the anti-oestrogen tamoxifen Eur J Obstet Gynecol Reprod Biol 1994 54(2):153 6 8070603
Valle RF Hysteroscopy in the evaluation of female infertility Am J Obstet Gynecol 1980 137(4):425 31 7386525
van Dam JH, Gosselink MJ, Drogendijk AC, et al Changes in bowel function after hysterectomy Dis Colon Rectum 1997 40(11):1342 7 9369110
Van der Ven LTM, Van Buul-Offers SC, Gloudemans T, et al Modulation of insulin-like growth factor (IGF) action by IGF-binding proteins in normal, benign, and mALIGNant smooth muscle tissues J Clin Endocrinol Metab 1996 18(10):3629 35
Van Dinh T, Woodruff JD Leiomyosarcoma of the uterus Am J Obstet Gynecol 1982 144(7):817 23 7148905
van Leusden HA Symptom-free interval after triptorelin treatment of uterine fibroids: long-term results Gynecol Endocrinol 1992 6(3):189 98 1442164
Varasteh NN, Neuwirth RS, Levin B, et al Pregnancy rates after hysteroscopic polypectomy and myomectomy in infertile women Obstet Gynecol 1999 94(2):168 71 10432121
Varma JS Autonomic influences on colorectal motility and pelvic surgery World J Surg 1992 16(5):811 9 1462613
Vashisht A, Studd J, Carey A, et al Fatal septicaemia after fibroid embolisation Lancet 1999 354(9175):307 8
Vavala V, Lanzone A, Monaco A, et al Postoperative GnRH analog treatment for the prevention of recurrences of uterine myomas after myomectomy. A pilot study Gynecol Obstet Invest 1997 43(4):251 4 9194624
Velebil P, Wingo PA, Xia Z, et al Rate of hospitalization for gynecologic disorders among reproductive-age women in the United States Obstet Gynecol 1995 86(5):764 9 7566845
Vercellini P, Bocciolone L, Colombo A, et al Gonadotropin releasing hormone agonist treatment before hysterectomy for menorrhagia and uterine leiomyomas Acta Obstet Gynecol Scand 1993 72(5):369 73 8392268
Vercellini P, Crosignani PG Goserelin (Zoladex) and the anaemic patient Br J Obstet Gynaecol 1994 101(10 Suppl.):33 7 8199103
Vercellini P, Crosignani PG, Mangioni C, et al Treatment with a gonadotrophin releasing hormone agonist before hysterectomy for leiomyomas: results of a multicentre, randomised controlled trial Br J Obstet Gynaecol 1998 105(11):1148 54 9853762
Vercellini P, Maddalena S, De Giorgi O, et al Determinants of reproductive outcome after abdominal myomectomy for infertility Fertil Steril 1999 72(1):109 14 10428157
Vercellini P, Oldani S, De Giorgi O, et al Endometrial ablation with a vaporizing electrode. II. Clinical outcome of a pilot study Acta Obstet Gynecol Scand 1998 77(6):688 93 9688250
Vercellini P, Zaina B, Yaylayan L, et al Hysteroscopic myomectomy: long-term effects on menstrual pattern and fertility Obstet Gynecol 1999 94(3):341 7 10472856
Vergani P, Ghidini A, Strobelt N, et al Do uterine leiomyomas influence pregnancy outcome? Am J Perinatol 1994 11(5):356 8 7993518
Verkauf BS Myomectomy for fertility enhancement and preservation Fertil Steril 1992 58(1):1 15 1623990
Verkauf BS Changing trends in treatment of leiomyomata uteri Curr Opin Obstet Gynecol 1993 5(3):301 10 8329644
Verkauf BS The myomatous uterus and reproductive failure. Diagnostic aids for planning therapy Infertil Reprod Med Clinics North Am 1995 6(1):103 34
Verkauf BS Myomectomy as a fertility-promoting procedure Infertil Reprod Med Clinics North Am 1996 7(1):69 89
Vervest HA, Kiewiet de Jonge M, Vervest TM, et al Micturition symptoms and urinary incontinence after non-radical hysterectomy Acta Obstet Gynecol Scand 1988 67(2):141 6 3176929
Vervest HA, van Venrooij GE, Barents JW, et al Non-radical hysterectomy and the function of the lower urinary tract. I: Urodynamic quantification of changes in storage function Acta Obstet Gynecol Scand 1989 68(3):221 9 2618605
Vervest HA, van Venrooij GE, Barents JW, et al Non-radical hysterectomy and the function of the lower urinary tract. II: Urodynamic quantification of changes in evacuation function Acta Obstet Gynecol Scand 1989 68(3):231 5 2618606
Vilos GA, Pispidikis JT, Botz CK Economic evaluation of hysteroscopic endometrial ablation versus vaginal hysterectomy for menorrhagia Obstet Gynecol 1996 88(2):241 5 8692509
Virtanen H, Makinen J, Tenho T, et al Effects of abdominal hysterectomy on urinary and sexual symptoms Br J Urol 1993 72(6):868 72 8306148
Viville B, Charnock-Jones DS, Sharkey AM, et al Distribution of the A and B forms of the progesterone receptor messenger ribonucleic acid and protein in uterine leiomyomata and adjacent myometrium Hum Reprod 1997 12(4):815 22 9159448
Vollenhoven B Introduction: The epidemiology of uterine leiomyomas Baillieres Clin Obstet Gynaecol 1998 12(2):169 76 10023416
Vollenhoven BJ, Healy DL Fibroids: Diagnosis and management Modern Med Aust 1993 36(2):46 55
Vollenhoven BJ, Herington AC, Healy DL Messenger ribonucleic acid expression of the insulin-like growth factors and their binding proteins in uterine fibroids and myometrium J Clin Endocrinol Metab 1993 76(5):1106 10 7684390
Vollenhoven BJ, Herington AC, Healy DL Messenger RNA encoding the insulin-like growth factors and their binding proteins, in women with fibroids, pretreated with luteinizing hormone-releasing hormone agonists Hum Reprod 1994 9(2):214 9 7517948
Vollenhoven BJ, Herington AC, Healy DL Epidermal growth factor and transforming growth factor-beta in uterine fibroids and myometriu Gynecol Obstet Invest 1995 40(2):120 4 8575689
Vollenhoven BJ, McCloud P, Shekleton P, et al An open study of luteinizing hormone releasing hormone agonists in infertile women with uterine fibroids Gynecol Endocrinol 1993 7(1):57 61 8506764
Vollenhoven BJ, Pearce P, Herington AC, et al Steroid receptor binding and messenger RNA expression in fibroids from untreated and gonadotrophin-releasing hormone agonist pretreated women Clin Endocrinol (Oxf) 1994 40(4):537 44 298219 8187322
Vollenhoven BJ, Shekleton P, McDonald J, et al Clinical predictors for buserelin acetate treatment of uterine fibroids: a prospective study of 40 women Fertil Steril 1990 54(6):1032 8 2123160
Vu K, Greenspan DL, Wu TC, et al Cellular proliferation, estrogen receptor, progesterone receptor, and bcl-2 expression in GnRH agonist-treated uterine leiomyomas Hum Pathol 1998 29(4):359 63 9563785
Wake CR The immediate effect of abdominal hysterectomy on intravesical pressure and detrusor activity Br J Obstet Gynaecol 1980 87(10):901 2 7426488
Wallach EE, Vu KK Myomata uteri and infertility Obstet Gynecol Clin North Am 1995 22(4):791 9 8786882
Walling AD The role of GnRH agonist therapy before hysterectomy Am Fam Physician 1995 52(1):253 258
Wamsteker K, Emanuel MH, de Kruif JH Transcervical hysteroscopic resection of submucous fibroids for abnormal uterine bleeding: results regarding the degree of intramural extension Obstet Gynecol 1993 82(5):736 40 8414318
Wang PH, Lee WL, Chao HT, et al Relationship between hormone receptor concentration and tumor shrinkage in uterine myoma after treatment with a GnRHa Chung Hua I Hsueh Tsa Chih (Taipei) 1999 62(5):294 9 10389284
Wang PH, Yang AH, Yuan CC, et al Uterine myoma after cessation of gonadotropin-releasing hormone agonist: ultrasound and histopathologic findings Chung Hua I Hsueh Tsa Chih (Taipei) 1998 61(11):625 9 9872018
Warnock JK, Bundren JC, Morris DW Depressive symptoms associated with gonadotropin-releasing hormone agonists Depress Anxiety 1998 7(4):171 7 9706454
Watanabe Y, Nakamura G Effects of two different doses of leuprolide acetate depot on uterine cavity area in patients with uterine leiomyomata Fertil Steril 1995 63(3):487 90 7851574
Watanabe Y, Nakamura G, Matsuguchi H, et al Efficacy of a low-dose leuprolide acetate depot in the treatment of uterine leiomyomata in Japanese women Fertil Steril 1992 58(1):66 71 1624025
Watson NR, Studd JW, Garnett T, et al Bone loss after hysterectomy with ovarian conservation Obstet Gynecol 1995 86(1):72 7 7784026
Weather L Jr Carbon dioxide laser myomectomy J Natl Med Assoc 1986 78(10):933 6 3097332
Webb MJ, Aronson MP, Ferguson LK, et al Posthysterectomy vaginal vault prolapse: primary repair in 693 patients Obstet Gynecol 1998 92(2):281 5 9699767
Weber AM, Mitchinson AR, Gidwani GP, et al Uterine myomas and factors associated with hysterectomy in premenopausal women Am J Obstet Gynecol 1997 176(6):1213 9 9215176
Weber AM, Walters MD, Schover LR, et al Functional outcomes and satisfaction after abdominal hysterectomy Am J Obstet Gynecol 1999 181(3):530 5 10486459
Weeks AD, Duffy SRG, Walker JJ Uterine ultrasonographic changes with gonadotropin-releasing hormone agonists Am J Obstet Gynecol 1999 180(1 Pt 1):8 13 9914569
Weinreb JC, Brown CE, Lowe TW, et al Pelvic masses in pregnant patients: MR and US imaging Radiology 1986 159(3):717 24 3517956
West C Management of uterine fibroids Practitioner 1992 236(1511):117 8,121 1598325
West CP LHRH analogues in the management of uterine fibroids, premenstrual syndrome and breast mALIGNancies Baillieres Clin Obstet Gynaecol 1988 2(3):689 709 3069270
West CP Hysterectomy and myomectomy by laparotomy Baillieres Clin Obstet Gynaecol 1998 12(2):317 35 10023424
West CP, Lumsden MA Fibroids and menorrhagia Baillieres Clin Obstet Gynaecol 1989 3(2):357 74 2692925
West CP, Lumsden MA, Baird DT LHRH analogues and fibroids -- Potential for longer-term use Horm Res 1989 32(Suppl. 1):146 9 2693325
West CP, Lumsden MA, Hillier H, et al Potential role for medroxyprogesterone acetate as an adjunct to goserelin (Zoladex) in the medical management of uterine fibroids Hum Reprod 1992 7(3):328 32 1534089
Whittemore AS, Harris R, Itnyre J Characteristics relating to ovarian cancer risk: collaborative analysis of 12 US case-control studies. II. Invasive epithelial ovarian cancers in white women. Collaborative Ovarian Cancer Group Am J Epidemiol 1992 136(10):1184 203 1476141
Wilson EE, Little BB, Byrd W, et al The effect of gonadotropin-releasing hormone agonists on adrenocorticotropin and cortisol secretion in adult premenopausal women J Clin Endocrinol Metab 1993 76(1):162 4 8380603
Winer-Muram HT, Muram D, Gillieson MS Uterine myomas in pregnancy J Can Assoc Radiol 1984 35(2):168 70 6384226
Wood C Alternative treatment Baillieres Clin Obstet Gynaecol 1995 9(2):373 97 7554619
Wood C Surgical and medical treatment of adenomyosis Hum Reprod Update 1998 4(4):323 36 9825848
Wood C, Maher P Endoscopic treatment of uterine fibroids Baillieres Clin Obstet Gynaecol 1998 12(2):289 316 10023423
Woolf SH, DiGuiseppi CG, Atkins D, et al. Developing evidence-based clinical practice guidelines: lessons learned by the US Preventive Services Task Force. Ann Rev Publ Health. 1996;17:511-38.
Worthington-Kirsch RL, Popky GL, Hutchins FL Jr Uterine arterial embolization for the management of leiomyomas: quality-of-life assessment and clinical response Radiology 1998 208(3):625 9 9722838
Wortman M, Dagget A Hysteroscopic myomectomy J Am Assoc Gynecol Laparosc 1995 3(1):39 46 9050615
Yamada T, Ikeda A, Okamoto Yu, et al Intraoperative blood salvage in abdominal simple total hysterectomy for uterine myoma Int J Gynecol Obstet 1997 59(3):233 6
Yamada T, Yamashita Y, Terai Y, et al Intraoperative blood salvage in abdominal uterine myomectomy Int J Gynaecol Obstet 1997 56(2):141 5 9061388
Yamashita Y, Torashima M, Takahashi M, et al Hyperintense uterine leiomyoma at T2-weighted MR imaging: differentiation with dynamic enhanced MR imaging and clinical implications Radiology 1993 189(3):721 5 8234695
Yao SL, Lu-Yao G Population-based study of relationships between hospital volume of prostatectomies, patient outcomes, and length of hospital stay J Nat Cancer Inst 1999 91(22):1950 6 10564679
Yin CS, Wei RY, Chao TC, et al Hysteroscopic endometrial ablation without endometrial preparation Int J Gynaecol Obstet 1998 62(2):167 72 9749888
Ylikorkala O, Pekonen F Naproxen reduces idiopathic but not fibromyoma-induced menorrhagia Obstet Gynecol 1986 68(1):10 2 3523328
Ylikorkala O, Tiitinen A, Hulkko S, et al Decrease in symptoms, blood loss and uterine size with nafarelin acetate before abdominal hysterectomy: a placebo-controlled, double-blind study Hum Reprod 1995 10(6):1470 4 7593517
Ylostalo P, Granberg S, Backstrom AC, et al Uterine findings by transvaginal sonography during percutaneous estrogen treatment in postmenopausal women Maturitas 1996 23(3):313 7 8794426
Zamberlan N, Castello R, Gatti D, et al Intermittent etidronate partially prevents bone loss in hirsute hyperandrogenic women treated with GnRH agonist Osteoporos Int 1997 7(2):133 7 9166393
Zawin M, McCarthy S, Scoutt L, et al Monitoring therapy with a gonadotropin-releasing hormone analog: utility of MR imaging Radiology 1990 175(2):503 6 2109336
Zhao SZ, Wong JM, Arguelles LM Hospitalization costs associated with leiomyoma Clin Ther 1999 21(3):563 75 10321423
Zullo E, Pellicano M, De Stefano R, et al GnRH analogues and laparoscopic myomectomy Ital J Gynaecol Obstet 1997 9(2):63 7
Zullo F, Pellicano M, De Stefano R, et al A prospective randomized study to evaluate leuprolide acetate treatment before laparoscopic myomectomy: efficacy and ultrasonographic predictors Am J Obstet Gynecol 1998 178(1 Pt 1):108 12 9465812
Zullo F, Pellicano M, Di Carlo C, et al Ultrasonographic prediction of the efficacy of GnRH agonist therapy before laparoscopic myomectomy J Am Assoc Gynecol Laparosc 1998 5(4):361 6 9782139
Zussman L, Zussman S, Sunley R, et al Sexual response after hysterectomy-oophorectomy: recent studies and reconsideration of psychogenesis Am J Obstet Gynecol 1981 140(7):725 9 7196155