# References

Abramovici H, Dirnfeld M, Auslander R, et al Pregnancies following treatment by GnRH-a (Decapeptyl) and myomectomy in infertile women with uterine leiomyomata Int J Fertil Menopausal Stud 1994 39(3):150 5 7920751
Acien P, Quereda F Abdominal myomectomy: results of a simple operative technique Fertil Steril 1996 65(1):41 51 8557153
Adamson GD. Myomectomy, GnRH analogs, and adhesions. Prog Clin Biol Res. 1993;381:155-85. [pmid: 8316560].
Aharoni A, Reiter A, Golan D, et al Patterns of growth of uterine leiomyomas during pregnancy. A prospective longitudinal study Br J Obstet Gynaecol 1988 95(5):510 3 3042016
Akkad AA, Habiba MA, Ismail N, et al Abnormal uterine bleeding on hormone replacement: the importance of intrauterine structural abnormalities Obstet Gynecol 1995 86(3):330 4 7651636
Alexander DA, Naji AA, Pinion SB, et al Randomised trial comparing hysterectomy with endometrial ablation for dysfunctional uterine bleeding: psychiatric and psychosocial aspects BMJ 1996 312(7026):280 4 8611783
Andersen J, Barbieri RL Abnormal gene expression in uterine leiomyomas J Soc Gynecol Invest 1995 2(5):663 72
Anderson RN. United States Life Tables, 1997. National Vital Statistics Reports, Vol. 47, No. 28. Hyattsville, MD: National Center for Health Statistics, 1999.
Andrei B, Crovini G, Rosi A Uterine myomas: Pelviscopic treatment Clin Exp Obstet Gynecol 1999 26(1):44 6 10490357
Anonymous Prophylaxis of pelvic sidewall adhesions with Gore-Tex surgical membrane: a multicenter clinical investigation. The Surgical Membrane Study Group Fertil Steril 1992 57(4):921 3 1555708
Anonymous Effects of estrogen or estrogen/progestin regimens on heart disease risk factors in postmenopausal women. The Postmenopausal Estrogen/Progestin Interventions (PEPI) Trial. The Writing Group for the PEPI Trial [published erratum appears in JAMA 1995 Dec 6;274(21):1676] JAMA 1995 273(3):199 208 7807658
Anonymous Drugs in the peri-operative period: 3-Hormonal contraceptives and hormone replacement therapy Drug Ther Bull 1999 37(10):78 80 10696684
Anteby SO, Yarkoni S, Ever Hadani P The effect of a prostaglandin synthetase inhibitor, indomethacin, on excessive uterine bleeding Clin Exp Obstet Gynecol 1985 12(3-4):60 3 4064305
Ashraf T Management of uterine leiomyomas J Coll Phys Surg Pakistan 1997 7(4):160 2
Aslan P, Brooks A, Drummond M, et al Incidence and management of gynaecological-related ureteric injuries Aust N Z J Obstet Gynaecol 1999 39(2):178 81 10755773
Audebert AJ, Madenelat P, Querleu D, et al Deferred versus immediate surgery for uterine fibroids: clinical trial results Br J Obstet Gynaecol 1994 101(Suppl 10):29 32
Averette HE, Nguyen HN The role of prophylactic oophorectomy in cancer prevention Gynecol Oncol 1994 55(3 Pt 2):S38 41 7835808
Ayala AR, Meza E, Cervera Aguilar R, et al. Effect of insuflated Nafarelin (D-Nal-6-GnRH) upon uterine leiomyomata. Arch Med Res. 1995;26:S23-S26. [pmid: 8845654].
Babaknia A, Rock JA, Jones HW Jr Pregnancy success following abdominal myomectomy for infertility Fertil Steril 1978 30(6):644 7 729825
Baggish MS, Sze EHM, Morgan G Hysteroscopic treatment of symptomatic submucous myomata uteri with the Nd: YAG laser J Gynecol Surg 1989 5(1):27 36
Balasch J, Manau D, Mimo J, et al Trial of routine gonadotropin releasing hormone agonist treatment before abdominal hysterectomy for leiomyoma Acta Obstet Gynecol Scand 1995 74(7):562 5 7618457
Ballard LA, Walters MD Transvaginal mobilization and removal of ovaries and fallopian tubes after vaginal hysterectomy Obstet Gynecol 1996 87(1):35 9 8532262
Benagiano G, Kivinen ST, Fadini R, et al Zoladex (goserelin acetate) and the anemic patient: results of a multicenter fibroid study Fertil Steril 1996 66(2):223 9 8690106
Benagiano G, Morini A, Aleandri V, et al Sequential Gn-RH superagonist and medroxyprogesterone acetate treatment of uterine leiomyomata Int J Gynaecol Obstet 1990 33(4):333 43 1979288
Ben-Baruch G, Schiff E, Menashe Y, et al. Immediate and late outcome of vaginal myomectomy for prolapsed pedunculated submucous myoma. Obstet Gynecol. 1988;72:858-61. [pmid: 3186093].
Berkeley AS, DeCherney AH, Polan ML Abdominal myomectomy and subsequent fertility Surg Gynecol Obstet 1983 156(3):319 22 6828976
Bernard G, Darai E, Poncelet C, et al Fertility after hysteroscopic myomectomy: effect of intramural myomas associated Eur J Obstet Gynecol Reprod Biol 2000 88(1):85 90 10659923
Bernhard LA Consequences of hysterectomy in the lives of women Health Care Women Internat 1992 13(3):281 91
Bhattacharya S, Mollison J, Pinion S, et al A comparison of bladder and ovarian function two years following hysterectomy or endometrial ablation [published erratum appears in Br J Obstet Gynaecol 1996 Dec;103(12):1273] Br J Obstet Gynaecol 1996 103(9):898 903 8813310
Bianchi G, Costantini S, Anserini P, et al Effects of gonadotrophin-releasing hormone agonist on uterine fibroids and bone density Maturitas 1989 11(3):179 85 2512467
Borgfeldt C, Andolf E Transvaginal ultrasonographic findings in the uterus and the endometrium: low prevalence of leiomyoma in a random sample of women age 25-40 years Acta Obstet Gynecol Scand 2000 79(3):202 7 10716301
Bradham DD, Stovall TG, Thompson CD Use of GnRH agonist before hysterectomy: a cost simulation Obstet Gynecol 1995 85(3):401 6 7862380
Broder MS, Kanouse DE, Mittman BS, et al. The appropriateness of recommendations for hysterectomy. Obstet Gynecol. 2000;95:199-205. [pmid: 10674580].
Broekmans FJ, Hompes PG, Heitbrink MA, et al Two-step gonadotropin-releasing hormone agonist treatment of uterine leiomyomas: standard-dose therapy followed by reduced-dose therapy Am J Obstet Gynecol 1996 175(5):1208 16 8942490
Brooks PG, Loffer FD, Serden SP Resectoscopic removal of symptomatic intrauterine lesions J Reprod Med 1989 34(7):435 7
Brown D, Fletcher HM, Myrie MO, et al Caesarean myomectomy -- A safe procedure. A retrospective case controlled study J Obstet Gynaecol 1999 19(2):139 41 15512253
Brown JS, Seeley DG, Fong J, et al Urinary incontinence in older women: who is at risk? Study of Osteoporotic Fractures Research Group Obstet Gynecol 1996 87(5 Pt 1):715 21 8677073
Burton CA, Grimes DA, March CM Surgical management of leiomyomata during pregnancy Obstet Gynecol 1989 74(5):707 9 2812645
Bush TL, Barrett-Connor E, Cowan LD, et al Cardiovascular mortality and noncontraceptive use of estrogen in women: results from the Lipid Research Clinics Program Follow-up Study Circulation 1987 75(6):1102 9 3568321
Buttram VC Jr, Reiter RC Uterine leiomyomata: Etiology, symptomatology, and management Fertil Steril 1981 36(4):433 45 7026295
Cagnacci A, Paoletti AM, Soldani R, et al Role of goserelin-depot in the clinical management of uterine fibroids Clin Exp Obstet Gynecol 1994 21(4):263 5 7994879
Caird LE, West CP, Lumsden MA, et al Medroxyprogesterone acetate with Zoladex for long-term treatment of fibroids: effects on bone density and patient acceptability Hum Reprod 1997 12(3):436 40 9130735
Candiani GB, Fedele L, Parazzini F, et al Risk of recurrence after myomectomy Br J Obstet Gynaecol 1991 98(4):385 9 2031897
Carlson KJ, Miller BA, Fowler FJ Jr The Maine Women's Health Study: I. Outcomes of hysterectomy Obstet Gynecol 1994a 83(4):556 65 8134066
Carlson KJ, Miller BA, Fowler FJ Jr The Maine Women's Health Study: II. Outcomes of nonsurgical management of leiomyomas, abnormal bleeding, and chronic pelvic pain Obstet Gynecol 1994b 83(4):566 72 8134067
Carr BR, Marshburn PB, Weatherall PT, et al An evaluation of the effect of gonadotropin-releasing hormone analogs and medroxyprogesterone acetate on uterine leiomyomata volume by magnetic resonance imaging: a prospective, randomized, double blind, placebo-controlled, crossover trial J Clin Endocrinol Metab 1993 76(5):1217 23 8496313
Carter JE, McCarus SD Laparoscopic myomectomy: time and cost analysis of power vs. manual morcellation J Reprod Med 1997 42(7):383 8 9252927
Cetin MT, Vardar MA, Demir SC, et al Administration of preoperative gonadotropin releasing hormone agonist (buserelin) for uterine leiomyomas Ann Med Sci 1995 4(2):102 8
Chapman R New therapeutic technique for treatment of uterine leiomyomas using laser-induced interstitial thermotherapy (LITT) by a minimally invasive method Lasers Surg Med 1998 22(3):171 8 9510102
Chong RK, Thong PH, Tan SL, et al Myomectomy: indications, results of surgery and relation to fertility Singapore Med J 1988 29(1):35 7 3406762
Cirkel U, Ochs H, Schneider HP, et al Experience with leuprorelin acetate depot in the treatment of fibroids: a German multicentre study Clin Ther 1992 14(Suppl A):37 50 1606593
Clarke A, Black N, Rowe P, et al Indications for and outcome of total abdominal hysterectomy for benign disease: a prospective cohort study Br J Obstet Gynaecol 1995 102(8):611 20 7654638
Coddington CC, Brzyski R, Hansen KA, et al Short term treatment with leuprolide acetate is a successful adjunct to surgical therapy of leiomyomas of the uterus Surg Gynecol Obstet 1992 175(1):57 63 1621201
Colditz GA, Willett WC, Stampfer MJ, et al Menopause and the risk of coronary heart disease in women N Engl J Med 1987 316(18):1105 10 3574358
Connelly CS, Panush RS Should nonsteroidal anti-inflammatory drugs be stopped before elective surgery? Arch Intern Med 1991 151(10):1963 6 1929684
Coppen A, Bishop M, Beard RJ, et al Hysterectomy, hormones, and behaviour. A prospective study Lancet 1981 1(8212):126 8 6109801
Cornelison TL, Natarajan N, Piver MS, et al. Tubal ligation and the risk of ovarian carcinoma. Cancer Detect Prev. 1997;21:1-6. [pmid: 9043756].
Coronado GD, Marshall LM, Schwartz SM. Complications in pregnancy, labor, and delivery with uterine leiomyomas: a population-based study. Obstet. Gynecol. 2000;95:764-9. [pmid: 10775744].
Corson SL, Brooks PG Resectoscopic myomectomy Fertil Steril 1991 55(6):1041 4 2037101
Costantini S, Anserini P, Valenzano M, et al Luteinizing hormone-releasing hormone analog therapy of uterine fibroid: analysis of results obtained with buserelin administered intranasally and goserelin administered subcutaneously as a monthly depot Eur J Obstet Gynecol Reprod Biol 1990 37(1):63 9 2142921
Coulam CB, Adamson SC, Annegers JF Incidence of premature ovarian failure Obstet Gynecol 1986 67(4):604 6 3960433
Courban D, Blank S, Harris MA, et al Acute renal failure in the first trimester resulting from uterine leiomyomas Am J Obstet Gynecol 1997 177(2):472 3 9290476
Coutinho EM. Gestrinone in the treatment of myomas. Acta Obstet Gynecol Scand Suppl. 1989;150:39-46. [pmid: 2694740].
Coutinho EM Treatment of large fibroids with high doses of gestrinone Gynecol Obstet Invest 1990 30(1):44 7 2227612
Coutinho EM, Boulanger GA, Goncalves MT Regression of uterine leiomyomas after treatment with gestrinone, an antiestrogen, antiprogesterone Am J Obstet Gynecol 1986 155(4):761 7 3532799
Coutinho EM, Goncalves MT Long-term treatment of leiomyomas with gestrinone Fertil Steril 1989 51(6):939 46 2656310
Cramer SF, Patel A The frequency of uterine leiomyomas Am J Clin Pathol 1990 94(4):435 8 2220671
Cravello L, D'Ercole C, Boubli L, et al Hysteroscopic treatment of uterine fibroids J Gynecol Surg 1995 11(4):227 32
Cravello L, Farnarier J, De Montgolfier R, et al Hysteroscopic resection of fibroids: Results with a 6-year follow-up period J Gynecol Surg 1999 15(1):1 5
Criqui MH, Suarez L, Barrett-Connor E, et al Postmenopausal estrogen use and mortality. Results from a prospective study in a defined, homogeneous community Am J Epidemiol 1988 128(3):606 14 3414664
Crosignani PG, Vercellini P, Apolone G, et al Endometrial resection versus vaginal hysterectomy for menorrhagia: long-term clinical and quality-of-life outcomes Am J Obstet Gynecol 1997 177(1):95 101 9240590
Cruikshank SH, Kovac SR Randomized comparison of three surgical methods used at the time of vaginal hysterectomy to prevent posterior enterocele Am J Obstet Gynecol 1999 180(4):859 65 10203653
D'Addato F, Repinto A, Andreoli C Pre-surgical treatment of uterine myomas with LH-RH agonists Clin Exp Obstet Gynecol 1992 19(1):45 50 1535032
Daly JW, Higgins KA Injury to the ureter during gynecologic surgical procedures Surg Gynecol Obstet 1988 167(1):19 22 3381180
Daniell J Argon beam coagulator for laparoscopic myomectomy Gynaecol Endoscopy 1995 4(3):219 22
Darai E, Dechaud H, Benifla JL, et al Fertility after laparoscopic myomectomy: preliminary results Hum Reprod 1997 12(9):1931 4 9363709
Davies A, Hart R, Magos AL The excision of uterine fibroids by vaginal myomectomy: a prospective study Fertil Steril 1999 71(5):961 4 10231066
Davies A, O'Connor H, Magos AL A prospective study to evaluate oophorectomy at the time of vaginal hysterectomy Br J Obstet Gynaecol 1996 103(9):915 20 8813313
de Aloysio D, Altieri P, Penacchioni P, et al Bleeding patterns in recent postmenopausal outpatients with uterine myomas: comparison between two regimens of HRT Maturitas 1998 29(3):261 4 9699198
de Aloysio D, Altieri P, Pretolani G, et al The combined effect of a GnRH analog in premenopause plus postmenopausal estrogen deficiency for the treatment of uterine leiomyomas in perimenopausal women Gynecol Obstet Invest 1995 39(2):115 9 7737580
De Blok S, Dijkman AB, Hemrika DJ Transcervical resection of fibroids (TCRM): results related to hysteroscopic classification Gynaecol Endoscopy 1996 4(4):243 6
De Leo V, la Marca A, Morgante G Short-term treatment of uterine fibromyomas with danazol Gynecol Obstet Invest 1999 47(4):258 62 10352389
De Leo V, Morgante G, Lanzetta D, et al Danazol administration after gonadotrophin-releasing hormone analogue reduces rebound of uterine myomas [published erratum appears in Hum Reprod 1997 Mar;13(3):780] Hum Reprod 1997 12(2):357 60 9070725
De Lia JE, Michelin DP, Johnson SC, et al Cherney versus midline vertical incision for myomectomy or hysterectomy of a significantly enlarged uterus Am J Obstet Gynecol 1995 173(6):1714 8 8610750
Deligdisch L, Hirschmann S, Altchek A Pathologic changes in gonadotropin releasing hormone agonist analogue treated uterine leiomyomata Fertil Steril 1997 67(5):837 41 9130887
Dequesne J, Schmidt N Laser hysteroscopic treatment of uterine fibroids References En Gynecologie Obstetrique 1996 4(3):251 6
Derman SG, Rehnstrom J, Neuwirth RS The long-term effectiveness of hysteroscopic treatment of menorrhagia and leiomyomas Obstet Gynecol 1991 77(4):591 4 2002983
Diamond MP, Bieber E, Coddington C, et al Reduction of adhesions after uterine myomectomy by Seprafilm membrane (HAL-F): A blinded, prospective, randomized, multicenter clinical study Fertil Steril 1996 66(6):904 10 8941053
Dicker RC, Scally MJ, Greenspan JR, et al Hysterectomy among women of reproductive age. Trends in the United States, 1970-1978 JAMA 1982 248(3):323 7 7087126
Dickersin K, Scherer R, Lefebvre C Identifying relevant studies for systematic reviews BMJ 1994 309(6964):1286 91 7718048
Diokno AC, Brock BM, Herzog AR, et al Medical correlates of urinary incontinence in the elderly Urology 1990 36(2):129 38 2385880
Donnez J, Gillerot S, Bourgonjon D, et al Neodymium: YAG laser hysteroscopy in large submucous fibroids Fertil Steril 1990 54(6):999 1003 2245860
Donnez J, Schrurs B, Gillerot S, et al Treatment of uterine fibroids with implants of gonadotropin-releasing hormone agonist: Assessment by hysterography Fertil Steril 1989 51(6):947 50 2498131
Dubuisson JB, Chapron C, Chavet X, et al Fertility after laparoscopic myomectomy of large intramural myomas: preliminary results Hum Reprod 1996 11(3):518 22 8671257
Dubuisson JB, Chapron C, Fauconnier A. Laparoscopic myomectomy: operative technique and results. Ann NY Acad Sci. 1997;828:326-31. [pmid: 9329853].
Dubuisson JB, Chapron C, Fauconnier A, et al Laparoscopic myomectomy and myolysis Curr Opin Obstet Gynecol 1997 9(4):233 8 9263713
Dubuisson JB, Chapron C, Levy L Difficulties and complications of laparoscopic myomectomy J Gynecol Surg 1996 12(3):159 65
Dubuisson JB, Lecuru F, Foulot H, et al Myomectomy by laparoscopy: a preliminary report of 43 cases Fertil Steril 1991 56(5):827 30 1834484
Dubuisson JB, Lecuru F, Foulot H, et al Gonadotrophin-releasing hormone agonist and laparoscopic myomectomy Clin Ther 1992 14(Suppl. A):51 6 1535022
Dueholm M, Forman A, Ingerslev J Regression of residual tissue after incomplete resection of submucous myomas Gynaecol Endoscopy 1998 7(6):309 14
Dunn TS, Stamm C, Delorit M, et al A key clinical pathway for the evaluation of women with abnormal uterine bleeding Obstet Gynecol 2000 95(4 Suppl 1):
Dwyer N, Hutton J, Stirrat GM Randomised controlled trial comparing endometrial resection with abdominal hysterectomy for the surgical treatment of menorrhagia Br J Obstet Gynaecol 1993 100(3):237 43 8476829
Ecker JL, Foster JT, Friedman AJ. Abdominal hysterectomy or abdominal myomectomy for symptomatic leiomyoma: a comparison of preoperative demography and postoperative morbidity. J Gynecol Surg. 1995;11:11-8.
Egwuatu VE Fertility and fetal salvage among women with uterine leiomyomas in a Nigerian Teaching Hospital Int J Fertil 1989 34(5):341 6 2571594
Eldar-Geva T, Meagher S, Healy DL, et al Effect of intramural, subserosal, and submucosal uterine fibroids on the outcome of assisted reproductive technology treatment Fertil Steril 1998 70(4):687 91 9797099
Emanuel MH, Wamsteker K, Hart AAM, et al Long-term results of hysteroscopic myomectomy for abnormal uterine bleeding Obstet Gynecol 1999 93(5):743 8 10912978
Ettinger B, Genant HK, Cann CE Postmenopausal bone loss is prevented by treatment with low-dosage estrogen with calcium Ann Intern Med 1987 106(1):40 5 3789576
Exacoustos C, Rosati P Ultrasound diagnosis of uterine myomas and complications in pregnancy Obstet Gynecol 1993 82(1):97 101 8515934
Falsetti L, Mazzani MD, Rubessa S, et al Presurgical treatment of uterine fibroids by using gonadotropin-releasing hormone agonists Acta Eur Fertil 1992 23(1):29 32 1293897
Farhi J, Ashkenazi J, Feldberg D, et al Effect of uterine leiomyomata on the results of in-vitro fertilization treatment Hum Reprod 1995 10(10):2576 8 8567773
Farquhar CM, Lethaby A, Sowter M, et al An evaluation of risk factors for endometrial hyperplasia in premenopausal women with abnormal menstrual bleeding Am J Obstet Gynecol 1999 181(3):525 9 10486458
Farquhar CM, Vandekerckhove P, Watson A, et al. Barrier agents for preventing adhesions after surgery for subfertility [systematic review]. Cochrane Database of Systematic Reviews. The Cochrane Library: Oxford, UK, 2000, Issue 1. 2000; (Update Software, online or CD-ROM, updated quarterly).
Fedele L, Bianchi S, Baglioni A, et al Intranasal buserelin versus surgery in the treatment of uterine leiomyomata: long-term follow-up Eur J Obstet Gynecol Reprod Biol 1991 38(1):53 7 1899079
Fedele L, Bianchi S, Raffaelli R, et al A randomized study of the effects of tibolone and transdermal estrogen replacement therapy in postmenopausal women with uterine myomas Eur J Obstet Gynecol Reprod Biol 2000 88(1):91 4 10659924
Fedele L, Parazzini F, Luchini L, et al Recurrence of fibroids after myomectomy: A transvaginal ultrasonographic study Hum Reprod 1995 10(7):1795 6 8582982
Fedele L, Vercellini P, Bianchi S, et al Treatment with GnRH agonists before myomectomy and the risk of short-term myoma recurrence Br J Obstet Gynaecol 1990 97(5):393 6 2115379
Felberbaum RE, Germer U, Ludwig M, et al Treatment of uterine fibroids with a slow-release formulation of the gonadotrophin releasing hormone antagonist Cetrorelix Hum Reprod 1998 13(6):1660 8 9688409
Fiscella K, Franks P, Gold MR, et al Inequality in quality: addressing socioeconomic, racial, and ethnic disparities in health care JAMA 2000 283(19):2579 84 10815125
Fletcher H, Frederick J, Hardie M, et al A randomized comparison of vasopressin and tourniquet as hemostatic agents during myomectomy Obstet Gynecol 1996 87(6):1014 8 8649682
Franklin R, Haney A, Kettel LM, et al An expanded polytetrafluoroethylene barrier (Gore-Tex surgical membrane) reduces post-myomectomy adhesion formation Fertil Steril 1995 63(3):491 3 7851575
Frederick J, Fletcher H, Simeon D, et al Intramyometrial vasopressin as a haemostatic agent during myomectomy Br J Obstet Gynaecol 1994 101(5):435 7 8018617
Friedman AJ, Barbieri RL, Benacerraf BR, et al Treatment of leiomyomata with intranasal or subcutaneous leuprolide, a gonadotropin-releasing hormone agonist Fertil Steril 1987 48(4):560 4 3115833
Friedman AJ, Barbieri RL, Doubilet PM, et al A randomized, double-blind trial of a gonadotropin releasing-hormone agonist (leuprolide) with or without medroxyprogesterone acetate in the treatment of leiomyomata uteri Fertil Steril 1988 49(3):404 9 2963759
Friedman AJ, Daly M, Juneau-Norcross M, et al Recurrence of myomas after myomectomy in women pretreated with leuprolide acetate depot or placebo Fertil Steril 1992 58(1):205 8 1624009
Friedman AJ, Daly M, Juneau-Norcross M, et al A prospective, randomized trial of gonadotropin-releasing hormone agonist plus estrogen-progestin or progestin "add-back" regimens for women with leiomyomata uteri J Clin Endocrinol Metab 1993 76(6):1439 45 8501148
Friedman AJ, Daly M, Juneau-Norcross M, et al Long-term medical therapy for leiomyomata uteri: a prospective, randomized study of leuprolide acetate depot plus either oestrogen-progestin or progestin "add-back" for 2 years Hum Reprod 1994 9(9):1618 25 7836510
Friedman AJ, Haas ST Should uterine size be an indication for surgical intervention in women with myomas? Am J Obstet Gynecol 1993 168(31):751 5 8456874
Friedman AJ, Harrison-Atlas D, Barbieri RL, et al A randomized, placebo-controlled, double-blind study evaluating the efficacy of leuprolide acetate depot in the treatment of uterine leiomyomata Fertil Steril 1989 51(2):251 6 2492232
Friedman AJ, Hoffman DI, Comite F, et al Treatment of leiomyomata uteri with leuprolide acetate depot: a double-blind, placebo-controlled, multicenter study. The Leuprolide Study Group Obstet Gynecol 1991 77(5):720 5 1901638
Friedman AJ, Thomas PP Does low-dose combination oral contraceptive use affect uterine size or menstrual flow in premenopausal women with leiomyomas? Obstet Gynecol 1995 85(4):631 5 7898846
Garnet JD. Uterine rupture during pregnancy. Obstet Gynecol. 1964;23:898-905. [pmid: 14170210].
Gath D, Cooper P, Day A. Hysterectomy and psychiatric disorder: I. Levels of psychiatric morbidity before and after hysterectomy. Br J Psychiatry. 1982;140:335-42. [pmid: 7093609].
Gatti D, Falsetti L, Viani A, et al Uterine fibromyoma and sterility: role of myomectomy Acta Eur Fertil 1989 20(1):11 3 2781982
Gehlbach DL, Sousa RC, Carpenter SE, et al Abdominal myomectomy in the treatment of infertility Int J Gynecol Obstet 1993 40(1):45 50
Gerris J, Degueldre M, Peters AA, et al The place of Zoladex in deferred surgery for uterine fibroids. Zoladex Myoma Study Group Horm Res 1996 45(6):279 84 8793522
Giatras K, Berkeley AS, Noyes N, et al Fertility after hysteroscopic resection of submucous myomas J Am Assoc Gynecol Laparosc 1999 6(2):155 8 10226124
Ginsburg ES, Benson CB, Garfield JM, et al The effect of operative technique and uterine size on blood loss during myomectomy: a prospective randomized study Fertil Steril 1993 60(6):956 62 8243699
Golan A, Bukovsky I, Pansky M, et al Pre-operative gonadotrophin-releasing hormone agonist treatment in surgery for uterine leiomyomata Hum Reprod 1993 8(3):450 2 8473466
Golan A, Bukovsky I, Schneider D, et al D-Trp-6-luteinizing hormone-releasing hormone microcapsules in the treatment of uterine leiomyomas Fertil Steril 1989 52(3):406 11 2528476
Goldfarb HA Bipolar laparoscopic needles for myoma coagulation J Am Assoc Gynecol Laparosc 1995 2(2):175 9 9050553
Goodwin SC, McLucas B, Lee M, et al Uterine artery embolization for the treatment of uterine leiomyomata midterm results J Vasc Interv Radiol 1999 10(9):1159 65 10527191
Gordon SJ, Westgate J The incidence and management of failed Pipelle sampling in a general outpatient clinic Aust N Z J Obstet Gynaecol 1999 39(1):115 8 10099766
Gordon T, Kannel WB, Hjortland MC, et al Menopause and coronary heart disease. The Framingham Study Ann Intern Med 1978 89(2):157 61 677576
Gregoriou O, Vitoratos N, Papadias C, et al Effect of tibolone on postmenopausal woman with myomas Maturitas 1997 27(2):187 91 9255754
Griffith-Jones MD, Jarvis GJ, McNamara HM Adverse urinary symptoms after total abdominal hysterectomy -- fact or fiction? Br J Urol 1991 67(3):295 7 2021819
Gross CP, Nicholson W, Powe NR Factors affecting prophylactic oophorectomy in postmenopausal women Obstet Gynecol 1999 94(6):962 8 10576183
Grover SR, Quinn MA Is there any value in bimanual pelvic examination as a screening test? Med J Austr 1995 162(8):408 10
Guillaume AJ, Benjamin F, Spitzer M Myomectomy performed concurrently with tuboplasty J Reprod Med 1998 43(6):483 6 9653693
Hackenberg R, Gesenhues T, Deichert U, et al The response of uterine fibroids to GnRH-agonist treatment can be predicted in most cases after one month Eur J Obstet Gynecol Reprod Biol 1992 45(2):125 9 1386817
Hallez JP Single-stage total hysteroscopic myomectomies: indications, techniques, and results Fertil Steril 1995 63(4):703 8 7890051
Han GS Assessing the role of laparoscopically assisted vaginal hysterectomy in the everyday practice of gynecology J Reprod Med 1996 41(7):521 8 8829066
Haney AF Removal of surgical barriers of expanded polytetrafluoroethylene at second-look laparoscopy was not associated with adhesion formation Fertil Steril 1997 68(4):721 3 9341618
Harkki-Siren P, Sjoberg J, Tiitinen A Urinary tract injuries after hysterectomy Obstet Gynecol 1998 92(1):113 8 9649105
Harmon JW, Tang DG, Gordon TA, et al Hospital volume can serve as a surrogate for surgeon volume for achieving excellent outcomes in colorectal resection Ann Surg 1999 230(3):404 11; discussion 411-3 10493487 1420885
Hart R, Molnar BG, Magos A Long term follow up of hysteroscopic myomectomy assessed by survival analysis Br J Obstet Gynaecol 1999 106(7):700 5 10428527
Hasan F, Arumugam K, Sivanesaratnam V Uterine leiomyomata in pregnancy Int J Gynaecol Obstet 1991 34(1):45 8 1671020
Hasson HM Cervical removal at hysterectomy for benign disease. Risks and benefits J Reprod Med 1993 38(10):781 90 8263867
Hasson HM, Rotman C, Rana N, et al Laparoscopic myomectomy Obstet Gynecol 1992 80(5):884 8 1407934
Heaton KW, Parker D, Cripps H Bowel function and irritable bowel symptoms after hysterectomy and cholecystectomy -- a population based study Gut 1993 34(8):1108 11 8174964 1374364
Helstrom L, Lundberg PO, Sorbom D, et al Sexuality after hysterectomy: a factor analysis of women's sexual lives before and after subtotal hysterectomy Obstet Gynecol 1993 81(3):357 62 8437786
Helstrom L, Sorbom D, Backstrom T Influence of partner relationship on sexuality after subtotal hysterectomy Acta Obstet Gynecol Scand 1995 74(2):142 6 7900511
Helstrom L, Weiner E, Sorbom D, et al Predictive value of psychiatric history, genital pain and menstrual symptoms for sexuality after hysterectomy Acta Obstet Gynecol Scand 1994 73(7):575 80 8079610
Hillis SD, Marchbanks PA, Peterson HB Uterine size and risk of complications among women undergoing abdominal hysterectomy for leiomyomas Obstet Gynecol 1996 87(4):539 43 8602305
Ho V Evolution of the volume-outcome relation for hospitals performing coronary angioplasty Circulation 2000 101(15):1806 11 10769281
Hoffman MS, DeCesare S, Kalter C Abdominal hysterectomy versus transvaginal morcellation for the removal of enlarged uteri Am J Obstet Gynecol 1994 171(2):309 15 8059807
Hording U, Pedersen KH, Sidenius K, et al Urinary incontinence in 45-year-old women. An epidemiological survey Scand J Urol Nephrol 1986 20(3):183 6 3787195
Hreshchyshyn MM, Hopkins A, Zylstra S, et al Effects of natural menopause, hysterectomy, and oophorectomy on lumbar spine and femoral neck bone densities Obstet Gynecol 1988 72(4):631 8 3419740
Hulley S, Grady D, Bush T, et al Randomized trial of estrogen plus progestin for secondary prevention of coronary heart disease in postmenopausal women. Heart and Estrogen/progestin Replacement Study (HERS) Research Group JAMA 1998 280(7):605 13 9718051
Hutchins FL Jr Myomectomy after selective preoperative treatment with a gonadotropin releasing hormone analog J Reprod Med 1992 37(8):699 702 1432986
Hutchins FL Jr A randomized comparison of vasopressin and tourniquet as hemostatic agents during myomectomy [letter] Obstet Gynecol 1996 88(4 Pt 1):639 40 8841235
Hutchins FL Jr, Worthington-Kirsch R, Berkowitz RP Selective uterine artery embolization as primary treatment for symptomatic leiomyomata uteri J Am Assoc Gynecol Laparosc 1999 6(3):279 84 10459027
Ikpeze OC, Nwosu OB Features of uterine fibroids treated by abdominal myomectomy at Nnewi, Nigeria J Obstet Gynaecol 1998 18(6):569 71 15512182
Indman PD Hysteroscopic treatment of menorrhagia associated with uterine leiomyomas Obstet Gynecol 1993 81(51):716 20 8469459
Iosif CS, Bekassy Z, Rydhstrom H Prevalence of urinary incontinence in middle-aged women Int J Gynaecol Obstet 1988 26(2):255 9 2898402
Itzkowic D Submucous fibroids: Clinical profile and hysteroscopic management Aust N Z J Obstet Gynaecol 1993 33(1):63 7 8498943
Iverson RE Jr, Chelmow D, Strohbehn K, et al Relative morbidity of abdominal hysterectomy and myomectomy for management of uterine leiomyomas Obstet Gynecol 1996 88(3):415 9 8752251
Iverson RE Jr, Chelmow D, Strohbehn K, et al Myomectomy fever: testing the dogma Fertil Steril 1999 72(1):104 8 10428156
Iyer V, Farquhar C, Jepson R. Oral contraceptive pills for heavy menstrual bleeding [systematic review]. Cochrane Database of Systematic Reviews. The Cochrane Library: Oxford, UK. 2000, Issue 1. 2000; (Update Software, online or CD-ROM, updated quarterly).
Jequier AM Urinary symptoms and total hysterectomy Br J Urol 1976 48(6):437 41 1009326
Juni P, Witschi A, Bloch R, et al The hazards of scoring the quality of clinical trials for meta-analysis JAMA 1999 282(11):1054 60 10493204
Kadar N Extraperitoneal laparoscopic hyoterectomy for the large uterus Gynaecol Endoscopy 1996 5(5):271 6
Katz VL, Dotters DJ, Droegemeuller W Complications of uterine leiomyomas in pregnancy Obstet Gynecol 1989 73(4):593 6 2927854
Kilkku P Supravaginal uterine amputation versus hysterectomy. Effects on coital frequency and dyspareunia Acta Obstet Gynecol Scand 1983 62(2):141 5 6868962
Kilkku P Supravaginal uterine amputation versus hysterectomy with reference to subjective bladder symptoms and incontinence Acta Obstet Gynecol Scand 1985 64(5):375 9 4061057
Kilkku P, Gronroos M, Hirvonen T, et al Supravaginal uterine amputation versus hysterectomy. Effects on libido and orgasm Acta Obstet Gynecol Scand 1983 62(2):147 52 6868963
Kilkku P, Hirvonen T, Gronroos M Supra-vaginal uterine amputation versus abdominal hysterectomy: the effects on urinary symptoms with special reference to pollakisuria, nocturia and dysuria Maturitas 1981 3(3-4):197 204 7334931
Kiltz RJ, Rutgers J, Phillips J, et al Absence of a dose-response effect of leuprolide acetate on leiomyomata uteri size Fertil Steril 1994 61(6):1021 6 8194611
Kjerulff KH, Guzinski GM, Langenberg PW, et al Hysterectomy and race Obstet Gynecol 1993 82(5):757 64 8414322
Kjerulff KH, Langenberg PW, Rhodes JC, et al Effectiveness of hysterectomy Obstet Gynecol 2000 95(3):319 26 10711536
Kjerulff KH, Langenberg PW, Seidman JD, et al Uterine leiomyomas: Racial differences in severity, symptoms and age at diagnosis J Reprod Med 1996 41(7):483 90 8829060
Kuhlmann M, Gartner A, Schindler EM, et al Uterine leiomyomata and sterility: therapy with gonadotropin-releasing hormone agonists and leiomyomectomy Gynecol Endocrinol 1997 11(3):169 74 9209897
La Vecchia C, Franceschi S Oral contraceptives and ovarian cancer Eur J Cancer Prev 1999 8(4):297 304 10493304
Lalos O, Bjerle P Bladder wall mechanics and micturition before and after subtotal and total hysterectomy Eur J Obstet Gynecol Reprod Biol 1986 21(3):143 50 3956833
Lambden MP, Bellamy G, Ogburn-Russell L, et al Women's sense of well-being before and after hysterectomy J Obstet Gynecol Neonatal Nurs 1997 26(5):540 8
LaMorte AI, Lalwani S, Diamond MP Morbidity associated with abdominal myomectomy Obstet Gynecol 1993 82(6):897 900 8233261
Langer R, Golan A, Neuman M, et al The effect of large uterine fibroids on urinary bladder function and symptoms Am J Obstet Gynecol 1990 163(4 Pt 1):1139 41 2145766
Langer R, Neuman M, Ron-el R, et al The effect of total abdominal hysterectomy on bladder function in asymptomatic women Obstet Gynecol 1989 74(2):205 7 2748057
Lee CL, Soong YK Laparoscopic hysterectomy: is dissecting the ureter necessary? Int Surg 1995 80(2):167 9 8530236
Leibsohn S, d'Ablaing G, Mishell DR Jr, et al Leiomyosarcoma in a series of hysterectomies performed for presumed uterine leiomyomas Am J Obstet Gynecol 1990 162(4):968 74; discussion 974-6 2327466
Lepine LA, Hillis SD, Marchbanks PA, et al Hysterectomy surveillance -- United States, 1980-1997 MMWR 1997 46(4):1 15
Lethaby A, Augood C, Duckitt K. Nonsteroidal anti-inflammatory drugs for heavy [systematic review]. Cochrane Database of Systematic Reviews. The Cochrane Library: Oxford, UK. 2000, Issue 1. 2000; (Update Software, online or CD-ROM, updated quarterly).
Lethaby A, Irvine G, Cameron I. Cyclical progestogens for heavy menstrual bleeding [systematic review]. Cochrane Database of Systematic Reviews. The Cochrane Library: Oxford, UK. 2000, Issue 1. 2000; (Update Software, online or CD-ROM, updated quarterly).
Lethaby A, Vollenhoven B, Sowter M. Pre-operative gonadotropin-releasing hormone analogue before hysterectomy or myomectomy for uterine fibroids. The Cochrane Library: Oxford, UK. 1999, Issue 3. 1999; (Update Software, Online or CD-ROM, Updated Quarterly).
Li TC, Mortimer R, Cooke ID Myomectomy: a retrospective study to examine reproductive performance before and after surgery Hum Reprod 1999 14(7):1735 40 10402378
Lin BL, Iwata Y, Liu KH Removing a large submucous fibroid hysteroscopically with the two-resectoscope method J Am Assoc Gynecol Laparosc 1994 1(3):259 63 9050497
Lindsay R, Hart DM, Clark DM The minimum effective dose of estrogen for prevention of postmenopausal bone loss Obstet Gynecol 1984 63(6):759 63 6374537
Loffer FD Removal of large symptomatic intrauterine growths by the hysteroscopic resectoscope Obstet Gynecol 1990 76(5 Pt 1):836 40 2216235
Lomano J Endometrial ablation for the treatment of menorrhagia: a comparison of patients with normal, enlarged, and fibroid uteri Lasers Surg Med 1991 11(1):8 12 1825511
Lumsden MA, Wallace EM Clinical presentation of uterine fibroids Baillieres Clin Obstet Gynaecol 1998 12(2):177 95 10023417
Maheux R, Lemay A Treatment of peri-menopausal women: potential long-term therapy with a depot GnRH agonist combined with hormonal replacement therapy Br J Obstet Gynaecol 1992 99(Suppl 7):13 7
Mais V, Ajossa S, Guerriero S, et al Laparoscopic versus abdominal myomectomy: a prospective, randomized trial to evaluate benefits in early outcome Am J Obstet Gynecol 1996 174(2):654 8 8623802
Mais V, Ajossa S, Piras B, et al Prevention of de-novo adhesion formation after laparoscopic myomectomy: a randomized trial to evaluate the effectiveness of an oxidized regenerated cellulose absorbable barrier Hum Reprod 1995 10(12):3133 5 8822429
Malone LJ Myomectomy: recurrence after removal of solitary and multiple myomas Obstet Gynecol 1969 34(2):200 3 5816311
Mant J, Painter R, Vessey M Epidemiology of genital prolapse: observations from the Oxford Family Planning Association Study Br J Obstet Gynaecol 1997 104(5):579 85 9166201
March CM, Boyers S, Franklin R, et al. Prevention of adhesion formation/reformation with the Gore-Tex Surgical Membrane. Prog Clin Biol Res. 1993;381:253-9. [pmid: 8316567].
Marshall LM, Spiegelman D, Barbieri RL, et al Variation in the incidence of uterine leiomyoma among premenopausal women by age and race Obstet Gynecol 1997 90(6):967 73 9397113
Marshall LM, Spiegelman D, Goldman MB, et al A prospective study of reproductive factors and oral contraceptive use in relation to the risk of uterine leiomyomata Fertil Steril 1998 70(3):432 9 9757871
Marshall LM, Spiegelman D, Manson JE, et al Risk of uterine leiomyomata among premenopausal women in relation to body size and cigarette smoking Epidemiology 1998 9(5):511 7 9730029
Martin LC, Puente I, Sosa JL, et al Open versus laparoscopic appendectomy. A prospective randomized comparison Ann Surg 1995 222(3):256 62 7677456 1234801
Matchar DB, Samsa GP, Matthews JR, et al The stroke prevention policy model: linking evidence and clinical decisions Ann Intern Med 1997 127(8 Pt 2):704 11 9382384
Mazdisnian F, Kurzel RB, Coe S, et al Vaginal hysterectomy by uterine morcellation: an efficient, non-morbid procedure Obstet Gynecol 1995 86(1):60 4 7784024
McCrory DC, Matchar D, Bastian L, et al. Evaluation of Cervical Cytology. Evidence Report/Technology Assessment No. 5 (Prepared by Duke University under Contract No. 290-97-0014). AHCPR Publication No. 99-E010. Rockville, MD: Agency for Health Care Policy and Research. February 1998.
McKinlay SM, Brambilla DJ, Posner JG The normal menopause transition Maturitas 1992 14(2):103 15 1565019
McNaughton Collins M, Ransohoff DF, Barry MJ Early detection of prostate cancer. Serendipity strikes again JAMA 1997 278(18):1516 9 9363972
Drug Topics Red Book. Oradell, NJ: Medical Economics Co., 2000.
Meldrum DR, Erlik Y, Lu JK, et al Objectively recorded hot flushes in patients with pituitary insufficiency J Clin Endocrinol Metab 1981 52(4):684 8 6782116
Mettler L, Alvarez-Rodas E, Semm K Myomectomy by laparoscopy: a report of 482 cases Gynaecol Endoscopy 1995 4(4):259 64
Miller CE, Johnston M, Rundell M Laparoscopic myomectomy in the infertile woman J Am Assoc Gynecol Laparosc 1996 3(4):525 32 9050683
Milsom I, Ekelund P, Molander U, et al The influence of age, parity, oral contraception, hysterectomy and menopause on the prevalence of urinary incontinence in women J Urol 1993 149(6):1459 62 8501788
Mints M, Radestad A, Rylander E Follow up of hysteroscopic surgery for menorrhagia Acta Obstet Gynecol Scand 1998 77(4):435 8 9598954
Moher D, Jadad AR, Tugwell P Assessing the quality of randomized controlled trials. Current issues and future directions Inter J Tech Assess Health Care 1996 12(2):195 208
Mollica G, Pittini L, Minganti E, et al Elective uterine myomectomy in pregnant women Clin Exp Obstet Gynecol 1996 23(3):168 72 8894327
Motashaw ND, Dave S, Paghdiwalla K Hysteroscopic management of submucous uterine myomata Gynaecol Endoscopy 1995 4(3):207 12
Murphy AA, Morales AJ, Kettel LM, et al Regression of uterine leiomyomata to the antiprogesterone RU486: dose-response effect Fertil Steril 1995 64(1):187 90 7789557
Murray C, Tulandi T Prevention of postmyomectomy adhesions Infertil Reprod Med Clinics North Am 1996 7(1):169 77
Myers ER, Steege JF Risk adjustment for complications of hysterectomy: limitations of routinely collected administrative data Am J Obstet Gynecol 1999 181(3):567 75 10486465
Nachtigall LE, Nachtigall RH, Nachtigall RD, et al Estrogen replacement therapy I: a 10-year prospective study in the relationship to osteoporosis Obstet Gynecol 1979 53(3):277 81 218151
Nakamura Y, Yoshimura Y Treatment of uterine leiomyomas in perimenopausal women with gonadotropin-releasing hormone agonists Clin Obstet Gynecol 1993 36(3):660 7 8403612
Nakamura Y, Yoshimura Y, Yamada H, et al Treatment of uterine leiomyomata with a luteinizing hormone-releasing hormone agonist: the possibility of nonsurgical management in selected perimenopausal women Fertil Steril 1991 55(5):900 5 1902420
Narayan R, Rajat, Goswamy K Treatment of submucous fibroids, and outcome of assisted conception J Am Assoc Gynecol Laparosc 1994 1(4 Pt 1):307 11 9138869
[electronic database]. Release 6; 1997 data. Agency for Healthcare Research and Quality: Rockville, MD. Available from: http://www.ntis.gov/fcpc/cpn8834.htm. 1997.
Nezhat C, Nezhat F, Bess O, et al Laparoscopically assisted myomectomy: a report of a new technique in 57 cases Int J Fertil 1994 39(1):39 44
Nezhat C, Nezhat F, Silfen SL, et al Laparoscopic myomectomy Int J Fertil 1991 36(5):275 80 1683655
Nezhat FR, Roemisch M, Nezhat CH, et al Recurrence rate after laparoscopic myomectomy J Am Assoc Gynecol Laparosc 1998 5(3):237 40 9668143
Nimaroff ML, Dimino M, Maloney S Laparoscopic-assisted vaginal hysterectomy of large myomatous uteri with supracervical amputation followed by trachelectomy J Am Assoc Gynecol Laparosc 1996 3(4):585 7 9050693
Nisolle M, Smets M, Malvaux V, et al Laparoscopic myolysis with the Nd: YAG laser J Gynecol Surg 1993 9(2):95 9 10171973
Ojeda VJ The pathology of hysterectomy specimens N Z Med J 1979 89(631):169 71 287933
Oldenhave A, Jaszmann LJ, Everaerd WT, et al Hysterectomized women with ovarian conservation report more severe climacteric complaints than do normal climacteric women of similar age Am J Obstet Gynecol 1993 168(3 Pt 1):765 71 8456877
Olsen AL, Smith VJ, Bergstrom JO, et al Epidemiology of surgically managed pelvic organ prolapse and urinary incontinence Obstet Gynecol 1997 89(4):501 6 9083302
Paganini-Hill A, Ross RK, Gerkins VR, et al Menopausal estrogen therapy and hip fractures Ann Intern Med 1981 95(1):28 31 7247123
Palomba S, Affinito P, Di Carlo C, et al Long-term administration of tibolone plus gonadotropin-releasing hormone agonist for the treatment of uterine leiomyomas: Effectiveness and effects on vasomotor symptoms, bone mass, and lipid profiles Fertil Steril 1999 72(5):889 95 10560995
Palomba S, Affinito P, Tommaselli GA, et al A clinical trial of the effects of tibolone administered with gonadotropin-releasing hormone analogues for the treatment of uterine leiomyomata Fertil Steril 1998 70(1):111 8 9660431
Parazzini F, Bortolotti A, Chiantera V, et al Goserelin acetate to avoid hysterectomy in pre-menopausal women with fibroids requiring surgery Eur J Obstet Gynecol Reprod Biol 1999 87(1):31 3 10579613
Parazzini F, Negri E, La Vecchia C, et al Oral contraceptive use and risk of uterine fibroids Obstet Gynecol 1992 79(3):430 3 1738528
Parazzini F, Negri E, La Vecchia C, et al Reproductive factors and risk of uterine fibroids Epidemiology 1996 7(4):440 2 8793374
Parker WH, Fu YS, Berek JS Uterine sarcoma in patients operated on for presumed leiomyoma and rapidly growing leiomyoma Obstet Gynecol 1994 83(3):414 8 8127535
Parys BT, Haylen BT, Hutton JL, et al The effects of simple hysterectomy on vesicourethral function Br J Urol 1989 64(6):594 9 2627634
Parys BT, Haylen BT, Hutton JL, et al Urodynamic evaluation of lower urinary tract function in relation to total hysterectomy Aust N Z J Obstet Gynaecol 1990 30(2):161 5 2400362
Pelage JP, Le Dref O, Soyer P, et al Fibroid-related menorrhagia: treatment with superselective embolization of the uterine arteries and midterm follow-up Radiology 2000 215(2):428 31 10796920
Perino A, Chianchiano N, Petronio M, et al Role of leuprolide acetate depot in hysteroscopic surgery: a controlled study Fertil Steril 1993 59(3):507 10 8458448
Phillips DR, Milim SJ, Nathanson HG, et al Experience with laparoscopic leiomyoma coagulation and concomitant operative hysteroscopy J Am Assoc Gynecol Laparosc 1997 4(4):425 33 9224575
Phillips DR, Nathanson HG, Meltzer SM, et al Transcervical electrosurgical resection of submucous leiomyomas for chronic menorrhagia [published erratum appears in J Am Assoc Gynecol Laparosc 1995 Aug; 2(4):496] J Am Assoc Gynecol Laparosc 1995 2(2):147 53 9050549
Phillips DR, Nathanson HG, Milim SJ, et al The effect of dilute vasopressin solution on blood loss during operative hysteroscopy: a randomized controlled trial Obstet Gynecol 1996 88(5):761 6 8885909
Phillips SM, Sherwin BB Effects of estrogen on memory function in surgically menopausal women Psychoneuroendocrinology 1992 17(5):485 95 1484915
Piazze Garnica J, Gallo G, Marzano PF, et al Clinical and ultrasonographic implications of uterine leiomyomatosis in pregnancy Clin Exp Obstet Gynecol 1995 22(4):293 7 8777782
Piscitelli JT, Simel DL, Addison WA Who should have intravenous pyelograms before hysterectomy for benign disease? Obstet Gynecol 1987 69(4):541 5 3822294
Piver MS, Jishi MF, Tsukada Y, et al Primary peritoneal carcinoma after prophylactic oophorectomy in women with a family history of ovarian cancer. A report of the Gilda Radner Familial Ovarian Cancer Registry Cancer 1993 71(9):2751 5 8467455
Plockinger B, Kolbl H Development of ovarian pathology after hysterectomy without oophorectomy J Am Coll Surg 1994 178(6):581 5 8193751
Pokras R, Hufnagel VG Hysterectomy in the United States, 1965-84 Am J Public Health 1988 78(7):852 3 3381968 1350353
Pooley AS, Ewen SP, Sutton CJG Does transcervical resection of the endometrium for menorrhagia really avoid hysterectomy? Life table analysis of a large series J Am Assoc Gynecol Laparosc 1998 5(3):229 35 9668142
Prior A, Stanley KM, Smith AR, et al Relation between hysterectomy and the irritable bowel: a prospective study Gut 1992 33(6):814 7 1624165 1379342
Qazi F, McGuire WP The treatment of epithelial ovarian cancer Ca: a Cancer Journal for Clinicians 1995 45(2):88 101 7889393
Ramzy AM, Sattar M, Amin Y, et al Uterine myomata and outcome of assisted reproduction Hum Reprod 1998 13(1):198 202 9512257
Ransohoff DF, Lang CA Small adenomas detected during fecal occult blood test screening for colorectal cancer. The impact of serendipity JAMA 1990 264(1):76 8 2192093
Ravina JH, Vigneron NC, Aymard A, et al Pregnancy after embolization of uterine myoma: report of 12 cases Fertil Steril 2000 73(6):1241 3 10856491
Ravn P, Lind C, Nilas L Lack of influence of simple premenopausal hysterectomy on bone mass and bone metabolism Am J Obstet Gynecol 1995 172(3):891 5 7892881
Ravnikar VA Compliance with hormone therapy Am J Obstet Gynecol 1987 156(5):1332 4 3578453
Reilly RJ, Nour N Abdominal myomectomy is associated with few surgical complications J Gynecol Tech 1998 4(3):107 12
Rein MS, Barbieri RL, Friedman AJ Progesterone: a critical role in the pathogenesis of uterine myomas Am J Obstet Gynecol 1995 172(1 Pt 1):14 8 7847524
Rein MS, Powell WL, Walters FC, et al Cytogenetic abnormalities in uterine myomas are associated with myoma size Mol Hum Reprod 1998 4(1):83 6 9510016
Reiter RC, Wagner PL, Gambone JC Routine hysterectomy for large asymptomatic uterine leiomyomata: a reappraisal Obstet Gynecol 1992 79(4):481 4 1553162
Rekers H, Drogendijk AC, Valkenburg HA, et al The menopause, urinary incontinence and other symptoms of the genito-urinary tract Maturitas 1992 15(2):101 11 1470043
Rendina GM, Patrono D The use of a biological preparation in the treatment of some gynaecological diseases Curr Med Res Opin 1976 4(2):151 7 776538
Rhodes JC, Kjerulff KH, Langenberg PW, et al Hysterectomy and sexual functioning JAMA 1999 282(20):1934 41 10580459
Ribeiro SC, Reich H, Rosenberg J, et al Laparoscopic myomectomy and pregnancy outcome in infertile patients Fertil Steril 1999 71(3):571 4 10065802
Rice JP, Kay HH, Mahony BS The clinical significance of uterine leiomyomas in pregnancy Am J Obstet Gynecol 1989 160(5 Pt 1):1212 6 2658611
Richardson RE, Bournas N, Magos AL Is laparoscopic hysterectomy a waste of time? Lancet 1995 345(8941):36 41 7799707
Roos NP Hysterectomies in one Canadian province: a new look at risks and benefits Am J Public Health 1984 74(1):39 46 6689840 1651382
Rosenfeld DL Abdominal myomectomy for otherwise unexplained infertility Fertil Steril 1986 46(2):328 30 3732540
Rossetti A, Paccosi M, Sizzi O, et al Dilute ornitin vasopressin and a myoma drill for laparoscopic myomectomy J Am Assoc Gynecol Laparosc 1999 6(2):189 93 10226131
Rowe MK, Kanouse DE, Mittman BS, et al Quality of life among women undergoing hysterectomies Obstet Gynecol 1999 93(6):915 21 10362154
Sakamoto S, Kudo H, Kawasaki T, et al Effects of a Chinese herbal medicine, keishi-bukuryo-gan, on the gonadal system of rats Ethnopharmacology 1988 23(2-3):151 8 3143030
Sakamoto S, Yoshino H, Shirahata Y, et al Pharmacotherapeutic effects of kuei-chih-fu-ling-wan (keishi-bukuryo-gan) on human uterine myomas Am J Chin Med 1992 20(3-4):313 7 1471615
Samuelsson EC, Arne Victor FT, Tibblin G, et al Signs of genital prolapse in a Swedish population of women 20 to 59 years of age and possible related factors Am J Obstet Gynecol 1999 180(2 Pt 1):299 305 9988790
Scher KS Unplanned reoperation for bleeding Am Surg 1996 62(1):52 5 8540646
Schlaff WD, Zerhouni EA, Huth JA, et al A placebo-controlled trial of a depot gonadotropin-releasing hormone analogue (leuprolide) in the treatment of uterine leiomyomata Obstet Gynecol 1989 74(6):856 62 2511532
Schneider A, Merker A, Martin C, et al Laparoscopically assisted vaginal hysterectomy as an alternative to abdominal hysterectomy in patients with fibroids Arch Gynecol Obstet 1997 259(2):79 85 9059748
Schofield MJ, Bennett A, Redman S, et al Self-reported long-term outcomes of hysterectomy Br J Obstet Gynaecol 1991 98(11):1129 36 1760425
Schulz KF, Chalmers I, Grimes DA, et al Assessing the quality of randomization from reports of controlled trials published in obstetrics and gynecology journals JAMA 1994 272(2):125 8 8015122
Schulz KF, Chalmers I, Hayes RJ, et al Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials JAMA 1995 273(5):408 12 7823387
Schutter EM, Kenemans P, Sohn C, et al Diagnostic value of pelvic examination, ultrasound, and serum CA 125 in postmenopausal women with a pelvic mass. An international multicenter study Cancer 1994 74(4):1398 406 8055463
Schweppe KW, Beller FK [Prophylactic oophorectomy (author's transl)] Geburtshilfe Und Frauenheilkunde 1979 39(12):1024 32 [German] 520781
Scialli AR, Jestila KJ Sustained benefits of leuprolide acetate with or without subsequent medroxyprogesterone acetate in the nonsurgical management of leiomyomata uteri Fertil Steril 1995 64(2):313 20 7615109
Seinera P, Arisio R, Decko A, et al Laparoscopic myomectomy: Indications, surgical technique and complications Hum Reprod 1997 12(9):1927 30 9363708
Sener AB, Seckin NC, Ozmen S, et al The effects of hormone replacement therapy on uterine fibroids in postmenopausal women Fertil Steril 1996 65(2):354 7 8566261
Seoud MA-F, Patterson R, Muasher SJ, et al Effects of myomas or prior myomectomy on in vitro fertilization (IVF) performance J Assist Reprod Genet 1992 9(3):217 21 1525449
Serra GB, Panetta V, Colosimo M, et al Efficacy of leuprorelin acetate depot in symptomatic fibromatous uteri: the Italian Multicentre Trial Clin Ther 1992 14(Suppl A):57 73 1606594
Shekelle PG, Kahan JP, Bernstein SJ, et al The reproducibility of a method to identify the overuse and underuse of medical procedures N Engl J Med 1998 338(26):1888 95 9637810
Siddle N, Sarrel P, Whitehead M The effect of hysterectomy on the age at ovarian failure: identification of a subgroup of women with premature loss of ovarian function and literature review Fertil Steril 1987 47(1):94 100 3539646
Sirjusingh A, Bassaw B, Roopnarinesingh S The results of abdominal myomectomy West Indian Med J 1994 43(4):138 9 7900378
Siskin GP, Stainken BF, Dowling K, et al. Outpatient uterine artery embolization for symptomatic uterine fibroids: experience in 49 patients. J Vasc Interv Radiol. 2000;11:305-11. [pmid: 10735424].
Sivin I, Stern J Health during prolonged use of levonorgestrel 20 micrograms/d and the copper TCu 380Ag intrauterine contraceptive devices: a multicenter study. International Committee for Contraception Research (ICCR) Fertil Steril 1994 61(1):70 7 8293847
Skoner MM, Thompson WD, Caron VA Factors associated with risk of stress urinary incontinence in women Nurs Res 1994 43(5):301 6 7937177
Smith DC, Uhlir JK Myomectomy as a reproductive procedure Am J Obstet Gynecol 1990 162(6):1476 9; discussion 1479-82 2360579
Sosa JL, Sleeman D, McKenney MG, et al A comparison of laparoscopic and traditional appendectomy J Laparoendosc Surg 1993 3(2):129 31 8518464
Speroff L, Dawson NV, Speroff L, et al A risk-benefit analysis of elective bilateral oophorectomy: effect of changes in compliance with estrogen therapy on outcome Am J Obstet Gynecol 1991 164(1 Pt 1):165 74 1986605
Speroff L, Glass RH, Kase NG. Clinical gynecologic endocrinology and infertility. 6th edition. Philadelphia, PA: Lippincott Williams & Wilkins, 1999: pp. 149-53.
Spies JB, Scialli AR, Jha RC, et al Initial results from uterine fibroid embolization for symptomatic leiomyomata J Vasc Interv Radiol 1999 10(9):1149 57 10527190
Spies JB, Warren EH, Mathias SD, et al Uterine fibroid embolization: measurement of health-related quality of life before and after therapy J Vasc Interv Radiol 1999 10(10):1293 303 10584643
Stanton SL, Hilton P, Norton C, et al Clinical and urodynamic effects of anterior colporrhaphy and vaginal hysterectomy for prolapse with and without incontinence Br J Obstet Gynaecol 1982 89(6):459 63 7082603
Starks GC CO2 laser myomectomy in an infertile population J Reprod Med 1988 33(2):184 6 3351816
Stewart EA, Nowak RA Leiomyoma-related bleeding: a classic hypothesis updated for the molecular era Hum Reprod Update 1996 2(4):295 306 9080227
Stovall DW, Parrish SB, Van Voorhis BJ, et al Uterine leiomyomas reduce the efficacy of assisted reproduction cycles: results of a matched follow-up study Hum Reprod 1998 13(1):192 7 9512256
Stovall TG, Ling FW, Crawford DA Hysterectomy for chronic pelvic pain of presumed uterine etiology Obstet Gynecol 1990 75(4):676 9 2248635
Stovall TG, Ling FW, Henry LC, et al A randomized trial evaluating leuprolide acetate before hysterectomy as treatment for leiomyomas Am J Obstet Gynecol 1991 164(6 Pt 1):1420 3; discussion 1423-5 1904681
Stovall TG, Muneyyirci-Delale O, Summitt RL Jr, et al GnRH agonist and iron versus placebo and iron in the anemic patient before surgery for leiomyomas: a randomized controlled trial. Leuprolide Acetate Study Group Obstet Gynecol 1995 86(1):65 71 7784025
Stovall TG, Summit RL Jr, Washburn SA, et al Gonadotropin-releasing hormone agonist use before hysterectomy Am J Obstet Gynecol 1994 170(6):1744 8; discussion 1748-51 8203435
Stringer NH Laparoscopic myomectomy in African-American women J Am Assoc Gynecol Laparosc 1996 3(3):375 81 9050659
Stringer NH One hundred laparoscopic myomectomies with ultrasonic energy: Surgical evaluation of a new energy source Gynaecol Endoscopy 1998 7(2):85 93
Stringer NH, McMillen MA, Jones RL, et al Uterine closure with the endo stitch 10-mm laparoscopic suturing device -- a review of 50 laparoscopic myomectomies Int J Fertil Womens Med 1997 42(5):288 96 9406833
Stringer NH, Walker JC, Meyer PM Comparison of 49 laparoscopic myomectomies with 49 open myomectomies J Am Assoc Gynecol Laparosc 1997 4(4):457 64 9224580
Strobelt N, Ghidini A, Cavallone M, et al Natural history of uterine leiomyomas in pregnancy J Ultrasound Med 1994 13(5):399 401 8015049
Stroup DF, Berlin JA, Morton SC, et al. Meta-analysis of observational studies in epidemiology: a proposal for reporting. JAMA. 2000;283:2008-12. [pmid: 10789670].
Sudik R, Husch K, Steller J, et al Fertility and pregnancy outcome after myomectomy in sterility patients Eur J Obstet Gynecol Reprod Biol 1996 65(2):209 14 8730626
Tahir MM, Bigrigg MA, Browning JJ, et al A randomised controlled trial comparing transvaginal ultrasound, outpatient hysteroscopy and endometrial biopsy with inpatient hysteroscopy and curettage Br J Obstet Gynaecol 1999 106(12):1259 64 10609719
Takamizawa S, Minakami H, Usui R, et al Risk of complications and uterine malignancies in women undergoing hysterectomy for presumed benign leiomyomas Gynecol Obstet Invest 1999 48(3):193 6 10545745
Taylor T, Smith AN, Fulton PM Effect of hysterectomy on bowel function BMJ 1989 299(6694):300 1 2504409 1837168
Thom DH, van den Eeden SK, Brown JS Evaluation of parturition and other reproductive variables as risk factors for urinary incontinence in later life Obstet Gynecol 1997 90(6):983 9 9397116
Tulandi T, Murray C, Guralnick M Adhesion formation and reproductive outcome after myomectomy and second-look laparoscopy Obstet Gynecol 1993 82(2):213 5 8336866
Tulandi T, Youseff H Laparoscopy-assisted myomectomy of large uterine myomas Gynaecol Endoscopy 1997 6(2):105 8
Ueki M, Okamoto Y, Tsurunaga T, et al Endocrinological and histological changes after treatment of uterine leiomyomas with danazol or buserelin J Obstet Gynaecol 1995 21(1):1 7 8591104
Ugur M, Turan C, Mungan T, et al Laparoscopy for adhesion prevention following myomectomy Int J Gynaecol Obstet 1996 53(2):145 9 8735295
Valle RF Hysteroscopy in the evaluation of female infertility Am J Obstet Gynecol 1980 137(4):425 31 7386525
van Dam JH, Gosselink MJ, Drogendijk AC, et al Changes in bowel function after hysterectomy Dis Colon Rectum 1997 40(11):1342 7 9369110
Van Dinh T, Woodruff JD Leiomyosarcoma of the uterus Am J Obstet Gynecol 1982 144(7):817 23 7148905
van Leusden HA Symptom-free interval after triptorelin treatment of uterine fibroids: long-term results Gynecol Endocrinol 1992 6(3):189 98 1442164
Varasteh NN, Neuwirth RS, Levin B, et al Pregnancy rates after hysteroscopic polypectomy and myomectomy in infertile women Obstet Gynecol 1999 94(2):168 71 10432121
Vavala V, Lanzone A, Monaco A, et al Postoperative GnRH analog treatment for the prevention of recurrences of uterine myomas after myomectomy. A pilot study Gynecol Obstet Invest 1997 43(4):251 4 9194624
Velebil P, Wingo PA, Xia Z, et al Rate of hospitalization for gynecologic disorders among reproductive-age women in the United States Obstet Gynecol 1995 86(5):764 9 7566845
Vercellini P, Bocciolone L, Colombo A, et al Gonadotropin releasing hormone agonist treatment before hysterectomy for menorrhagia and uterine leiomyomas Acta Obstet Gynecol Scand 1993 72(5):369 73 8392268
Vercellini P, Crosignani PG, Mangioni C, et al Treatment with a gonadotrophin releasing hormone agonist before hysterectomy for leiomyomas: results of a multicentre, randomised controlled trial Br J Obstet Gynaecol 1998 105(11):1148 54 9853762
Vercellini P, Maddalena S, De Giorgi O, et al Determinants of reproductive outcome after abdominal myomectomy for infertility Fertil Steril 1999 72(1):109 14 10428157
Vercellini P, Oldani S, De Giorgi O, et al Endometrial ablation with a vaporizing electrode. II. Clinical outcome of a pilot study Acta Obstet Gynecol Scand 1998 77(6):688 93 9688250
Vercellini P, Zaina B, Yaylayan L, et al Hysteroscopic myomectomy: long-term effects on menstrual pattern and fertility Obstet Gynecol 1999 94(3):341 7 10472856
Vervest HA, van Venrooij GE, Barents JW, et al Non-radical hysterectomy and the function of the lower urinary tract. II: Urodynamic quantification of changes in evacuation function Acta Obstet Gynecol Scand 1989a 68(3):231 5 2618606
Vervest HA, van Venrooij GE, Barents JW, et al Non-radical hysterectomy and the function of the lower urinary tract. I: Urodynamic quantification of changes in storage function Acta Obstet Gynecol Scand 1989b 68(3):221 9 2618605
Virtanen H, Makinen J, Tenho T, et al Effects of abdominal hysterectomy on urinary and sexual symptoms Br J Urol 1993 72(6):868 72 8306148
Vollenhoven BJ, McCloud P, Shekleton P, et al An open study of luteinizing hormone releasing hormone agonists in infertile women with uterine fibroids Gynecol Endocrinol 1993 7(1):57 61 8506764
Vollenhoven BJ, Shekleton P, McDonald J, et al Clinical predictors for buserelin acetate treatment of uterine fibroids: a prospective study of 40 women Fertil Steril 1990 54(6):1032 8 2123160
Wake CR The immediate effect of abdominal hysterectomy on intravesical pressure and detrusor activity Br J Obstet Gynaecol 1980 87(10):901 2 7426488
Wamsteker K, Emanuel MH, de Kruif JH Transcervical hysteroscopic resection of submucous fibroids for abnormal uterine bleeding: results regarding the degree of intramural extension Obstet Gynecol 1993 82(5):736 40 8414318
Watanabe Y, Nakamura G, Matsuguchi H, et al Efficacy of a low-dose leuprolide acetate depot in the treatment of uterine leiomyomata in Japanese women Fertil Steril 1992 58(1):66 71 1624025
Watson NR, Studd JW, Garnett T, et al Bone loss after hysterectomy with ovarian conservation Obstet Gynecol 1995 86(1):72 7 7784026
Webb MJ, Aronson MP, Ferguson LK, et al Posthysterectomy vaginal vault prolapse: primary repair in 693 patients Obstet Gynecol 1998 92(2):281 5 9699767
Weber AM, Mitchinson AR, Gidwani GP, et al Uterine myomas and factors associated with hysterectomy in premenopausal women Am J Obstet Gynecol 1997 176(6):1213 9 9215176
Weber AM, Walters MD, Schover LR, et al Functional outcomes and satisfaction after abdominal hysterectomy Am J Obstet Gynecol 1999 181(3):530 5 10486459
West CP, Lumsden MA, Hillier H, et al Potential role for medroxyprogesterone acetate as an adjunct to goserelin (Zoladex) in the medical management of uterine fibroids Hum Reprod 1992 7(3):328 32 1534089
Whittemore AS, Harris R, Itnyre J Characteristics relating to ovarian cancer risk: collaborative analysis of 12 US case-control studies. II. Invasive epithelial ovarian cancers in white women. Collaborative Ovarian Cancer Group Am J Epidemiol 1992 136(10):1184 203 1476141
Woolf SH, DiGuiseppi CG, Atkins D, et al. Developing evidence-based clinical practice guidelines: lessons learned by the US Preventive Services Task Force. Ann Rev Publ Health. 1996;17:511-38.
Worthington-Kirsch RL, Popky GL, Hutchins FL Jr Uterine arterial embolization for the management of leiomyomas: quality-of-life assessment and clinical response Radiology 1998 208(3):625 9 9722838
Wortman M, Dagget A Hysteroscopic myomectomy J Am Assoc Gynecol Laparosc 1995 3(1):39 46 9050615
Yamada T, Yamashita Y, Terai Y, et al Intraoperative blood salvage in abdominal uterine myomectomy Int J Gynaecol Obstet 1997 56(2):141 5 9061388
Yao SL, Lu-Yao G Population-based study of relationships between hospital volume of prostatectomies, patient outcomes, and length of hospital stay J Nat Cancer Inst 1999 91(22):1950 6 10564679
Ylikorkala O, Pekonen F Naproxen reduces idiopathic but not fibromyoma-induced menorrhagia Obstet Gynecol 1986 68(1):10 2 3523328
Ylikorkala O, Tiitinen A, Hulkko S, et al Decrease in symptoms, blood loss and uterine size with nafarelin acetate before abdominal hysterectomy: a placebo-controlled, double-blind study Hum Reprod 1995 10(6):1470 4 7593517
Ylostalo P, Granberg S, Backstrom AC, et al Uterine findings by transvaginal sonography during percutaneous estrogen treatment in postmenopausal women Maturitas 1996 23(3):313 7 8794426
Zhao SZ, Wong JM, Arguelles LM Hospitalization costs associated with leiomyoma Clin Ther 1999 21(3):563 75 10321423
Zullo E, Pellicano M, De Stefano R, et al GnRH analogues and laparoscopic myomectomy Ital J Gynaecol Obstet 1997 9(2):63 7
Zullo F, Pellicano M, De Stefano R, et al A prospective randomized study to evaluate leuprolide acetate treatment before laparoscopic myomectomy: efficacy and ultrasonographic predictors Am J Obstet Gynecol 1998 178(1 Pt 1):108 12 9465812
Zullo F, Pellicano M, Di Carlo C, et al Ultrasonographic prediction of the efficacy of GnRH agonist therapy before laparoscopic myomectomy J Am Assoc Gynecol Laparosc 1998 5(4):361 6 9782139