# Future Research

Few of the articles we reviewed met all or even most of our criteria for establishing internal and external validity. Given strong patient and provider preferences for different treatments in the absence of good data, recruitment into methodologically "ideal" studies, especially randomized trials, is likely to be difficult. However, if researchers, especially surgical researchers, followed basic principles of study design, analysis, and reporting, more meaningful conclusions could be drawn, even from case series.

The combination of public health importance and lack of knowledge creates a unique opportunity for funding agencies: any valid research will represent a substantial addition to our fund of knowledge and will lead to improvement in the health care provided to women.

## Improving Comparability Across Studies

It is clear from our review that comparing results across studies is extremely difficult, making informed decisionmaking almost impossible. Therefore, one of the highest priorities for future research should be the development of standardized reporting measures of disease severity and outcomes of therapy that will facilitate comparison of studies. Such measures would help providers and patients decide between alternative therapies and, if extended into routine practice and reporting, help patients decide between alternative providers of similar therapies (similar to reporting of assisted reproductive technology outcomes). Suggested areas include:

- Standardized reporting of disease severity, especially for those symptoms most bothersome to patients, such as excess bleeding or pain. More precise descriptions of pain (for example, distinguishing between dysmenorrhea and noncyclic pain) also would be useful.
- Better description of anatomical detail, such as size, location, and number of fibroids. Strong consideration should be given to development and validation of a staging system similar to that used for gynecological cancers; these staging systems were developed specifically to improve the ability to compare results across time and space. The model here should be cervical cancer staging, which is based on clinical rather than surgical findings. Criteria based on easily obtainable clinical and radiological measurements should be developed, validated, and put into use.
- A systematic review of the test characteristics, benefits, risks, and costs of the various methods available for the diagnosis and measurement of fibroids.
- Better description of symptoms through the use of validated symptom and/or quality-of-life measures for abnormal bleeding, dysmenorrhea, and other symptoms.
- Better description of comorbidities. Risk-adjustment methods that identify key factors affecting the probability of both symptom relief and adverse events for both medical and surgical therapies should be developed and validated.
- Standardized reporting of outcomes through the use of validated symptom and/or quality-of-life measures for abnormal bleeding, dysmenorrhea, and so forth, as well as for side effects and/or complications of therapy. For example, studies could be done comparing blood loss (using published, validated measures) between women with fibroids in different locations or with different numbers of fibroids. Studies also should be performed using measures that capture patient preferences for outcomes so that quality-adjusted life years can be estimated.
- Standardized methods for reporting outcomes for both new and established procedures. Physician experience may affect the probability of both favorable and adverse outcomes of invasive interventions.

## Improving Knowledge About the Effectiveness of Medical Therapies

Although recruitment into trials of surgical therapies may be difficult, there is no reason why trials of medical treatments cannot take place. High priority should be given to proving or disproving the effectiveness of commonly used medical agents such as NSAIDs, progestins, and oral contraceptives in the treatment of symptomatic fibroids. If these agents are effective, then evidence of effectiveness should increase their use and may decrease unnecessary surgical procedures. If they are ineffective, then symptomatic patients should not be forced to deal with persistent symptoms for some arbitrary length of time prior to undergoing effective surgical therapy. New agents for the management of fibroids should be held to the same methodological standards.

Funding for rigorous research into the effectiveness of existing medical therapies is unlikely to come from industry, since there would appear to be little incentive for any company manufacturing oral contraceptives or NSAIDs to apply for a specific indication for fibroids.

In addition, significant additional research into the basic mechanisms of the development of fibroids is needed. Such research has the potential to lead to new noninvasive therapies and to provide insight into other conditions affecting the uterus. For example, black women are significantly more likely to have premature labor and deliver preterm infants than white women, a phenomenon that is independent of socioeconomic status or access to health care. Black women also are much more likely to develop fibroids. Understanding the genetic and molecular basis for the observed racial difference in fibroid incidence may lead to understanding of racial differences in the basic physiology of the uterus that may shed light on the reasons for observed differences in preterm labor.

Additionally, research into methods of primary prevention should be encouraged. A report of a decreased risk of fibroids with the use of a levonorgestrel-containing intrauterine contraceptive device (Sivin and Stern, 1994) suggests that data on the effects of various contraceptive methods on the risk of fibroids may help guide contraceptive choices in women at high risk of developing fibroids.

## Improving Knowledge About Long-Term Outcomes

The majority of studies in our initial review are limited by lack of long-term followup (this is especially true of hysterectomy studies), incomplete followup, or failure to use appropriate statistical methods. Because patients need information about short- and long-term outcomes to understand the trade-offs involved, collecting better data about long-term outcomes should be a high priority. Examples include:

- Long-term followup of cohorts from existing randomized and nonrandomized trials. With appropriate detail, cohort studies, such as those from registries, can provide a great deal of information. If sufficient clinical information is recorded, parallel registries (for example, of uterine artery embolization and myomectomy) could at least provide information to help design a randomized trial.
- Use of appropriate statistical tools such as survival analysis.
- Studies of the impact of premenopausal therapy for fibroids, both surgical and nonsurgical, on postmenopausal women, in both users and nonusers of hormone replacement therapy.

## Improving Knowledge About Basic Epidemiology and Use of Health Services

The majority of the data available at the population level concerns surgical management. Population-based information is needed on:

- The prevalence of fibroids in asymptomatic women, with long-term followup to determine the likelihood of development of symptoms.
- Outpatient management of symptomatic fibroids, with estimation of the number of patients proceeding to surgical therapy.
- Variations in outpatient management across regions and across specialties.
- Racial and ethnic differences in biology, epidemiology, and use of health services. For example, the consistent observation that black women have larger and more numerous fibroids than white women has several possible explanations (which are not mutually exclusive). -- The biology of either the fibroids or the uterus is different in black women. -- Reproductive factors (such as age at first pregnancy) may influence fibroid development and affect black and white women in different ways. -- Biological and/or cultural differences exist in the way symptoms present, either in terms of severity or perceived "bother," resulting in different thresholds for seeking treatment. -- Differences exist in the experience, training, or practice patterns of physicians who provide care for black and white women. -- Socioeconomic factors affect the threshold for seeking care (such as competing concerns about income or child care).

## Improving Knowledge About the Economics of Fibroids

Despite the high incidence of symptomatic fibroids, limited data exist on the economic impact of this condition. The few studies that do attempt economic analysis focus on hospital charges. Studies are needed that:

- Estimate nonmedical costs associated with symptomatic fibroids (time lost from work, use of over-the-counter medications or feminine hygiene products).
- Estimate nonmedical costs associated with treatment of symptomatic fibroids (time lost from work, child care costs, transportation costs, etc.).
- Estimate direct medical costs associated with the diagnosis and management of symptomatic fibroids.

Ideally, estimation of these costs would be included in all future studies of treatment efficacy.