# Conclusions

In this section we discuss the implications of our findings, the limitations of the current literature, the limitations of the report, and suggested strategies for using this report for developing quality improvement tools.

## Research Implications

The primary implication of our review of the literature is that there is almost no high-quality evidence on which to base treatment strategies for a condition that:

- Affects at least one-third of women during their reproductive years.
- Is the leading indication for the most commonly performed nonobstetric major surgical procedure in women.
- Exhibits consistent epidemiological differences between racial groups.
- Results in hospital charges of more than $2 billion annually.

We were unable to identify any published literature or other data source that allowed us to reach definitive conclusions regarding any of our research questions. The fact that there is so little evidence for patients, clinicians, and policymakers to use in making decisions about the management of such a common condition is striking. Given this lack of evidence, it is not surprising that provider and patient preferences have come to play such a large role in determining therapy. Recommendations from expert panels, clinical pathways, utilization review criteria, or other methods used to determine the most "appropriate" management would appear to be no more likely to have a basis in strong, consistent scientific evidence than individual patient or clinician opinion.

We summarize our findings and conclusions for the individual research questions below.

### What are the risks and benefits of hysterectomy and myomectomy in the treatment of symptomatic and asymptomatic fibroids?

There is no evidence documenting any benefit for the use of either hysterectomy or myomectomy for management of asymptomatic fibroids. Each of these procedures has definite risks. We did not identify any randomized trials directly comparing hysterectomy with myomectomy in women with symptomatic fibroids.

The majority of reviewed studies of abdominal and laparoscopic myomectomy did not report on the effects of the procedure on relieving symptoms. Studies of hysteroscopic myomectomy did report symptomatic relief, but followup and methods for determining symptom severity were variable. Results of hysteroscopic myomectomy appear to be related to fibroid anatomy, with success decreasing as a greater percentage of the fibroid involves the myometrium. Blood loss resulting in blood transfusion was the most commonly reported short-term complication of all myomectomy procedures, ranging from 2-10 percent. Hysteroscopic procedures carried risks of uterine perforation and fluid/electrolyte disturbances.

Three prospective studies of women undergoing hysterectomy reported overall favorable outcomes at followup of up to 2 years; results for women with fibroids appeared to be consistent with results for the overall cohort. Up to 12 percent of women reported new symptoms after hysterectomy, with menopausal symptoms being most common.

Unfortunately, because of the lack of data that would allow comparison between the baseline characteristics of patients undergoing each procedure, no inferences can be drawn about relative short- or long-term risks and benefits. Although some retrospective multivariate analyses suggest that much of an observed increased risk of hysterectomy is because of larger uterine size, this needs to be confirmed in larger studies.

### What are the risks associated with single versus multiple myomectomies?

Women with a single clinically apparent fibroid who have a surgical removal may be less likely to experience short-term complications or long-term recurrence, and they may have higher pregnancy rates than women with multiple fibroids who undergo surgical management. However, variations in reporting methodology prevent quantitative synthesis of these findings. In addition, it is unclear whether these variations in outcomes are related to differences in surgical success rates or underlying patient biology.

### Who are appropriate candidates for each procedure?

Women who desire to retain childbearing potential obviously are not candidates for hysterectomy. There is insufficient evidence to draw any conclusions about appropriate candidates for other procedures or treatments based on patient characteristics (beyond issues such as overall risk of complications from surgery because of medical comorbidity, contraindications to particular medications, and so forth).

### What is the incidence of need for additional treatment after myomectomy or other uterus-sparing interventions?

It is clear that some women do develop symptomatic fibroids after treatment with medical therapy, uterine artery embolization, or myomectomy. Reported cumulative recurrence rates after myomectomy range up to 50 percent at 5 years, with up to 14 percent of patients subsequently undergoing hysterectomy. Increasing preoperative uterine size, increasing number of fibroids, increasing fibroid penetration into the myometrium, and residual tissue at the completion of the procedure were all associated with recurrence risk in at least two series. However, inconsistency in reporting definitions of recurrence, loss to followup, length of followup, use of other adjunctive treatments, and patient characteristics that might affect recurrence preclude a more precise estimation of incidence. In addition, it is not at all clear that "recurrent" fibroids after conservative therapy do not simply represent de novo development of additional fibroids; in this case, the association between "recurrence" and number of preoperative fibroids may represent an individual patient's propensity to develop myomas or the results of surgically induced changes in the uterus that actually facilitate fibroid growth.

### Does additional treatment result in significantly increased morbidity?

Although there are potential mechanisms by which additional treatment might result in significantly increased morbidity, we were unable to identify any studies that provided information that would allow us to address this question. The trade-offs in terms of risks and benefits of immediate definitive therapy (i.e., hysterectomy) compared with conservative therapy, with a possible need for definitive therapy at a later date, are unclear. If additional treatment does result in increased morbidity (an increased relative risk), patients and clinicians need to take into account the actual probability of needing additional treatment (for which there are no data) in order to estimate an individual patient's overall absolute morbidity risk.

### What are the risks and benefits of nonsurgical treatment?

We found surprisingly little literature on the benefits and risks of commonly used medical treatments for fibroids, such as nonsteroidal agents, progestins, and oral contraceptives. Data on long-term outcomes of GnRH agonist therapy also were lacking, although there is consistent evidence from randomized trials that preoperative use of GnRH agonist therapy reduces estimated blood loss and operating room time and may allow changes in surgical technique. The short- and long-term clinical significance of these findings is unclear.

### What are the costs associated with effective surgical and nonsurgical treatments?

We found no data on nonmedical costs or outpatient costs other than prescription drug costs for diagnosis and management of symptomatic fibroids. Nonsteroidals are the least expensive of the medical treatments, followed by progestins and oral contraceptives. Drug costs for a 3-month course of GnRH therapy are in the range of $1,500. Data on hospital costs suggest that abdominal myomectomy is somewhat less expensive than hysterectomy, with a mean cost differential of approximately $800. Determining the relative cost-effectiveness of different treatments depends on data on effectiveness, which are lacking.

### Do risks and benefits differ for women according to race, ethnicity, age, and interest in future childbearing?

#### Race

Fibroids appear to be more common, appear at earlier ages, and be larger and more numerous at diagnosis and treatment in black women compared with white women. Both hysterectomy and myomectomy appear to be performed more frequently in black women. Although black women undergoing surgical procedures for treatment of fibroids have a higher complication rate, this may be due to differences in technical difficulty related to a greater fibroid size and number.

#### Age

Therapy with GnRH agonists, myomectomy, or uterine artery embolization may be more effective in preventing recurrence of bleeding symptoms in perimenopausal women compared with premenopausal women. The effects of hormone replacement therapy on women with treated or untreated fibroids are unclear.

#### Pregnancy Complications

Fibroids may be associated with an increased risk of complications of pregnancy and are clearly associated with an increased risk of cesarean section (c-section). However, some of this increased risk may be due to ascertainment bias, since women with c-sections have a greater opportunity to have fibroids diagnosed, and many of the complications associated with fibroids (abruption, abnormal presentations) are more likely to result in c-sections. There are no data suggesting that myomectomy improves pregnancy outcomes; data also are lacking on optimal management of pregnancy in women who have undergone myomectomy.

#### Fertility

The exact role that fibroids play in infertility, the effectiveness of treatment of fibroids in enhancing fertility, and the role of nonsurgical management in treating fibroids in patients with a desire for future childbearing are unclear.

### What are the effects of surgical management of uterine fibroids, especially hysterectomy, on the aging process?

We found no evidence on the effects of myomectomy on the aging process. We found scant evidence on the effects of hysterectomy specifically performed for fibroids on the aging process. Hysterectomy in general does appear to affect ovarian function, even without removal of the ovaries. It does not appear to adversely affect sexual function in the short term in most women, and it may improve sexual function in many women with preoperative sexual dysfunction. Data on the effects of hysterectomy on pelvic floor dysfunction are scanty. Removal of both ovaries at the time of hysterectomy increased the likelihood of development of new symptoms or failure to improve from preoperative symptoms in one large prospective study.

## Limitations of the Current Literature

The limitations of the current literature are significant.

### Study Design

Given that there is no Food and Drug Administration (FDA) requirement for trials before the introduction of surgical procedures, strong patient and provider beliefs about the risks and benefits of surgery, and the methodological difficulties of performing randomized trials of surgical procedures, it is not surprising that randomized trials of surgical treatments for fibroids are exceedingly rare. However, given the frequency with which fibroids are diagnosed and the almost universal recommendation for a trial of medical management prior to surgical intervention (Broder, Kanouse, Mittman, et al., 2000), we expected to find better evidence supporting the use of these medical therapies. Even the best-designed cohort study reporting on outcomes of nonsurgical treatment (Carlson, Miller, and Fowler, 1994b) presents combined results for no therapy, hormones, and nonsteroidals, precluding estimation of a treatment effect. Until well-designed trials of the effectiveness of nonsurgical treatments are performed, insisting on a trial of medical management prior to definitive surgical therapy is somewhat difficult to justify on effectiveness grounds alone, especially when the quality of the evidence supporting the effectiveness of hysterectomy is superior to that supporting most medical treatments. If the major symptom is bleeding, it should be acknowledged that the best available data show that hysterectomy has nearly 100 percent effectiveness and provides definitive therapy.

### Comparability of Subjects

Although randomized trials, including trials of surgical therapies, would be ideal, other study designs are likely to continue to be reported. The ability to synthesize data from these studies would be significantly enhanced by common standards for reporting important characteristics of the patients and treatment. This is especially true for factors likely to affect short-term outcomes (e.g., complications). At a bare minimum, data on uterine size, number of fibroids, size of fibroids, and location of fibroids should be provided. These data should be reported in a way that would facilitate comparison between studies and use in multivariate methods. For example, reporting of distributions of number of fibroids may be a more useful way of characterizing the patient population than reporting means and standard deviations, especially since noninteger numbers are meaningless.

### Comparability of Symptom Measures

The ability to compare studies would be significantly enhanced by use of common measures, preferably measures that have been validated in appropriate populations. This specifically includes comparability in definition and ascertainment of persistence or recurrence after conservative therapy. Similarly, uniform timing of measurement before and after treatment would allow direct comparison of true rates of improvement, persistence, or recurrence by facilitating calculation of these events over time.

### Duration of Followup

Even the best-designed and implemented studies of hysterectomy outcomes are limited to a 2-year followup. Longer term prospective studies, with data reported specifically by indication, are needed.

## Limitations of the Report

### Literature Search

We used standard methods for identifying, reviewing, and abstracting published studies focused on management of uterine fibroids. Our criteria for study inclusion were notably less strict than those used in other systematic reviews, such as those conducted by the Cochrane Collaboration. We included a variety of nonrandomized study designs, including case series and studies with as few as 20 patients. We did not search the literature prior to 1975, primarily because we assumed that surgical technique (such as use of prophylactic antibiotics) and reporting standards had changed sufficiently to prevent generalization of results. We also limited our search to articles published in English, primarily for reasons of convenience and resources. It is possible that including older studies or studies published in other languages would have identified additional evidence that would have substantially changed our conclusions. This may be especially true for "alternative" therapies, such as herbal medications or for studies performed in populations where extensive emigration to the United States is a factor. Another limitation of our exclusion criteria is that rare but severe complications of treatments may have been overlooked because they were reported as case reports or small case series.

### Grading Articles

We used a nonstandard method to grade the articles we reviewed. However, we believe that the rationale for each criterion is reasonable, and that the operational definitions are clear and reproducible. In addition, we used the grading criteria primarily to provide additional detail to other researchers; we did not establish a "threshold" for including articles or use these criteria to weight the results of a quantitative analysis.

### Other Data Sources

We used two additional data sources for this report, the Nationwide Inpatient Sample (NIS) and primary chart abstraction from Duke University Medical Center. The NIS, like most administrative databases, is limited by a lack of clinically relevant detail that may affect short-term outcomes (Myers and Steege, 1999). In addition, economic data are based on patient charges rather than costs.

The Duke data, like most chart abstractions, are limited by inconsistency in clinical charting and missing data; data from an academic medical center also may not be generalizable to other settings. Sample size, while larger than previously published studies, is also somewhat small, especially for performing multivariate analyses.

Both data sets lack data on patient symptoms, response to treatment, and long-term outcomes.

We were unable to identify any readily accessible additional data sets that would supplement these or allow estimation of nonmedical costs or the costs of outpatient care, although it is possible that such data sets exist.

### Decision Model

Like all models, ours has simplifying assumptions. It is possible that these assumptions invalidate the model or would prohibit its use in certain populations. It is also possible that our estimation of clinically important states for use in the model are not valid or do not represent states or concepts important to patients and clinicians. However, the main limitation to the use of the model is the lack of input data available for estimating transition probabilities and outcomes. Given the quality of the literature available for validation of the model, we clearly do not intend for it to be used in its current state to make treatment or policy decisions.

## Suggested Strategies for Using This Report

The state of the available evidence clearly does not allow the data presented in this report to be used to establish clinical guidelines or performance measures since, for most interventions, there is little evidence either supporting or refuting their use. Organizations may want to use this report as a starting point for discussion about current practices or to suggest clinical research topics. One activity that might prove immediately useful would be the development of standardized reporting tools for patients with fibroids. The inability to compare results across studies because of uncertainty about baseline patient characteristics is also a problem when comparing results across hospitals or providers. Development of a standardized reporting mechanism, which includes anatomical and historical features that might affect outcomes (such as fibroid size, number, and location; prior surgical procedures; or patient body mass index), would greatly facilitate such comparisons. Ideally, a reliable and validated instrument also would be used to measure symptoms before and after treatment.