# Decision Model

## Approach

Decisionmaking regarding fibroids can be difficult for a variety of reasons, including the wide range of treatment options, the lack of detailed information about the natural history of the condition and the effectiveness of treatments, and the large number of potential outcomes of importance. In this context, decision modeling can be useful both descriptively and prescriptively. Decision models can be useful descriptively by providing a concise and explicit framework for presenting what is known about the problem at hand. Such models can further describe the quantitative implications of this information by generating projections of the various outcomes of different choices. These projections can be useful prescriptively in making decisions about which treatment strategy is preferred.

Models also can serve as a guide to research priorities by showing how reduction in uncertainty regarding any issue translates into reduction (or not) in uncertainty about the preferred treatment decision. In addition, when health outcomes are valued quantitatively in terms of utilities and economic outcomes are viewed in terms of social resource value, then decision models can be used prescriptively to provide explicit guides to decisionmaking by permitting the calculation of incremental effectiveness and incremental cost-effectiveness ratios.

To serve both descriptive and prescriptive goals, we have developed a general purpose decision model based on a synthesis of available data. The model simulates the natural history of a woman (or cohort of women) with fibroids, provides projections of the possible outcomes of various treatment options, and helps identify areas where additional information is needed to permit informed decisions.

## Clinical Scenario

The purpose of this chapter is to describe the general purpose fibroid model. To illustrate the operation of the fibroid model we considered a specific clinical scenario of a woman with fibroids, with symptoms of both pain and bleeding, who does not wish to preserve childbearing ability and is therefore a candidate for hysterectomy. Additional considerations for this illustrative case are:

- The patient has failed a trial of medical therapy with oral contraceptives or nonsteroidal anti-inflammatory drugs (NSAIDs).
- The patient does not live near a center capable of performing uterine artery embolization.
- The patient is not anemic and wishes to avoid the side effects of gonadotropin-releasing hormone (GnRH) agonist therapy.
- The size and location of her fibroids dictate an abdominal approach to either hysterectomy or myomectomy based on the experience of the surgeons available to her.

Thus, the treatment choices available in this particular circumstance are (1) no additional therapy, (2) abdominal myomectomy, and (3) abdominal hysterectomy. The specific questions are:

1. For the woman described above, what are the likely outcomes of the three possible treatment choices?
2. For which factors is uncertainty crucial to the outcomes of the treatment choice (and thus are prime candidates for further research)?

In this illustration, we do not include medical or nonmedical costs.

## Methods

### Model Structure and States

To simulate the natural history of fibroids, we developed a semi-Markov model of possible important events that might occur when a woman has symptomatic or asymptomatic fibroids, whether resulting from the condition or from its treatment. As represented in Figure 6, events (arrows) lead to health states (ovals). This approach allows for the modeling of a complex time sequence of health states associated with fibroids. Each state is associated with a series of permissible transitions to the other states, and each transition is associated with a probability of occurrence (transition probability). To permit a more precise simulation of patient history, we allowed transition probabilities to vary with time. The model consists of the following states:

- Asymptomatic fibroids (prior to any intervention).
- Symptomatic fibroids, no side effects/complications of therapy.
- Symptomatic fibroids, side effects/complications of therapy.
- Improved symptoms, no side effects/complications.
- Improved symptoms, side effects/complications.
- No symptoms, no side effects/complications (after an intervention that successfully resolves symptoms and does not result in any side effects or complications).
- No symptoms, side effects/complications.
- Uncomplicated pregnancy (no complications attributable to fibroids).
- Complicated pregnancy (complications attributable to fibroids).
- Menopause.
- Death.

Figure 6. Schematic of fibroids model

Note: Possible transitions between states are shown by arrows. Some transitions are not shown for clarity. For example, symptomatic fibroids with side effects and complications from a treatment could transition to no complications with no side effects or complications if another treatment were implemented. Additionally, uncomplicated pregnancy, pregnancy complicated by fibroids, menopause, and death from other causes are possible transitions from any state.

These states were chosen based on our clinical experience with patients with fibroids and input from the advisory panel. The goal was to allow the model to reflect the history of the condition and its treatment in sufficient detail to permit estimates of the rate and timing of occurrence of specific outcomes of interest. This detail allows explicit presentation of different outcomes for different treatments -- benefits and risks that occur at different rates or with different timing.

### Assumptions

We made several assumptions in constructing the model to make the structure more tractable and to permit estimation of model parameters from available data.

- The likelihood of symptomatic improvement is independent of the probability of side effects or complications. Although this is likely to be true for some symptomatic states (e.g., those related to bleeding), it may not be for others (e.g., those related to pain). For infertility, there are some complications (adhesions, necessity for hysterectomy) that may actually decrease the probability of success. However, given that we were unable to identify any study that reported data using similar groupings, this assumption seems reasonable. For hysterectomy, at least, data from the Maryland Women's Health Study suggest that the likelihood of symptomatic improvement is not related to the occurrence or severity of perioperative complications (Kjerulff, Langenberg, Rhodes, et al., 2000).
- Symptoms resolve with the onset of menopause. This assumption simplifies the model. However, if hormone replacement therapy is used, the assumption may be less valid. The model can be readily modified to allow continuation of symptomatic states into menopause, with appropriate adjustments in probabilities as data become available. For women who are perimenopausal, we assumed that symptoms will continue. Bleeding problems during the perimenopausal phase were common in the Massachusetts Women's Study (McKinlay, Brambilla, and Posner, 1992), so it seems likely that abnormal bleeding related to fibroids would persist during this phase.
- For simplicity, the model considers a "pregnancy" to occur when it has reached 24 weeks. Thus, "pregnancy" excludes failure to conceive, habitual abortion, or early second trimester loss. Again, because the likelihood of these outcomes, the associated costs, and their quality-of-life impact may well differ, the model will need to be modified to incorporate these outcomes specifically for those patients with concerns about future pregnancies.

### Operation of the Model

The operation of the model is illustrated by the following description of a simulation run for a patient with symptomatic fibroids:

- The patient's age, race, and particular symptoms or problem (bleeding, dysmenorrhea, infertility, etc.) are specified at the start of the simulation. Depending on the treatments under consideration, other factors that might influence the likelihood of particular outcomes (other causes of infertility, comorbid conditions, severity of disease) would also be specified.
- All future health states are tracked for discrete cycles (the default cycle length in this model is 1 year, although shorter lengths might be appropriate in certain situations). At the beginning of each cycle the patient may either become menopausal or die of other causes; these probabilities are age-dependent and can be adjusted for race.
- If future pregnancy is not a consideration, the age-dependent probability of pregnancy (modifiable by treatment or underlying morbidity) can be "switched off."
- Patients who elect no treatment have a probability of spontaneous resolution of symptoms or a lessening of the degree to which the symptoms are bothersome; for the purposes of the model, these two are equivalent. Alternatively, symptoms can persist or worsen.
- Patients who elect treatment have a treatment-specific probability of improved symptoms (which can be further divided into complete and partial resolution), as well as treatment-specific probabilities of side effects and/or complications.

Note that because the length of the simulation can be varied, long-term data, if available, can be incorporated. For example, patients undergoing surgical management who experience short-term complications may transition to a "no side effect/complication" branch after one or two cycles. Similarly, recurrence or need for additional treatment after conservative therapy also can be incorporated.

### Model Transition Probabilities

Transition probabilities used in this model (Table 26) are divided into (1) natural history probabilities, such as probability of mortality, menopause, and spontaneous symptom resolution; and (2) treatment probabilities, such as probability of treatment-specific symptom resolution and complication. In each case, we provide the source of the parameter estimate, derivation of the parameter estimate, and a "base case" and "range" estimates. The base case estimate is used for the principal results of the analysis for the illustrative case. The range estimates are the plausible high and low values reflecting uncertainty in the true values of the parameters. This range is used in the sensitivity analysis (described below).

Table 26. Probabilities used for estimating outcomes of hysterectomy, myomectomy, and no treatment

Probability | Estimate | Range
All options
All cause mortality | Age-specific, from life-tables
Menopause | Age-specific, derived above
No treatment option
Spontaneous resolution | 30% at 1 year | 20-40%
Need for hysterectomy | 10% at 1 year | 10-20%
Myomectomy option
Symptomatic improvement | 90% | 60-95%
Short-term complications | Equivalent to hysterectomy
Recurrence leading to hysterectomy | 3% at 2 years | 3-10%
Long-term complications | 0% | 0%
Hysterectomy option
Symptomatic improvement | 90% | 60-95%
Short-term complications | Equivalent to myomectomy
Long-term complications | 12% at 2 years | 0-15%

#### Natural History Parameters

##### Mortality

Age-specific mortality rates were obtained from 1997 U.S. life-tables (Anderson, 1999). The probability (p) of an event occurring in a time interval (d) based on an event rate (r) is calculated using the standard formula: p = 1 − e^(−r)x(d)^.

##### Menopause

The age-specific rate of becoming amenorrheic secondary to natural menopause was estimated from several sources. For women aged 30 to 39, Coulam and colleagues reported a rate of 76/100,000 per year derived from a cohort study in Minnesota, resulting in a prevalence of 1 percent by age 40 (Coulam, Adamson, and Annegers, 1986). This rate was converted to an annual transition probability as above.

Probabilities for women aged 45 through 55 were estimated from cross-sectional and prospective data from the Massachusetts Women's Study (McKinlay, Brambilla, and Posner, 1992). McKinlay and colleagues reported on the transition from premenopause through perimenopause to postmenopause.

Annual transition probabilities from pre- and perimenopause to postmenopause were derived by estimating the age-specific prevalence of postmenopause from figures in McKinlay and colleagues (McKinlay, Brambilla, and Posner, 1992) and calculating the age-specific transition rates required to achieve those prevalences for a cohort beginning at age 45.

Probabilities between age 40 and 45 were estimated by fitting an exponential curve to the observed data:

Proportion postmenopausal = 0.0115 * e^0.6989 x^, where x = number of years after age 40.

The resulting transition probabilities used in the simulation are shown in Table 27.

Table 27. Estimated age-specific transition rates from pre- and perimenopausal to postmenopausal state

Age | Proportion post-menopausal | Transition rate/year | Transition probability
39 | 0.0089 | 1/1000 | 0.0008
40 | 0.010 | 4/1000 | 0.0040
41 | 0.014 | 5/1000 | 0.0050
42 | 0.019 | 7/1000 | 0.0070
43 | 0.026 | 7.2/1000 | 0.0072
44 | 0.039 | 32/1000 | 0.0315
45 | 0.07 | 32.2/1000 | 0.0317
46 | 0.1 | 55/1000 | 0.0535
47 | 0.15 | 59/1000 | 0.0573
48 | 0.2 | 94/1000 | 0.0897
49 | 0.275 | 103/1000 | 0.0979
50 | 0.35 | 215/1000 | 0.1935
51 | 0.49 | 216/1000 | 0.1943
52 | 0.6 | 300/1000 | 0.2592
53 | 0.72 | 300/1000 | 0.2592
54 | 0.8 | 286/1000 | 0.2487
55 | 0.85 | 250/1000 | 0.2212

Note: Based on data from McKinlay, Brambilla, and Posner, 1992

##### Natural history of symptomatic fibroids

Relevant probabilities for a woman with symptomatic fibroids who does not undergo any further therapy include (1) spontaneous resolution of symptoms, (2) no change in symptoms, and (3) worsening of symptoms resulting in the need for surgical therapy. The likelihood of spontaneous resolution of symptoms was obtained from the nonsurgical cohort in the Maine Women's Health Study (Carlson, Miller, and Fowler, 1994b). Unfortunately, results in this study are reported for all nonsurgical treatments, including hormonal therapy and NSAIDs rather than for individual treatment options. Because 68 percent of women with fibroids received no treatment, we have assumed that the results for no treatment alone are not substantially altered by the inclusion of women receiving medical therapy. At 1 year after initiation of the cohort, the proportion of women with fibroids who reported that their symptoms were not bothersome increased from 47 percent to 63 percent. This is equivalent to a resolution rate of 30 percent per year.

Carlson and colleagues (Carlson, Miller, and Fowler, 1994a) reported a 23 percent incidence of hysterectomy at the end of 1 year, with the rates not differing between indications. Weber and colleagues reported a 22 percent incidence over 29 months (Weber, Mitchinson, Gidwani, et al., 1997). These two incidences result in a probability range of 9.5 to18 percent. In the base case, we use the lower end.

#### Treatment Parameters

##### Myomectomy

Relevant probabilities to consider for myomectomy include (1) symptom relief, (2) short-term complications, (3) risk of recurrence, and (4) long-term complications.

##### Symptom relief

Estimating the likelihood of symptom relief 2 years after abdominal myomectomy is difficult given that none of the research studies we identified reported on symptoms. Studies of laparoscopic myoterectomy do give some symptom data, but quantification is hampered by variability in methods used to measure symptoms, failure to account for all subjects, and imprecision in reporting length of followup. Studies listed in Table 10 (from Question 1) report success rates of 80-100 percent for bleeding symptoms and 50-90 percent for pain. For the base case, we use a 90 percent likelihood of symptomatic relief at 2 years.

##### Short-term complications

Short-term complication rates also are variable, with transfusion rates as high as 20 percent. In the series of Iverson and colleagues (Iverson, Chelmow, Strohbehn, et al., 1996), there were no serious intraoperative complications for abdominal myomectomy. In this study, although hysterectomy was associated with a higher estimated blood loss compared with myomectomy, this difference was not significant when adjusted for uterine size. Hysterectomy also was associated with a higher intraoperative complication rate, although there was no apparent attempt to control for the impact of uterine size.

For patients undergoing hysterectomy, the occurrence of intraoperative complications does not appear to influence the likelihood of a good or bad outcome by 2 years after surgery (Kjerulff, Langenberg, Rhodes, et al., 2000). In considering complication risks for the purposes of this example, we make the following assumptions:

- Overall complication rates are equivalent for abdominal hysterectomy and myomectomy, given equivalent uterine size and number of fibroids.
- Even if this were not the case, in-hospital complications do not influence the likelihood of symptomatic relief.

Therefore, because we are primarily interested in patient outcome at 2 years, we did not consider complications in the base case analysis. We did consider the impact of a higher short-term complication risk for hysterectomy in sensitivity analysis.

##### Risk of recurrence

Estimating the probability of symptomatic recurrence is fraught with the same difficulties as estimating symptom relief. Reported hysterectomy rates after myomectomy, presumably for recurrent or persistent symptoms, range from 2 to 8 percent, with indeterminate times. We use a hysterectomy rate of 3 percent after 2 years in the base case.

We found no data on long-term complications or development of new symptoms after abdominal myomectomy. We assume that this probability is 0 percent (at least for women not considering future pregnancy).

##### Abdominal hysterectomy

Relevant probabilities related to abdominal hysterectomy include symptom relief, short-term complications, and long-term complications.

##### Symptom relief

All three cohort studies in U.S. populations reported substantial improvement in symptoms after 1 to 2 years (Carlson, Miller, and Fowler, 1994a; Kjerulff, Langenberg, Rhodes, et al., 2000; Weber, Mitchinson, Gidwani, et al., 1997). For symptoms related to bleeding, relief was nearly 100 percent (given the procedure, it seems likely that those reporting persistent bleeding after hysterectomy represent either supracervical hysterectomies with some residual endometrial tissue or symptoms related to granulation tissue at the vaginal cuff). For symptoms related to pain, there was an 83 percent chance of having significant relief at 2 years (Kjerulff, Langenberg, Rhodes, et al., 2000). We use 90 percent (equivalent to myomectomy) in the base case.

##### Short-term complications

As discussed above, short-term complications do not appear to affect the likelihood of a positive response, so we will not consider hysterectomy complications. Clearly, if the risk is increased compared with myomectomy, these would need to be considered; because complications are associated with higher costs (Myers and Steege, 1999), they would clearly need to be included in a cost-effectiveness analysis.

##### Long-term complications

New problems were noted in 12.9 percent of patients at 2 years in the Maryland cohort (Kjerulff, Langenberg, Rhodes, et al., 2000). For this analysis, we assume a 12 percent probability of new symptoms at 2 years.

### Assigning Values to Outcomes

In this example, we again simplify by assigning a value of 1 for complete relief or entering menopause and 0 for all other states (persistent symptoms, long-term complications, or death). Obviously, values for these states will differ between patients, and temporary states (such as short-term complications) or patient preferences for outcome process (a strong preference to avoid hysterectomy, for example) play important roles. However, this simplified system helps illustrate how the various probabilities in the model affect outcomes.

### Outcomes

The primary outcome of interest is relief of symptoms. In this illustrative example, response to treatment is dichotomous, either complete relief or no relief. Secondary outcomes include either immediate complications or development of new symptoms after treatment.

### Analytic Horizon

Because the longest published followup in prospective cohort studies of hysterectomy patients is 2 years, the analytic horizon for this analysis is 2 years.

### Sensitivity Analysis

To assess the impact of uncertainty in parameter estimates, we performed one-way sensitivity analysis. Outcomes were calculated for the range of plausible values.

### Software

The tree was constructed and all calculations performed using DATA 3.5 (TreeAge, Williamstown, MA).

## Results

### Base Case

Using the base case assumptions, the probabilities of complete relief or menopause, without development of long-term complications, for a 35-year-old woman choosing between these options are 35.8 percent for no treatment, 83.4 percent for hysterectomy, and 89.9 percent for myomectomy.

### Sensitivity Analyses

We performed sensitivity analysis on all parameters by varying the values across the ranges described above, both individually and in two- and three-way combinations. We illustrate the effect of uncertainty surrounding four specific parameters, all of which are related to key questions addressed in this report, in the figures that follow. In all figures, the vertical axis represents the "expected value" of the decision -- the probability of a favorable outcome multiplied by the value (1.0, in this case) of a favorable outcome, plus the probability of an unfavorable outcome multiplied by the value of an unfavorable outcome (0).

#### Long-Term Complications

The probability of a favorable outcome is higher with hysterectomy if the probability of a long-term complication is less than 5.2 percent (see Figure 7).

Figure 7. Sensitivity analysis on probability of long-term complications after hysterectomy

#### Recurrence after Myomectomy

Recurrence risk did not substantially affect the probabilities (see Figure 8).

Figure 8. Sensitivity analysis on probability of recurrence after myomectomy

#### Spontaneous Resolution of Symptoms

As the likelihood of spontaneous resolution increased, the likelihood of a favorable outcome also increased, although this probability always remained less than for myomectomy or hysterectomy (see Figure 9).

Figure 9. Sensitivity analysis on probability of improvement with no treatment

#### Patient Age

Because patient age strongly affects the likelihood of undergoing menopause, the probabilities of a favorable outcome of each strategy also were affected by patient age (see Figure 10).

Figure 10. Sensitivity analysis on patient's age

The likelihood of a favorable outcome with no therapy increases substantially with increasing age. This likelihood also increases slightly for the surgical options because of the increased probability of menopause in those women who do not respond favorably to the initial therapy.

#### Discussion

Based on this simplified model, uncertainty surrounding the long-term side effects of hysterectomy and the effect of menopause on symptoms related to fibroids appear to be more important factors in determining the likelihood of a favorable outcome than recurrence after myomectomy or even the probability of spontaneous resolution. If a more sophisticated analysis of a validated model had similar findings, this could help direct research priorities toward longer term prospective studies of hysterectomy outcomes and the natural history of fibroids in peri- and postmenopausal women.

## Methodological Issues

The main methodological issue related to the model is the substantial uncertainty surrounding the majority of important parameters due to a lack of a data. Although uncertainty is always inherent in any decision model (indeed, certainty precludes the need for models), the lack of data necessary to validate, calibrate, and test this model is striking.

However, in our example case, changes in parameters resulted in changes in outcomes in ways that make intuitive sense (for example, an inverse relationship between long-term complications of surgery and probability of a favorable outcome or an increasing likelihood of a favorable outcome of "watchful waiting" as the likelihood of menopause increases).

## Summary

We constructed a comprehensive general-purpose model to estimate outcomes of different strategies for management of fibroids. Despite significant limitations in available data for key parameter estimates, the model is able to generate qualitatively reasonable estimates for a focused clinical scenario.

In our base case analysis, surgical interventions appear attractive when the outcomes of interest are defined in terms of relief of symptoms related to bleeding. Within the constraints imposed by the limitations of available data, sensitivity analysis suggests that this conclusion is robust. Key factors revealed in our sensitivity analysis were the probability of menopause within the next 1-2 years and the likelihood of the development of new symptoms after hysterectomy.

Clearly, the model is currently overly dependent on assumptions and estimates based on poor-quality data. Our outcomes were dichotomized for simplicity in this illustrative example -- a more useful approach would be to use continuous measures of quality of life or patient preferences. In addition, we excluded any consideration of economic concerns (again primarily because of a lack of data).

Despite these shortcomings, this modeling exercise suggests the fibroid model has the potential to aid in interpretation of available data and to guide future research priorities.