# Methodology

This chapter describes the basic methodology used to develop the evidence report from topic assessment and refinement through the literature search, screening, and data abstraction process. Included are descriptions of the literature search strategies and results, literature sources, screening and grading criteria, and quality control procedures. The methods used to abstract and analyze data from Duke University Medical Center are also described.

## Topic Assessment and Refinement

A national advisory panel of technical experts was convened to work with the Duke research team. The 10-member panel was composed of obstetrician-gynecologists (ob-gyns), including subspecialists in reproductive medicine; an interventional radiologist; family practice and internal medicine physicians; a patient care representative; and representatives of the American College of Obstetricians and Gynecologists (ACOG), the study partner. In addition to ACOG, other major interest organizations represented on the panel included the American College of Physicians-American Society for Internal Medicine, American College of Radiology, American Society for Reproductive Medicine, and the National Medical Association.

Prior to their first meeting (via conference call), the panel received a document that summarized the incidence and prevalence of fibroids, described the characteristics and size of the affected population, identified the relevant practice settings and providers, assessed the burden of illness, and investigated the extent to which there is variation in practice associated with the prevention, diagnosis, treatment, and management of uterine fibroids. The panel was also presented with the nine key questions specified in the task order, as modified by the Duke research team on the basis of their preliminary assessment of the literature. The panel members suggested additional modifications. The questions subsequently accepted by all parties, and the data sources and data synthesis methods used to address them, are summarized in Table 3. The causal pathway is represented in Figure 1.

Table 3. Methodological approach to key research questions

Key questions (modifications from original questions specified in Task Order are shown in italics) All questions address the following symptoms both individually and as a group: abnormal bleeding; dysmenorrhea; noncyclic symptoms; other. | Data sources | Data synthesis method
1. What are the risks and benefits of hysterectomy and myomectomy in the treatment of symptomatic and asymptomatic fibroids? | Literature; Primary DUMC data | Evidence table; Logistic regression
2. What are the risks associated with single vs. multiple myomectomies? | Literature; Primary DUMC data | Evidence table; Logistic regression
3. Who are appropriate candidates for each procedure or treatment? | Answers to other questions | Decision model
4. What is the incidence of need for additional treatment after myomectomy or other uterus-sparing interventions? | Literature | Evidence table
5. Does additional treatment result in significantly increased morbidity? | Literature | Evidence table
6. What are the risks and benefits of nonsurgical treatment? a. No intervention b. Oral contraceptives c. Progestins d. NSAIDs e. GnRH agonists | Literature | Evidence table
7. What are the costs associated with effective surgical (abdominal myomectomy, hysteroscopic myomectomy, hysterectomy) and nonsurgical treatments? a. Oral contraceptives b. Progestins c. NSAIDs d. GnRH agonists e. Fulgeration f. Embolization g. Abdominal myomectomy h. Hysteroscopic myomectomy i. Abdominal hysterectomy j. Vaginal hysterectomy k. No intervention | Literature; HCUP; Primary DUMC data; | Evidence table; Linear regression
8. Do risks and benefits differ for women according to race, ethnicity, age, interest in future childbearing, and so forth? a. Race b. Age/menopausal status c. Pregnancy outcomes d. Fertility | Literature; Primary DUMC data; HCUP | Evidence table; Logistic regression; Decision model
9. What are the effects of surgical management of uterine fibroids, especially hysterectomy, on the aging process, specifically on: a. Ovarian function b. Prophylactic oophorectomy c. Sexual function d. Pelvic floor function | Literature | Evidence table; Decision model

Abbreviations: DUMC = Duke University Medical Center; GnRH = gonadotrophin-releasing hormone; HCUP = Healthcare Cost and Utilization Project; NSAIDs = nonsteroidal anti-inflammatory drugs

Figure 1. Causal pathway

In addition to reaching consensus on the key research questions, the advisory panel agreed on the patient population, practice settings, and target audiences of the report, as described in Chapter 1.

## Literature Search and Selection

The comprehensive review of the literature, from the identification of databases through the abstraction of individual articles into evidence tables, was a multistep, sequential process.

### Literature Sources

The primary sources of literature were six of the most widely used computerized bibliographical databases (search years shown in parentheses): MEDLINE (1975-February 2000), HealthSTAR (1975-February 2000), CINAHL (1983-February 2000), CancerLit (1983-February 2000), the Cochrane Library (Issue 3 1999), and EMBASE (1980-January 2000). Searches of these databases were supplemented by secondary searches that included e-mail subscriptions to the tables of contents of current medical journals and thorough searching of the reference lists of all included articles and review articles.

### Search Strategy

We developed the basic search strategy using the National Library of Medicine medical subject headings (MeSH) key word nomenclature developed for MEDLINE. The same strategy was used to search HealthSTAR, CINAHL, and CancerLit. A Duke University Medical Center librarian checked the strategy and assisted with its translation to the key word structure used by EMBASE.

The initial search was performed in MEDLINE (and then duplicated in the other databases) and was limited to articles in English and with human subjects. It employed a previously validated (Dickersin, Scherer, and Lefebvre, 1994) search strategy that identifies three subsets: (a) high specificity for randomized controlled trials (RCTs), using terms such as "randomized"; (b) moderate specificity, using terms such as "blinding"; and (c) low specificity, using terms such as "followup studies." The overwhelming majority of RCTs identified by this initial search examined the use of gonadotropin-releasing hormone (GnRH) agonists, frequently as adjunctive treatment prior to surgery. The remainder of the citations identified were either uncontrolled case series, case series with historical or nonrandomized controls, or, in a few instances, prospective cohort studies. A subsequent search (performed initially in EMBASE and then duplicated in MEDLINE and the other databases) was targeted to surgical interventions and included other, less robust, study designs. Finally, because few of the targeted articles on hysterectomy and fibroids provided data relevant to Question 9 (on the effects of hysterectomy on the aging process), we performed a supplemental search on hysterectomy without limiting studies to those including patients with fibroids.

The basic search strategy, the surgery search strategy, and the hysterectomy search strategy are reproduced in Tables 4-6.

Table 4. Basic fibroids search strategy

1 | leiomyoma/
2 | fibroid$.tw.
3 | (uter$ and leiomyoma$).tw.
4 | exp hysterectomy/
5 | hysterectomy, vaginal/
6 | surgical procedures, laparoscopic/
7 | hysterectom$.tw.
8 | myomectom$.tw.
9 | or/4-8
10 | co.fs.
11 | dt.fs.
12 | th.fs.
13 | su.fs.
14 | or/10-13
15 | or/1-3
16 | 14 and 15
17 | 9 and 15
18 | 16 or 17
19 | limit 18 to human
20 | limit 19 to female
21 | limit 20 to English language
22 | limit 21 to yr = 1975-2000
23 | 13 and 15
24 | 17 or 23
25 | limit 24 to human
26 | limit 25 to female
27 | limit 26 to English language
28 | limit 27 to yr = 1975-2000
29 | 15 and 11
30 | limit 29 to human
31 | limit 30 to female
32 | limit 31 to English language
33 | limit 32 to yr = 1975-2000
34 | 28 or 33
35 | 15 and 12
36 | limit 35 to human
37 | limit 36 to female
38 | limit 37 to English language
39 | limit 38 to yr = 1975-2000
40 | 15 and 10
41 | limit 40 to human
42 | limit 41 to female
43 | limit 42 to English language
44 | limit 43 to yr = 1975-2000
45 | 44 or 39 or 33 or 28
46 | 45 or 22
47 | randomized controlled trials/
48 | random allocation/
49 | double-blind method/4
50 | single-blind method/
51 | randomized controlled trial.pt.
52 | 47 or 48 or 49 or 50 or 51
53 | animal/
54 | human/
55 | 53 and 54
56 | 53 not 55
57 | 52 not 56
58 | clinical trial.pt.
59 | exp clinical trials/
60 | (clin$ adj trial$).tw.
61 | ((singl$ or doubl$ or trebl$ or tripl$) adj (blind$ or mask$)).tw.
62 | Placebos/
63 | placebo$.tw.
64 | random$.tw.
65 | research design/
66 | or/58-65
67 | 66 not 56
68 | comparative-study/
69 | exp evaluation studies/
70 | follow-up studies/
71 | prospective studies/
72 | (control$ or prospectiv$ or volunteer$).tw.
73 | or/68-72
74 | 73 not 56
75 | 67 not 57
76 | 74 not (67 or 57)
77 | 28 and 57
78 | 28 and 75
79 | 28 and 76
80 | or/77-79
81 | 33 and 57
82 | 33 and 75
83 | 33 and 76
84 | or/81-83
85 | 39 and 57
86 | 39 and 75
87 | 39 and 76
88 | or/85-87
89 | 44 and 57
90 | 44 and 75
91 | 44 and 76
92 | or/89-91
93 | from 92 keep 10

Table 5. Fibroids surgery search strategy

1 | *uterine neoplasms/su
2 | *uterine neoplasms/
3 | *leiomyoma/su
4 | *leiomyoma/
5 | 1 and 4
6 | 2 and 3
7 | 5 or 6
8 | uterine fibroid$1.tw.
9 | exp *hysterectomy/
10 | myomectom$.tw.
11 | 9 or 10
12 | 8 and 11
13 | 2 and 4
14 | 13 and 11
15 | 7 or 12 or 14
16 | limit 15 to (human and English language and yr = 1975-2000)
17 | limit 16 to (clinical trial or clinical trial, phase i or clinical trial, phase ii or clinical trial, phase iii or clinical trial, phase iv or controlled clinical trial or meta analysis or multicenter study or review or review literature or review of reported cases or review, academic or review, multicase)
18 | cohort.tw.
19 | (prospective or retrospective).tw.
20 | case series.tw.
21 | exp cohort studies/
22 | 18 or 19 or 20 or 21
23 | 16 and 22
24 | 17 or 23
25 | from 24 keep 1-166
26 | from 25 keep 10

Table 6. Hysterectomy search strategy

1 | exp hysterectomy/
2 | "myomectomy".mp.
3 | hysterectom$.tw.
4 | myomectom$.tw.
5 | exp hysterectomy, vaginal/
6 | "uterine artery embolization".mp.
7 | or/1-6
8 | exp ovary/
9 | exp Ovariectomy/
10 | Menopause/or Menopause, premature/
11 | or/8-10
12 | 8 or 9
13 | 10 and 12
14 | 7 and 13
15 | 7 and 11
16 | limit 15 to human
17 | limit 15 to English
18 | limit 16 to English
19 | limit 18 to female
20 | limit 19 to yr = 1975-2000
21 | limit 14 to human
22 | limit 21 to English
23 | limit 22 to female
24 | limit 23 to yr = 1975-2000
25 | 9 and 10
26 | and 7
27 | limit 26 to human
28 | limit 27 to English
29 | limit 28 to female
30 | limit 29 to yr = 1975-2000
31 | 7 and 10
32 | limit 31 to human
33 | limit 32 to female
34 | limit 33 to English
35 | limit 34 to yr = 1975-2000
36 | randomized controlled trials/
37 | random allocation/
38 | double-blind method/
39 | Single-blind method/
40 | randomized controlled trial.pt.
41 | or/36-40
42 | exp Cohort studies/
43 | cohort.tw.
44 | (prospective or retrospective).tw.
45 | exp Clinical trials/
46 | cross-sectional studies/
47 | prospective studies/
48 | Follow-up studies/
49 | "comparative study"/
50 | case series.tw.
51 | or/42-50
52 | 41 or 51
53 | 20 and 52
54 | 23 and 52
55 | 24 and 52
56 | 30 and 52
57 | 35 and 52
58 | exp sex disorders/
59 | exp sex behavior/
60 | 58 or 59
61 | and 7
62 | and 52
63 | exp Urination disorders/
64 | exp Colonic diseases/
65 | exp Fecal incontinence/
66 | exp Uterine prolapse/
67 | "VAGINAL PROLAPSE".mp.
68 | exp Pelvic floor/
69 | 63 and 7
70 | and 52
71 | limit 70 to human
72 | limit 71 to English language
73 | limit 72 to female
74 | limit 73 to yr = 1975-2000
75 | 64 and 65
76 | 64 or 65
77 | and 7
78 | and 52
79 | limit 78 to human
80 | limit 79 to English language
81 | limit 80 to female
82 | limit 81 to yr = 1975-2000
83 | or/67-69
84 | or/66-68
85 | and 7
86 | and 52
87 | limit 86 to human
88 | limit 87 to English language
89 | limit 88 to female
90 | limit 89 to yr = 1975-2000

### Screening Criteria

#### Interventions Assessed

We reviewed studies of the following treatments for symptomatic fibroids:

- No intervention ("watchful waiting")
- Medical therapies -- Nonsteroidal anti-inflammatory drugs (NSAIDs) -- Oral contraceptive pills (OCPs) -- Progestational agents -- Other oral agents -- GnRH agonists (both as primary therapy and as adjunct therapy to myomectomy or hysterectomy)
- Invasive therapies -- Uterine artery embolization -- Coagulation using cautery or laser -- Myomectomy -- Hysterectomy

In addition, we reviewed the available evidence on the following strategies for managing asymptomatic fibroids:

- No intervention
- Prophylactic myomectomy
- Prophylactic hysterectomy

#### Other Inclusion and Exclusion Criteria

We developed further inclusion and exclusion criteria so that the yield of articles would be appropriately focused. Empirical study designs considered included controlled trials, prospective trials with historical controls, prospective or retrospective cohort studies, and medium to large case series (n > 20). Studies of these types and review articles were included if they met the following criteria:

- Included women with uterine fibroids.
- Provided data relevant to one or more of the key questions identified in Chapter 1.
- Reported health outcomes, health services utilization outcomes, or economic outcomes related to the management of uterine fibroids.

Exclusion criteria were as follows:

- Article was not original research or relevant review.
- Patient population did not include women with uterine fibroids.
- Study design was a single case report.
- Study design was a small case series with fewer than 20 subjects.

For studies addressing the effects of hysterectomy on aging (Question 9), we expanded the inclusion criteria to include studies of all hysterectomies for benign disease, even if the patient population did not include women with fibroids or results were not reported separately for patients with fibroids.

### Screening Results

The main searches (the basic search and the surgery search) yielded 1,084 English-language articles. The abstracts of these articles were reviewed against the inclusion/exclusion criteria by five physician investigators. A team of two physicians reviewed each abstract. Abstracts were available for more than three-fourths of the citations; however, when no abstract was available, the title, source, and MeSH words were reviewed. At this stage, articles were included if requested by one member of the review team.

Each abstract in the first set to be reviewed (n = 309) was reviewed by four physicians, and a kappa statistic was calculated to determine the strength of the agreement to include or exclude articles and the reason for exclusion. As seen in Table 7, the results showed strong agreement between reviewers, representing consistency in applying the inclusion and exclusion criteria. These kappa values are the highest first-round results observed by the Duke EPC in our experience performing systematic reviews.

Table 7. Results of kappa test

| Reviewer 1 | Reviewer 2 | Reviewer 3 | Reviewer 4
Reviewer 1 | n/a | 0.597 | 0.579 | 0.641
Reviewer 2 | 0.567 | n/a | 0.621 | 0.530
Reviewer 3 | 0.639 | 0.601 | n/a | 0.542
Reviewer 4 | 0.647 | 0.616 | 0.604 | n/a

Notes: (1) The upper right numbers show kappa statistics based on dichotomizing the ratings to "include" versus "exclude." (2) The lower left numbers show kappa statistics based on multilevel ratings (1 through 8), representing the inclusion and exclusion criteria.

At the full-text screening stage, each article was independently reviewed by two physicians, who forwarded their decisions to the task order manager for recording and comparison. When necessary, the reviewers were asked to reconcile differences of opinion. Overall, the teams initially disagreed on about 20-25 percent of their decisions, but all disagreements were resolved.

The articles identified by the supplemental hysterectomy search were reviewed by a single reviewer with a special interest in gynecological surgery and the aging process. Eighty-eight of these articles were included in the discussion of Question 9; these articles were added to the project database.

The task order manager coded the records in the bibliographical database at each screening stage. Results are summarized in Tables 8 and 9.

Table 8. Number of records identified in main literature searches, by database

Database | Number of records | Percent of total
MEDLINE | 539 | 49.7
EMBASE | 491 | 45.3
CancerLit | 20 | 1.8
Cochrane | 1 | <1
PreMEDLINE | 3 | <1
HealthSTAR | 2 | <1
Other | 28 | 2.6
Total | 1,084 | 100

Table 9. Results of abstract screening and full-text article reviews

Description | No. | Percent
Abstracts
Number of abstracts reviewed (note: some records did not contain abstracts) | 1,084 | --
Number of relevant articles included: | 637 | 58.8
1-Original research on treatment (for abstraction into evidence tables) | 325 | 51.0
2-Review articles on treatment | 141 | 22.1
3-Other (epidemiology, health services utilization) | 76 | 11.9
4-Basic science | 95 | 14.9
Number excluded: | 447 | 41.2
Reasons for exclusion:
1-Not original research | 37 | 8.3
2-Not uterine fibroids | 38 | 8.5
3-Case report | 138 | 30.9
4-Small case series (n < 20) | 50 | 11.2
5-Background | 184 | 41.1
Full-Text Articles
Number of full-text articles reviewed | 637 | --
Number of relevant articles: | 550 | 86.3
1-Original research on treatment (for abstraction into evidence tables) | 200 | 36.4
2-Review articles on treatment | 144 | 26.2
3-Other (epidemiology, health services utilization) | 95 | 17.3
4-Basic science | 102 | 18.5
5-Other (no separate fibroids results) | 9 | 1.6
Number excluded: | 87 | 13.7
Reasons for exclusion:
1-Not original research | 22 | 25.3
2-Not uterine fibroids | 14 | 16.1
3-Case report | 7 | 8.0
4-Small case series (n < 20) | 40 | 46.0
5-Other (e.g., unobtainable, not English) | 4 | 4.6

We also performed a review of Issue 3 of the 1999 Cochrane Database of Systematic Reviews. Fifteen citations for "fibroids" were found, three for "myomectomy," and 28 for "hysterectomy." However, only one review specifically addressed hysterectomy or myomectomy for fibroids, and the focus of this review was on preoperative treatment with GnRH agonists (Lethaby, Vollenhoven, and Sowter, 1999). Nineteen trials identified in this review met our inclusion criteria, and all 19 were identified in our online database searches. Two other Cochrane reviews focused on adjunctive treatments to prevent adhesions at the time of infertility surgery (including myomectomy). Although there were four Cochrane reviews of trials of medical therapies for heavy menstrual bleeding, all but one of the included trials explicitly excluded women with fibroids; this trial was identified in our online database search.

During the peer review process, additional articles were suggested by many of the reviewers. All suggested articles went through the same screening process as the original articles and were added to the evidence tables if they met our criteria. Several reviewers also pointed out case reports of particularly severe complications of certain procedures that were excluded by our screening criteria. In reviews of surgical procedures, excluding case reports or small case series clearly leads to omission of these reports. However, for the purposes of this review, we are more concerned with the question "How likely is something to happen?" than the question "Can something happen?" since almost any conceivable complication can occur with any procedure. In addition, it is likely that there is a bias toward both reporting small numbers of complications of newer procedures and publishing those results, since similar complications of more established procedures might be deemed less "reportable." Therefore, we have mentioned case reports of complications where more than one reviewer felt that discussion of these complications was important, but we did not revise our search and screening criteria or systematically review all case reports and small case series that had been previously excluded.

## Data Abstraction

Teams of two physicians performed the data abstraction for articles identified through the main searches (the basic search and the surgery search). Data abstraction forms were developed prior to initiation of the formal abstraction process. Draft forms were reviewed by each abstractor and by a nonclinician abstractor/editor for clarity and completeness. Subsequent versions were pretested by abstracting an article and entering data into the evidence table format. For each included article, one physician completed the data abstraction form, while the other served as over-reader. The physician responsible for the primary abstraction also entered data on relevant outcomes and results into a Microsoft Word document; this document duplicated some of the data on the abstracting form but also had preformatted areas for information on specific quality criteria (see discussion below). The information from the data abstraction form and the corresponding outcomes and results data was then merged into the evidence table format. The data abstraction assignments were made based on the physicians' clinical interests, for example, medicine versus surgery. Again, articles identified through the supplementary hysterectomy search were not subject to the same level of review: a single reviewer was responsible for screening the articles and assessing their relevance. Because these articles did not explicitly focus on women with fibroids, they were not abstracted into the evidence tables.

The focus of the data abstraction was on outcomes that were clinically relevant and relevant to the key questions. We included anatomical outcomes, such as changes in uterine or fibroid size with treatment. However, studies that reported only such outcomes, without reporting additional clinically important outcomes (such as changes in symptoms), were not considered relevant. Although there is clearly a correlation between size and some symptoms (pelvic pressure, urinary frequency), there may not be as strong a correlation with other symptoms, such as bleeding. Because we were primarily interested in clinical outcomes, and because we could not identify any data that allowed inferences about symptomatic relief based on changes in uterine or fibroid size, we did not include such studies after consultation with the advisory panel.

Outcomes recorded, depending on the study, included:

- Anatomical/physiological outcomes: Change in uterine size; change in fibroid size; change in hemoglobin or hematocrit.
- Symptomatic outcomes: Change in symptoms of bleeding, cyclic pain, or noncyclic pain.
- Pregnancy-related outcomes: Pregnancy rates, live-birth rates, pregnancy complications.
- Quality-of-life measures: Changes in quality-of-life scales.
- Adverse outcomes: Side effects of treatment, complications of treatment, development of new symptoms.
- Need for additional treatment: Recurrence after uterus-conserving therapy, need for surgery (including hysterectomy).
- Resource utilization: Length of stay, medical costs, time lost from work or usual activities.

## Quality Scoring

Given the paucity of randomized trials, especially surgical trials, we took an approach similar to that used in previous evidence reports in which the majority of the evidence was not of the highest quality according to commonly used grading systems, such as that used by the U.S. Preventive Services Task Force (Woolf, DiGuiseppi, Atkins, et al., 1996). Dismissing the lower quality literature entirely would severely limit the investigators' ability to make any inferences at all; in fact, some nonrandomized study designs, such as large cohort studies or retrospective reviews of administrative data, may be better suited to certain questions, such as those concerning disease incidence or resource utilization. However, the quality of these studies clearly varies widely. Therefore, each study was evaluated for factors affecting internal and external validity. The grading criteria used, along with the rationale for their inclusion and their operational definitions, are described below. These criteria were developed based on our previous experience with producing evidence reports, a review of the literature on systematic reviews, and consultation with the advisory panel. For each treatment study described in the evidence tables, the presence or absence of each of these criteria is noted.

### Internal Validity

The criteria for assessing internal validity were as follows:

Randomized allocation to treatment:

- Rationale: By randomly assigning groups to the intervention of interest, other factors that may confound the results are equally distributed between groups (assuming a large enough sample size). This equal distribution minimizes the chances of over- or underestimation of treatment effect based on unequal distribution of confounding factors.
- Operational definition: Criterion met if (and only if) the trial report explicitly stated that treatment was randomly allocated.

If randomized, appropriate randomization methods used:

- Rationale: "Pseudo-randomization" methods may be susceptible to bias, as demonstrated by evidence of unequal distribution of subject characteristics (Schulz, Chalmers, Grimes, et al., 1994) and larger effect sizes compared with studies using more rigorous methods (Schulz, Chalmers, Hayes, et al., 1995). In addition, methods of allocation concealment are also important in preventing bias (e.g., use of preprepared sealed envelopes).
- Operational definition: Criterion met if randomization methods were not susceptible to bias, such as computer-generated numbers in sealed envelopes. Criterion not met by studies that either used methods more prone to bias, such as alternate medical record numbers, or did not describe randomization methods or methods of allocation concealment.

Adequate description of patients and controls:

- Rationale: Patient characteristics that might affect outcomes (such as obesity, prior surgery, medical comorbidities) are likely to differ between two interventions. If these differences are not characterized, then erroneous conclusions may be drawn. For example, comparison of outcomes from a series of laparoscopic appendectomies with those from concurrent open appendectomies found better outcomes with the laparoscopic procedure (Sosa, Sleeman, McKenney, et al., 1993). These differences were not seen when the same group performed a randomized trial, a finding attributable to differential patient selection criteria in the nonrandomized study (Martin, Puente, Sosa, et al., 1995).
- Operational definition: Criterion met if (a) inclusion and exclusion criteria for participation in the study were described or (b) for nonrandomized studies, description of the rationale for selecting a particular intervention was given. Criterion not met if (a) inclusion/exclusion criteria were not described or (b) description of the rationale for selection of the interventions was not given (e.g., a nonrandomized comparison of concurrent laparoscopic and abdominal myomectomies that did not describe why patients received one or the other procedure).

Description of length of followup:

- Rationale: Patient and provider decision-making is dependent on knowledge of the likelihood of benefits and risks over time.
- Operational definition: Criterion met if a summary statistic (mean, median, or minimum) and range of followup were given for studies reporting nonhospital outcomes. Criterion not met if summary statistic and range not given. Criterion not applicable for studies reporting only hospital-based outcomes.

Description of loss to followup:

- Rationale: Failing to account for patients lost to followup may lead to erroneous conclusions, especially if the loss to followup is related to either the underlying disease or the intervention (e.g., patients seeking care elsewhere because of continuing symptoms or unacceptable side effects of treatment).
- Operational definition: Criterion met if (a) loss to followup was explicitly reported, (b) number of subjects for whom data was presented was equal to number of subjects receiving intervention at start of study, or (c) for studies reporting only hospital-based outcomes, number of missing charts or records was reported. Criterion not met if loss to followup was not reported and number of subjects at beginning and end of study was not equal.

Description of dropout rates:

- Rationale: Dropout rates may reflect differences in clinically important variables, such as side effects or treatment response. Failure to account for dropouts may result in erroneous conclusions similar to those seen with failure to account for loss to followup.
- Operational definition: Criterion met if (a) patients dropping out of the study prior to completion were reported or (b) number of subjects at beginning and end of study were equal. Criterion not met if patients dropping out were not reported and numbers of subjects at beginning and end of study were not equal. Criterion not applicable for studies reporting only hospital-based outcomes.

Recognition and description of statistical issues:

- Rationale: Use of inappropriate tests may lead to misleading conclusions. For example, variables such as blood loss, length of stay, or costs are often not normally distributed; use of means instead of medians when data may be affected by outlying observations can be misleading. Many studies, especially case series, may lack sufficient power to detect clinically important differences in outcomes or patient characteristics.
- Operational definition: Criterion met if (a) appropriate statistical tests were used (e.g., nonparametric methods for variables with nonnormal distributions, or survival analysis techniques to account for loss to followup and dropouts) and (b) potential study limitations regarding design and analysis, especially sample size and power issues, were discussed. Criterion not met if (a) inappropriate statistical tests were used or (b) study limitations were not discussed.

### External Validity

The criteria for assessing external validity were as follows:

Description of age of study population:

- Rationale: The outcomes of many interventions are affected by patient age. Age is especially important in studies of reproductive disorders in women, since childbearing potential and ovarian hormone production, both key components in decisionmaking regarding management of fibroids, are directly related to age.
- Operational definition: Criterion met if summary statistics of subject age were given. Criterion not met if summary statistics were not given.

Description of racial/ethnic distribution of population:

- Rationale: The epidemiology, and possibly the biology, of fibroids clearly varies between white and black women. Additionally, there is widespread racial variation in the United States in utilization and outcomes of a wide variety of interventions (Fiscella, Franks, Gold, et al., 2000).
- Operational definition: Criterion met if (a) racial/ethnic distribution was described or (b) the geographical setting of the study strongly implied the racial/ethnic background of the entire population (e.g., studies of hysterectomy outcomes in Japan or Nigeria). Criterion not met if (a) racial/ethnic distribution was not described and (b) geographic setting was likely to include subjects of diverse racial/ethnic background.

Description of pregnancy history of population:

- Rationale: Pregnancy history may affect the natural history or biology of fibroids (Parazzini, Negri, La Vecchia, et al., 1996). For surgical interventions, pregnancy history may affect the technical difficulty of a procedure; for example, prior vaginal delivery may facilitate vaginal hysterectomy, while prior cesarean section, by increasing the risk of adhesions, may make either abdominal or vaginal hysterectomy more difficult.
- Operational definition: Criterion met if (a) summary statistics on gravidity or parity were given or (b) percentage of women with prior pregnancy was given. Criterion not met if (a) no summary statistics were given and (b) no distribution data on prior pregnancies were given.

Description of prior surgery:

- Rationale: A history of prior surgery for fibroids might reflect differences in the natural history or biology between patients. Additionally, previous abdominal surgery might increase the risk of complications by increasing the likelihood of intraperitoneal adhesions.
- Operational definition: Criterion met if (a) any description of history of intra-abdominal surgery was given or (b) proportion of women with prior surgery for fibroids was given. Criterion not met if no description of prior surgery was given.

Adequate characterization of fibroid and/or uterine size:

- Rationale: Individual fibroid size, or aggregate uterine size, may affect the nature or severity of symptoms, the response to various treatments, and the risk of complications of surgical treatments.
- Operational definition: Criterion met if data given on (a) uterine size in weeks gestational age; (b) uterine volume, area, or length as estimated by radiologic techniques; (c) uterine weight in grams (for hysterectomy specimens); (d) fibroid diameter or volume as estimated by radiologic techniques; or (e) fibroid dimensions or weight based on pathological examinations. Criterion not met if none of the above were provided.

Adequate characterization of fibroid number:

- Rationale: The number of fibroids may affect the nature or severity of symptoms, the response to various treatments, and the risk of complications of surgical treatments.
- Operational definition: Criterion met if summary statistics or distribution of number of fibroids was provided. Criterion not met if no data were provided on number of fibroids.

Adequate characterization of fibroid location:

- Rationale: The location of fibroids may affect the nature or severity of symptoms, the response to various treatments, and the risk of complications of surgical treatments.
- Operational definition: Criterion met if (a) distribution of fibroids by location (subserosal, intramural, submucosal, or pedunculated) was given or (b) other anatomical descriptions were given (e.g., anterior, posterior, fundal, or within the broad ligament). Criterion not met if no anatomical description was given.

Adequate characterization of baseline symptoms:

- Rationale: Because fibroids may present with a variety of symptoms, assessing the effectiveness of therapy requires an adequate description of the nature and severity of symptoms prior to institution of therapy.
- Operational definition: Criterion met if distribution of specific symptoms or symptom classes associated with fibroids were provided. Criterion not met if specific symptoms were not described (e.g., if the only description of inclusion criteria was "symptomatic fibroids").

Adequate description of timing of outcome measurement:

- Rationale: Outcome measures may vary depending on when they are obtained. Description of when outcomes were measured facilitates comparison between studies.
- Operational definition: Criterion met if (a) time after initiation of therapy at which outcomes were measured was reported or (b) study was limited to hospital-based outcomes. Criterion is not met if (a) time was not reported and (b) study was not strictly hospital-based.

Adequate description of methods used for outcome measurement:

- Rationale: Comparison between studies requires common methods of measurement, which in turn requires adequate description of the methods used to assess comparability.
- Operational definition: Criterion met if (a) methods used to measure outcomes were adequately described or referenced (e.g., pain or bleeding scales), (b) definitions were given (e.g., description of outcomes classified as "complications"), or (c) outcomes were unambiguous (e.g., pregnancy, need for hysterectomy). Criterion not met if (a), (b), or (c) was not present.

Adequate description of validity and reliability of outcome measurement:

- Rationale: Measurements of outcomes are only useful if changes in the outcome being measured are reflected in changes in the measurement (validity) and if these changes are reasonably consistent between the same observer measuring at different times or between different observers (reliability). For example, changes in a scale to assess menstrual blood flow should correlate with some other physiological measure of menstrual blood loss, and this correlation should be consistent when different women apply the same scale.
- Operational definition: Criterion met if (a) a description of the methods used to assess validity and reliability of at least one outcome measure was provided, (b) a reference to another article documenting validity and reliability was provided, or (c) only unambiguous outcomes such as pregnancy were included. Criterion not met if (a), (b), or (c) was not present.

Adequate description of clinical care provided to subjects:

- Rationale: The ability to replicate study results is dependent on adequate description of methods. Additionally, readers should be aware of aspects of clinical care that might influence outcomes.
- Operational definition: Criterion met if (a) a detailed description of the therapy (dose, dosing schedule, and route of administration for medications and/or techniques for invasive therapies) was provided; (b) a reference to another publication describing the procedure was provided; or (c) statistical adjustment was made for likely sources of variation in clinical care (e.g., site where care was given, type of specialist providing care, individual provider). Criterion not met if (a), (b), or (c) was not provided.

Use of previously validated and standardized measures:

- Rationale: Use of measures used by other researchers enhances the ability to compare results across studies. Use of measures used with other medical conditions enhances the ability to compare the impact of uterine fibroids to that of other common conditions, which may be important when setting research and resource allocation priorities.
- Operational definition: Criterion met if at least one measure previously used by another group was used. Criterion not met if all measures were internally developed.

### Reporting of Quality Scores

These criteria were not aggregated into an overall quality score but were considered and reported individually. This approach was preferred for several reasons:

- Previous work has shown that numeric grading systems may not discriminate well between high- and low-quality studies, even randomized trials (Juni, Witschi, Bloch, et al., 1999; Moher, Jadad, and Tugwell, 1996).
- Development and use of a new quality score would require additional work for validation.
- Identification of specific weaknesses in each study will be helpful in identifying trends, which in turn will assist with recommendations for future research.

Our approach of describing key study design components, rather than assigning a single aggregate score, is also consistent with recent recommendations from an expert panel on meta-analysis of observational studies (Stroup, Berlin, Morton, et al., 2000).

Summaries of each evaluation are provided in the evidence table entry for each abstracted article. A "+" indicates that a given criterion was met, a "−" denotes that the criterion was not met. Grades were assigned by the primary reviewer and confirmed by the over-reader.

## Quality Control Procedures

We employed quality-monitoring checks at every phase of the literature search, review, and data abstraction process to reduce bias, enhance consistency, and check accuracy:

- Review of the literature search strategy by medical librarian.
- Review of literature search strategies by advisory panel of technical experts.
- Review for completeness of the literature search results through reference list checks by the article reviewers.
- Use of Kappa statistics to demonstrate strength of agreement among and between reviewers.
- Reconciliation of all differences of opinion by reviewers on all full-text articles.
- Agreement of two reviewers for all eligible studies.
- Data abstractions completed by two physician-investigators, a primary abstractor, and an over-reader.
- Solicitation of advice at key decision points from the advisory panel of technical experts.
- Extensive peer review by a 21-member panel representing clinicians (including ob/gyns, internists, family practitioners, and interventional radiologists), epidemiologists, patient representatives, and the Agency for Healthcare Research and Quality (AHRQ).

## Supplemental Data Sources

Our preliminary review of the literature indicated that published studies would not provide the evidence needed to address many of the key questions. Therefore, we used two additional data sources: administrative data from the Nationwide Inpatient Sample (NIS) of AHRQ's Healthcare Cost and Utilization Project (HCUP) and administrative and clinical data from Duke University Medical Center records.

### Nationwide Inpatient Sample

The NIS contains administrative discharge data from more than 1000 hospitals in 22 States, representing a stratified sample of 20 percent of U.S. hospitals (NIS, 1997). Weights are provided to permit estimation of national data based on this sample. We used this data set to provide supplemental data on frequency and resource utilization for hysterectomy and myomectomy by age and race (Question 7 on cost and Question 8 on age and racial variation). Because previous work has shown that administrative data may lack sufficient clinical detail to compare outcomes (Myers and Steege, 1999), we did not attempt to directly compare complication rates between these procedures (Question 1).

Hysterectomies for fibroids were identified by searching the 1997 NIS data set for all patients with International Classification of Diseases, Revision 9 (ICD-9) procedure codes of 68.3, 68.4, and 68.5 (all nonradical hysterectomies) who also had diagnosis codes of 218.0, 218.1, 218.2, and 218.9 (submucous, intramural, subserous, and unspecified fibroids).

Myomectomies were identified by searching the 1997 NIS data set for all patients with ICD-9 procedure codes of 68.29 (uterine lesion destruction) who also had diagnosis codes of 218.0, 218.1, 218.2, and 218.9. We used these codes to identify myomectomies at Duke after discussion with hospital coders; only three nonmyomectomy cases were identified using this strategy. Further validation of this coding strategy, especially trying to estimate the proportion of myomectomies not identified, would be useful for future health services research.

Data from the sampled hospitals were converted to national estimates using the weighting variables provided by AHRQ. To assess differences in the proportion of white and black women undergoing each procedure, logistic regression was performed using myomectomy versus hysterectomy as the dependent variable, race as the main independent variable, and controlling for age, payer type, and median income.

### Duke University Medical Center Data

Data on hospital costs and clinical characteristics affecting cost and complications of patients undergoing myomectomy were obtained from Duke University Medical Center. Subsequent analyses will include additional chart data on patients undergoing hysterectomy for fibroids. This data source was used to provide additional information for Question 1 (risks and benefits of hysterectomy and myomectomy), Question 7 (costs of interventions), and Question 8 (racial differences in outcomes).

#### Identification of Records

Records for patients undergoing abdominal myomectomy at Duke University Medical Center between July 1, 1993, and June 30, 1998, were identified using the hospital's cost-accounting system. The starting date was chosen because it represented the implementation of an accounting system that is based on estimates of resource utilization including personnel, cost of supplies, and fixed costs, which we felt would be more reliable in estimating costs than more conventional billing data using hospital charges. Appropriate ICD-9 codes were determined after consultation with medical records personnel experienced in coding; codes 68.29 and 69.19 were used.

Duke serves both as a tertiary care center and as the primary hospital for much of the surrounding community, including all university employees. The patient population is therefore economically and ethnically diverse. Because there are no consensus guidelines or local "clinical pathways" for managing symptomatic fibroids, strategies for management of fibroids may vary between physicians. Physicians performing surgery for uterine fibroids represent full-time academic faculty, clinical faculty, and community faculty whose primary outpatient activities take place away from the main medical center campus. Although data from any teaching hospital may not be generalizable to all settings, the Duke patient and physician populations are reasonably reflective of the surrounding community.

#### Collection of Data

Data on each patient's age, race, length of stay, insurance status, ZIP code, attending physician, and hospital costs were available from the abstracted discharge data. After identification of appropriate records, charts were reviewed by trained abstractors to collect information on the following:

- Patient clinical characteristics: -- Preoperative uterine size. -- Number of fibroids removed. -- Location of fibroids. -- Prior abdominal surgery. -- Presence of adhesions at surgery. -- Pregnancy history. -- Medical comorbidity. -- Body mass index. -- Presenting symptoms. -- Preoperative hematocrit.
- Outcomes data: -- Estimated blood loss. -- Need for transfusion. -- Complications. -- Need for readmission or reoperation within 6 weeks of original procedure (excluding patients on research protocols requiring second-look laparoscopy).

#### Analysis of Data

The relationship between patient characteristics and outcomes was explored using bivariate analysis. Multivariate analysis was used to determine the effects of multiple patient characteristics on outcomes using linear regression for continuous outcomes (length of stay and costs) and logistic regression for dichotomous outcomes (transfusions and complications).

## Data Synthesis

During the initial planning phase for this report, three principal methods of data synthesis were considered:

- Formal meta-analysis based on results of the data abstraction process as shown in the evidence tables.
- Formal decision analysis using results from the evidence tables, along with supplemental data from the NIS and Duke.
- Use of the evidence tables to summarize results from studies relevant to individual questions.

### Meta-analysis

#### Randomized Trials

Based on our initial overview of the literature, we determined that the number of randomized trials relevant to the key questions was so limited that formal meta-analysis based on clinical trials would not be possible for most questions. The one exception to this was the use of GnRH agonists as adjunctive therapy prior to surgical therapy; however, a meta-analysis had recently been performed and reported by the Cochrane Collaboration (Lethaby, Vollenhoven, and Sowter, 1999), and insufficient additional data were available to justify another meta-analysis.

#### Nonrandomized Studies

Although meta-analysis of nonrandomized observational studies is possible, such analyses may be even more controversial than meta-analyses of randomized trials (Stroup, Berlin, Morton, et al., 2000). Given the methodological deficiencies of the majority of the studies we reviewed, meta-analysis of even relatively limited questions (for example, recurrence rates after uterus-conserving therapy) was not possible.

### Decision Analysis

Decision-analytic models can be a useful means of synthesizing information from a variety of sources, and they have been used by the Duke group in studies of stroke (Matchar, Samsa, Matthews, et al., 1997) and cervical cytology (McCrory, Matchar, Bastian, et al., 1998). We had planned on using a decision model to synthesize the disparate data on fibroid management to help answer the key questions or at least to identify key areas of uncertainty to direct future research. We were able to use decision modeling for some purposes (e.g., estimating cumulative incidence of fibroids based on reported age-specific rates). However, the methodological limitations of the available literature precluded us from using decision analysis as a formal synthesis tool. In particular, heterogeneity of methods for measuring and reporting patient outcomes and for reporting clinically important preintervention patient characteristics limited our ability to perform even preliminary decision analyses.

Developing a decision model in parallel with our literature review did enable us to consider the nature of the data and the potentially important parameters that would be needed to use such a model to assist patients, clinicians, or policymakers. Therefore, we have provided a detailed description of the framework for such a model, along with some potential examples of its use, in Chapter 4.

### Evidence Tables

The evidence tables summarize each study meeting the inclusion criteria described above; as such, they represent studies reporting on outcomes of prophylactic or symptomatic treatments for fibroids. Articles cited in the text but not in the evidence tables include (1) review articles; (2) articles addressing background issues such as basic biology, epidemiology, or health services research; and (3) articles either describing methods or illustrating relevant methodological issues.

Many of the studies included in the review of the effects of hysterectomy on the aging process (Question 9) also were not abstracted in evidence tables. Because our initial searches focused on patients with fibroids, many of the articles discussed under Question 9 did not meet our original inclusion criteria. Late in the review process, after it became apparent that the vast majority of studies addressing this question would be excluded, we revisited the question and performed a revised search. Because a large proportion of women, especially premenopausal women, who undergo hysterectomy do so because of symptomatic fibroids, we assumed that these articles would have some validity for women with fibroids. As mentioned above, the review of these articles did not follow the same strict methodology used in the review of articles from the basic search and the surgery search. For that reason, and because they did not explicitly focus on women with fibroids, these articles were not abstracted into the evidence tables.

Because formal data synthesis techniques were not applicable to the majority of the literature on management of fibroids, we elected to summarize the results of our review without attempting quantification. We did attempt to identify qualitatively similar findings that could be suggestive of consistent results. We also tried to identify the characteristics of data that would be needed to address the question adequately and, in some cases, to identify conceptual issues that should be considered by patients and providers given the lack of data (issues surrounding prophylactic surgery for asymptomatic fibroids, for example).