# Evidence Tables

Evidence Table 1 Summary of Rejected Studies

Number of Rejected Studies | Reason for Rejection*
253 | Risk factors not reported**
131 | Cancer population***
128 | Animal or in vitro studies
101 | No outcome of interest
55 | Screening population
55 | Reviews, meta-analyses, letters, case reports, editorials, commentaries
39 | Suspicious findings not reported
11 | Outcomes not extractable
10 | Less than 10 patients total sample size
7 | Languages other than English
7 | Risk factor outcomes not extractable
7 | Indication for sentinel node biopsy not reported
6 | Unpublished study reports, abstracts
5 | LCIS/AH: Management options not reported
3 | DCIS
2 | Results of biopsy not reported
1 | Male gender
821 | TOTAL

*Based on protocol-defined inclusion/exclusion criteria.

** Applies only to questions 1 and 3

*** Applies only to questions 1, 2, and 3

Evidence Table 2 Study Level Characteristics

| | Total* | | Questions I & III | | Question II | | Question IV | | Question V
| | k | n | k | n | k | n | k | n | k | n
Location:
North America | | 69 | 28,698 | 25 | 21,360 | 19 | 3,344 | 26 | 4,013 | 6 | 2,605
Europe | | 33 | 10,438 | 19 | 8,394 | 1 | 157 | 13 | 1,887 | 0 | 0
Other | | 8 | 492 | 8 | 492 | 0 | 0 | 0 | 0 | 0 | 0
Sponsorship:
Industry | | 2 | 2,085 | 1 | 66 | 1 | 2,019 | 0 | 0 | 0 | 0
Not Reported | | 108 | 37,543 | 51 | 30,180 | 19 | 1,482 | 39 | 5,900 | 6 | 2,605
Study Design
UCS | | 67 | 14,092 | 24 | 8,217 | 7 | 357 | 36 | 5,518 | 2 | 343
NRCT | | 2 | 256 | 1 | 41 | 0 | 0 | 1 | 215 | 0 | 0
RCT | | 1 | 2,019 | 0 | 0 | 1 | 2,019 | 0 | 0 | 0 | 0
Observational
| Retrospective | 33 | 14,923 | 23 | 14,070 | 9 | 705 | 2 | 167 | 4 | 2,262
| Prospective | 6 | 5,082 | 3 | 4,662 | 3 | 420 | 0 | 0 | 0 | 0
| Cross-sectional | 1 | 3,256 | 1 | 3,256 | 0 | 0 | 0 | 0 | 0 | 0
Level of Evidence:
I | | 1 | 2,019 | 0 | 0 | 1 | 2,019 | 0 | 0 | 0 | 0
II | | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
III | | 109 | 37,609 | 52 | 30,246 | 19 | 1,482 | 39 | 5,900 | 6 | 2,605

k = number of studies.

*Totals do not include question V, as these studies are a subset of questions 1 & 3.

*One study is included for both Questions 1 & 3 and Question 2. This study is included only once in the total.

n = number of patients.

Evidence Table 3 Question 1, 3 Age and Clinical Findings

Risk Factor Age* | Baseline reported | | Cancer dx reported | | Cancer diagnosis | | Cancer diagnosis
| k | n | k | n | # Patients | % | # Lesions | %
Total
> 50 years | 29 | 7,325 | 29 | 7,325 | 1,732 | 23.6
< 50 years | 29 | 5,855 | 29 | 5,855 | 559 | 9.5
> 50 years | 14 | 5,288 | 14 | 5,288 | | | 1,195 | 22.6
< 50 years | 14 | 3,370 | 14 | 3,370 | | | 550 | 16.3
Patient detected
> 50 years | 2 | 258 | 2 | 258 | 12 | 4.7
< 50 years | 2 | 254 | 2 | 254 | 14 | 5.5
Clinician detected
> 50 years | 1 | 11 | 1 | 11 | | | 11 | 100
< 50 years | 1 | 4 | 1 | 4 | | | 3 | 75.0
Palpable mass
> 50 years | 7 | 402 | 6 | 382 | 132 | 34.6
< 50 years | 7 | 1,393 | 6 | 1,338 | 117 | 8.7
> 50 years | 4 | 222 | 3 | 137 | | | 74 | 54.0
<50 years | 4 | 293 | 3 | 180 | | | 48 | 26.7
Nipple discharge
> 50 years | 2 | 71 | 2 | 71 | 5 | 7.0
< 50 years | 2 | 343 | 2 | 343 | 13 | 3.8
> 50 years | 1 | 47 | 0 | 0
< 50 years | 1 | 20 | 0 | 0
Breast pain
> 50 years | 1 | 149 | 0 | 0
<50 years | 1 | 72 | 0 | 0

k=Number of studies. n=Number of patients.

*The category of *ge; 50 vs. < 50 includes one study where the demarcation was ≥ 53 and < 53, and one study where the demarcation was > 50 and ≤ 50

Evidence Table 4 Questions 1, 3 Age and Mammographic Findings

Risk Factor Age* | Baseline reported | | Cancer dx reported | | Cancer diagnosis | | Cancer diagnosis
| k | n | k | n | # Patients | % | # Lesions | %
Microcalcifications
≥ 50 years | 1 | 12 | 1 | 12 | 8 | 66.7
< 50 years | 1 | 9 | 1 | 9 | 5 | 55.6
≥ 50 years | 2 | 18 | 2 | 18 | | | 14 | 77.8
< 50 years | 2 | 14 | 2 | 14 | | | 11 | 78.6
Clustered Calcifications
≥ 50 years | 1 | 1 | 1 | 1 | 0 | 0
< 50 years | 1 | 6 | 1 | 6 | 5 | 83.3
≥ 50 years | 2 | 406 | 2 | 406 | | | 95 | 23.4
< 50 years | 2 | 309 | 2 | 309 | | | 91 | 29.4
Masses
≥ 50 years | 2 | 13 | 2 | 13 | 13 | 100
< 50 years | 2 | 8 | 2 | 8 | 8 | 100
≥ 50 years | 3 | 888 | 3 | 888 | | | 370 | 41.7
< 50 years | 3 | 879 | 3 | 879 | | | 125 | 14.2
Parenchymal distortion
≥ 50 years | 1 | 13 | 1 | 13 | 2 | 15.3
≥ 50 years | 2 | 10 | 2 | 10 | | | 3 | 30.0
<50 years | 2 | 14 | 2 | 14 | | | 2 | 14.3
Density
≥ 50 years
< 50 years
≥ 50 years | 1 | 2 | 1 | 2 | | | 0 | 0
<50 years | 1 | 4 | 1 | 4 | | | 2 | 50.0
BI-RADS 3
≥ 50 years | 1 | 725 | 1 | 725 | 12 | 1.7
< 50 years | 1 | 678 | 1 | 678 | 7 | 1.0
BI-RADS 4
≥ 50 years | 3 | 31 | 3 | 31 | 19 | 61.3
< 50 years | 2 | 23 | 2 | 23 | 11 | 47.8
BI-RADS 5
≥ 50 years | 2 | 48 | 2 | 48 | 45 | 93.8
< 50 years | 2 | 35 | 2 | 35 | 33 | 94.3

k=Number of studies. n=Number of patients.

*The category of ≥ 50 vs. < 50 includes one study where the demarcation was ≥ 53 and < 53, and one study where the demarcation was > 50 and ≤ 50.

Evidence Table 5 Questions 1, 3 Abnormal Findings

Sign or Symptom | Baseline reported | | Cancer dx reported | | Cancer diagnosis | | Cancer diagnosis
| k | n | k | n | # Patients | % | # Lesions | %
Clinical
Patient-detected | 4 | 451 | 2 | 167 | 37 | 22.2
Clinician-detected | 3 | 236 | 3 | 236 | 50 | 21.2
Palpable masses | 11 | 2,102 | 10 | 2,027 | 303 | 14.9
Palpable masses | 6 | 1,094 | 6 | 1,094 | | | 358 | 32.7
Nipple discharge | 4 | 570 | 4 | 570 | 18 | 3.2
Nipple discharge | 2 | 79 | 1 | 67 | | | 2 | 3.0
Breast pain | 3 | 255 | 1 | 216 | 7 | 3.2
Breast pain | 2 | 269 | 1 | 221 | | | 4 | 1.8*
Mammographic
Microcalcifications | 6 | 826 | 5 | 819 | 316 | 38.6
Microcalcifications | 5 | 704 | 5 | 704 | | | 250 | 35.5
Clustered Calcifications | 2 | 29 | 2 | 29 | 13 | 44.8
Clustered Calcifications | 3 | 796 | 3 | 796 | | | 207 | 26.0
Masses | 8 | 462 | 6 | 260 | 83 | 31.9
Masses | 7 | 2,514 | 7 | 2,514 | | | 672 | 26.7
Mass + Calcification | 1 | 3 | 1 | 3 | 0 | 0
Mass + Calcification | 2 | 96 | 2 | 96 | | | 30 | 31.3
Parenchymal distortion | 4 | 79 | 4 | 79 | 22 | 27.8
Parenchymal distortion | 3 | 50 | 3 | 50 | | | 9 | 18.0
Densities | 4 | 65 | 3 | 39 | 5 | 12.8
Densities | 1 | 6 | 1 | 6 | | | 2 | 33.3
BI-RADS 1 | 3 | 963 | 2 | 163 | 7 | 4.3
BI-RADS 2 | 2 | 1,163 | 1 | 883 | 19 | 2.2
BI-RADS 3 | 4 | 2,061 | 3 | 2,034 | 22 | 1.1
BI-RADS 4 | 5 | 218 | 3 | 54 | 30 | 55.6
BI-RADS 5 | 4 | 99 | 2 | 83 | 78 | 94.0
BIRADS 4+5 | 3 | 304 | 3 | 304 | 117 | 38.5

* refers to number of episodes

k = number of studies

n = number of patients or number of lesions

Evidence Table 6 Questions 1, 3 Statistical Measures

| Description | k | Sens (%) | k | Spec (%) | k | Acc (%) | k | PPV (%) | k | NPV (%)
Clinical | Clinician detected | 1 | 71.4 | 1 | 55.5 | 0 | NR | 1 | 65.2 | 1 | 62.5
Clinical | Palpable mass | 3 | 94.0-100 | 2 | 91.0-98.0 | 1 | 98 | 2 | 67.0-92.0 | 2 | 91.0-100
Mammography | Mammography | 9 | 71.0-100 | 9 | 40.0-94.8 | 3 | 74.0-93.4 | 7 | 3.5-86.0 | 5 | 53.0-98.0
Mammography | Masses | 1 | 60.0 | 1 | 79.0 | 0 | NR | 0 | NR | 0 | NR
Mammography | Microcalcifications | 1 | 88.8 | 0 | NR | 0 | NR | 1 | 42.0 | 0 | NR
Mammography | Nonspecified calcifications | 1 | 82.0 | 1 | 69.0 | 0 | NR | 1 | 3.3 | 0 | NR
Mammography | Parenchymal distortion | 0 | NR | 0 | NR | 0 | NR | 2 | 15.4-20.0 | 0 | NR
Mammography | BI-RADS 4 | 1 | 75.0 | 1 | 92.6 | 0 | NR | 0 | NR | 0 | NR
Ultrasound | Ultrasound | 5 | 67.6-100 | 5 | 26.0-97.7 | 3 | 75.0-93.0 | 5 | 33.0-86.0 | 4 | 58.0-100
MRI | MRI | 1 | 92.0 | 1 | 72.0 | 0 | NR | 1 | 84.0 | 1 | 86.0
TL-201 | TL-201 | 2 | 90.0-91.0 | 2 | 72.0-95.0 | 2 | 86.0-92.0 | 2 | 90.0-98.0 | 2 | 72.0-79.0

k = number of studies

NR = not reported

Sens = Sensitivity

BI-RADS = Breast Imaging Reporting and Data System

Spec = Specificity

MRI = magnetic resonance imaging

Acc = Accuracy

TL-201 = thallium

PPV = Positive Predictive Value

NPV = Negative Predictive Value

Evidence Table 7 Question 2 Lobular Carcinoma in situ and Atypical Hyperplasia

Author | Diagnosis | n | CA < 5 yrs | Incidence (%) | CA >5-40 yrs | Incidence (%)** | CA ever | Incidence (%)
Bodian | LCIS | 236 | 10 | 4.2 | 52 | 23.0 | 62 | 26.3
Carson | LCIS | 65 | 3 | 4.6 | 2 | 3.2 | 5 | 7.7
Fisher B^ | LCIS | 411 | 18 | 4.4 | | | 18 | 4.4
Fisher E | LCIS | 182 | 17 | 9.3 | | | 17 | 9.3
Zurrida | LCIS | 120 | 5 | 4.2 | 5 | 4.2 | 10 | 8.3
Total | LCIS | 1,014 | 53 | 5.2 | 59 | 14.5 | 112 | 11.0
Author | Diagnosis | n | CA < 5 yrs | Incidence (%) | CA >5-40 yrs | Incidence (%)** | CA ever | Incidence (%)
Dupont | AH | 287 | NR | | NR | | 39 | 13.6
Fisher B^ | AH | 614 | 23 | 3.7 | | | 23 | 3.7
Marshall* | AH | 119 | 23 | 19.3 | 17 | 17.7 | 40 | 33.6
Marshall* | ALH | 49 | 15 | 0.6 | 7 | 20.6 | 22 | 44.9
Marshall* | ADH | 70 | 8 | 11.4 | 10 | 16.1 | 18 | 25.7
Raju | ADH | 19 | 2 | 10.5 | 2 | 11.8 | 4 | 21.1
Total | AH | 1,039 | 48 | 6.4 | 19 | 16.8 | 106 | 10.2

These reflect cancer or DCIS diagnosed after LCIS or AH. They do NOT include cancers or DCIS diagnosed at open biopsy immediately following LCIS or AH diagnoses.

LCIS = Lobular Carcinoma in Situ

AH = Atypical Hyperplasia

ALH = Atypical Lobular Hyperplasia

ADH = Atypical Ductal Hyperplasia

CA = Cancer

yrs = years

pts = patients

n= number

*Marshall is one study, which has been divided into ALH and ADH patients. In Marshall's study, cancer incidence is divided into ≤ 9 years and > 9 years.

**>5-40 year incidence is calculated based on number of cancer-free patients at end of 5 years. In Zurrida's study, 2 patients were diagnosed with 2 cancers each; one before 5 years, and 1 after.

^ Does not include patients who received Tamoxifen prophylaxis.

Evidence Table 8 Question 2 Lobular Carcinoma in situ (LCIS)

| | | | Subsequent Cancer diagnosis | Subsequent Cancer incidence
| | LCIS diagnosis | | Subsequent Cancer diagnosis | Subsequent Cancer incidence
| | k | n | (# patients) | (%)
Total | | 6 | 1,482 | 122 | 8.2
Location of cancer reported
| Ipsilateral breast | 5 | 656 | 54 | 8.2
| Contralateral breast | 4 | 640 | 33 | 5.2
| Bilateral breasts | 3 | 483 | 9 | 1.9
| NR | 1 | 826 | 26 | 3.1
Management
| Observation | 4 | 794 | 31 | 3.9
| Local Excision | 3 | 214 | 17 | 7.9
| Ipsilateral Mastectomy | 3 | 49 | 4 | 8.2
| Bilateral Mastectomy | 2 | 7 | 0 | 0
| Tamoxifen | 1 | 415 | 8 | 1.9

Timing of subsequent cancer diagnosis ranges from 4 to 50 years.

k= Number of studies.

n= Number of patients.

Evidence Table 9 Question 2 Atypical Hyperplasia

| | | Surgical Biopsy | | Change in Diagnosis | | New CA Diagnosis | | New DCIS Diagnosis | | Follow-up information | | Later CA Diagnosis
| k | n | k | n | (# pts) | (%) | (# pts) | (%) | (#pts) | (%) | k | n | (#pts) | (%)
Total AH | 16* | 2,019 | 12 | 361 | 183 | 50.7 | 48 | 26.2 | 87 | 47.5 | 4* | 1,039 | 106 | 10.2**
ADH | 10 | 403 | 8 | 314 | 133 | 42.4 | 26 | 19.5 | 76 | 57.1 | 2 | 89 | 22 | 24.7
ALH | 2 | 56 | 1 | 4 | 1 | 25.0 | 0 | 0 | 0 | 0 | 1 | 49 | 22 | 44.9
NR | 5 | 1,560 | 3 | 75 | 47 | 62.7 | 22 | 46.8 | 11 | 23.4 | 2 | 901 | 62 | 6.9

*Includes one study which divided patients into ADH and ALH. Patients are counted once, but study is listed twice.

** Incidence of cancer at 5 years is 3.9%, at ≥ 10 years is 19.5%

AH = atypical hyperplasia

ADH = atypical ductal hyperplasia

ALH = atypical lobular hyperplasia

NR = not reported (atypical hyperplasia not identified as ductal or lobular)

CA = cancer

DCIS = ductal carcinoma in situ

k = number of studies

n = number of patients

Evidence Table 10 Question 4 Sentinel Node Biopsy Study Characteristics

| | | | | | | | | Sentinel node positive | | Axillary note positive | Sentinel node false negative
| All studies | | ALND on all patients | | Sentinel node detected | | | | Sentinel node positive | | Axillary note positive | Sentinel node false negative
| All studies | | ALND on all patients | | | | number detected | percent detected | | percent positive | Axillary note positive | Sentinel node false negative
Study characteristics | k | n | k | n | k | n | number detected | percent detected | n | percent positive | n | n | %
Total | 39 | 5,900 | 27 | 3,182 | 27 | 3,182 | 2,909 | 91.4 | 1,089 | 37.4 | 1,184 | 84 | 2.9
VB only | 7 | 506 | 6 | 462 | 6 | 462 | 385 | 83.3 | 148 | 38.4 | 160 | 9 | 2.3
RCM only | 12 | 1,524 | 9 | 1,275 | 9 | 1,275 | 1,191 | 93.4 | 409 | 34.3 | 447 | 39 | 3.3
Both VB and RCM | 20 | 3,866 | 12 | 1,439 | 12 | 1,439 | 1331 | 92.5 | 532 | 40.0 | 577 | 36 | 2.7
Location described* | 17 | 1,443 | 10 | 504 | 4 | 158 | 144 | 91.1 | 49 | 34.0 | 53 | 3 | 2.1
Size described* | 16 | 2,707 | 10 | 716 | 3 | 191 | 153 | 80.1 | 61 | 39.9 | 69 | 5 | 3.3
History of breast surgery* | 13 | 1,064 | 8 | 672 | 5 | 373 | 315 | 84.5 | 107 | 34.0 | 122 | 6 | 1.9

VB = vital blue dye

RCM = radiocolloid mapping

ALND = axillary lymph node dissection

k= Number of studies. n= Number of patients.

Sentinel node detected, sentinel node positive, axillary node positive, sentinel node false negative pertain only to studies in which all patients had full ALND

* For these rows, the k and n are lower in the "sentinel node detected" column than the "ALND on all patients" column, because studies that reported ALND on all patients did not always distinguish tumor location, size, or surgical history.

Evidence Table 11 Question 4 Sentinel Node Identification

Description* | Baseline Reported | | SN Identification Reported | | # with SN Identified | % success SN Ident
| Baseline Reported | | SN Identification Reported | | # with SN Identified | % success SN Ident
| k | n | k | n | n | %
Location:
UOQ | 17 | 695 | 6 | 374 | 352 | 94.1
UIQ | 15 | 203 | 5 | 90 | 79 | 87.8
LOQ | 15 | 184 | 5 | 76 | 70 | 92.1
LIQ | 13 | 105 | 4 | 52 | 49 | 94.2
Central | 13 | 219 | 6 | 131 | 121 | 92.4
Size:
T0 | 3 | 629 | 1 | 150 | 144 | 96
T1 | 16 | 1,619 | 5 | 990 | 925 | 93.4
T2 | 14 | 486 | 3 | 143 | 131 | 91.6
T3 | 8 | 45 | 2 | 17 | 14 | 82.4
T2+3 | 2 | 67 | 2 | 67 | 62 | 92.5
T4 | 1 | 1 | 0 | 0 | 0 | 0
Hx Breast Surgery:
Yes | 13 | 844 | 8 | 549 | 494 | 90
No | 12 | 682 | 8 | 515 | 468 | 90.9

Includes only studies in which full axillary node dissection was done on all patients

SN = sentinel node

Ident = identification

UOQ = upper outer quadrant

UIQ = upper inner quadrant

LOQ = lower outer quadrant

LIQ = lower inner quadrant

Hx = history

NR = not reported

K= number of studies

N= number of patients

T0 = no evidence of primary tumor

T1 = tumor < 2 cm

T2 = tumor 2-5 cm

T3 = tumor > 5 cm

T4 = tumor fixed to chest wall or skin

Evidence Table 12 Question 4 Sentinel Node Identification

| Sensitivity | | | Accuracy | | | NPV
| k | n | Range (%) | k | n | Range (%) | k | n | Range (%)
Total Patients | 17 | 2,004 | 81.0-100 | 18 | 2,524 | 94.0-100 | 12 | 1,603 | 93.0-100
Combination
of Methods | 9 | 723 | 85.0-100 | 7 | 925 | 95.0-100 | 6 | 470 | 93.0-100
Vital Blue Dye | 3 | 275 | 83.3-95.0 | 3 | 215 | 93.8-100 | 2 | 175 | 96.0-100
Radiocolloid
Mapping | 5 | 1,006 | 81.0-93.3 | 8 | 1,384 | 96.8-98.0 | 4 | 958 | 94.1-95.7

k = number of studies

n = number of patients

NPV = Negative Predictive Value